# Methods

## Topic Assessment and Refinement

Two panels of experts, one local and one national (see Appendix A), worked with the research team to identify key questions in the rehabilitation and survivor phases of recovery from TBI for children and adolescents. The panels were composed of three pediatric physiatrists, the mother of a child with brain injury, two neuropsychologists, an educational psychologist, a clinical psychologist, and two speech pathologists -- one from a children's hospital and one who works in the public school system. The local panel met to develop a common understanding of the main concepts bearing on questions of effectiveness in rehabilitation specific to children and adolescents and to identify key questions for investigation. Prior to the first meeting, the panel was sent a document describing the prevalence, incidence, and burden of illness of TBI, as well as the key questions that directed the adult evidence report investigation. The format of the meeting was structured to promote a full and free interaction among the members. This first meeting was aimed at identifying the main issues of rehabilitation for children with TBI, including their integration into the educational system.

Five questions concerning the rehabilitation of children and the effect of the disability on families were proposed by the local panel. Questions were refined through further discussion and submitted to the national panel for review.

The national panel traced the child's path through the medical, rehabilitative, and educational systems to highlight differences in the context of adult and pediatric rehabilitation. Unlike adults, most children's rehabilitation occurs in schools rather than in medical settings. Also, provisions for children with handicaps are mandated by law, whereas choice of adult rehabilitation setting is driven primarily by insurance funding. An understanding of these issues contributed to the final articulation of the key research questions. The final questions are:

1 Does the application of early, intensive medical rehabilitation in the acute care hospital improve outcomes for children with TBI?
2 For children diagnosed with TBI, what is the proportion provided special education that is designed to accommodate the needs of TBI?
3 Do children with traumatic brain injury who are provided special education that is designed to accommodate the needs of TBI have better outcomes than (a) those provided special education that is not so designed, and (b) those who do not receive special education?
4 For children who have sustained brain injury, does the early identification of (a) the child's developmental stage at the time of injury, (b) the child's developmental stage at the time of assessment, and (c) the extent to which the injury has arrested the child's normal developmental process increase the ability to predict when the child will present the needs, behaviors, and problems resulting from brain injury?
5 Does the provision of support to families of children with brain injury enhance the family's ability to cope and reduce the burden of illness?

The rationale for asking these questions, and the definitions, target populations, and outcome measures for them, can be found in Appendix B. Members of the expert panel specified a wide range of outcomes, from physiological complications and health status at discharge from the acute setting to long-term functional measures, such as academic achievement, play skills, language development, social integration, and cognitive abilities. Each outcome can be located within a developmental category presented in Table 1, and this matrix should be used to organize the array of outcomes that would be evaluated in a comprehensive systematic review.

## Literature Search and Retrieval

A research librarian worked with the principal investigator to compose search strategies designed to locate studies about child and adolescent TBI from a number of databases (see Appendix C). Literature was searched using MEDLINE (1976-1998), CINAHL (1982-1998), HealthSTAR (1995-1998), PsychINFO (1982-1998), ERIC (1996-1998), the Cochrane Library, and Current Contents (1998). Figure 1 presents the results of the searches. From MEDLINE, we retrieved a total of 1,098 references; CINAHL, 144; HealthSTAR, 6; PsychINFO, 119; ERIC, 74; the Cochrane Library, 2; and Current Contents, 21, for a total of 1,464 references.

Figure 1. Process of search and selection of articles for review

Two members of the research team read the abstracts of these references and eliminated articles based on the following exclusion criteria: (1) not TBI (e.g., cerebral palsy); (2) adult sample; (3) instrument development; or (4) alcohol/drug abuse. Following this process, we were left with 376 studies about TBI in children or adolescents. Note that we included all study designs and did not limit inclusion by our five key questions. Our intention was to begin assembling a bibliography for use in future research. We categorized each study by (1) design, (2) deficit resulting from the injury, (3) therapeutic intervention, (4) outcome of intervention, and (5) predictors of outcome; within those categories, each study was coded (refer to Appendix D).

There were additional exclusion criteria for the second research question. This question sought information about referral to special education for students with TBI. For this question, the following studies were excluded:

- Studies that predated the 1975 All Handicapped Children Act and those that were conducted outside the United States. It was thought that these studies would artificially inflate the observed variability in student placement patterns after TBI.
- Studies that relied on selected samples.
- Prospective studies with a design that may have influenced school placement, thus introducing bias to the outcome.

Of the 376 studies, 236 addressed one of the five key questions. An additional 120 articles were added from reference lists, book chapter bibliographies, and the advice of peers. A total of 356 full-text articles were retrieved and read. Studies containing data relevant to one of the questions were evaluated by a member of the research team. For question 1, we found 1 study containing relevant data; for question 2, 15; for question 3, 8; for question 4, 61; and for question 5, 3, for a total of 88 studies. The remaining 268 articles described programs or interventions without providing patient or student data.

## Review of Key Studies

The investigation for each key question was managed by a member of the research team. That person read all articles containing data relevant to the question and specified and read additional articles to be included from reference lists. Investigators met individually with the principal investigator to confer about included studies, and the entire team met weekly to discuss progress and maintain a common theme across the five questions.

A template for constructing evidence tables is presented in Appendix E. Categories from the evidence tables in the adult report were used as a guide for data abstraction. The template also incorporates variables specifically relevant to child and adolescent TBI that should be abstracted in a comprehensive systematic review. More details of the construction of evidence tables are given in sections on each key question. Summaries of key studies are presented in Chapter 3 of this report.