# Introduction

In 1997, the Evidence-Based Practice Center (EPC) at Oregon Health Sciences University (OHSU) contracted with the Agency for Health Care Policy and Research (AHCPR) to produce an evidence report on rehabilitation from traumatic brain injury (TBI) (Chesnut, Carney, Maynard, et al., 1999).

At the conclusion of the project, AHCPR requested that the OHSU EPC conduct a survey of the literature regarding child and adolescent TBI rehabilitation. Specific objectives for the project were to:

1 Identify studies of the effectiveness of all phases of rehabilitation for child/adolescent TBI from a variety of bibliographic databases and assemble a data set of studies ranging from acute care through in- and outpatient rehabilitation, educational reintegration, and long-term functional status.
2 Document the process of applying search strategies to the literature, including where the strategies failed and succeeded, producing a road map to this body of literature for use in future investigations.
3 Categorize the retrieved studies and produce a bibliography.
4 Work with a panel of technical experts, including a parent of a child with TBI, to define key questions regarding child and adolescent TBI rehabilitation and use the questions to search the database we developed for studies with evidence for effectiveness of interventions.
5 Summarize the studies relevant to each key question.
6 Construct a template for evidence tables that addresses the key questions.
7 Propose a research agenda for rehabilitation of child and adolescent TBI.

Our main goal was to create a template for a comprehensive, systematic review of existing literature. Our second goal was to describe research projects capable of closing information gaps revealed by a survey of the literature. Using this report as a guide, the International Brain Injury Association (IBIA) convened a pediatric and adolescent working group at the 1999 Aspen Neurobehavioral Conference and initiated a project to produce guidelines for the management of children with TBI. Their goal is to present the guidelines to the World Health Organization for consideration as international standards.

An understanding of child and adolescent development is necessary to an understanding of recovery from TBI during those phases of life. That is, developmental change is not merely an aspect of childhood and adolescence -- it is the main fact of that stage of life and comprises the main set of processes in play. The following section outlines the intersection between developmental science and TBI recovery and provides a schema for containing information generated from that intersection.

## Conceptual Model for Rehabilitation of TBI in Children and Adolescents

### Human Development and Recovery from TBI: Synthesizing the Literature

Children are naturally changing and developing both before and after they are injured, including while they are receiving rehabilitative interventions (Fletcher, Ewing-Cobbs, Francis, et al., 1994; Michaud, 1994). For this reason, in order to examine the effects of rehabilitation, there is a critical need for information on normal child development and for longitudinal studies comparing the development of injured and uninjured children. Such studies should assess the capabilities of children at different ages. They also should examine individual variation in developmental outcomes of children with different injuries and in different social environments (Broman and Michel, 1994; Jaffe, Polissar, Fay, et al., 1995; Taylor and Alden, 1997; Thompson, Francis, Stuebing, et al., 1994; Yeates, Taylor, Drotar, et al., 1997).

The literature on child and adolescent TBI is extremely varied, ranging from studies of brain growth and sensorimotor deficit to studies focused on language, school performance, and psychiatric symptoms. The best organizing principle for reviewing this literature comes from the modern study of human development and, in particular, the metatheoretical approach known as life-span developmental psychology. Simply stated, any research question about child and adolescent TBI must be oriented to the relevant developmental category and age group. Also, subsets of information within a research question must address developmental phases. For example, when describing the sample of a particular study, all of the following variables should be identified: age at injury, age at evaluation, and time since injury, as well as the developmental implications of those age-related landmarks.

The rate and intensity of change in the brain is more rapid in childhood than in any other period of life. The great growth spurt in the human brain begins prenatally at about 3 months before term and ends at the age of 2 years. Initially, the brain adds neurons at the rate of about 250,000 per minute, and the new cells quickly migrate to specific brain sites and begin to grow. About twice as many neurons are made as will eventually survive in the mature brain (Kolb, 1989). A newborn infant's brain has reached 25 percent of its adult mass, and by the age of 2 years it grows to 75 percent of its final weight. In the last stages of this period of intense growth, the addition of new cells gives way to rapid myelination, extensive growth of axons, dendrites, and synapses, and increasing levels of neurotransmitters. After 2 years, growth slows and changes. Neural connections proliferate, while the total number of neurons is reduced by cell atrophy and death, presumably by the selective pruning of experience. The brain may lose up to one-half of its original neurons by puberty, but with the rapid growth of the remaining neurons, the brain achieves its full adult mass well within the range of pediatric age. It reaches 95 percent of adult size by the age of 7 years and full adult weight between 14 and 16 years of age. The brain grows to its full size before the end of adolescence (Berger, 1998; Berk, 1998; Sigelman and Shaffer, 1995).

A question that illustrates the shared territory of development and TBI recovery is, do injuries early or late in life afford better chances for recovery of function? In the 1930s, Margaret Kennard studied brain lesions in monkeys (Kolb, 1989) and found three things about focal lesions in the brains of young monkeys:

1 They produced deficits that were different than those in mature brains.
2 The behavioral effects in young and old animals varied with the type of behavior under study.
3 Certain deficits did not appear in young animals until a much later stage of development (Dennis, Wilkinson, Koski, et al., 1994).

The results of this work acquired an oversimplified interpretation, known as the "Kennard Doctrine," that better recovery from TBI can be expected in children than in adults, after accounting for severity of injury. In fact, the work of Kennard was an attempt to sort out the vulnerabilities and strengths of developmental stages. The key concepts introduced by Kennard were plasticity, sparing, lateralization, and crowding. The large surplus of brain cells produced in the first 2 years of life implies that damage at that time might be less harmful because there is ample time to re-grow lost connections with extra, undamaged cells. This high plasticity of a young brain might result in sparing of a function that would be lost in an older person, an example of the hypothetical benefit of being injured in an early stage of development compared with being injured later in life.

The limits of plasticity and sparing, however, involve the pace of lateralization in the growing brain. The timing of localization of function in one hemisphere or another of the developing brain will limit the extent to which a lost function can be regained once lateralization takes place because the function can no longer be exported to an undamaged hemisphere. This limit is partly a function of crowding, which suggests that attempts to re-route connections in the brain will take up too many neurons needed for other functions and result in two deficits instead of one. This is an example of the developmental principle of critical periods -- originally observed in embryology -- in which a change must happen at a particular time or the chance is permanently lost. The idea of critical periods also points up a vulnerability of early age of injury. If a budding function never starts because of early injury, it might never have the chance to appear at all or be so distorted in its beginnings that it never reaches full potential. This may be much worse than interruption of a process already under way. A process might be derailed by early injury that would suffer only a detour if injury occurred later in development. This is a crucial difference between prevented and interrupted development (Thompson, Francis, Stuebing, et al., 1994; Taylor and Alden, 1997).

### Life-Span Perspective on Human Development

Life-span developmental psychology is a metatheory of human development that focuses on the study of stability and change in human behaviors throughout the entire life course (Baltes, 1987; Montado and Schmitt, 1982). The life-span approach emphasizes differential individual change and the developmental outcomes of interactions between the individual and his or her environment. One major goal of the life-span approach is to focus on understanding stability and change in human behavior within individuals (intraindividual change) and differences in patterns of stability and change between individuals (interindividual differences). In other words, concentration is on the "description, explanation, and modification (optimization) of intraindividual change in behavior across the life-span and with interindividual differences (and similarities) in intraindividual change" (Baltes, Reese, and Nesselroade, 1977, p. 4). In the literature of developmental psychology and education, these individual profiles of change are often called developmental growth curves or trajectories.

A second major goal of the life-span approach is to stress that individual developmental trajectories are simultaneously influenced by multiple and interacting individual and environmental systems. (Baltes and colleagues (1977) summarize the definition of development as: Change in B_A_ = f(H, E_pa_, E_pr_) where "Change in B_A_" is behavior change with age, and is a function of H (heredity), E_pa_ (past environment) and E_pr_ (present environment)

This formula makes it clear that change in behavior is produced by a continual interaction between individual biology, cumulative interactions with environments of the past, and current interactions with present environments.

## Matrix of Developmental Stages and Categories of Development

Table 1 presents dimensions of the developmental process discussed above. Adapted from several sources (Berger, 1998; Berk, 1998; Sigelman and Shaffer, 1995), the matrix is a guide to orient key questions about children and TBI and to locate questions within the appropriate developmental category and age group. It maps human development on two dimensions. The first dimension is chronological age. It shows the periods in which distinct and important changes appear in a child's progress toward maturity. Early in life, changes are most rapid, and the timing of changes is more finely calibrated, so that the first 2 years of life alone are divided into four stages of infancy, and the next 6 years of life are divided into four stages of childhood. Later, the changes are less rapid and the blocks of time larger, so three stages account for the whole second decade of life. The second dimension comprises the categories of change during development. The first two are almost entirely somatic change; the other four are almost entirely psychological and social changes. We say "almost" because all of the categories interact during development, and none is free of the influences of the others.

Table 1. Developmental stages and categories of development

Development Category
Chronological developmental stage | Somatic: neurological/hormonal | Somatic: sensorimotor | Intel./cognitive executive functions | Language | Emotional/ behavioral | Social
Infancy: 0 to 6 months
Infancy: 7 to 12 months
Infancy: 13 to 18 months
Infancy: 19 to 24 months
Childhood: 2 years
Childhood: 3 to 4 years
Childhood: 5 to 6 years
Childhood: 6 to 8 years
Pre-puberty: 9 to 11 years
Early Adolescence: 11 to 14 years
Late Adolescence: 15 to 20 years

Table 1 is a tool for considering the range of studies discussed in this report. The age of the sample for a particular study determines the row or rows of the matrix. The cells made by intersection of row and column represent the important issues identified by the dimension of developmental science and the expected capacities of the sample at that stage in life. The more we know about how brain injury affects conditions specific to each cell, the more effectively we can help the survivor. This is especially true if the matrix also serves to remind us of all the relevant issues in the person's life that must be addressed in a complete treatment program.

Table 1 also can be used to map existing research and present knowledge (or uncertainty) onto the matrix to provide a rough assay of the present state of knowledge, to identify the places where work is needed, and as a way to find neglected topics of study (empty cells).

Plainly, the more we can say about plasticity and critical periods in the first column of the matrix, the more we will know about the possibilities of recovery after early injury. Work by Levin, Eisenberg, Wigg, et al., (1982) found that younger children had worse deficits in memory and intelligence, and Woods (1980) found effects of lateralization as early as 1 year of age. Similar results have been found many times since (e.g., Riva and Cazzaniga, 1986; Kaufmann, Fletcher, Levin, et al., 1993; Anderson and Moore, 1995; Dennis, Barnes, Donnelly, et al., 1996). It may be that too much weight has been given to simple anatomical plasticity of childhood and not enough to the idea of critical periods and how other aspects of development interact with the somatic categories (Krashen, 1973).

## Burden of Illness of TBI in Children and Adolescents

The estimated incidence of TBI doubles between the ages of 5 and 14 years, and peaks for both males and females during adolescence and early adulthood to approximately 250 per 100,000 (Centers for Disease Control and Prevention, 1998). Motor vehicle accidents are the cause of one-third to one-half of TBI in adolescents. In younger children, pedestrian traffic accidents are the leading cause of TBI, followed by falls.

The greatest proportion of people who survive TBI are children and adolescents. Because the lives of most survivors of moderate to severe TBI involve chronic, life-long disabilities with varying degrees of dependence (Chesnut, Carney, Maynard, et al., 1999), the cost in individual suffering, family burden, and financial burden to society may be greater for those who have more years to live.

For children with TBI who have multiple functional deficits, limitations in bathing, dressing, and walking are observed in between 50 percent and 90 percent, depending upon and directly proportional to the number of functional deficits (DiScala, Osberg, and Savage, 1997). For children with four or more functional deficits, impairments in self-feeding, cognition, and behavior can be observed in 75 percent, as well as impairments in speech in 67 percent, vision in 29 percent, and hearing in 16 percent (DiScala, Osberg, and Savage, 1997).

The opinion has been expressed by a number of clinicians and researchers that one of the most important problems in child and adolescent TBI is underdiagnosis (Bergman, 1998; DePompei, 1998; Glang, 1999; Gordon, 1999; Sohlberg, 1999; Ylvisaker, 1998). They believe that many children with TBI are either not identified as having a problem or receive the wrong diagnosis. The concern is that the problems of these children remain unrecognized or are treated with methods developed for other pathologies that are inappropriate to the special needs of TBI. In the 18^th^ Annual Report to Congress on the Implementation of the Individuals with Disabilities Education Act (U.S. Department of Education, 1996) the number of children receiving services because of their disabilities was tabulated by diagnosis. For the 1994-1995 school year, only 7,188 students ages 6 to 21 years were identified within the school system as having a traumatic brain injury. The gap between this number and reports of incidence of TBI among children and adolescents suggests that many children with TBI may be misidentified or unidentified. Consequently, we do not have a complete picture of the burden of illness, either on an individual level or a population basis.

For children who have been accurately identified, comparative studies of TBI need to include mediators of outcome that account for variations in outcome. Individuals with TBI are part of a diverse group. For example, with respect to severity, the range of outcome is from death or persistent unresponsiveness at one extreme to full recovery within a relatively short period of time at the other extreme. Between these two extremes are different profiles of ability and need -- at every level of severity -- depending on preexisting factors, the exact location and nature of the brain injury, and other factors. In addition to type and location of injury and the child's developmental stage, factors such as injury severity, time from injury to evaluation, age at injury, and pre-injury characteristics appear to be important predictors of recovery.

### Injury Severity

The National Pediatric Trauma Registry (NPTR) is a multi-institutional database of information on children and adolescents (0 to 19 years of age) who have been admitted to a hospital for an injury since 1985. A review of data from the NPTR on 24,021 cases of TBI that occurred over a period of 7.5 years revealed that 16.6 percent of the children sustained severe injuries based on the Injury Severity Score (ISS), and 11.5 percent of the children sustained severe head injuries based on the Glasgow Coma Scale score (GCS) (DiScala, Osberg, and Savage, 1997). The same study indicated that 6.1 percent of children with brain injuries in the sample died, compared with 0.5 percent of children without brain injuries from the entire data set of all traumas. This study also revealed a relationship between multiple injuries and degree of functional limitation. For children with injuries to the head, extremities, and other areas of the body, 54 percent had four to nine functional limitations, compared with 32 percent who had injuries to the head and other body regions (but not to extremities), and 14 percent with head injury only.

Two studies about long-term outcomes from mild (Klonoff, Clark, and Klonoff, 1993) and severe (Boyer and Edwards, 1991) brain injury sustained during childhood or adolescence suggest a better outcome for children who suffer less severe brain injuries. In the first study, 159 children from an original sample of 231 children (average age 8 years) admitted to one of two university hospitals for brain injury (90 percent mild) over a 15-month period were located and interviewed 23 years after injury. Fifty-nine percent of participants were married, and 80 percent were employed full-time; 1 percent were disabled, and 3 percent were unemployed. In the second study, the severely injured sample (n = 220) was prospectively followed for 3 years after discharge from one inpatient rehabilitation program that receives referrals from regional trauma centers. At discharge, the following proportions by age group returned home: 0-5 years, 75 percent; 6-10 years, 100 percent; 10-15 years, 80 percent; 16-21 years, 60 percent. After 3 years, 79 percent were home, and 10 percent were in long-stay nursing facilities. At 1-year followup, 8 percent were in regular education, 39 percent in special education, and 17 percent in cognitive therapy; 26 percent were not in an educational program, and 1 percent were in day care. The disposition of the remaining 9 percent was not specified. Glasgow Outcome Scale scores (GOS) after 3 years were 3 percent dead, 14 percent vegetative, 14 percent severe, 17 percent moderate, and 52 percent good.

A series of six prospective studies from one cohort of patients treated at one of two regional hospitals suggests an indirect relationship between severity of injury and scores on neuropsychological tests (Fay, Jaffe, Polissar, et al., 1993; Fay, Jaffe, Polissar, et al., 1994; Jaffe, Fay, Polissar, et al., 1992; Jaffe, Fay, Polissar, et al., 1993; Jaffe, Polissar, Fay, et al., 1995; Yorkston, Jaffe, Polissar, et al., 1997). Children injured between the ages of 6 and 15 years who were admitted to the hospital were prospectively followed beyond 3 years. Results showed consistent association of severity with neuropsychological test scores at early outcome, 1 year, 3 years, and > 3 years. The written language skills of the more severely injured children were worse than those of their less severely injured counterparts. However, no significant difference was evident on test scores between the less severely injured children (GCS 13-15) and controls.

The weakness in these studies is the failure to stratify by other factors that interact to influence outcome; thus, their results should be viewed with caution when attempting to infer a direct relationship between severity and outcome. For example, pooling age groups or not accounting for pre-injury characteristics may mask variability in outcomes associated with severity. Although children with less severe injuries may have better outcomes, there may be many exceptions to the general "dose response" rule (Ylvisaker, 1999).

### Time from Injury to Evaluation

A review that focused on age-related differences in child and adolescent TBI (Taylor and Alden, 1997) found that with longer time since injury, children's cognitive and academic skills decreased, suggesting that deficits may appear or become worse over time. The question of deterioration over time and its measurement is complex and must be examined with all potential influences in mind. Assessments conducted sooner after injury may be less reliable in measuring or predicting long-term outcome than those taken at a later time. Many assessment tools have built increases into their age-related norms for scoring. With these tools, an observed decrease in scores may actually reflect no change (no decrease or increase in abilities). Additionally, factors that interact to produce deterioration over time are (1) neurologic maturation (part of the brain that is injured may need to mature physically to support later developmental acquisitions, but this maturation is blocked by the earlier injury); (2) psychoreactivity (related to personal loss, loss of friends, etc.); and (3) teaching and behavior management strategies that are not appropriate for children with TBI (Ylvisaker, 1999).

The Taylor and Alden study (1997) also suggests that assessment during puberty may be particularly unreliable because of influences during that phase such as social difficulties, verbal memory impairment, and behavioral problems. A second study describing pediatric TBI rehabilitation medical management (Jaffe and Hays, 1986) indicated that special problems with brain injury incurred during childhood and adolescence include hypopituitarism, growth impairment, and isosexual precocious puberty.

### Age at Injury

A retrospective, population-based study (Michaud, Rivara, Grady, et al., 1992) of severe admissions for head injury (GCS < 8, N = 75, < 16 years of age) to a level 1 trauma center found that as age increased, the proportion of good recovery also increased, and the proportion of death decreased. The Taylor and Alden review (1997) reported that outcomes were worse for children < 7 years old compared with those > 7 years but did not specify whether severity of injury was accounted for in the studies reviewed. Therefore, the less favorable outcome they reported in younger children may reflect (1) a higher probability of severe injuries for children < 7 years, or (2) a lower probability of recovery from injuries for children younger than 7 compared with children 7 or older, after accounting for injury severity.

### Pre-Injury Characteristics

Two studies, one prospective (Boyer and Edwards, 1991) and one descriptive (Jaffe and Hays, 1986), indicate that a greater proportion of children than adults who sustain TBI have premorbid behavioral and emotional problems. In the Boyer and Edwards (1991) sample (n = 220), 35 percent had learning disabilities, attention deficit, or emotional difficulties prior to injury. Emotionally or psychologically compromised children may be particularly vulnerable to TBI.

In a study about the effects of family on recovery from TBI in children (Taylor, Drotar, Wade, et al., 1994), a predictive model that includes measures of pre-injury child and family status was developed on 96 children with TBI and 71 orthopedic controls, ages 6 to 12 years at time of injury. Pre-injury factors including child behavior, marital adjustment, family functioning, health and daily living, and parent behavior accounted for 57 percent of the variance in postinjury behavior problems, 37 percent of the variance in adaptive behavior, and 13 percent of the variance in achievement.

## Practice Settings

### Referral to Rehabilitation

Several studies indicate that referral to rehabilitation for children with TBI may depend on a variety of factors. Osberg and colleagues (1990) examined a subset of the National Pediatric Trauma Registry (NPTR) of children with more than four impairments. Eighty percent (374 children) had sustained a head injury. Of these, 31 percent were discharged to inpatient rehabilitation. While their study associated severity of injury and functional impairment with the likelihood of discharge to inpatient rehabilitation, it also found that children treated in centers with on-site rehabilitation were significantly more likely to be discharged to rehabilitation than those treated in centers without such a resource. A subsequent study using the NPTR (DiScala, Osberg, and Savage, 1997) revealed that approximately 90 percent of children with one to three functional limitations were discharged from the acute hospital to home, whereas 50 percent with four to nine functional limitations were discharged to rehabilitation or other extended care. Although half the children discharged to home were diagnosed with specific limitations in walking, bathing, and/or dressing, only 13.2 percent were referred to occupational therapy and 23.7 percent to physical therapy.

### Educational Settings and Programs

Although many children may transition to inpatient rehabilitation and some to long-term care facilities, the goal, when possible, is return to school. Laws requiring schools to provide for the special educational needs of students define schools as the practice setting for ongoing rehabilitation of most children with TBI. Public Law 94-142 (Federal Register, 1975) mandates the accommodation of students with special needs within the school system. Its subsequent version, Public Law 101-476 (Individuals with Disabilities Education Act, 1990) officially recognizes the category of traumatic brain injury, entitling students with special needs to a free, appropriate, public education, and providing for reimbursement for this service to State and local educational agencies. Ideally, a child identified with TBI would be evaluated for special needs, and an individual education program (IEP) designed to meet those needs would be provided. The content and quality of the program depends on resources available in the school, and varies across States and regions.

Characteristics such as social inappropriateness, lack of awareness, and decreased control of attention, memory, and strategic thinking (Ylvisaker and Feeney, 1995) may result in difficulties when integrating a child with TBI into mainstream educational settings. Some States provide training for public school teachers that focuses on the special needs of children with TBI (Savage, 1997). Some programs serve children who live at home together with those who require residential treatment in a specialized educational/neurorehabilitative setting (Luiselli, Gardner, Arons, et al., 1998). Choice of model (mainstream vs. separate) may be dictated by the severity of deficits and functional capabilities of the child; it also may be influenced by the availability of resources within the community, family choice, or the local or regional philosophy of inclusive vs. segregated education of students with disabilities.

## Assessment and Outcome Evaluation

Ylvisaker and Gioia (1998) defined the complexities of assessing children and adolescents with TBI as follows:

1 Most children with severe TBI improve neurologically in ways that are difficult to predict for several weeks or months or possibly even years after the injury. Therefore, an assessment completed in the early weeks or months following injury may quickly lose its validity as an accurate description of the child's profile of strengths and weaknesses.
2 Executive function deficits (associated with prefrontal lobe injury) are notoriously resistant to identification and classification with standardized office tests alone.
3 Recovered knowledge and skills acquired before the injury can combine with new disability, including severe difficulty acquiring new knowledge and skills, to create misleading profiles of ability.
4 Pronounced inconsistency in a child's performance, related to neurologic, emotional, and contextual factors, adds to the difficulty of straightforward interpretation of test results. (Ylvisaker and Gioia, 1998, p. 161)

This account of the difficulties associated with assessing children with TBI echoes our earlier evidence report on rehabilitation for traumatic brain injury in adults (Chesnut, Carney, Maynard, et al., 1999) and introduces special problems with assessment that are unique to children. In the adult report, we tabulated all tests of cognitive function used to evaluate adult samples from studies included in the report. Ninety-one different assessment tools were used in 160 separate testing sessions reported in 24 studies, indicating extreme lack of standardization. Additionally, we found little evidence of an association between high scores on tests and better functional capacity. We concluded that the value of these tests as accurate indicators of functional capacity and predictors of performance in life situations is questionable.

In addition to the question of the predictive validity of assessment methods, the tools also may lack reliability, especially with children who have sustained prefrontal injury. Inconsistency in test scores is commonly observed in both children and adults with executive function deficits (Ylvisaker and Gioia, 1998). Also, a person may perform poorly when new information or skills are required or when effective behavior regulation is necessary but perform adequately when knowledge and skill acquired before the injury are needed. First it must be determined which tests are reliable indicators for which subgroups of children with TBI. The question of their predictive validity can then be addressed.

## Summary

In this chapter, we have outlined our goals and objectives for the study. Our purpose was to conduct a systematic review of the literature about TBI in children and adolescents oriented around key research questions and to produce a tool for other research groups to use to conduct systematic reviews and create strong research projects. We proposed that developmental science is a necessary background for this and future projects about child and adolescent TBI, and we presented a matrix (Table 1) that serves to organize information about this topic. Finally, we described the characteristics of TBI, outcomes, practice settings, and assessment that are unique to children and adolescents.