# Appendix F: Key to Rating Categories in Columns of Table 3 (Question 4)

Appendix F

Column | Meaning of entries
(1) | Name of senior author of rated article
(2) | Date of publication
(3) | List of studied categories of development [see matrix of Table 1]
(4) | Study Length
| 5=Longitudinal study lasting > 3 years
| 4=Longitudinal study lasting 3 years
| 3=Longitudinal study lasting 2 years
| 2=Longitudinal study lasting 1 year
| 1=Longitudinal study lasting <1 year
| 0=cross-sectional study
(5) | Design
| 2=prospective study
| 1=retrospective study
(6) | Setting
| 3=population-based sample
| 2=multi-center sample
| 1=local, 1-center sample
| 0=nature of sample not reported
(7) | Selection
| 4=entire population of cases studied
| 3=random or other representative sample
| 2=consecutive sample
| 1=convenience sample
| 0=nature of sample not reported
(8) | Range of ages in sample at time of measurement
(9) | Span of development stages covered by (8) [see Table 1]
| 4=within one sub-stage (e.g., ages 0-6 mo. in Infancy stage)
| 3=within 1 stage (e.g., ages 7-24 mo.: all still in Infancy stage)
| 2=spanning 2 stages (e.g., ages 19 m-4 y, Infancy - Childhood)
| 1=spanning 3 stages
| 0=spanning 4 stages
(10) | Comparison Method
| 4=experimental group compared with >1 control, including uninjured
| 3=compared with uninjured/normative control
| 2=compared with >1 TBI group (e.g., RH vs LH focal lesion)
| 1=compared within TBI group (e.g., gender, age at testing)
| 0=no comparison group
(11) | Specification of Severity of Injury
| 4=severity determined by brain scan
| 3=severity determined by length of coma
| 2=severity determined by scale (e.g., GCS)
| 1=severity determined by clinical estimation
| 0=severity not reported
(12) | Location of Injury
| 2=location of injury reported
| 1=location of injury not reported
(13) | Span of development stages covered by range of age at injury in sample
| Same entries and criteria as 9
(14) | Time from Injury to Assessment
| 2=30 days interval between injury and 1st measurement in study
| 1= >30 days interval between injury and 1st measurement in study
| 0=injury-measurement interval not reported
(15) | Number of years follow-up measures taken after injury
(16) | Analysis
| 5=innovative design, procedures, or analysis
| 4=covariance or multiple regression designs
| 3=MANOVA or correlation
| 2=univariate comparisons or 1-way ANOVA
| 1=descriptive statistics
| 0=case histories only
(17) | Sum of columns 4-7 and 9-14 and 16 (columns 1, 2, 3, 8, and 15 not part of sum)