# Appendix E: Evidence Table Template

Appendix E: Evidence Table Template

Source | Study Design | Setting/ Population | Sample | Intervention | Co-Interventions | Confounding Variables
| RCT Controlled Comparison Group Prospective Retrospective Population-Based Observational Longitudinal Followup ABA Review Case Study Program Descript. Allocation Method Blinding | | Groups/n Baseline differences Developmen. Categ. Chronicity Age at Injury Age at Evaluation Mechanism of Inj. Severity Focal Inj. Location Family Status Inclusions/Exclus. | Target Deficit Procedure Duration Setting
| Pre-Morbid Baseline Outcome | Method Control for Spontaneous Recovery Control for Confounders