# Appendix D: Categorization and Code System for Bibliography

Appendix D: Categorization and Code System for Bibliography

Main Category | Sub-Category | Code
1. Design of the study | Random Controlled Trial | rct
| Controlled | control
| Comparison Groups | comp
| Intervention | int
| Prospective | pro
| Retrospective | retro
| Population Based | pop
| Observational | observ
| Longitudinal | long
| Followup | fu
| ABA Design | aba
| Review/Theory | rev
| Case Study | case
| Program Description | prog
| Opinion/Editorial/Letter | oped
| Case Control Study | cscon
| Correlational Study | cor
| Methods Study | meth
| Blind Conditions | bl
| Double-Blind Conditions | dbl
| Survey | surv
| Convenience Sample | conv
| Consecutive Sample | cons
2. Deficit resulting from injury | Physiological/Medical | phys
| Language/Communication | lang
| Behavior | beh
| Psychiatric | psyc
| Social | soc
| Psychological | psy
| Educational | edu
| Intellectual/Cognitive | cog
| Reintegration/Independence | reint
| Motor | mot
| Family Function | famf
| Work | work
| Mortality | mort
3. Therapeutic intervention or treatment being studied or applied | Acute Management | acute
| Surgical | surg
| Pharmacological | pharm
| Emergency Department/Acute Care Procedures | ed
| Acute Care Rehabilitation | arehab
| Outpatient Rehabilitation | oprehab
| Inpatient Rehabilitation | iprehab
| Education Programs | edu
| External Aid | ext
| Behavior Management | behm
| Family/Caregiver | fam
| Prevention Program | prev
4. Outcome of intervention or treatment | Physiological/Medical | phy
| Language/Communication | lang
| Behavior | beh
| Psychiatric | psych
| Social | soc
| Psychological | psy
| Educational | edu
| Intellectual/Cognitive | cog
| Reintegration | reint
| Activities of Daily Living | adl
| Family/Caregiver | ofam
| Work | work
| Cost | Cost
| Mortality | omort
5. Predictors of outcome under evaluation | Severity of Injury | sev
| Pre-injury Measures | pre
| Age at Injury or Assessment | age
| Developmental Phase at Injury or Assessment | dev
| Cognitive Deficit | cogd
| Sex | sex
| Family Function | pfam
| Socio-Economic Class | socio
| Payer Benefits | pay
| Cause of Injury | cause
| Site of Injury | site
| Social Support | socs
| Treatment | treat
| Physiological/Medical | med
| Psychiatric | psych
| Education | pedu

## Bibliographic Entries with Coding^1^ 1 This listing includes nearly all citations in the bibliography. Please refer to the bibliography for complete citations and to the categorization and coding system at the beginning of this appendix for a key to these codes.

Adelson,Kochanek, 1998. des/rev

Alexander, 1993. des/oped

Alexander, Schor, Smith Jr, 1986. des/case observ; def/phys

Anderson, Moore, 1995. des/control long pro; observ fu; def/lang cog; predict/sev age fam socio cause

Anderson, Morse, Klug, et al, 1997. des/pro observ; def/cog; predict/sev

Andrews, Rose, Johnson, 1998. des/control observ; def/beh psyc soc

Aram,1986. des/control pro observ; def/lang; predict/site

Aram, 1988. des/rev

Aram, Ekelman, Whitaker, 1987. des/control pro observ; def/lang; predict/age dev sex socio site

Arnarson, Halldorsson, 1995. des/pop observ retro; def/mort

Asarnow, Satz, Light, et al, 1991. des/retro observ fu; def/beh reint

Ashwal, Eyman, Call, 1994. des/retro observ fu; def/lang mot mort

Asikainen, Kaste, Sarna, 1996. des/long observ pop; def/soc; reint work; predict/sev age pedu

Asikainen, Kaste, Sarna, 1998. des/long observ pop; def/reint; predict/sev age

Bagnato, Feldman, 1989. des/review

Bagnato, Mayes, 1986. des/comp cor pro int conv; def/phys mot lang psyc soc; interv/iprehab; out/phys mot lang psyc soc adl

Bagnato, Neisworth, 1986. des/case int; def/cog beh; interv/iprehab; out/phys beh cog

Bagnato, Neisworth, 1989. des/case fu; def/cog edu famf; predict/pfam treat pedu

Bailey, Burchinal, McWilliam, 1993. des/method

Baltes, 1987. des/method

Baltes, Reese, Nesselroade, 1977. des/method

Baracchini-Muratorio, Cantini, Pruneti, 1985. des/pro observ long; def/phys; cog psy; predict/age

Barry, Clark, 1992. des/pro int; def/reint; interv/iprehab; out/oreint; predict/sev pre pfam

Bassett, Slater, 1990. des/comp pro observ; def/mot lang cog

Basso, Scarpa, 1990. des/comp pro observ fu; def/lang edu

Bawden, Knights, Winogron, 1985. des/comp observ pro; def/phys mot cog; predict/sev

Beattie, 1997. des/rev

Beca, Cox, Taylor, et al, 1995. des/retro observ; def/phys; predict/sev

Beers, 1992. des/rev; def/cog ed; predict/dev

Benz, McIntosh, Kallieris, et al, 1993. des/observ; def/phys; interv/prev

Berger E, Worgotter, Oppolzer, et al, 1997. des/observ int fu pro; def/reint; interv/iprehab; out/oreint

Berger K, 1998. des/method

Bergman, Eklund, Magnusson, 1991. des/method

Berney, Favier, Froidevaux AC, 1994. des/retro cons; def/phys mort

Berney, Favier, Rilliet, 1995. des/retro observ; out/mort

Berney, Froidevaux, Favier, 1994. des/retro cons observ; def/phys

Biagas, Gaeta, 1998. des/rev

Bigler, Clark, Farmer, 1997. des/rev; text book

Bijur, Haslum, Golding, 1990. des/comp long pro observ pop; def/phys beh psyc soc cog fam; predict/sev age cog sex socio soc

Bijur, Haslum, Golding, 1996. des/control retro observ; def/phys cog edu; predict/sev

Bishop, 1981. des/rev

Blau, 1936. des/case retro observ cons; def/phys psyc

Blendonohy, Philip, 1991. des/case; def/phys

Blosser, DePompei, 1989. des/prog

Blosser, DePompei, 1992. des/oped; def/lang cog famf

Blosser, Pearson, 1997. des/rev; def/edu

Bohn D, 1993. des/rev

Bowen, Clark, Bigler, 1997. des/observ retro; def/cog mot; predict/sev cause

Boyer, Edwards P, 1991. des/pro int cons long; def/mot; lang beh edu cog; interv/oprehab; out/ophys olang ocog adl oedu; predict/sev cogd

Brett, Laatsch, 1998. des/pro int long; def/cog; interv/edu; out/ocog

Brink, Garrett, Hale, et al, 1970. des/comp retro observ fu; def/mot; lang beh psyc edu cog reint; predict/sev age

Brodsky, 1988. des/case

Brookes, MacMillan, Cully, et al, 1990. des/comp pro retro observ; def/phys; predict/sev age sex cause

Brooks, Campsie, Symington, et al, 1986. des/observ pro long; def/phys psy beh famf; predict/sev

Brown, Chadwick, Shaffer, et al, 1981. des/control pro observ long fu; def/psyc beh; predict/pre

Bruce, Schut, Sutton, 1982. des/rev

Bryk, Raudenbush, 1987. des/method

Bryk, Raudenbush, 1992. des/method

Burchinal, Appelbaum, 1991. des/method

Burke, 1984. des/case; def/famf

Burke, Wesolowski, Buyer, et al, 1990. des/retro int fu; def/reint work; interv/oprehab

Burke, Wesolowski, Guth, 1988. des/retro observ fu; def/cog psy; predict/sev cogd

Burkett, 1989. des/rev

Butinar, Gostisa, 1996. des/pro observ; def/mort

Campbell D, Stanley, 1966. des/method

Campbell TF, Dollaghan, 1990. des/comp pro long int; def/lang; interv/oprehab; out/lang; predict/sev

Capruso, Levin, 1992. des/rev; def/cog

Carney, Gerring, 1990. des/rev

Cattelani, Lombardi, Brianti, et al, 1998. des/retro observ long; def/cog soc beh psyc; predict/sev

Chadwick, Rutter, Brown, et al, 1981. des/control pro observ long fu; def/cog; predict/sev age cog sex

Chadwick, Rutter, Shaffer, et al, 1981. des/control pro observ long fu; def/cog; predict/cogd

Chadwick, Rutter, Thompson, et al, 1981. des/pro observ pop; def/lang edu cog; predict/sev age site

Chapman, Culhane, Levin, et al, 1992. des/pro observ fu; def/lang cog; predict/cogd

Chapman, Levin, Wanek, et al, 1998. des/pro observ fu; def/lang; predict/age site

Chesnut, Carney, Maynard, et al, 1999. des/rev

Cioni, Prechtl, Ferrari, et al, 1997. des/method

Clark, 1996. des/case rev; def/edu soc

Cockrell, Gregory, 1992. des/retro observ; def/phys

Connell, Skinner, 1990. des/method

Connor, Steingard, 1996. des/rev

Conoley, Sheridan, 1996. des/rev; def/psy soc famf

Costeff, Abraham, Brenner, et al, 1988. des/retro comp observ fu; def/phys cog mot; predict/cog

Costeff, Groswasser, Landman, et al, 1985. des/pro observ fu; def/mot lang psyc

Coster, Haley, Baryza, 1994. des/comp long pro observ pop; def/beh soc reint fam; predict/sev

Crowley, Miles, 1991. des/case int pro; def/cog; interv/cog; out/ocog

D'Amato, Rothlisberg, 1996. des/rev

Dalby, Obrzut, 1991. des/rev

Dall' Oglio, Bates, Volterra, et al, 1994. des/long case pro observ fu; def/lang; predict/age

Dam Hieu, Sizun, Person, et al, 1996. des/retro observ case; interv/surg; out/ophys

Davidson, 1990. def/work

Day, Ulatowska, 1979. des/case pro observ; def/mot lang cog

Deaton, Poole, Long, 1987. des/rev; def/work

Dennis, 1985. des/cor retro observ pop; def/cog; predict/med

Dennis, 1992. des/rev; def/lang

Dennis, Barnes, 1990. des/comp cor observ conv; def/lang

Dennis, Barnes, Donnelly, et al, 1996. des/comp cor pro pop; def/lang cog; predict/sev age site

Dennis, Barnes, Wilkinson, 1998. des/comp cor pro observ pop; def/lang; predict/age site

Dennis, Lovett, Wiegel-Crump, 1981. des/case

Dennis, Whitaker, 1976. des/case

DePompei, Blosser, 1997. des/oped; def/edu

DePompei, Williams, 1994. des/rev; def/famf

DiScala, Grant, Brooke, et al, 1992. des/comp retro observ fu; def/phys

DiScala, Osberg, Savage, 1997. des/retro pop surv; def/phys reint

Doelling, Bryde, Parette, 1997. des/method

Donders, J Abnorm Child Psychol, 1992. des/comp surv; def/beh psy soc; predict/pre

Donders, J Clin Psychol 48(2), 1992. des/cor observ; def/cog

Donders, J Clin Psychol 48(3), 1992. des/observ cor; def/cog

Donders, 1993. des/comp observ; def/cog

Donders, 1994. des/retro observ cons fu; def/phys cog; predict/sev pre age cogd

Donders, Ballard E, 1996. des/cor retro surv fu; def/psys psy soc beh; predict/sev psy soc pre

Donders, Strom, 1997. des/control retro observ; def/ed cog; predict/pre cogd

dos Santos, Plese, Ciquini Jr, 1994. des/cor observ; def/phys

Duhaime, Eppley, Margulies, et al, 1995. des/case retro observ; def/phys

Edwards, 1987. des/retro observ fu; def/phys reint

Eiben, Anderson, Lockman, et al, 1984. des/retro surv; def/lang soc cog; predict/sev age

Eisele, Aram, 1994. des/control pro observ conv; def/lang; predict/site

Eisele, Lust, Aram, 1998. des/control pro observ conv; def/lang; predict/site

Emanuelson, Von Wendt, 1998. des/cor retro observ pop fu; def/phys

Emanuelson, Von Wendt, 1998. des/cor retro observ pop fu; def/phys

Emanuelson, Von Wendt, Beckung, et al, 1998. des/case observ fu; def/cog mot soc reint

Emanuelson, Von Wendt, Bjure, et al, 1997. des/comp pro observ; def/phys

Emanuelson, Von Wendt, Lundalv, et al, 1996. des/retro observ long fu; def/lang beh cog soc

Engberg, Teasdale, 1998. des/retro observ pop fu; def/phys

Eriksson, Perfilieva, Bjork-Eriksson, et al, 1998. des/anatomy

Ersahin, Mutluer, Mirzai, et al, 1996. des/retro observ pop; def/phys

Ewing-Cobbs, 1986. des/rev

Ewing-Cobbs, Brookshire, Scott, et al, 1998. des/comp observ fu; def/cog lang

Ewing-Cobbs, Fletcher, Levin, 1989. des/comp pro observ fu; def/cog mot lang; predict/sev age

Ewing-Cobbs, Fletcher, Levin, et al, 1997. des/pro observ long; def/lang cog mot

Ewing-Cobbs, Kramer, Prasad, et al, 1998. des/comp pro long observ; def/phys cog mot

Ewing-Cobbs, Levin, Eisenberg, et al, 1987. des/comp pro observ conv; def/lang; predict/sev age

Ewing-Cobbs, Levin, Fletcher, et al, 1990. des/pro observ fu; def/cog

Ewing-Cobbs, Thompson, Miner, et al, 1994. des/long pro observ cons; def/mot lang beh edu cog reint; predict/age dev

Farley, 1990. des/rev; def/phys

Farmer JE, Clippard, Luehr-Wiemann, et al, 1996. des/rev

Farmer JE, Peterson, 1995. des/rev

Farmer M, Singer, Mellits, et al, 1987. des/comp pro surv cons; def/phys mot lang beh psyc soc; predict/age site

Fay, Jaffe, Polissar, et al, 1993. des/control cor pro cons observ fu; def/phys soc psy edu reint; predict/sev

Fay, Jaffe, Polissar, et al, 1994. des/control pro observ pop fu; def/phys soc psy edu reint; predict/sev

Feldman HM, Holland, Brown, 1992. des/case pro observ fu; def/lang; predict/site

Feldman HM, Holland, Kemp, et al, 1992. des/control long pro observ conv; def/lang; predict/age site

Feldman HM, Janosky, Scher, et al, 1994. des/comp cor pro observ fu; def/lang

Feldman KW, Brewer, Shaw, 1995. des/retro observ; def/phys

Fields, Coble, Pollack, et al, 1993. des/case pro observ surv fu; def/phys

Filley, Cranberg, Alexander, et al, 1987. des/comp pro observ cons; def/beh soc edu reint work;predict/sev site

Fisher, 1997. des/rev

Fletcher, 1990. des/comp long pro observ cons fu; def/phys beh soc; predict/sev age sex socio cause site

Fletcher, Levin, 1988. des/method

Fletcher, Levin, Lachar, et al, 1996. des/comp observ; def/cog psy psyc; predict/sev

Fletcher-Janzen, Kade, 1997. des/method

Fowler, Kriel, Krach, 1992. des/retro observ cons; def/phys

Frances, Jensen, 1985. def/phys psy

Francis, Fletcher, Stuebing, et al, 1991. des/method

Franzen, Roberts, Schmits, et al, 1996. des/aba case; def/cog

Freeman, Burrell, Sedger, 1990. des/int case observ fu; def/reint; interv/oprehab; out/oreint ofam cost

Frewen, Sumabat, Del Maestro, 1985. des/comp observ fu; def/phys

Fuld, Fisher, 1977. des/case pro observ conv fu; def/sev mot lang soc edu cog

Gaidolfi, Vignolo, 1980. des/observ long fu; def/psy cog soc; predict/sev age

Gambardella, Zaccone, Cardia, et al, 1993. des/pro int; def/phys; interv/surg; out/ophys

Genuardi, King, 1995. des/retro pop observ; def/phys

Gerberich, Finke, Madden, et al, 1987. des/observ surv; def/phys; sports hockey

Gill, Cohen, Korn, et al, 1996. des/observ fu; def/beh cog lang mot work

Glang, Todis Cooley, et al, 1997. des/case pro int fu; def/edu soc reint; interv/educ

Glass, Bulas, Wagner, et al, 1998. des/comp pro; def/phys cog mot

Godbout, 1997. des/aba case int; def/phys mot; interv/iprehab

Gold, 1985. des/case; def/cog edu

Goldberg, Sachs, 1992. des/rev

Goldstein B, DeKing, DeLong, et al, 1993. des/pro observ; def/phys mort

Goldstein F, 1985. des/rev

Goshen, Zwas, Shahar, et al, 1996. des/int pro; def/phys; interv/acute

Gotschall, Papero, Snyder, et al, 1995. des/cor pro observ cons long; def/phys beh soc cog mot

Greenspan, 1996. des/rev

Greenspan, MacKenzie, 1994. des/comp pro surv sons fu; def/phys beh edu; predict/sev pre socs pfam

Greenwald, Ghajar, 1995. des/rev int; def/phys; interv/acute

Groswasser, Costeff, Tamir, 1985. des/retro surv; def/phys cog

Guerriere, McKeever, 1997. des/case; def/famf

Gulbrandsen, 1984. des/control observ fu; def/cog; predict/age

Gutentag, Naglieri, Yeates, 1998. des/control observ; def/cog

Haley, Cioffi, Lewin, et al, 1990. des/rev; def/mot

Hall DM, Johnson, Middleton, 1990. des/rev

Hall JR, Reyes, Meller, et al, 1996. des/comp retro observ cons; def/phys; interv/acute; out/ophys omort; predict/sev treat

Hallett, 1997. des/comp observ; def/cog lang; predict/age dev

Hanigan, Wright, Wright, 1986. des/retro observ; def/phys

Harris, 1996. des/comp pro observ conv; def/cog; predict/sev

Hart BL, Dudley, Zumwalt, 1996. des/case retro observ; def/phys

Hart K, Faust, 1988. des/surv; des/phys; predict/age dev

Hayward, 1987. des/prog

Hegel, 1988. des/case int; def/beh; interv/behm

Heindl, Laub, 1996. des/comp retro observ fu; def/phys; predict/sev

Helfaer, Wilson, 1993. des/rev

Helgadottir, 1996. des/case; def/lang reint psy soc

Hemphill, Feldman, Camp, et al, 1994. des/comp pro observ; def/lang

Hendrickson, Becker, 1996. des/rev int; def/phys; interv/prev

Henry, 1983. des/prog rev; def/cog

Hicks, Gaughan, 1995. des/retro observ; def/mort

Hinnant, 1994. des/case; def/phys

Hirsch, DuBois, 1991. des/method

Hofer, 1993. des/retro observ; def/phys mort

Horton Jr, 1996. des/rev int; interv/edu

Hu, Wesson, Kenney, et al, 1993. des/long pro observ cons; def/phys beh psyc reint fam; predict/fam psyc age sev

Hudspeth, Pribram, 1990. des/control retro observ pop; def/phys; predict/age dev

Humphreys, Hendrick, Hoffman, 1990. des/case; def/lang mort

Hurvitz, Mandac, Davidoff, et al, 1992. des/retro observ; def/phys

Jaffe, Fay, Polissar, et al, 1992. des/cscon long pro cons; def/phys beh edu cog; predict/sev age cogd sex

Jaffe, Fay, Polissar, et al, 1993. des/cscon cor long pro observ pop; def/phys cog mot edu; predict/sev

Jaffe, Hays, 1986. des/rev

Jaffe, Massagli, Martin, et al, 1993. des/cor long pro observ; out/cost; predict/sev cause site

Jaffe, McDonald, 1992. des/long pop

Jaffe, Okamoto, Lemire, 1986. des/rev

Jaffe, Polissar, Fay, et al, 1995. des/cscon long pro observ; def/phys cog mot; predict/sev pre

James, Madauss, Tibbs, et al, 1979. des/int; def/phys; interv/pharm; out/ophys ocog oreint omort

Johnson BP, 1995. des/case; def/famf

Johnson DA, 1992. des/rev; def/sev cog

Johnson DL, Krishnamurthy, 1996. des/retro pop; def/phys mort; interv/acute surg; out/omort; predict/sev treat

Johnston, Gerring, 1992. des/rev

Johnstone, Zuberi, Scobie, 1996. des/retro observ pop; def/phys; predict/sev age sex cause

Jordan, Cannon, Murdoch, 1992. des/control pro observ fu; def/lang

Jordan, Cremona-Meteyard, King, 1996. des/control pro observ conv; def/lang cog

Jordan, Murdoch, 1990. des/cont pro observ conv; def/mot lang; predict/sev

Jordan, Murdoch, 1994. des/control pro observ conv; def/lang

Jordan, Murdoch, Buttsworth, 1991. des/control pro observ conv; def/lang; predict/sev

Jordan, Ozanne, Murdoch, 1990. des/control observ; def/lang

Kaiser, Pfenninger, 1984. des/ pro int long fu; def/phys psy cog ed; int/acute surg pharm; out/ophys omort opsy ocog oreint

Kaufmann, Fletcher, Levin, et al, 1993. des/comp pro observ cons; def/cog; predict/sev age

Kehle, Clark, Jenson, 1996. des/rev prog; def/beh

Kennedy, Freeman, 1986. des/rev

Kersenbrock, Kirchner, Sammons, 1983. des/case

Kinsella, Prior, Sawyer, et al, 1995. des/long observ; def/cog edu; predict/sev cog

Kinsella, Prior, Sawyer, et al, 1997. des/long observ; def/sev cog; predict/sev cog

Kissoon, Dreyer, Walia, 1990. des/rev; def/phys

Kleinpeter, 1976. def/soc reint

Klonoff, Paris, 1974. des/comp long pro observ cons; def/phys mot lang beh psyc soc psy edu cog reint fam; predict/sev pre age dev sex cogd

Klonoff, Low, Clark, 1977. des/control pro observ cons fu; def/phys mot cog; predict/age

Knights, Ivan, Ventureyra, et al, 1991. des/comp long pro observ cons; def/phys mot lang cog psyc soc edu; predict/sev

Koelfen, Freund, Dinter, et al, 1997. des/comp observ fu; def/phys cog; predict/sev

Kolb, 1989. des/rev

Krach, Kriel, Morris, et al, 1997. des/observ retro cons fu; def/phys cog mot mort; predict/sev

Krashen, 1973. des/rev

Kraus, Fife, Conroy, 1987. des/retro observ pop; def/phys mort

Kraus, Fife, Cox, et al, 1986. des/retro observ surv; def/phys age

Kraus, Rock, Hemyari, 1990. des/rev; interv/prev

Krell, 1997. des/case

Kriel, Krach, Panser, 1989. des/comp retro; def/phys mot cog; predict/age treat

Kumar, West, Quirke, et al, 1991. des/comp bl retro observ cons; def/phys lang cog mort; interv/acute; out/phys cog; predict/sev age treat

Kuyper, van Tol-de Jager, Post, et al, 1996. des/cor retro surv fu; def/phys cog

Lange-Cosack, Riebel, Grumme, et al, 1981. des/comp pro observ fu; def/phys psy cog soc ed reint; predict/sev

Lawson, Rice, 1989. des/case; def/cog lang

Leathem, Body, 1997. des/control pro observ; def/beh cog

Lehr, Psychological management, 1990. des/rev; def/cog edu psyc beh soc famf; text book

Lehr, A developmental perspective, 1990. des/method

Leichtman, 1992. des/case; def/psyc

Levin, 1992. des/rev; def/psy soc famf; interv/pharm

Levin, 1993. des/rev; def/psyc cog; predict/age site

Levin, Culhane, Fletcher, et al, 1994. des/control observ fu; def/phys cog; predict/age site

Levin, Culhane, Mendelsohn, et al, 1993. des/control cor observ fu; def/phys cog; predict/sev site

Levin, Eisenberg, 1979. des/observ; def/psy cog; predict/sev

Levin, Eisenberg, Wigg, et al, 1982. des/control pro observ conv fu; def/cog; predict/sev age

Levin, High, Ewing-Cobbs, et al, 1988. des/control pro observ fu; def/cog; predict/sev age

Levy ML, Masri, Levy, et al, 1993. des/comp observ; def/phys; predict/age sex site socio

Levy Y, Amir, Shaley, 1992. des/long case; def/lang

Lewis, Shanok, Pincus, et al, 1982. des/observ; def/psyc beh

Lieh-Lai, Theodorou, Sarnaik, et al, 1992. des/comp retro observ; def/phys mort; predict/sev

Lloyd, Martin, Taylor, et al, 1985. des/cor int pro; def/phys; interv/acute pharm; out/phys

Lord-Maes, Obrzut, 1996. des/rev

Loroni, Ciucci, Piccinini, et al, 1996. des/retro observ pro int phys; def/phys; predict/sev age

Luerssen, 1997. des/rev; def/phys

Luerssen, Klauber, Marshall, 1988. des/long pro observ pop fu; def/mort; predict/age

Luiselli, Gardner, Arons, et al, 1998. des/prog; def/phys psyc soc ed cog

Lumenta, Kramer, Sprick, et al, 1985. des/pro int fu; def/phys; interv/acute surg; predict/age site

Macnab, 1991. des/retro observ; def/phys; interv/prev; predict/treat

Manchester, Hodgkinson, Pfaff, et al, 1997. des/case int; def/soc beh; interv/behm

Mansfield, 1997. des/rev; def/phys

Marchman, Miller, Bates, 1991. des/comp long pro observ; def/lang; predict/site

Massagli, Jaffe, Gay, et al, 1996. des/cscon cor pro fu; def/phys cog beh; predict/sev

Massagli, Michaud, Rivara, 1996. des/retro observ cons fu; def/phys reint cog edu work; predict/sev

Mateer, Kerns, Eso, 1996. des/rev int; def/cog reint

Matthews, 1997. des/oped

Max, Bowers, Baldus, et al, 1998. des/comp cor observ blind; def/phys psyc; predict/sev

Max, Castillo, Bokura, et al, 1998. des/observ long pro observ cons; def/psyc; predict/sev psy socio

Max, Castillo, Robin, et al, 1998. des/cor long pro observ; def/psyc famf; predict/pre pfam

Max, Lindgren, Knutson, et al, 1997. des/cor retro observ cons; def/psyc; predict/sev pre cogd pfam socio

Max, Lindgren, Knutson, et al, . . . disruptive behavior, 1998. des/cor retro observ cons; def/beh psyc famf; predict/sev pre pfam

Max, Lindgren, Knutson, et al, . . . injury severity, 1998. des/cor retro observ cons; def/lang beh psyc ed; predict/sev

Max, Lindgren, Robin, et al, 1997. des/pro observ fu; def/psyc beh famf; predict/sev pre pfam

Max, Robin, Lindgren, et al, 1998. des/cor pro observ; def/phys psyc beh cog; predict/pre pfam socio cogd

Max, Sharma, Qurashi, 1997. des/cscon retro observ cons; def/psyc

Mayer, Walker, 1982. des/pro observ; def/phys mort; predict/sev

Mazza, Pasqualin, Feriotti, et al, 1982. des/pro observ; def/phys; predict/sev site

McArdle, Epstein, 1987. des/method

McClelland, Rekate, Kaufman, et al, 1980. des/retro; def/phys

McCrea, Kelly, Kluge, et al, 1997. des/retro int; def/phys; interv/acute; out/phys

McDonald, Jaffe, 1992. def/phys beh famf

McDonald, Jaffe, Fay, et al, 1994. des/cscon cons pro observ fu; def/phys cog edu; predict/sev pre age sex

McLean, Kaitz, Keenan, et al, 1995. des/rev; def/phys

Melamed, Wozniak, 1998.

Merten, Osborne, 1983. des/rev; def/phys

Michaud, 1994.

Michaud, 1995. out/cost

Michaud, Duhaime, 1995. des/rev; def/phys

Michaud, Rivara, Grady, et al, 1992. des/long retro observ cons; def/phys mot mort; predict/sev treat

Michaud, Rivara, Jaffe, et al, 1993. des/cscon retro surv; def/beh cog edu; predict/age

Milton, Scaglione, Flanagan, et al, 1991. des/rev case; def/cog edu

Minde, 1984. des/rev

Miner, Cabrera, Ford, et al, 1986. des/case; def/phys

Mitchell, Cusick, 1998. des/prog int; def/reint cog

Mittenberg, Wittner, Miller, 1997. des/rev; def/phys

Molnar, Easton, Badell, et al, 1987. des/rev

Montgomery, 1984. des/case

Moviat, Janssen, Jaeken, et al, 1995. des/retro case observ; def/cog beh

Muller, Rothermel, Behen, et al, 1998. des/comp observ; def/phys cog lang; predict/site

Mwaria, 1990. des/case; def/psyc famf

Nass, Koch, 1987. des/comp pro observ conv; def/psy; predict/site

Newcombe, 1982. des/rev

Newman, Lovett, Dennis, 1986. des/case; def/lang

Noah, Hahn, Rubenstein, et al, 1992. des/rev; def/phys

O' Sullivan, 1996. des/case

Oberg, Turkstra, 1998. des/case int fu; def/lang; interv/oprehab edu; out/ocog

Ong, Selladurai, Dhillon, et al, 1996. des/cor retro observ; def/phys mort; predict/sev

Osberg, Brooke, Baryza, et al, 1997. des/cor pro observ surv fu; def/phys famf; predict/sev pfam socio pay

Osberg, DiScala, Gans, 1990. des/retro observ pop; def/phys mot soc reint; predict/sev treat

Ottewell, 1992. des/case

Otto, 1960. des/case retro observ; def/phys cog psyc

Paret, Barzilay, 1995. des/cor pro observ; def/phys mort; predict/med

Paret, Dekel, Yellin, et al, 1996. des/cor retro observ; def/phys; predict/sev med

Parker, 1994. des/rev; def/phys cog mot lang psyc; predict/sev age socs psych

Parkin, Maas, Rodger, 1996. des/cor retro surv fu; def/phys cog beh psyc; predict/pre pfam socs med

Parmelee, 1989. des/rev; def/psyc

Parmelee, Kowatch, Sellman, et al, 1989. des/case

Parmelee, O' Shanick, 1987. des/case; def/psyc

Patterson, 1998. des/oped

Perrott, 1991. des/cscon pro observ conv; def/phys mot beh psyc soc cog reint fam; predict/sev

Pettersen, 1991. des/control pro observ conv; def/psy cog

Pfenninger, Kaiser, Lutschg, et al, 1983. des/pro int; def/phys; interv/acute surg; out/phy

Polissar, Fay, Jaffe, et al, 1994. des/cscon cor retro cor fu; def/phys reint; predict/sev

Pollack, Patel, Ruttimann, 1997. des/cor pro observ cons; def/phys mort

Prior, Kinsella, Sawyer, et al, 1994. des/comp pro observ cons fu; def/beh soc cog; predict/sev

Quine, Pierce, Lyle, 1988. des/pro int fu; def/famf; int/fam; out/ofam

Ramundo, McKnight, Kempf, et al, 1995. des/pro int; def/phys; interv/acute; out/ophys; predict/med

Reilly, Bates, Marchman, 1998. des/cscon int; def/lang; interv/ed; out/olang; predict/age site

Ried, Strong, Wright, et al, 1995. des/oped; def/soc; predict/socs

Riva, Cazzaniga, 1986. des/control pro observ conv; def/cog; predict/age site

Rivara F, Mueller, 1986. des/rev

Rivara JB, 1994. des/cons pro fu; def/famf phys; predict/sev pre pfam

Rivara JB, Fay, Jaffe, et al, 1992. des/comp observ survcons pro fu; def/famf phys; predict/sev pre pfam

Rivara JB, Jaffe, Fay, et al, 1993. des/cor cons pro fu; def/famf phys reint; predict/sev age pre pfam

Rivara JB, Jaffe, Polissar, et al, 1994. des/cor cons pro fu; def/famf phys edu beh; predict/sev pre pfam

Rivara JB, Jaffe, Polissar, et al, 1996. des/long pro cons fu; def/phys famf reint beh soc; predict/pre pfam sev

Roddy, Cohn, Moller, et al, 1998. des/retro observ; def/phys; predict/med

Rogers, Kreutzer, 1984. def/famf

Rose, Johnson, Attree, 1997. des/oped

Ross, Ernst, Kreis, et al, 1998. des/observ; def/phys

Rossi, Sullivan, 1996. des/pro observ fu; def/mot

Rudel, Teuber, 1971. des/control pro observ conv; def/mot lang cog

Rudel, Teuber, Twitchell, 1974. des/control pro observ conv; def/phys mot cog; predict/age

Ruijs, Keyser, Gabreels, 1990. des/pro observ long; def/phys mot cog beh psy soc

Ruijs, Keyser, Gabriel, 1994. des/rev

Russo, Bressolle, Duboin, 1997. des/case int; def/phys; interv/pharm; out/ophys

Rutter, 1981. des/rev; def/cog psyc; predict/sev med pre socs

Rutter, 1982. des/rev; def/cog beh psy

Rutter, Chadwick, Shaffer, et al, 1980. des/cscon pro long; def/phys lang beh psyc soc psy ed cog; predict/sev

Sakzewski, Ziviani, 1996. des/rev; def/phys; predict/sev med treat

Sakzewski, Ziviani, Swanson, 1996. des/comp pro int; def/phys; predict/age sex cause treat; out/cost phys

Sandermann, Haase, Bartholdy, et al, 1986. des/case pro int fu; def/phys; int/acute surg; out/phys

Savage, 1991. des/rev

Savage, 1997. des/oped; predict/treat

Schmitt, Bauersfeld, Fanconi, et al, 1997. des/pro observ; def/phys

Schmitz, Skinner, 1993. des/method

Segalowitz, Brown, 1991. des/surv pop; def/mot beh edu; predict/age

Segalowitz and Lawson, 1995. des/cor retro surv; def/phys cog beh psyc

Sellars, Vegter, and Flaig, 1997. des/case rev

Selz, 1979. des/com pro observ conv; def/mot cog

Shaffer, Bijur, Chadwick, et al, 1980. des/pro observ pop fu; def/lang; predict/site

Sharma and Sharma, 1994. des/retro pop observ; def/phys mort reint

Shurtleff, Massagli, Hays, et al, 1995. des/case; def/cog

Sigelman and Shaffer, 1995. des/method

Silver, Boake, and Cavazos, 1994. des/case int fu; def/cog beh reint; interv/behm; out/beh adl

Skinner, Zimmer-Gembeck, and Connell, 1998. des/method

Skippen, Seear, Poskitt, et al, 1997. des/pro int; def/phys; interv/phys; out/ophys

Slater and Bassett, 1988. des/control retro observ fu; def/cog lang

Slifer, Cataldo, Babbitt, et al, 1993. des/case int; def/beh; interv/behm; out/obeh

Slifer, Cataldo, Kurtz, 1995. des/case int; def/beh; interv/behm; out/beh

Slifer, Tucker, Gerson, et al, 1996. des/case int; def/beh; interv/behm; out/obeh

Slifer, Tucker, Gerson, et al, 1997. des/case pro int fu; def/beh; interv/behm; out/obeh

Sobus, Alexander, Harcke, 1993. des/pro observ cons; def/phys

Sokol, Ferguson, Pitcher, et al, 1996. des/comp observ fu; def/beh famf; predict/age pfam socio psych

Sollee, Kindlon, 1987. des/comp pro; def/cog beh; predict/site

Song, Kim, Kim, et al, 1997. des/rev; def/phys mort

Splaingard, Gaebler, Havens, et al, 1989. des/comp retro observ fu; def/phys mort reint; predict/med

St. James-Roberts, 1979. des/rev

Sternlicht, 1989. des/method

Stiles, Nass, 1991. des/cscon observ; def/cog; predict/site

Stiles, Stern, Trauner, et al, 1996. des/control observ; def/phys cog; predict/site

Stiles-Davis, Sugarman, Nass, 1985. des/comp pro observ conv; def/cog; predict/site

Stiles-Davis, Janowsky, Engel, et al, 1988. des/control pro observ conv; def/mot cog; predict/site

Sutton, Wang, Duhaime, et al, 1995. des/pro observ; def/phys; interv/acute; out/ophys

Suzman, Morris, Morris, et al, 1997. des/case pro int fu; def/phys cog; interv/edu; out/ocog oedu

Szatmari, 1985. des/rev

Taylor, Alden, 1997. des/rev; def/phys beh cog; predict/pre site socs

Telzrow, 1987. des/rev; def/ed

Tepas, DiScala, Ramenofsky, et al, 1990. des/retro observ pop; def/mort; predict/cause

Thakker, Splaingard, Zhu, et al, 1997. des/retro observ pop fu; def/phys reint mort; predict/sev age

Thal, Marchman, Stiles, et al, 1991. des/long pro observ pop fu; def/lang; predict/age dev site

Thatcher, 1991. des/control retro observ pop; def/phys; predict/age site

Thompson, Francis, Stuebing, et al, 1994. des/long pro observ conv; def/mot cog; predict/sev age dev

Tomberg, Rink, Pikkoja, et al, 1996. des/retro observ cons; def/phys reint; predict/med

Tompkins, Holland, Ratcliff, et al, 1990. des/cor long observ; def/beh cog lang phys; predict/sev pre age pfam

Trauner, Ballantyne, Friedland, et al, 1996. des/control pro observ conv; def/lang; predict/site

Tucker, Colson, 1992. des/rev

Turkstra, Holland, 1998. des/cscon observ; def/lang cog

Turkstra, McDonald, Kaufmann, 1996. des/comp case observ; def/lang cog

Vander, Sherman, Luciano, 1970. des/method

Vander Schaaf, Kriel, Krach, et al, 1997. des/comp cor observ cons fu; def/phys mot; predict/sev cause

Vartiainen, Karjalainen, Karja, 1985. des/case observ fu; def/phys

Vigil-Sewell, Sargent, 1996. des/oped

Virginia, 1991. des/retro surv pop; def/phys mot lang psyc edu

Waaland, Kreutzer, 1988. des/rev

Waaland, 1991. des/rev; famf

Waaland, Burns, Cockrell, 1993. des/surv; def/famf reint

Wade, Drotar, Taylor, et al, 1995. des/rev; def/famf; predict/pre pfam

Wade, Taylor, Drotar, et al, 1996. des/control cor pro observ fu; def/phys psy famf; predict/socs psych

Wade, Taylor, Drotar, et al, 1998. des/control long observ; def/phys famf psyc; predict/sev

Ward, 1995. des/oped

Warschausky, Cohen, Parker, et al, 1997. des/cscon observ; def/cog soc; predict/sev sex

Warzak, Allan, Ford, et al, 1995. des/comp surv cor; def/reint

Webb, Rose, Johnson, et al, 1996. des/comp observ sur; def/reint; predict/age

Willett, Ayoub, Robinson, 1991. des/method

Willett, Sayer, 1994. des/method

Williams D, Mateer, 1992. des/case observ fu; def/cog beh soc; predict/site age

Williams SE, Ris, Ayyangar, et al, 1998. des/control pro dbl int; def/beh cog; int/acute pharm; out/obeh ocog

Wilson, Powell, Brock, et al, 1996. des/case int rev; def/phys; interv/acute; out/phys; predict/age sex

Winogron, Kinghts, Bawden, 1984. des/comp pro observ conv; def/mot cog; predict/sev

Wit, Maassen, Gabreels, et al, 1994. des/cscon control comp observ; def/lang; predict/cause

Wolcott, Lash, Pearson, 1995. des/prog rev; def/edu

Woods, 1980. des/comp pro observ cons; def/cog; predict/site

Woods, Carey, 1979. des/control pro observ conv; def/lang; predict/age

Worley, Hoffman, Paine, et al, 1995. des/case cor pro int fu; def/phys; interv/phys; out/ophys; predict/treat

Worthington, 1989. des/rev; def/psy famf soc reint

Yeates, Blumenstein, Patterson, et al, 1995. des/control pro observ consec; def/cog; predict/sev age

Yeates, Taylor, Drotar, et al, 1997. des/comp pro observ fu; def/cog beh famf soc; predict/sev pre pfam socs

Ylvisaker, 1986. des/rev

Ylvisaker, 1993. des/rev

Ylvisaker, Feeney, 1995. des/rev

Ylvisaker, Szekeres, Hartwick, et al, 1994. des/rev

Ylvisaker, Weinstein, 1989. des/rev; def/phys psy cog beh soc famf

Yorkston, Jaffe, Polissar, et al, 1997. des/cscon cor pop observ; def/cog lang; predict/sev cog

Zencius, Wesolowski, Burke, 1989. des/case pro int fu; def/beh psy; int/behm; out/reint

Zimmer-Gembeck, 1998. des/method

Zuckerman, Conway Jr, 1997. des/rev