# Appendix C: Search Strategies

MEDLINE Strategy (Identical for all questions) - 1976 to 1997

1 Explode Head Injuries/
2 Explode Brain/
3 brain.tw.
4 2 or 3
5 1 and 4
6 Exp brain injuries
7 5 or 6
8 Exp rehabilitation
9 Rehabilitation centers
10 rh.fs.
11 Rehabilitat$.tw
12 Developmental stages.tw
13 Schools/
14 Exp/family/
15 Case Management/
16 Counseling/
17 Social Support/
18 Exp treatment outcome/
19 Exp education special/
20 Piaget.tw
21 Educational measurement/
22 Exp hospitalization/
23 Child, hospitalized/
24 Exp critical care/
25 Intensive care units/
26 Intensive care units, pediatric/
27 Exp Social behavior
28 Comparative study/
29 Linear models/
30 *child development/
31 *family health/
32 Exp *cognition
33 cognition disorders/
34 *neuropsychological tests/
35 sequelae.tw
36 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
37 21 or 22 or 23 or 24 or 25 or 26 or 27 or 2
38 36 or 37
39 7 and 38
40 Limit 39 to human
41 Limit 40 to English language
42 Limit 41 to children 2 to 17

HealthSTAR strategy (identical for all questions) - 1995 to 1997 (same as MEDLINE search)

PsychINFO search strategy (all questions) - 1982 to 1997

1 Exp brain damage/ or exp brain damaged/
2 Exp head injuries/
3 Brain.ti.ab
4 2 and 3
5 1 or 4
6 Limit 5 to (human and English language)
7 Exp cognitive rehabilitation/or exp neuropsychological rehabilitation/or exp rehabilitation/or exp rehabilitation centers/ or exp rehabilitation counseling/or exp rehabilitation education/ or "rehabilitation".mp.
8 6 and 7
9 Limit 8 to (160 preschool ages < 2 to 5 years or 180 school age < age 6 to 12 years or 200 adolescents < age 13 to 17 years)

ERIC search strategy (all questions)

1 Brain injuries

CINAHL search strategy (all questions) - 1982 to 1997

1 Exp head injuries/
2 Brain Injuries.tw.
3 Head Injuries.tw
4 1 or 2 or 3
5 rh.fs
6 Exp rehabilitation/
7 Rehabilitation centers/
8 Exp schools/
9 Family centered care/
10 Exp family
11 Exp support, psychosocial
12 Case Management
13 Exp prognosis
14 Exp education, special
15 Piaget.tw
16 Educational measurement
17 Exp academic performance
18 Exp hospitalization
19 Child, hospitalized
20 Critical care
21 Intensive care units
22 Intensive care units/, pediatric
23 Exp social behavior
24 Comparative studies
25 Models, statistical
26 Child Development
27 Family health/
28 Exp cognition
29 Exp cognition disorders
30 Neuropsychological tests
31 sequelae.tw
32 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
33 20 or 21 or 22 or 23 or 24 or 25 or 26 or 2
34 32 or 33
35 4 and 34
36 Limit 35 to English
37 Limit 36 to age 2 - 17

Current Content search strategy (all questions) - 1998

1 Brain injur$
2 Head injur$

Cochrane search strategy (all questions)

1 Traumatic brain injur$
2 Traumatic head injur$