# Appendix A: Technical Expert Panels

## Local Panel

- Anita Asmussen, MA
- Speech Pathologist
- Emanuel Hospital

- Janice Cockrell, MD
- Pediatric Physiatrist
- Medical Director, Pediatric and Adolescent Rehabilitation
- Emanuel Children's Hospital

- Don Lange, PhD
- Neuropsychologist

- Margaret Sutko, PhD
- Neuropsychologist
- Emanuel Children's Hospital

- Robert Butler, PhD
- Psychologist
- OHSU/Doernbecher

- Colleen Hanson, EdD
- Legacy Health System
- Portland Public School System

- Shuana Perkins
- Parent

- Kathy Ware, MS
- Speech-Language Pathologist
- Portland Public School District

## National Panel

- Robert DePompei, PhD, CCCSLP/A
- Professor, School of Speech-Language
- Pathology and Audiology
- University of Akron, Ohio

- Marilyn Lash-Cluett, MSW
- Director, L & A Publishing/Training
- Wolfeboro, NH
- Assistant Clinical Professor, Department of Physical Medicine and Rehabilitation
- Tufts University School of Medicine
- Boston, MA

- Linda Michaud, MD
- Director, Pediatric Physical Medicine and Rehabilitation
- Children's Hospital Medical Center
- Cincinnati, OH

- Eldon Schulz, MD
- Chief, Pediatric Physical Medicine and Rehabilitation and Developmental Pediatrics
- University of Arkansas for Medical Sciences