# Evidence Tables

## Acronyms and Abbreviations Used in Evidence Tables

ABPM: ambulatory blood pressure monitoring

APLMS: arousing periodic leg movements of sleep

APS+age: aute physiology score + age

AV: arteriovenous

BP: blood pressure

CABG: coronary artery bypass

CAPD: continuous ambulatory peritoneal dialysis

CCPD: continuous cyclic peritoneal dialysis

CHF: congestive heart failure

CI: confidence interval

CO: cardiac output

CPT: Continuous Performance Task

CRF: chronic renal failure

CVA: cerebrovascular accident

Cz: central electrode

DBP: diastolic blood pressure

DM: diabetes mellitus

EEG: electroencephalogram

enr: enrolled

ERP: event-related potential

ESRD: endstage renal disease

eval: evaluated

Fz: frontal electrode

HCFA: Health Care Financing Administration

Hct: hematocrit

HD: hemodialysis

hosp: hospitalized

HTN: hypertension

HUI: Health Utilities Index

Hx: history

IHD: ischemic heart disease

inc: included

IV: intravenous

KDQ: Kidney Disease Questionnaire

KIC: alpha-keto-isocaproate

KS: Karnofsky scale

Kt/V: A measure of dialysis where K is the dialyzing membrane clearance, t is the time of dialysis delivered in minutes, and V is the volume of distribution

LE: life expectancy

LV: left ventricular

LVD: left ventricular dilatation

LVEDD: left ventricular end-diastolic dimension

LVESD: left ventricular end-systolic dimension

LVH: left ventricular hypertrophy

LVMI: left ventricular mass index

MI: myocardial infarction

mo./mos.: month/months

N: number of patients

NR: not reported

NYHA: New York Heart Association

OR: odds ratio

PCR: protein catabolic rate

PLMS: periodic leg movements of sleep

PSG: polysomnography

pt./pts.: patient/patients

PTCA: percutaneous transluminal coronary angioplasty

PVD: peripheral vascular disease

Pz: parietal electrode

QOL: quality of life

RBC: red blood cell

RCT: randomized controlled trial

RDI: Respiratory Disorder Index

REM: rapid eye movement

RR: relative risk; risk ratio

SD: standard deviation

SIP: Sickness Impact Profile

TIA: transient ischemic attack

TPRI: total peripheral resistance index

Tx: treatment

UCLA: University of California Los Angeles

USRDS: U.S. Renal Data System

VO2max: Volume of Oxygen

Evidence Table 1. Randomized controlled clinical studies

Study | Study Design | N Enr | N Eval | Patient Population | Inclusion/Exclusion Criteria | Study Protocol | Outcomes Reported
Besarab, Bolton, Browne, et al., 1998 | Randomized prospective, open-label trial | 1,233 | 1,233 | CHF or IHD pts. undergoing long-term HD Age: ≃ 65±12 yrs. Gender: ≃ 49% male Time on dialysis: ≃ 3 yrs. (mean) Race: ≃ 44% white, 42% black, 8% Hispanic, 6% Other Diabetic: ≃ 55% Hypertension: ≃70% NYHA Class: Class I: 30% Class II: 51.5% Class III: 17% PVD: 38.5% | Inclusion criteria:; - Long-term HD; - Documented CHF or IHD; - Serum transferrin saturation >20%; Exclusion criteria:; - DBP >100 mmHg; - LE <6 mos.; - severe cardiac disability (NYHA class IV); - MI, PTCA, or CABG in 3 mos. prior to study; - pericardial disease; - cardiac valvular disease likely to require surgery; - cardiac amyloidosis; - androgen therapy | Normal Hct group (N=618) treated with epoetin to achieve and maintain target Hct of 42±3% Low Hct group (n=615) treated with epoetin to maintain Hct at 30±3% epoetin administered iv=90% 3 times per week = 88% Iron administered to 85% of normal Hct group and 75.4% of low Hct group (p<0.001) Planned duration of study = 3 yrs. median duration = 14 mos. study stopped = 29 mos. Intention-to-treat analysis | Primary endpoint: Death or first nonfatal MI Secondary endpoints: CHF requiring hospitalization angina pectoris requiring hosp. CABG PTCA hospital utilization for all causes change in cardiovascular drugs red-cell transfusion changes in QOL scores Also measured: blood pressure vascular access thrombosis CVA TIA peripheral gangrene intestinal ischemia seizures
McMahon, McKenna, Sangkabutra, et al., 1999 | Randomized double-blind, crossover study | 30 | 14 | Stable, sedentary HD pts. without cardiovascular, respiratory, or musculoskeletal disease Age range: 23-66 yrs. Younger age group (n=9): Mean age = 34±10 yrs (range=23-45 yrs) Older age group (n=5) Mean age= 58±4 yrs (range=55-65 yrs) Duration of dialysis = 34±29 mos. (range = 12-59 mos.) | Stable, sedentary, HD pts. No cardiovascular, respiratory, or musculoskeletal disease | Pts. randomly assigned to epoetin to achieve Hct of 30% or 42% during the first time period and then crossed over to the other Hct level | Exercise performance: Peak oxygen consumption Peak ventilation Peak heart rate Work done Peak work rate
Foley, Parfrey, Morgan, et al., 1998 Abstract only (Canadian Study) | RCT | NR | 62/70 with LVH 63/76 with LVD | Asymptomatic HD pts. with either LVH or LVD No demographic data reported | Asymptomatic HD pts. with either LVH or LVD Exclusion criteria not reported | Pts. randomly assigned to partial (Hct 28-31.5%) or complete (Hct 39-42%) normalization of Hct using epoetin 48-week trial | Regression of concentric LVH and LVD LV cavity volume index LV mass index
Wells, Coyle, Lee, et al., 1998 Abstract only (Canadian Study) | RCT | NR | 130 | HD pts. without symptomatic cardiac disease No demographic data reported | HD pts. with symptomatic cardiac disease Exclusion criteria not reported | Pts. randomly assigned to partial correction of Hct (target 30%) or complete correction of Hct (target 40.5%) with epoetin | Quality of Life Kidney Disease Questionnaire SF-36 Health Utilities Index

Rows in italics indicate study available as abstract.

Evidence Table 2. Nonrandomized controlled clinical trials

Study | Study Design | N Eval | N Inc | Patient Population | Inclusion/Exclusion Criteria | Study Protocol | Outcomes Reported
Moreno, Sanz-Guajardo, Lopez-Gomez, et al., 2000 | Pre/post intervention Pt. serves as own control | 156 | 115 | Stable pts. on HD who had received epoetin for at least 3 mos. and had a stable Hct >28%. Age = 44±15 yrs. Males = 60% Time on dialysis = 37±40 mos. Friedman Comorbidity Index=3±2 Hct = 31±2% | Nondiabetic stable HD pts. between the ages of 18 and 65. All pts. had to have received epoetin for at least 3 mos. and have a stable Hct of > 28%. Pts. with DM, uncontrolled HTN, malfunction of the vascular access, history of stroke, seizures, symptomatic IHD or CHF, and the presence of severe disease (Friedman Comorbidity Index >7) or anemia unrelated to chronic renal failure were excluded. Pts. who received a kidney transplant or experienced complications possibly related to epoetin treatment or to increases in Hct were censored from the study. | Epoetin was gradually increased to obtain a stable increase of 4 or more points above baseline Hct. The route of administration previously used was maintained. If the desired increase in Hct was not reached within the recommended dose schedule, subsequent dosage increases were left to the decision of the attending physician. Pts. were then followed for 6 mos. Iron replacement was maintained by iron administration. Monthly serum ferritin levels were measured. | Death Quality of life SIP, KS Vascular access thrombosis Hypertension Hospital utilization rates
Pickett, Theberge, Brown, et al., 1999 | Pre/post intervention Pt. serves as own control | NR | 20 | Pts. with ESRD currently being treated with epoetin with a Hct <35% and receiving regular dialysis treatments at the UCLA Medical Center Age=48.8 yrs. (mean) Males=40.5% Time on dialysis=90.4 mos. (mean) | Criteria not reported | Electrophysiologic measures recorded at baseline Hct (mean 31.6%) and then retested after at least 2 weeks of correction of anemia with epoetin to target Hct of 40-45% (mean 42.8%) Iron replacement administered if transferrin saturation was less than 20% and/or ferritin level less than 100mg/mL | Cognitive function EEG power spectrum Tone-elicited P300 latency CPT performance Frontal P300 amplitude
Benz, Pressman, Hovick, et al., 1999 | Pre/post intervention Pt. serves as own control | 10 | 10 | Selected from 45 consecutive ESRD pts. referred to sleep disorder center for evaluation of complaints of poor sleep quality, frequent nocturnal awakenings, unrefreshing sleep, or daytime fatigue. and found to have PLMS by PSG | Pts. with ESRD requiring HD, age >18 yrs, anemia responsive to epoetin, PLMS Index >20, RDI <50 but actually attempted to select subjects with mildest sleep apnea. | Pts. with complaints of disrupted sleep and found to have PLMS by PSG received epoetin to normalize Hct then underwent repeat PSG Exact Hct target not reported | Sleep Disorders PLMS Index Arousing periodic movements of sleep Mean wakefulness test REM sleep Apnea index Oxygen saturation
Suzuki, Tsutsui, Yokoyama, et al., 1995 | Non-randomized, open label study with separate control group | NR | 49 total 10 cases 39 control | Pts. on chronic HD with no circulatory or musculoskeletal complications Gender: Normal Hct = 90% male Controls = 48.7% male Age: ≃ 40 yrs. Normal Hct = 43.7±6.2 Controls = 37.2±10.7 Dialysis duration (mos.) Normal Hct = 157.8±43.2 Controls = 73.6±47.8 | No circulatory or musculoskeletal complications. Diabetic neuropathy cases were excluded as well. Remainder served as controls. | Epoetin given IV 3 times per week and later adjusted to target level Target levels: Normal Hct = 35-40% Control Hct =approx. 30% Oral or iv iron supplementation as needed | Exercise performance: Maximal heart rate Duration of exercise VO_2max_
Eschbach, Glenny, Robertson, et al., 1993 Abstract only | Pre/post intervention Pt. serves as own control | NR | 13 | HD pts. No further information reported | No criteria reported | Pts. had physiologic and QOL measurements taken at mean Hct level of 32.6±1.5 for at least 4 mos. and then again 4 mos. later at a mean Hct of 42.0±1.9 | Maximal oxygen uptake Exercise duration Pulmonary diffusion of CO Quadricep isometrics Hand grip Distance walked Left ventricular mass Cardiac index TPRI QOL Adverse effects
Stray-Gunderson, Sams, Goodkin, et al., 1997 Abstract only | Crossover | ? | 27 | HD pts. | NR | Pts. pedaled a cycle ergometer during multiple dialysis sessions at target Hct levels of 30% and 42%. Hct was managed by adjusting epoetin dose. | Exercise performance (peak power (watts), oxygen uptake (VO_2_ peak, mi/kg/min)) Training periods between the 2 target Hct levels were separated by a 16 ± 4 week detraining and Hct crossover period
Mason, Skinner, Sangkabutra, et al., 1997 Abstract only | Prospective, double-blind crossover study | 19? | 11 | Chronic HD pts. Age range=18-70 yrs. | NR | Pts. were given epoetin to maintain an Hct of 30% and 42% from baseline of 25.8% | Echocardiographic findings (LVMI, CO, LVEDD, LVESD) 24 hour ABPM
Mason and McMahon, 1997 Abstract only | Prospective, double-blind crossover study | 19? | 10 | Stable HD pts. Age range=23-65 yrs. Question whether there is overlap with Mason, Skinner, Sangkabutra, et al., 1997 but there are different numbers, different age ranges, and different outcomes | NR | Pts. were given epoetin to maintain an Hct of 30% and 42% from baseline of 25.8% | Quality of life (SIP) Employment Potential adverse effects (ABPM, urea and electrolyte levels, AV access thrombosis)

Row in italics indicate study available as abstract.

Evidence Table 3. Studies reporting cross-sectional analyses

Study | N Eval | N Inc | Patient Population | Data Source | Methods of Analysis | Outcomes Reported
Levin, Thompson, Ethier, et al., 1999 | 446 | 246 | Consecutive pts. with chronic renal insufficiency but not on dialysis seen by nephrologists at 8 academic medical centers between July 1994 and April 1997 in Canada. Excluded: could not commit to followup, life expectancy <1 year, on immunosuppressive therapy for renal disease, likely to receive dialysis in <1 year. Age: 56.7±13.8 y Gender: male = 67.5% Race: White=89% Black=6% Asian=5.8% Duration of renal disease: 4 y (range 2-10 y) Diabetes: 25.8% Angina: 16.8% Cardiovascular disease: 39% Hemoglobin: 12.8 ±1.9 g/dL Systolic BP: 143.6 mmHg Diastolic BP: 84.6 mmHg | Observational study with baseline and 12 month followup data. Pt. serves as own control. | Logistic Regression Analysis | Left ventricular growth on echocardiography
Levin, Singer, Thompson, et al., 1996 | 197 | 175 | Pts. referred to nephrology clinic for assessment and followup of renal insufficiency between February 1990 and March 1993 as part of prospective study Mean age = 51.6±15.3 yrs Range = 20-82 Gender: Male = 66% Mild renal insufficiency = 9% Moderate renal insufficiency = 31% Severe renal insufficiency = 60% | Data collected as part of prospective study evaluating the prevalence and progression of renal insufficiency | Logistic regression analysis | Association with LVH
Lowrie, Huang, Lew, et al., 1994 | Not applicable | 16,153 | Pts. receiving 3 weekly HD treatments on January 1, 1991, who were still receiving dialysis or died by December 31, 1991 No demographic data reported | National Medial Care data as of January 1, 1991 | Logistic regression analysis Covariates: Case mix Laboratory variables | Death (mortality) Odds ratio reported
Ma, Ebben, Xia, et al., 1999 | Not applicable | 75,283 | Medicare pts. receiving HD and surviving 7/1/93 to 12/31/93; followup from 1/1/94 to 12/31/94. Pts. censored at time of dialysis modality switch, transplantation, loss to followup or on 12/31/94. Age: <45 = 18.6% 45-64 = 35.3% 65-74 = 29.4% >75 = 16.7% Gender: Male = 48.6% Race: White = 49.3% African American = 41.3% Native American = 1.4% Other = 8.1% | HCFA ESRD Databases | Cox proportional hazards model Covariates: age, gender, race, prior ESRD exposure, comorbidity, primary renal diagnosis, severity of disease (# vascular access procedures, # blood transfusions, hospital length of stay) | Death (mortality) Odds ratio reported
Xia, Ebben, Ma, et al., 1999 | Not applicable | 71,717 | Medicare HD pts. surviving a 6-month entry period from July 1-December 31, 1993, and then followed from January 1, 1994-December 31, 1994. Required to have at least 4 epoetin claims and 4 hematocrit levels reported. Mean age = 60.2 yrs. Race: White =49% Black = 41% Gender: Male = 48% Diabetes = 31% | HCFA ESRD registration and claims data and HCFA 2728 Medical Evidence forms | Cox proportional hazards model to assess relative risk and an Anderson-Gill multiple event model to evaluate pt. time between each hospitalization event | All cause hospital utilization and cause-specific hospital utilization (cardiovascular and infectious)
Levin, Lazarus, Nissenson, et al., 1993 | 324 | 324 | Adult pts. on dialysis in the U.S. (Phase IV surveillance) Receiving epoetin for at least 12 mos. in the study (but new users), age 18 yrs. or older, history of anemia associated with CRF. Met "package insert" eligibility. HD = 90.4% PD = 9.6% Male = 51.5% Age (yrs) < 19 = 0.6% 20-24 = 24.4% 45-64 = 39.2% 65-74 = 24.7% >75 = 11.1 Race White/Hispanic = 49.7% Black = 45.9% Asian/Oriental = 2.8% Native American = 1.2% Other/unknown = 0.3% Length of time on dialysis (yrs) < 1 = 57.3% 1-2 = 22.5% 3-4 = 13.0% 5-6 = 2.3% 7-8 = 2.0% 8-9 = 1.0% 9- 19 = 2.0% Infection or malignant or inflammatory disease = 8% | Data available from the USRDS 1991 Annual Data Report and institutional data | Comparison of means, proportions, and events/month without statistical analysis | Seizures Stroke/CVA TIA/MI/cardiac arrest Accelerated/malignant HTN Hospital utilization Blood pressure
Moreno, Gomez, Sanz-Guajardo, et al., 1996 | 1,188 | 1,013 | Pts. with CRF on dialysis, age >15 yrs., with absence of vascular access problems, and at least 3 mos. since the start of dialysis treatment and on the same dialysis technique if on epoetin for at least 3 mos. on the treatment, and at least 3 mos. since the last major complication (hospitalization of 7 days or more or with defined consequences) Exclusions Age = 53±15 yrs Hct = 30%+4.8% Time on renal replacement therapy = 5.7±4.6 yrs Comorbidity index = 4.6±3.2 ^1^ Socio-economic index = 1.8±0.5 ^2^ Hemodialysis - 88% Hemodialysis at home - 0.7% Hemofiltration - 7% Peritoneal dialysis - 4% | Questionnaires completed by participating hospital centers and pts. between June and December 1993 | Covariance analysis with adjustment for age, comorbidity index, presence of DM, gender, socio-economic level, educational level, Hct Stepwise linear regression with adjustment for personal characteristics, socio-economic and educational level, comorbidity, type of substitutive therapy, Hct, Kt/V, PCR, previously failed transplant time, time on dialysis, type of dialysis center, type of dialyser membrane, dialysis solution, and treatment with epoetin | Quality of life KS, SIP
Abstract Collins, Hao, Ebben, et al., 1999a | 6,650 | 6,650 | Incident Medicare CAPD/CCPD pts. during period 1993 to 1996. Followup through 6/30/97 was available. | Medicare data | Cox Regression Analysis Adjusted for age, gender, race, 10 comorbid conditions, 3 severity of disease measures, M | Hospital utilization
Abstract Collins, Hao, Ebben, et al., 1999b | 85,473 | 85,473 | Incident Medicare HD pts. during period 1993 to 1996. Followup through 6/30/97 was available. | Medicare data | Cox Regression Analysis Adjusted for age, gender, race, 10 comorbid conditions, 3 severity of disease measures, M | Hospital utilization
Abstract Collins, Hao, Ebben, et al., 1999c | 82,879 | 82,879 | 5,871 incident CAPD/CCPD and 77,008 incident HD Medicare pts. during period 1993 to 1996 Followup through 6/30/97 was available. | Medicare data | Cox Regression Analysis stratified by diabetic status Adjusted for age, gender, race, renal diagnosis, and entry year | Mortality
Riedel, Hampl, Nundel, et al., 1996 Abstract only | NR | 75 | HD pts. with epoetin therapy No additional information reported | HD pts. with epoetin therapy No exclusion criteria reported | Comparison of means | Nutritional status - amino acid levels Leucine Valine KIC Weight gain

Rows in italics indicate study available as abstract.

1 Range = 0-18.

2 1=low; 2=medium, 3=high.

Evidence Table 4. Mortality

Study/Study Design Population | N | Group Hct (%) | All-Cause Mortality | Cardiac Mortality | Infectious Mortality | Death or First Nonfatal MI | Comments
Randomized controlled clinical trials
Besarab, Bolton, Browne, et al., 1998 | 615 | 30±3 | 26% | 18.2% | 3.6% | 26.7% | When study was terminated, Hct 30 group had 150 deaths and 14 1st nonfatal MI Hct 42 group had 183 deaths and 19 1st nonfatal MI
CHF or IHD pts. undergoing HD | 618 | 42±3 | 31.6% sig. not given | 20.2 sig. not given | 5.2% sig. not given | 32.7% RR=1.3 95% CI = 0.9-1.9 | RR adjusted for baseline characteristics
Nonrandomized controlled clinical trials
Moreno, Sanz-Guajardo, Lopez-Gomez, et al., 2000 Pre/post Stable pts. on HD who had received epoetin for at least 3 mos. and had a stable Hct>28%. | 115 | 31 ± 2 38.5 ± 2.5 | --- No deaths reported
Cross-sectional analyses
Lowrie, Huang, Lew, et al., 1994 Pts. receiving 3 weekly HD treatments on Jan. 1, 1991 who were still receiving dialysis or died by December 31, 1991 | 16,153 | 30-35 | OR = 1.00 (Reference) | | | | OR adjusted for case-mix and laboratory variables
Lowrie, Huang, Lew, et al., 1994 Pts. receiving 3 weekly HD treatments on Jan. 1, 1991 who were still receiving dialysis or died by December 31, 1991 | 16,153 | 35-40 | OR = 1.45 (p<0.001) | | | | OR adjusted for case-mix and laboratory variables
Lowrie, Huang, Lew, et al., 1994 Pts. receiving 3 weekly HD treatments on Jan. 1, 1991 who were still receiving dialysis or died by December 31, 1991 | 16,153 | >40 | OR = 1.80 (p<0.01) | | | | OR adjusted for case-mix and laboratory variables
Ma, Ebben, Xia, et al., 1999 Hemodialysis pts. in Medicare database | 33,122 | 30-<33 | RR=1.00 | RR=1.00 | RR=1.00 | | Pts. in the Hct > 36% group in this database may have a negative selection bias because medical justification is necessary to permit payment for epoetin claims with Hct >36%
Ma, Ebben, Xia, et al., 1999 Hemodialysis pts. in Medicare database | 10,129 | 33-<36 | RR = 0.90 ^1^ (95% CI=0.85-0.95) | RR = 0.92 ^1^ (95% CI=0.85-0.99) | RR = 0.94 (95% CI=0.81-1.10) | | Pts. in the Hct > 36% group in this database may have a negative selection bias because medical justification is necessary to permit payment for epoetin claims with Hct >36%
Ma, Ebben, Xia, et al., 1999 Hemodialysis pts. in Medicare database | 685 | >36 | RR = 1.06 (95% CI=0.89-1.27) | RR = 1.15 (95% CI=0.90-1.47) | RR = 1.04 (95% CI=0.62-1.73) | | Pts. in the Hct > 36% group in this database may have a negative selection bias because medical justification is necessary to permit payment for epoetin claims with Hct >36%
Collins, Hao, Ebben, et al., 1999c Abstract only 82,879 Incident CAPD/CCPD or HD Medicare pts. during period 1993 to 1996. | 33,800 HD 2,530 PD | 30-<33 | RR=1.00
Collins, Hao, Ebben, et al., 1999c Abstract only 82,879 Incident CAPD/CCPD or HD Medicare pts. during period 1993 to 1996. | 21,400 HD 1,520 PD | >36 | HD: RR=0.85 p=0.0001 PD: RR=0.85 p=0.01
Collins, Hao, Ebben, et al., 1999c Abstract only 82,879 Incident CAPD/CCPD or HD Medicare pts. during period 1993 to 1996. | 2,630 HD 305 PD | 33-<36 | HD: RR=0.81 p=0.0001 PD: RR=0.95 p=0.67

Rows in italics indicate study available as abstract.

1 This RR estimate was derived from the model adjusted for risk factors without severity of disease.When severity of disease measures (including blood transfusions, vascular access procedures, and hospital length of stay) were included in the model, the RR for all-cause mortality in the 33-<36% Hct group was 0.96 (95% CI=0.91-1.01) and RR for cardiac mortality in the 33-<36% Hct group was 0.97 (95% CI=0.90-1.05), both relative to the 30-<33% Hct group.

Evidence Table 5. Quality of life

Study/Population | Assessment Tool(s) | N Enr | Group Hct | N Grp | Results | Comments
Randomized controlled clinical trials
Wells, Coyle, Lee, et al., 1998 Abstract only (Canadian Study) HD pts. with asymptomatic LVH or LVD | Kidney Disease Questionnaire^1^ SF-36^2^ Health Utilities Index (HUI)^3^ | 130 total 61 LVH 69 LVD | 30.0 40.5 | Not given Not given | For all pts., KDQ and SF-36 subscales showed improvement at 24 and 48 weeks. No change for the HUI. For normal Hct group, greater improvement seen in 2 out of 5 KDQ subscales at 24 weeks: fatigue (p=0.004) and relationships (p=0.016). Stratified analysis: No differences in QOL for LVH pts.In LVD pts., there was significant improvement at 24 weeks in 3 KDQ subscales: depression (p=0.039), fatigue (p=0.026), and relationships (p=0.004).
Nonrandomized controlled clinical trials
Moreno, Sanz-Guajardo, Lopez-Gomez, et al., 2000 Pre/post Stable pts. on HD who had received epoetin for at least 3 mos. and had a stable Hct >28%. | Karnofsky Performance Scale (KS) ^4^ Sickness Impact Profile (SIP) ^5^ | 156 | Pre 31 ± 2 | 115 | Pre and post comparisons for quality of life | Lower SIP scores mean better quality of life.
  Mean (SD) | Median | Change | p value
  SIP Physical Dimension
  5.4 (1.2) | 3.3 | approx
  4.1 (1.12) | 1.2 | 2 pts | >0.005
  SIP Psychosocial Dimension
  9.2 (1.8) | 6.8 | approx
  7 (1.7) | 4.6 | 2 pts | >0.001
  SIP Global score
  8.9 (1.39) | 7.9 | approx
  7.25 (1.3) | 5.5 | 2 pts | >0.001
  Karnofsky scale
  75.6 (2.7) | 80 | approx
  78.4 (2.8) | 80 | 0-3 pts | >0.01
Moreno, Sanz-Guajardo, Lopez-Gomez, et al., 2000 Pre/post Stable pts. on HD who had received epoetin for at least 3 mos. and had a stable Hct >28%. | Karnofsky Performance Scale (KS) ^4^ Sickness Impact Profile (SIP) ^5^ | 156 | Post 38.5 ± 2.5 | 115 | Pre and post comparisons for quality of life | Higher Karnofsky scores mean better functional status.
Mason and McMahon, 1997 Abstract only Prospective, double-blind crossover study Stable HD pts. | Sickness Impact Profile (SIP) | 10 | 30 42 | 10 10 | SIP scores at Hct of 42% were significantly better than at Hct of 30% for the Global (5.1±1.5 vs. 11.5±3.6, p < 0.02) and Psychosocial Dimension scores (3.0±1.7 vs. 13.7±4.6, p<0.02). Neither the Global nor Dimensional scores showed significant improvement over baseline (Hct = 25.8%) at Hct of 30%.
Mason and McMahon, 1997 Abstract only Prospective, double-blind crossover study Stable HD pts. | Employment status | | | | There was a progressive improvement in employment status as Hct increased which was significant at Hct of 42% (p<0.01).
Eschbach, Glenny, Robrtson, et al., 1993 Abstract only | Quality of life questionnaire Nottingham Health Profile^6^ | 10 | 32.6±1.5 42.0±1.9 | 10 10 | Perceived health improved from good to excellent in 50% to 90% of pts. Depression, muscle weakness, and leg cramps decreased Nottingham Health profile: energy improved from 23.8 to 4.8, sleep 43.2 to 17.8 | QOL changes reverted to baseline in 3 pts. who returned to baseline Hct
Cross-sectional analyses
Besarab, Bolton, Browne, et al., 1998 CHF or IHD pts. undergoing HD | Medical Outcomes Study Short-Form Health Survey (SF-36) ^2^ Time of assessment: baseline and at 6-month intervals | 1,233 | 30±3 42±3 | 615 control Hct 618 normal Hct | The physical-function score part of the QOL questionnaire at 12 mos. increased by 0.6 points for each percentage point in Hct (p=0.03) Using this, an increase in Hct from 30% to 42% would be associated with a 7.2 point increase in physical function score (clinically meaningful) No other significant differences in the other (7) scales (subscores) | Very limited reporting of QOL results. Unspecified method of data analysis. Does not appear to be a comparison between QOL scores between the 2 groups but rather a comparison of hematocrit versus quality of life scores in the population as a whole.
Moreno, Lopez-Gomez, Sanz-Guajardo, et al., 1996 Pts. with CRF on dialysis, aged >15 yrs., with absence of vascular access problems, and at least 3 mos. since the start of dialysis treatment and on the same dialysis technique if on epoetin for at least 3 mos. on the treatment, and at least 3 mos. since the last major complication (hospitalization of 7 days or more or with defined consequences) | Karnofsky Performance Scale (KS) ^4^ Sickness Impact Profile (SIP) ^5^ | 1,013 | Total <24 24-30 30-36 >36 | 105 385 335 85 | Increased Hct was associated with better SIP scores in the regression model. Global score (p<0.05) and Physical Dimension (p<0.01) Sickness Impact Profile No significant differences were found on the psychosocial dimension of the SIP or the KS. | These analyses were adjusted for differences in the case mix in age, comorbidity index, presence of diabetes mellitus, socioeconomic level, and educational level
  Hematocrit | Global Score | 95%CI
  30-36 | 10.6 | 9.9-11.6
  >36 | 9.9 | 8.4-11.6
  Hematocrit | Physical Dimension | 95%CI
  30-36 | 6.5 | 5.9-6.9
  >36 | 6.1 | 5.1-7.1

1 Kidney Disease Questionnaire has 5 subscores: fatigue, depression, relationships with others, frustration, and physical symptoms.Each subscore is scored on a Likert scale ranging from 7 (no problem) to 1 (a severe problem).

2 Medical Outcomes Study Short-Form Health Survey (SF-36) has 8 subscores each ranging from 0 (severe limitation) to 100 (no limitation):physical function, social function, physical role, emotional role, mental health, energy, pain, and general health perception.

3 Health Utilities Index (HUI) evaluates four major areas of health-related quality of life: physical function (including mobility and physical activity), role function (including self-care and role activity), social-emotional function (including well-being and social activity), and health problems.

4 Karnofsky Performance Scale measures performance on a scale from 0 (worst performance) to 100 (best performance).

5 Sickness Impact Profile (SIP) has a global score and two subscores (physical and psychosocial) with each score ranging from 0 (no impairment) to 100 (totally impaired).Thus lower numbers mean better quality of life.

6 Nottingham Health Profile (NHP) has two parts. In the first part, there are questions relating to 6 categories:sleep, physical mobility, energy, pain, emotional reactions, and social isolation.Scores on each dimension range from 0 (most healthy) to 100 (least healthy).The second part addresses how a health condition has affected their employment, household activities, social life, home life, sex life, hobbies and interests, and holidays.

Rows in italics indicate study available as abstract.

Evidence Table 6. Hospital utilization

Study/Population | N | Group Hct (%) | Hospitalization All-Cause | Hospitalization Events | Length of Stay
Randomized controlled clinical trials
Besarab, Bolton, Browne, et al., 1998 | 615 | 30±3 | 425 (69%)
CHF or IHD pts. undergoing HD | 618 | 42±3 | 445 (72%) p=0.29
Nonrandomized controlled clinical trials
Moreno, Sanz-Guajardo, Lopez-Gomez, et al., 2000 | 115 | 31 ± 2
  Total number of hospitalizations | Admissions per pt. year
  19 | 0.33
  8 | 0.14
  Total days
  152
  47
Pre/post | 115 | 38.5 ± 2.5
Stable pts. on HD who had received epoetin for at least 3 mos. and had a stable Hct >28%. | | | | 58% reduction in number of hospitalizations p<0.05 | 69% reduction in length of stay p<0.05
Cross-sectional analyses
Levin, Lazarus, Nissenson, et al., 1993 | Total=324 | | | (per pt. year)
Levin, Lazarus, Nissenson, et al., 1993 | 131-242 | <30 | | 1.44
Levin, Lazarus, Nissenson, et al., 1993 | 40-107 | 30-33 | | 0.96
Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study | 16-52 | 33.1-36 | | 0.72
Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study | 2-21 | >36 | | 0.60
Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study | (Varied by month) | | | No significance level provided
Xia, Ebben, Ma, et al., 1999 Medicare HD pts. with at least 4 epoetin claims and 4 hematocrit levels surviving a 6-month entry period from July 1-December 31, 1993 | 71,717 | Total | Cox Model adjusted for severity of disease RR (95% CI) | Admissions per pt. year
Xia, Ebben, Ma, et al., 1999 Medicare HD pts. with at least 4 epoetin claims and 4 hematocrit levels surviving a 6-month entry period from July 1-December 31, 1993 | 71,717 | 30-<33 | 1.0 (referent) | 1.87 | 14.8
Xia, Ebben, Ma, et al., 1999 Medicare HD pts. with at least 4 epoetin claims and 4 hematocrit levels surviving a 6-month entry period from July 1-December 31, 1993 | 71,717 | 33-<36 | 0.93 (CI=0.91-0.96) | 1.62 | 13.6
Xia, Ebben, Ma, et al., 1999 Medicare HD pts. with at least 4 epoetin claims and 4 hematocrit levels surviving a 6-month entry period from July 1-December 31, 1993 | 71,717 | >36 | 1.12 (CI=1.02-1.23) | 1.83 | 11.6
Xia, Ebben, Ma, et al., 1999 Medicare HD pts. with at least 4 epoetin claims and 4 hematocrit levels surviving a 6-month entry period from July 1-December 31, 1993 | 71,717 | | | p=0.0001 | 14.3
Xia, Ebben, Ma, et al., 1999 Medicare HD pts. with at least 4 epoetin claims and 4 hematocrit levels surviving a 6-month entry period from July 1-December 31, 1993 | 71,717 | | | | p=0.0001
Collins, Hao, Ebben, et al., 1999a | 2,874 | 30-<33 | -
Abstract only | 1,632 | 33-<36 | 0.88 p<0.03
Incident Medicare CAPD/CCPD pts. during period 1993 to 1996. | 329 | >36 | 0.88
Incident Medicare CAPD/CCPD pts. during period 1993 to 1996. | 329 | >36 | Note that hospitalization for infection was lower in Hct >36% group (RR=0.61, p<0.03), but no significant differences for cardiac hospital events noted.
Collins, Hao, Ebben, et al., 1999b | 37,732 | 30-<33 | --
Abstract only | 22,385 | 33-<36 | 0.89 p<0.002
Incident Medicare HD pts. during period 1993 to 1996. | 2,657 | >36 | 0.80 p<0.002
Incident Medicare HD pts. during period 1993 to 1996. | | | In this study no significant difference in hospitalization for infection was seen, but cardiac hospitalization was lower for both the Hct 33-<36 group (RR=0.89, p<0.002) and Hct >36 group (RR=0.74, p<0.002)

Rows in italics indicate study available as abstract.

Evidence Table 7. Use of red blood cell transfusion

Study/Study Design/Population | N | Group Hct (%) | Received RBC Transfusion Patients (%)
Besarab, Bolton, Browne, et al., 1998 | 615 | 30±3 | 192 (31%)
Randomized, prospective, open-label trial | 618 | 42±3 | 129 (21%)
CHF or IHD pts. undergoing HD | | | p<0.001

Evidence Table 8. Cardiac health outcomes

Study/Study Design/Population | N | Group Hct (%) | MI Patients (%) | Angina Requiring Hospitalization Patients (%) | CHF Requiring Hospitalization Patients (%) | PTCA Patients (%) | CABG Patients (%)
Randomized controlled clinical trials
Besarab, Bolton, Browne, et al., 1998 CHF or IHD pts. undergoing HD Median followup 14 mos. | | | Nonfatal MI
Besarab, Bolton, Browne, et al., 1998 CHF or IHD pts. undergoing HD Median followup 14 mos. | 615 | 30±3 | 4 (2.3%) | 76 (12%) | 90 (15%) | 15 (2%) | 21 (3%)
Besarab, Bolton, Browne, et al., 1998 CHF or IHD pts. undergoing HD Median followup 14 mos. | 618 | 42±3 | 19 (3.1%) p=0.48 | 78 (13%) p=0.93 | 80 (13%) p=0.41 | 17 (3%) p=0.86 | 20 (3%) p=0.86
Besarab, Bolton, Browne, et al., 1998 CHF or IHD pts. undergoing HD Median followup 14 mos. | | | Cardiac mortality was 18.2% versus 20.2% (significance level not provided)
Cross-sectional analyses
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | 324 Pt.-mos. (%) | | # Events (events/pt. month)
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | 48.6 | <30 | 2 (0.001)
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | 32.4 | 30-33 | 4 (0.003)
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | 14.1 | 33.1-36 | 1 (0.002)
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | 4.8 | >36 | 0
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | | | No significance level provided

Evidence Table 9. Cardiac intermediate health outcomes

Study/Population/Duration of Study | Hct (%) | N | Results | Outcome
Randomized controlled clinical Trials
Foley, Parfrey, Morgan, et al. 1998 Abstract only (Canadian Study) HD pts. with asymptomatic LVH or LVD 40 weeks | 28.5-31.5 39-42 | 62 of 70 (88%) LVH pts. and 63 of 76 (83%) LVD pts. had repeat cardiac echo and are included in analysis | LVH pts.:^1^ Change in mass index = -15, 7, 26 g/m^2^ Change in cavity volume index = -5, 10, 31ml/m^2^ LVD pts.:^1^ Change in mass index = -23, 11, 16 g/m^2^ Change in cavity volume index = -34, 17, -4 ml/m^2^ LVH pts.:^1^ Change in mass index = -21, 4, 15 g/m^2^ (p = n.s. for low vs. high Hct) Change in cavity volume index = -14, 5, 16 ml/m^2^ (p = 0.05 for low vs. high Hct) LVD pts.:^1^ Change in mass index = -32, -11, 11 g/m^2^ (p = ns for low vs. high Hct) Change in cavity volume index = -42, 18, 19 ml/m^2^ (p = ns for low vs. high Hct) | Concentric LVH or LVD
Nonrandomized controlled clinical trials
Mason, Skinner, Sangkabutra, et al., 1997 Abstract only Prospective, double-blind crossover study Chronic HD pts. Duration not specified | 30 42 | 11 11
  LVMI g/m^2^ | LVEDD cm | LVESD cm
  139 | 5.2 | not significantly changed
  123 p< 0.01 | 4.7 p<0.01
Eschbach, Glenny, Robertson, et al., 1993 Abstract only HD pts. 4 mos. | 32.6±1.5 42.0±1.9 | 13 13 | LV mass did not change by echocardiography, but cardiac index decreased toward normal (5.1 to 4.3 l/min) TPRI increased but remained normal (1625 to 1886 dynes-sec/cm^2^) | Left ventricular mass Cardiac index TPRI
Cross-sectional analyses
Levin, Thompson, Ethier, et al., 1999 Pts. with chronic renal failure but not on dialysis 12 mos. | N/A | 246 | Between baseline and 12-month followup, pts. without LV growth (n= 191) had smaller decrease in mean Hct compared with pts. with LV growth (n=55) (-0.33±0.36 versus -2.55±0.33, respectively) p=0.001 Each 1.5% decrease in Hct increased the odds of having LV growth by 32% (OR=1.32, 95% CI=1.1, 1.58) The mean baseline Hct level was approximately 38 percent in this group of pts. No significant difference was noted in Hct levels in pts who had a progression of cardiac symptoms versus those who did not have progressing cardiac symptoms (36.6%±5.7% vs. 38.7 ± 5.7%; p=0.06) | Left ventricular growth Cardiac symptoms
Levin, Singer, Thompson, et al., 1996 Pts. referred to nephrology clinic for assessment and followup of renal insufficiency between February 1990 and March 1993 as part of prospective study Duration-not applicable | 33.0±6.2 35.7±5.9 | 68 w/LVH 107 w/o LVH | Pts. without LVH had a higher mean Hct 35.7±5.9 compared to pts. with LVH 33.0±6.2, p=0.0049 For each decrease in Hct of 3% the risk of LVH increased by 6%, OR=0.98 (p=0.0062) for presence of LVH | LVH

1 All results expressed as 25th percentile, median, and 75th percentile.

Rows in italics indicate study available as abstract.

Evidence Table 10. Exercise performance intermediate health outcomes

Study/Study Design/Population | Group Hct (%) | N Enr | N Eval | Peak Work Rate (W) mean (SD) | Work Done (kJ) mean (SD) | Peak Oxygen Consumption mean (SD) | Exercise Duration (s) | 6-Minute Walk Distance | Peak Heart Rate (bpm) mean (SD) | Peak Ventilation V_E_, l/min mean (SD) | Comments
Randomized controlled clinical trials
McMahon, McKenna, Sangkabutra, et al., 1999 Randomized, double-blind, crossover study Stable, sedentary HD pts. without cardiovascular, respiratory, or musculoskeletal disease | 30 | 30 | 14 | 134±9 | 33.2±3.6 | 1.61±0.11 70% predicted | | | 155±6.4 | 74.8±4.9 | Dropouts: 1 died, 6 transplanted, 1 significant uremic bone disease, 2 poor compliance, 6 refused to continue Improvements in Peak Work Rate and Work Done were more marked in younger pts. Exercise performance was improved with higher hematocrit, but remained below predicted levels for age and weight-matched sedentary controls Effects on serum potassium during exercise showed 18% improved K+ regulation in response to work/stress at higher hematocrit level
McMahon, McKenna, Sangkabutra, et al., 1999 Randomized, double-blind, crossover study Stable, sedentary HD pts. without cardiovascular, respiratory, or musculoskeletal disease | 42 | 30 | 14 | 145±9 | 41.4±4.0 | 1.90±0.11 83% predicted | | | 162±6.8 | 80.5±5.7
McMahon, McKenna, Sangkabutra, et al., 1999 Randomized, double-blind, crossover study Stable, sedentary HD pts. without cardiovascular, respiratory, or musculoskeletal disease | | | | p<0.05 | p<0.01 | p<0.01 units-l/min | | | Not significant | Not significant
Stray-Gunderson, Sams, Goodkin, et al., 1997 Abstract only | 31±2 42±2 | ? ? | 27 27 | 101±35 134±49 p<0.001 | | 17.9±3.6 21.5±5.1 p<0.001 | | | | | For peak work rate: There was a 9% increase attributable to correcting anemia alone and a 23% increase attributable to exercise alone.The combination of correction of anemia and exercise resulted in a 33% increase. For peak oxygen consumption: There was a 10% increase attributable to correcting anemia alone and an 8% increase attributable to exercise alone.The combination of correction of anemia and exercise resulted in a 20% increase.
Nonrandomized controlled clinical trials
Suzuki, Tsutsui, Yokoyama, et al., 1995 Pts. on chronic HD with no circulatory or musculoskeletal complications | Approx. 30 | Not avail. | 39 | | | 27.1±2.7 | 467±85 | | 150±22 | | Peak oxygen consumption remained below predicted levels for 7 out of 10 pts.
Suzuki, Tsutsui, Yokoyama, et al., 1995 Pts. on chronic HD with no circulatory or musculoskeletal complications | 35-40 | Not avail. | 10 | | | 30.7±2.4 p<0.01 units=ml of O_2_/kg/min | 471±90 Not significant | | 144±15 Not significant | | Peak oxygen consumption remained below predicted levels for 7 out of 10 pts.
Eschbach, Glenny, Robertson, et al., 1993 Abstract only HD pts. | 32.6±1.5 | Not avail. | 13 | | | Max. oxygen uptake increased 24% and correlated with change in Hct | Exercise duration on the bicycle increased 20% | No difference | | | Pulmonary diffusion of CO increased from 54% to 64% of predicted values Quadricep isometrics increased (p=0.01) No difference in hand grip
Eschbach, Glenny, Robertson, et al., 1993 Abstract only HD pts. | 42.0±1.9 | Not avail. | 13 | | | Max. oxygen uptake increased 24% and correlated with change in Hct | Exercise duration on the bicycle increased 20% | No difference | | | Pulmonary diffusion of CO increased from 54% to 64% of predicted values Quadricep isometrics increased (p=0.01) No difference in hand grip

Rows in italics indicate study available as abstract.

Evidence Table 11. Cognitive function intermediate health outcomes

Study/Study Design/Population | Group Hct (%) | N Enr | N Eval | Results | Comments
Nonrandomized controlled clinical trials
Pickett, Theberge, Brown, et al., 1999 | 31.6 42.8 | 20 20 | 20 20 | | EEG spectral analysis with eyes closed was not significantly changed (data not shown)
  EEG Spectral analysis, Eyes Open, mean (SD)
  Pz | Cz | Fz
  0.35 (0.06) | 0.39 (0.06) | 0.40 (0.06)
  0.34 (0.06) | 0.37 (0.06) | 0.38 (0.06) p<0.02
Pickett, Theberge, Brown, et al., 1999 | 31.6 42.8 | 20 20 | 20 20 | | Significant reduction in P300 amplitude in Fz electrode only
  Cognitive ERP, Auditory Oddball Task
  P300 amplitude | | | P300 latency.
  Pz | Cz | Fz | Pz | Cz | Fz
  15.54 (5.55) | 14.43 (6.20) | 12.31 (7.31) | 374 (37) | 364 (40) | 364 (46)
  15.45 (5.50) | 14.63 (6.59) | 10.75 (7.46) | 369 (52) | 355 (62) | 355 (51)
  p = no significant time effect | | | p = no significant time effect
Pickett, Theberge, Brown, et al., 1999 | 31.6 42.8 | 20 20 | 19 19 | | Significant reduction in P300 amplitude in Fz electrode only
  Cognitive ERP, simple Continuous Performance Task
  P300 amplitude | | | P300 latency.
  Pz | Cz | Fz | Pz | Cz | Fz
  15.23 (7.09) | 14.51 (8.40) | 11.961 (9.13) | 398 (50) | 395 (49) | 385 (48)
  15.62 (7.52) | 14.42 (8.43) | 8.95 (7.39) | 405 (64) | 408 (64) | 408 (64)
  p = no significant time effect | | | p = no significant time effect
Pickett, Theberge, Brown, et al., 1999 | 31.6 42.8 | 20 20 | 19 19 | | Significant reduction in P300 amplitude in Fz electrode only
  Cognitive ERP, difficult Continuous Performance Task
  P300 amplitude | | | P300 latency.
  Pz | Cz | Fz | Pz | Cz | Fz
  13.68 (7.59) | 14.20 (8.81) | 11.86 (8.35) | 396 (52) | 390 (52) | 389 (52)
  15.83 (8.86) | 15.65 (11.17) | 12.04 (11.64) | 406 (69) | 404 (73) | 402 (73)
  p = no significant time effect | | | p = no significant time effect

Evidence Table 12. Sleep pattern intermediate health outcomes

Study/Study Design/Population | Group Hct (%) | N Enr | N Eval | Results | Comments
Nonrandomized controlled clinical trials
Benz, Pressman, Hovick, et al., 1999 Anemic HD pts. with complaints of disrupted sleep and found to have PLMS | 32.3 ± 3.8 | 10 | 10 | PLMS index = 147.5±121 APLMS index = 82.8±99.7 Mean wakefulness test = 9.7±13.8 minutes Stage 1 sleep = 61.9±27.1 minutes REM sleep = 37.9±23.1 minutes PLMS index = 97.7±82.9 (p=0.03) APLMS index = 40.3±50.3 (p<0.01) Mean wakefulness test = 17.7±13.3 minutes (p<0.04) Stage 1 sleep = 46.9±25.7 minutes (p=0.04) REM sleep = 53.9±27.4 minutes (p=0.07) Apnea index and O_2_saturation not significantly changed. | PLMS defined as periodic leg movements of sleep. PLMS index defined as number of periodic limb movements per hour of sleep. APLMS index defined as number of PLMS followed by arousal from sleep per hour of sleep.
Benz, Pressman, Hovick, et al., 1999 Anemic HD pts. with complaints of disrupted sleep and found to have PLMS | 42.3 ± 2.3 | 10 | 10

Evidence Table 13. Nutritional status intermediate outcomes

Study/Study Design/Population | Group Hct (%) | N Enr | N Eval | Results | Comments
Cross-sectional analyses
Riedel, Hampl, Nundel, et al., 1996 Abstract only HD pts. | 27-33 | ? | 25 | Leucine = 81±25 μmol/L Valine = 140±21 μmol/L KIC = 11±5 μmol/L | P values only given in abstract for comparison of low Hct (<24)(data not shown) vs. high Hct (36-42) and vs. control group
Riedel, Hampl, Nundel, et al., 1996 Abstract only HD pts. | 36-42 | ? | 25 | Leucine = 112±45 μmol/L Valine = 183±39 μmol/L KIC = 15±5 μmol/L | P values only given in abstract for comparison of low Hct (<24)(data not shown) vs. high Hct (36-42) and vs. control group
Riedel, Hampl, Nundel, et al., 1996 Abstract only HD pts. | Healthy control | ? | ? | Leucine = 130±27 μmol/L Valine = 232±38 μmol/L KIC = 36±8 μmol/L HD pts. who went from Hct of 27% to 42% also showed a weight gain of 3. 19±1.33 kg | P values only given in abstract for comparison of low Hct (<24)(data not shown) vs. high Hct (36-42) and vs. control group

Rows in italicsindicate study available as abstract.

Evidence Table 14. Treatment-related morbidity associated with normalization of hematocrit

Study/Study Design/Population | N | Group Hct (%) | Blood Pressure | Vascular Access Thrombosis Patients (%) | CVA | TIA | Peripheral Gangrene | Intestinal Ischemia | Seizures | Clotting Tests (PAI-1 and t-PA)
Randomized controlled clinical trials
Besarab, Bolton, Browne, et al., 1998 | 615 | 30±3 | No difference between groups | 176 (29%) | No difference between groups | No difference between groups | No difference between groups | No difference between groups | No difference between groups
CHF or IHD pts. undergoing HD | 618 | 42±3 | No difference between groups | 243 (39%) p=0.001 | No difference between groups | No difference between groups | No difference between groups | No difference between groups | No difference between groups
Nonrandomized controlled clinical trials
Moreno, Sanz-Guajardo, Lopez-Gomez, et al., 2000 Pre/post Stable pts. on HD who had received epoetin for at least 3 mos. and had a stable Hct >28%. | 156 | 31 ± 2 38.5 ± 2.5 | No significant difference but 3 (2%) had difficult to control hypertension | Nine pts. (5.7%) were censored due to vascular access thrombosis.The cumulative probability of developing thrombosis over the 6-month period was 0.067.
Nonrandomized controlled clinical trials
Stray-Gunderson, Sams, Goodkin, et al., 1997 Abstract only | 27 27 | 31±2 42±2 | | No difference in incidence of thrombotic events
Mason, Skinner, Sangkabutra, et al., 1997 Abstract only HD Pts. | 11 11 | 42 30 | No significant difference between groups
Mason and McMahon, 1997 Abstract only HD Pts. | 10 10 | 42 30 | No significant difference between groups | No significant difference
Eschbach, Glenny, Robertson, et al., 1993 Abstract only HD Pts. | 13 | 32.6±1.5 | 92 ± 16 | No clotted fistulas (n=7) | None occurred | | | | | No changes
Eschbach, Glenny, Robertson, et al., 1993 Abstract only HD Pts. | 13 | 42.0±1.9 | 91 ± 19 No significance level provided. Two pts. needed more medication. | No clotted fistulas (n=7) | None occurred | | | | | No changes
Suzuki, Tsutsui, Yokoyama, et al., 1995 HD pts. excluding circulatory or musculoskeletal problem | 39 | Approx 30 | Not reported for controls. 2 of 5 (40%) of hypertensives needed more medication
Suzuki, Tsutsui, Yokoyama, et al., 1995 HD pts. excluding circulatory or musculoskeletal problem | 10 | 35-40 | Not reported for controls. 2 of 5 (40%) of hypertensives needed more medication
Cross-sectional analyses
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | Total 324 pt.-mos. (%) | | No differences between groups Accelerated/malignant hypertension events/pt. month | NR by hematocrit group | Events/pt. Month | Events/pt. Month | NR | NR | Events/pt. Month | NR
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | 48.6% 32.4% 14.1% 4.8% | <30 30-33 33.1-36 >36 | 1 (0.001) 1 (0.001) 1 (0.002) 0 | | 2 (0.001) 0 1 (0.002) 1 (0.006) | 2 (0.001) 0 0 0 | | | 7(0.004) 0 1(0.002) 0
Levin, Lazarus, Nissenson, et al., 1993 Adult pts. on dialysis in the U.S. enrolled in a Phase IV open label, multicenter study >12 month followup | | | | | No significance level provided | No significance level provided | | | No significance level provided

Rows in italicsindicate study available as abstract.

Evidence Table 15. Randomized controlled clinical studies

Study | Study Design | N Enr | N Eval | Patient Population | Inclusion/Exclusion Criteria | Treatment Protocol | Outcomes Reported
Besarab, Bolton, Browne, et al., 1998 | Randomized, prospective, open-label trial | 1,233 | 1,233 | CHF or IHD HD pts. Age Normal Hct = 65±12 yrs. Low Hct = 64±12 yrs. Race; - Normal Hct =; - 45% White; - 41% Black; - 8% Hispanic; - 6% Other; - Low Hct =; - 42% White; - 44% Black; - 9% Hispanic; - 5% Other; Gender Normal Hct = 50% female Low Hct = 52% female Duration of dialysis Normal Hct = 3.2±3.6 yrs Low Hct = 3.1±3.3 yrs NYHA Class:; - Normal Hct =; - 29% class I; - 51% class II; - 19% class III; - Low Hct =; - 31% class I; - 52% class II; - 15% class III | DBP >100 mmHg LE <6 mos. Severe cardiac disability (NYHA class IV) MI PTCA Coronary-artery bypass grafting in 3 mos. prior to study Pericardial disease Cardiac valvular disease likely to require surgery Cardiac amyloidosis Androgen therapy | Normal Hct group (N= 618) treated with epoetin to achieve and maintain target Hct of 42±3% Low Hct group (N=615) treated with epoetin to maintain Hct at 30±3% Duration of study = 3 yrs. Intention-to-treat analysis | Primary endpoint: Death or first nonfatal MI: Secondary endpoints: CHF requiring hosp. Angina pectoris requiring hosp. CABG PTCA Hospitalization for all causes Change in cardiovascular drugs Red-cell transfusion Changes in QOL scores Also measured: Blood pressure Vascular access thrombosis CVA TIA Peripheral gangrene Intestinal ischemia Seizures
Besarab, Bolton, Browne, et al., 1998(cont'd) | Randomized, prospective, open-label trial | 1,233 | 1,233 | HTN: Normal Hct = 71% Low Hct = 69% Diabetes Normal Hct = 54% Low Hct = 58% Peripheral vascular disease Normal Hct = 39% Low Hct = 38% Hematocrit (baseline) Normal Hct = 30.5±3.0 Low Hct = 30.5±2.9

Evidence Table 16. Studies reporting cross-sectional analyses

Study | N Eval | N Inc | Patient Population | Data Source | Methods of Analysis | Outcomes Reported
Carson, Duff, Poses, et al., 1996 | | 1958 | Consecutive pts. aged 18 yrs. of age or older who underwent surgery and declined blood transfusion for religious reasons between 1981 and 1994 in 12 community and university hospitals. Open-heart procedures excluded. Must have agreed to have records copied and reviewed. | Primary data | Logistic regression | Primary outcome: 30-day mortality Secondary outcome: 30-day mortality or in-hospital 30-day morbidity
Carson, Duff, Poses, et al., 1996 | | 1958 | Gender = 29.4% male Age 18-59 = 68.1% 60-74 = 23.1% >75 = 8.8% Race = 52.6% white Cancer (Hx of in past 5 yrs)=10.3% Diabetes = 9.8% Hypertension = 28.6% Angina pectoris = 3.9% CHF = 3.4% Atherosclerosis = 9.5% CVD = 11.3% Cardiopulmonary disease = 11.8% | Primary data | Logistic regression | Primary outcome: 30-day mortality Secondary outcome: 30-day mortality or in-hospital 30-day morbidity
Kusunoki, Kimura, Nakamura, et al., 1981 | | 27 | Pts. with ischemic cerebrovascular disease in a physiological range of Hct between 31% and 53% | Primary data | Correlation coefficient Cochran's procedure for analysis of variance | Cerebral blood flow Oxygen delivery
Kusunoki, Kimura, Nakamura, et al., 1981 | | 27 | Mean age = 50±14 yrs Gender = 96.4% male | Primary data | Correlation coefficient Cochran's procedure for analysis of variance | Cerebral blood flow Oxygen delivery

Evidence Table 17. Studies addressing impact of cardiovascular disease on relationship between hematocrit and outcomes

Study | N | Group Hct (%) | Results | Comments
Randomized controlled clinical trial
Besarab, Bolton, Browne, et al., 1998 | 615 | 30±3 | Evidence Tables 4 through 14
Besarab, Bolton, Browne, et al., 1998 | 618 | 42±3 | Evidence Tables 4 through 14
Cross-sectional analysis
Carson, Duff, Poses, et al., 1996 | Not given | 30 33 36 | | There was a significant interaction between Hct level and cardiovascular disease (p=0.03 for interaction term). The risk of death was greater for pts. with a low Hct and cardiovascular disease. As Hct decreased below 30%, the risk of death increased much more dramatically in pts. with cardiovascular disease. When postoperative decline in Hct was examined (due to missing values n=1,080 thus 55.2% of pts. were evaluable), a decline in Hct of 6% or less in the absence of cardiovascular disease was not associated with an increased risk of postoperative death. The risk of death was greatest in pts. with cardiovascular disease and a decline in Hct of 12% or more. This analysis was based on small numbers and this group of pts. was older and sicker than the larger group of pts. on which the main analysis was based. Only significant confounders were APS+age score (p<0.001), Charlson score without cardiovascular points (p<0.001 for > 3 points) and cardiovascular disease (p=0.01).
  Adjusted odds ratio ^1^ for perioperative mortality
  No Cardiovascular Disease | Cardiovascular Disease
  1.9 | 3.0
  1.2 | 2.0
  1.0 | 1.0
  No statistical comparison reported
  ---------------------------------
Carson, Duff, Poses, et al., 1996 | 109 212 1,411 | 30-<33 33-<36 >36
  Perioperative Mortality Unadjusted RR (95% CI) | Perioperative Mortality or In-hospital Morbidity Unadjusted OR (95% CI)
  4.6% 3.6 (1.4-9.5) | 12.8% 3.2 (1.9-5.6)
  2.4% 1.9 (0.7-4.9) | 6.6% 1.7 (0.9-2.2)
  1.3% 1.0 (reference) | 4.0% 1.0 (reference)

1 Estimated from figure in article; no confidence intervals available; adjusted for APS+age score and Charlson score without cardiovascular points.

Evidence Table 18. Studies addressing impact of cerebrovascular disease on relationship between hematocrit and outcomes

Study/Study Design/Population | N | Group Hct (%) | Oxygen Delivery (ml O_2_/100g/min) | Cerebral Blood Flow (ml/100g/min) | Arterial Oxygen Content (ml O_2_/dl)
Cross-sectional analysis
Kusunoki, Kimura, Nakamura, et al., 1981 | 27 | Mean 42±5 Range 31-53% | Means ± SEM | Significant inverse relationship between CBF and Hct (r=0.49, p<0.05) | Exact linear correlation between oxygen content and Hct (r=0.91, p<0.001)
Kusunoki, Kimura, Nakamura, et al., 1981 | 27 | 30-35 | 6.35±0.33 | Significant inverse relationship between CBF and Hct (r=0.49, p<0.05) | Exact linear correlation between oxygen content and Hct (r=0.91, p<0.001)
Kusunoki, Kimura, Nakamura, et al., 1981 | 27 | 35-40 | 6.71±0.22 | Significant inverse relationship between CBF and Hct (r=0.49, p<0.05) | Exact linear correlation between oxygen content and Hct (r=0.91, p<0.001)
Kusunoki, Kimura, Nakamura, et al., 1981 | 27 | 40-45 | 7.72±0.39 | Significant inverse relationship between CBF and Hct (r=0.49, p<0.05) | Exact linear correlation between oxygen content and Hct (r=0.91, p<0.001)
Kusunoki, Kimura, Nakamura, et al., 1981 | 27 | >45 | 6.83±0.63 | Significant inverse relationship between CBF and Hct (r=0.49, p<0.05) | Exact linear correlation between oxygen content and Hct (r=0.91, p<0.001)
Kusunoki, Kimura, Nakamura, et al., 1981 | 27 | | p<0.05 for Hct comparisons between 30-35% and 40-45% and between 35-40% and 40-45% | Significant inverse relationship between CBF and Hct (r=0.49, p<0.05) | Exact linear correlation between oxygen content and Hct (r=0.91, p<0.001)