# Bibliography

Abels R Rate of progression of chronic renal failure in predialysis patients treated with erythropoietin Semin Nephrol 1990 Mar 10(2 Suppl 1):20 5 2192413
Abensur H [Substitutive treatment of renal function] Arq Bras Cardiol 1995 65(1):81 3 8546603
Abraham PA, Opsahl JA, Keshaviah PR, et al Body fluid spaces and blood pressure in hemodialysis patients during amelioration of anemia with erythropoietin Am J Kidney Dis 1990 Nov;16(5):438 46 2239934
Abraham PA, Opsahl JA, Rachael K M, et al Renal function during erythropoietin therapy for anemia in predialysis chronic renal failure patients Am J Nephrol 1990 10(2):128 36 2349956
Abraham PA Health care payment policies: lessons from erythropoietin Am J Kidney Dis 1993 22(4):596 597 8213802
Abraham PA Practical approach to initiation of recombinant human erythropoietin therapy and prevention and management of adverse effects Am J Nephrol 1990 10(Suppl 2):7 14 2260619
Acchiardo SR, Moore LW, Sargent JA, et al Is hematologic response to iron and erythropoietin in hemodialysis patients affected by other factors? ASAIO Trans 1991 37(3):M183 5 1751102
Acchiardo SR, Quinn BP, Burk LB, et al Are high flux dialysis and erythropoietin treatment in a collision course? ASAIO Trans 1989 35(3):308 10 2688711
Acchiardo SR, Quinn BP, Moore LW, et al Evaluation of hemodialysis patients treated with erythropoietin Am J Kidney Dis 1991 17(3):290 4 1996571
Acharya VN, Sinha DK, Almeida AF, et al Effect of low dose recombinant human omega erythropoietin (rHuEPO) on anaemia in patients on hemodialysis J Assoc Physicians India 1995 43(8):539 42 8772973
Adair C, Lappin TR, Cotes PM Changes in concentrations of atp and other nucleotides in erythrocytes during erythropoietin treatment in haemodialysis patients Biochem Soc Trans 1992 20(2):
Adamson JW The promise of recombinant human erythropoietin Semin Hematol 1989 26(2 Suppl. 2):5 8 2658101
Adamson JWW, Egrie JC, Browne JK, et al. The use of recombinant human erythropoietin (EPO) to correct the anemia of end-stage renal disease: a progress report. Behring Inst Mitt. 1988;83:188-92. [pmid: 3071336].
Adamson JW, Eschbach JW Erythropoietin for end-stage renal disease N Engl J Med 1998 339(9):625 7 9718384
Adamson JW, Eschbach JW Management of the anaemia of chronic renal failure with recombinant erythropoietin Q J Med 1989 73(272):1093 101 2694210
Adamson JW, Schuster M, Allen S, et al Effectiveness of recombinant human erythropoietin therapy in myelodysplastic syndromes Acta Haematol 1992 87(Suppl 1):20 4 1574963
Adamson JW, Vapnek D. Recombinant erythropoietin to improve athletic performance. N Engl Med. 1991;324:698-9.
Agroyannis B, Dalmangas A, Tzanatos H, et al Effect of acetate and erythropoietin on fetal hemoglobin in hemodialyzed uremic patients (4) Blood 1995 85(12):3765 3766 7540074
Ahmad R, Hand M Recombinant erythropoietin for the anemia of chronic renal failure N Engl J Med 1987 317(3):169 70 3600706
Ahn JH, Yoon KS, Lee WI, et al Bone marrow findings before and after treatment with recombinant human erythropoietin in chronic hemodialyzed patients Clin Nephrol 1995 43(3):189 95 7774077
Ahsan N Intravenous infusion of total dose iron is superior to oral iron in treatment of anemia in peritoneal dialysis patients: a single center comparative study J Am Soc Nephrol 1998 9(4):664 8 9555669
Ahsan N Intravenous infusion of total dose iron is superior to oral iron in treatment of anemia in peritoneal dialysis patients: a single center comparative study J Am Soc Nephrol 998 9(4):664 668 9555669
Akcicek F, Ozkahya M, Cirit M, et al. The efficiency of fractionated parenteral iron treatment in CAPD patients. Adv Perit Dial. 1997;13:109-12. [pmid: 9360661].
Akiba T, KoshikawaS, Mimura N, et al Randomized double-blind study of subcutaneous recombinant human erythropoietin in predialysis uraemic patients Nephrol Dial Transplant 1992 7(7):
Albertazzi A, Di Liberato L, Daniele F, et al Efficacy and tolerability of recombinant human erythropoietin treatment in pre-dialysis patients: results of a multicenter study Int J Artif Organs 1998 21(1):12 8 9554820
Albitar S, Genin R, Fen-Chong M, et al High-dose alfacalcidol improves anaemia in patients on haemodialysis Nephrol Dial Transplant 1997 12(3):514 518 9075133
Albitar S, Meulders Q, Hammoud H, et al. Subcutaneous versus intravenous administration of erythropoietin improves its efficiency for the treatment of anaemia in haemodialysis patients. Nephrol Dial Transplant. 1995;10:40-3. [pmid: 8524493].
Alexander SR, Sullivan EK, Harmon WE, et al. Maintenance dialysis in North American children and adolescents: a preliminary report. North American Pediatric Renal Transplant Cooperative Study (NAPRTCS). Kidney Int Suppl. 1993;43:S104-9. [pmid: 8246361].
Alexander SR Pediatric uses of recombinant human erythropoietin: the outlook in 1991 Am J Kidney Dis 1991 18(4 Suppl 1):42 53 1928079
Alfurayh O, Sobh M, Barri Y, et al Aluminum overload and response to recombinant human erythropoietin inpatients under chronic haemodialysis Nephrol Dial Transplant 1992 7(9):939 943 1328942
Allegra V, Martimbianco L, Mengozzi G, et al Erythropoietin and cardiovascular risk Blood Purif 1995 13(6):301 13 8821194
Allegra V, Martimbianco L, Vasile A Lipid and apolipoprotein patterns during erythropoietin therapy: roles of erythropoietin, route of administration, and diet Nephrol Dial Transplant 1997 12(5):924 32 9175044
Altun B, Erdem Y, Haznedaroglu I, et al Effect of recombinant human erythropoietin on soluble interleukin 2 receptor (SIL-2R) levels in haemodialysis patients Nephrol Dial Transplant 1995 10(11):
Amar J, Chamontin B, Vernier I, et al [Arterial blood pressure changes, circadian rhythm and arterial elasticity in hemodialysed patients] Arch Mal Coeur Vaiss 1994 87(7):921 924 7702436
American Thoracic Society. Quality of life resource: The Nottingham Health Profile (NHP). Available at: http://www.atsqol.org/nott.html. Accessed April 2000.
Amerling R, Levin NW Erythropoietin update Kidney 1993 26(1):1 8
Amgen, Inc. Epogen^®^ (epoetin alfa) prescribing information. In: Physicians' desk reference. 53rd ed. Montvale: Medical Economics Press; 1999.
Anagnostou A, Kurtzman NA The anemia of chronic renal failure Semin Nephrol 1985 5(2):115 27 3843785
Anderson S Effects of erythropoietin in predialysis patients Am J Kidney Dis 1991 17(5 Suppl 1):103 6 2024665
Anon Correction of the anemia of end-stage renal disease with recombinant human erythropoietin N Engl J Med 1987 317(4):249 51 3600716
Anon Increase haemoglobulin and objective QoL Drugs And Therapy Perspectives 1998 11(10):14 16
Anon Iritis-like reactions due to epoetin Geneesmiddelenbulletin 1996 30(8):
Anon The investigation of erythropoietin resistance Pract. Pediatr 1993 2(5):7 8
Anon USRDS research studies Am J Kidney Dis 1991 18(5 Suppl 2):105 10 1951351
Anon Adult screening for anemia and hemoglobinopathies Nurse Pract 1995Dec 20(12):48 51
Anon Analytical methods: technical notes Am J Kidney Dis 1991 Nov 18(5 Suppl 2):111 27 1951352
Anon Anemia guidelines suggest iron as missing link in managing hematocrits Nephrol News Issues 1997Oct 11(10):
Anon CDC criteria for anemia in children and childbearing-aged women MMWR Morb Mortal Wkly Rep 1989 Jun 9 38(22):400 4
Anon CDC releases new reference criteria for anemia screening Am Fam Physician 1989 Sep 40(3):
Anon Current trends: CDC criteria for anemia in children and childbearing-aged women Am J Dis Child 1990 144(2):151 152
Anon DOQI Guidelines/fifth in a series. A focus on iron management for better HCTs Nephrol News Issues 1997 Sep 11(9):
Anon Effect of recombinant human erythropoietin on renal function deterioration in patients with anemia and progressive renal failure J Nephrol 1991 4(4):269 273
Anon Effect of recombinant human erythropoietin therapy on blood pressure in hemodialysis patients. Canadian Erythropoietin Study Group Am J Nephrol 1991 11(1):23 6 2048574
Anon Epoetin alfa: clinical trial therapy ANNA J 1989 Aug 16(5):344 8 2673077
Anon Erythropoietin 1991-biology, clinical use, and impact on patients: an international symposium. February 8-9, 1991, Nashville, Tennessee Am J Kidney Dis 1991 Oct 18(4 Suppl 1):1 116
Anon Erythropoietin for anemia and related indications Perspect Clin Pharm 1990 8(4):27 29
Anon Erythropoietin for anemia Med Lett Drugs Ther 1989 Sep 22 31(801):85 6
Anon Erythropoietin in chronic renal failure Natl Med J India 1989 2(4):159 161
Anon HCFA anemia cooperative project unveiled at ASN Dialysis And Transplantation 1996 25(1):
Anon Human recombinant erythropoietin Urologe Ausg B 1989 29(5):299 301
Anon Medication use among dialysis patients in the DMMS Am J Kidney Dis 1998 32(2 Suppl. 1):S60 S68 9713408
Anon NKF-DOQI reports significant progress in the drafting of ESRD clinical practice guidelines Dial Transplant 1996 25(5):242,244,248,250,252 3,257-8
Anon Recombinant human erythropoietin: implications for nephrology. Proceedings of a symposium. Quebec City, Canada Semin Nephrol 1990 Mar 10(2 Suppl 1):1 72
Anon Recormon (r) Munch Med Wochenschr 1991 133(37):
Anon Results of the cross-Canada survey of recombinant human erythropoietin (r-HuEPO) therapy programs. The Medicine Group (Canada) Ltd J CANNT 1992 Summer 2(3):11 5 1515304
Anon Subcutaneous erythropoietin in the treatment of renal anemia? Fortschr Med 1991 109(19):
Anon Treatment modalities for ESRD patients. USRDS. United States Renal Data System Am J Kidney Dis 1997 Aug 30(2 Suppl 1):S54 66 9259693
Antonoff A EPO-one year later: a look at rehabilitation. Patient attitude key in impacting the job rate Nephrol News Issues 1990 Jun 4(6):33 4, 48 2402310
Arinsoy T, Ozdemir O, Arik N, et al Recombinant human erythropoietin treatment may induce antithrombin-III depletion Nephron 1992 62(4):480 1 1300451
Aronoff GR, Duff DR, Sloan RS, et al The treatment of anemia with low-dose recombinant human erythropoietin Am J Nephrol 1990 10Suppl 2:40 3 2260617
Asano Y [Complications of long-term hemodialysis patients and the countermeasures] Nippon Naika Gakkai Zasshi 1992 Aug 10 81(8):1273 8 1431471
Ashai NI, Paganini EP, Wilson JM Intravenous versus subcutaneous dosing of epoetin: a review of the literature Am J Kidney Dis 1993 22(2 Suppl. 1):23 31 8352268
Asimacopoulos PJ, Skoumas IN, Yawn DH, et al Angina pectoris caused by pernicious anemia Chest 1994 Mar 105(3):653 4 8131519
Auer J, Oliver DO, Winearls CG. The quality of life of dialysis patients treated with recombinant human erythropoietin. Scand J Urol Nephrol Suppl. 1990;131:61-5. [pmid: 2075472].
Auer J, Simon G, Stevens J, et al Quality of life improvements in CAPD patients treated with subcutaneously administered erythropoietin for anemia Perit Dial Int 1992 12(1):40 2 1543779
Auerbach M, Winchester J, Wahab A, et al A randomized trial of three iron dextran infusion methods for anemia in EPO-treated dialysis patients Am J Kidney Dis 1998 Jan 31(1):81 6 9428456
Aufricht C, Balzar E, Steger H, et al Subcutaneous recombinant human erythropoietin in children with renal anemia on continuous ambulatory peritoneal dialysis Acta Paediatr 1993 Nov 82(11):959 62 8111178
Aunsholt NA, Steffensen G, Povlsen JV, et al Lymphocytotoxic panel reactive antibodies in hemodialyzed patients treated with recombinant human erythropoietin Nephron 1991 59(3):
Austrian Multicenter Study Group of r-HuEPO in Predialysis Patients Effectiveness and safety of recombinant human erythropoietin in predialysis patients Nephron 1992 61(4):399 403 1501735
Avram MM, Sreedhara R, Batish R, et al. Characteristics of very long-term survivors on hemodialysis (HD); Survival up to 30 years. J Am Soc Nephrol. 1996;7.
Avram MM Update in nephrology '97: hypertension, lipids, and uremia therapy Am J Kidney Dis 1997 30(6):896 898 9417765
Bagon JA, Vernaeve H, De Muylder X, et al Pregnancy and dialysis Am J Kidney Dis 1998 May 31(5):756 65 9590184
Bailie GR, Plitnick R, Eisele G, et al. Experience with subcutaneous erythropoietin in CAPD patients. Adv Perit Dial. 1991;7:292-5. [pmid: 1680449].
Bailie GR Erythropoietin and iron use in peritoneal dialysis patients: Report from the 1997 HCFA end-stage renal disease core indicators project Am J Kidney Dis 1999 33(6):1187 89 10352214
Bajo MA, Selgas R, Miranda B, et al. Medium term response to H-R erythropoietin in CAPD patients: the influence of erythropoietin plasmatic levels and the effects on peritoneal transport capacity. Adv Perit Dial. 1991;7:296-300. [pmid: 1680450].
Balaskas EV, Melamed IR, Gupta A, et al Effect of erythropoietin treatment on nutritional status of continuous ambulatory peritoneal dialysis patients Perit Dial Int 1993 13(Suppl 2):S544 9 8399661
Baldamus CA, Steffen AM, Brunner R, et al. Role of blood rheology in the pathogenesis of hypertension of hemodialysis patients treated for renal anemia with recombinant human erythropoietin. Contrib Nephrol. 1990;82:79-85. [pmid: 2093531].
Baldus M, Brass H [What are the potentials of erythropoietin?] Krankenpfl J 1993 Jan-Feb 31(1-2):23 8 8445873
Baldus M, Brass H Erythropoietin - a new approach in the treatment of renal anemia Nieren- Hochdruckkr 1990 19(5):170 177
Balkovetz DF, Frazier C, Sanders PW Crossover comparison of intravenous and subcutaneous recombinant human erythropoietin in a small haemodialysis unit [6] Nephrol Dial Transplant 1998 13(11):2979 80 9829525
Barany P, Clyne N, Hylander B, et al Subcutaneous epoetin beta in renal anemia: an open multicenter dose titration study of patients on continuous peritoneal dialysis Perit Dial Int 1995 15(1):54 60 7734561
Barany P, Divino Filho JC, Bergstrom J High C-reactive protein is a strong predictor of resistance to erythropoietin in hemodialysis patients Am J Kidney Dis 1997 Apr 29(4):565 8 9100046
Barany P, Fehrman I, Godoy C Long-term effects on lymphocytotoxic antibodies and immune reactivity in hemodialysis patients treated with recombinant human erythropoietin Clin Nephrol 1992 Feb 37(2):90 6 1551255
Barany P, Freyschuss U, Pettersson E, et al Treatment of anaemia in haemodialysis patients with erythropoietin: long-term effects on exercise capacity Clin Sci 1993 84(4):441 447 8482049
Barany P, Pettersson E, Ahlberg M, et al Nutritional assessment in anemic hemodialysis patients treated with recombinant human erythropoietin Clin Nephrol 1991 Jun 35(6):270 9 1873941
Barany P, Pettersson E, Konarski-Svensson JK Long-term effects on quality of life in haemodialysis patients of correction of anaemia with erythropoietin Nephrol Dial Transplant 1993 8(5):426 32 8393547
Barany P Endocrinology and PD: optimal treatment of anemia in peritoneal dialysis patients Perit Dial Int 1996 16(Suppl 1):S260 6 8728204
Barany P. Physiological effects of correcting anemia in hemodialysis patients (HD pts) to a normal HB. J Am Soc Nephrol. 1996;7.
Bargman J Erythropoietin: a hormone finds a purpose J Rheumatol 1991 18(8):1121 1123 1941810
Bargman J Recombinant human erythropoietin in patients on peritoneal dialysis Perit Dial Int 1989 9(4):245 6 2488375
Bartova V, Nemecek K, Lachmanova J Erythropoietin or blood transfusion? Vnitr Lek 1993 39(5):445 450 8351875
Bartunkova J, Fucikova T, Sulkova S, et al Influence of erythropoietin and some lymphocyte and granulocyte functions in dialyzed patients Cas Lek Cesk 1989 128(42):1332 35 2598245
Bartunkova J, Sulkova S, Cebecauer M [The effect of recombinant erythropoietin on candidicidal activity of polymorphonuclear leukocytes in hemodialyzed patients] Cas Lek Cesk 1995 Dec 6 134(23):756 9
Baskin S, Lasker N Erythropoietin-associated hypertension N Engl J Med 1990 323(14):
Bass EB, Jenckes MW, Fink NE, et al Use of focus groups to identify concerns about dialysis Medical Decision Making 1999 19(3):287 295 10424835
Bassi S, Montini G, Edefonti A, et al Cardiovascular function in a chronic peritoneal dialysis pediatric population on recombinant human erythropoietin treatment Perit Dial Int 1993 13(Suppl 2):S267 9 8399585
Beard JL, Haas JD, Tufts D, et al Iron deficiency anemia and steady-state work performance at high altitude J Appl Physiol 1988 May 64(5):1878 84 3134329
Beccari M, Romagnoni M, Sorgato G Seizures in dialysis patients treated with recombinant erythropoietin Nephrol Dial Transplant 1995 10(3):423 4 7792048
Beccari M Seizures in dialysis patients treated with recombinant erythropoietin: review of the literature and guidelines for prevention Int J Artif Organs 1994 17(1):5 13 8188400
Becker N, Brandt JR, Sutherland TA, et al Improved outcome of young children on nightly automated peritoneal dialysis Pediatr Nephrol 1997 Dec 11(6):676 9 9438640
Bedani PL, Cecchetti E, Gilli P Effectiveness of subcutaneous low-dose erythropoietin in patients with chronic renal failure despite functional iron deficiency Nephron 1995 71(4):459 60 8587628
Beer J Treatment of anaemia in chronic renal failure Nurs Times 1988 Nov 23-29 84(47):55 7 3211795
Beguin Y, Fillet G [Erythropoietin: diagnostic and therapeutic use] Rev Med Liege 1990 Jun 45(6):261 7 2367756
Beguin Y, Loo M, R'Zik S, et al Early prediction of response to recombinant human erythropoietin inpatients with the anemia of renal failure by serum transferrin receptor and fibrinogen Blood 1993 82(7):2010 2016 8400253
Beguin Y, Loo M, R'Zik S, et al Quantitative assessment of erythropoiesis in haemodialysis patients demonstrates gradual expansion of erythroblasts during constant treatment with recombinant human erythropoietin Br J Haematol 1995 Jan 89(1):17 23 7833259
Beguin Y, Sautois B, Fillet G Diagnostic and therapeutic aspects of erythropoietin Med Hyg 1991 49(1897):2034 40
Beguin Y A risk-benefit assessment of epoetin in the management of anaemia associated with cancer Drug Safety 1998 19(4):269 82 9804442
Bellinghieri G, Savica V, De Gregorio C, et al. Use of erythropoietin in ischemic and arrhythmic cardiopathy of hemodialyzed patients. Contrib Nephrol. 1994;106:135-7. [pmid: 8174359].
Belsha CW, Berry PL Effect of hyperparathyroidism on response to erythropoietin in children on dialysis Pediatr Nephrol 1998 May 12(4):298 303 9655362
Bennett L The anaemia research nurse in effective multi-disciplinary management of patients on erythropoietin EDTNA-ERCA Journal 1998 24(3):38 9
Bennett TA, Todd MW, Sandroni S Criteria for use of epoetin Clin Pharm 1991 10(4):303 6 2032449
Bennett WM A multicenter clinical trial of epoetin beta for anemia of end-stage renal disease J Am Soc Nephrol 1991 Jan 1(7):990 8 1883969
Bennett WM Side effects of erythropoietin therapy Am J Kidney Dis 1991 Oct 18(4 Suppl 1):84 6 1928085
Benz RL, Pressman MR, Hovick ET et al A preliminary study of the effects of correction of anemia with recombinant human erythropoietin therapy on sleep, sleep disorders, and daytime sleepiness in hemodialysis patients (The SLEEPO Study) Am J Kidney Dis 1999 34(6):1089 95 10585319
Benz RL. Relationship between anemia of chronic renal failure (ACRF) and sleep, sleep disorders and daytime alertness: benefits if normalizing hematocrit (The SLEEPO Trial). J Am Soc Nephrol. 1996;7.
Beresford CH Erythropoietin N Z Med J 1989 Apr 26 102(866):185 6 2652007
Beresford CH Therapeutics. Iron deficiency New Zealand Med. J 1992 105(930):110 111 1553116
Bergen DC, Ristanovic R, Gorelick PB, et al Seizures and renal failures Int J Artif Organs 1994 17(5):247 251 7960192
Berger J, Aguayo VM, San Miguel JL, et al Definition and prevalence of anemia in Bolivian women of childbearing age living at high altitudes: the effect of iron-folate supplementation Nutr Rev 1997 Jun 55(6):247 56 9279061
Berger J, Aguayo VM, Tellez W, et al Weekly iron supplementation is as effective as 5 day per week iron supplementation in Bolivian school children living at high altitude European Journal Of Clinical Nutrition 1997 51(6):381 6 9192196
Berglund B, Birgegard G, Hemmingsson P Serum erythropoietin in cross-country skiers Med Sci Sports Exerc 1988 20(2):208 9 3367758
Berglund B High-altitude training. Aspects of haematological adaptation Sports Med 1992 Nov 14(5):289 303 1439397
Bergstrom J New aspects of erythropoietin treatment J Intern Med 1993 233(6):445 62 8099117
Beris P Indication and contraindication: application of recombinant human erythropoietin as blood substitute Therapiewoche Schweiz 1994 10(12):636 40
Berns JS, Cahill C, Okupinski V, et al Improving management of anemia using CQI techniques Nephrol News Issues 1997 Sep 11(9):11 3
Berns JS, DeOreo PB Clinical applications of iron management in hemodialysis patients Seminars in Dialysis 1999 12(4):249 56
Besarab A, Bolton WK, Browne JK, et al The effects of normal as compared with low hematocrit values in patients with cardiac disease who are receiving hemodialysis and epoetin N Engl J Med 1998 Aug 27 339(9):584 90
Besarab A, Flaharty KK, Erslev AJ, et al Clinical pharmacology and economics of recombinant human erythropoietin in end-stage renal disease: the case for subcutaneous administration J Am Soc Nephrol 1992 Mar 2(9):1405 16 1627763
Besarab A, Golper TA Response of continuous peritoneal dialysis patients to subcutaneous recombinant human erythropoietin differs from that of hemodialysis patients ASAIO Trans 1991 Jul-Sep 37(3):M395 6
Besarab A, McCrea JB Evolution of recombinant human erythropoietin usage in clinical practice in the United States. Is there an optimal way to use rHuEPO? ASAIO J 1993 Jan-Mar 39(1):11 8 8439674
Besarab A, Medina F, Musial E, et al Recombinant human erythropoietin does not increase clotting in vascular accesses ASAIO Trans 1990 Jul-Sep 36(3):M749 53
Besarab A, Ross RP, Nasca TJ The use of recombinant human erythropoietin in predialysis patients Curr Opin Nephrol Hypertens 1995 Mar 4(2):155 61 7600046
Besarab A Optimizing epoetin therapy in end-stage renal disease: the case for subcutaneous administration Am J Kidney Dis 1993 Aug 22(2 Suppl 1):13 22 8352267
Besarab A Parenteral iron therapy: Safety and efficacy Seminars in Dialysis 1999 12(4):237 42
Beusterien KM, Nissenson AR, Port FK, et al The effects of recombinant human erythropoietin on functional health and well-being in chronic dialysis patients J Am Soc Nephrol 1996 May 7(5):763 73 8738812
Bezerra HM, Maia GP, Bezerra Neto FA, et al [Severity of acquired cystic kidney disease determines improvement in chronic kidney failure anemia] Rev Assoc Med Bras 1997 Jan-Mar 43(1):4 8 9224984
Bhandari S, Norfolk D, Brownjohn AM, et al Novel haematological parameters in patients receiving recombinant human erythropoietin and undergoing haemodialysis Hematology 1998 3(1):67 75
Bianchetti MG, Hammerli I, Roduit C, et al Epoetin alfa in anaemic children or adolescents on regular dialysis Eur J Pediatr 1991 May 150(7):509 12 1915505
Biggers PB Administering epoetin alfa. More RBCs with fewer risks Nursing 1991 Apr 21(4):
Birmingham DJ, Shen XP, Hartman JA, et al Effect of chronic human recombinant erythropoietin therapy on antibody responses to immunization in chronic hemodialysis patients Kidney Int 1996 Aug 50(2):543 9 8840284
Blagg CR The socioeconomic impact of rehabilitation Am J Kidney Dis 1994 Jul 24(1 Suppl 1):S17 21; discussion S31-2 8023834
Blake GJ Epoetin alfa for renal and H. I.V.-positive patients Nursing 1992 Nov 22(11):
Bloomfield RJ, Wilson IJ Nomifensine, acute hemolytic anemia, and renal failure Ann Intern Med 1986 105(5):
Blumberg A, Zehnder Treatment of the anemia of renal failure with recombinant human erythropoietin Ther. Umsch 1988 45(12):895 9 3065970
Boccardo P, Remuzzi A Hemostasis in renal failure Intensivmedizin Und Notfallmedizin 1998 35(6):382 9
Bocker A, Reimers E, Nonnast-Daniel B, et al. Effect of erythropoietin treatment on O2 affinity and performance in patients with renal anemia. Contrib Nephrol. 1988;66:165-75. [pmid: 3391031].
Boineau FG, Lewy JE, Roy S, et al Prevalence of anemia and correlations with mild and chronic renal insufficiency J Pediatr 1990 116(2):S60 S62 2299484
Bolton WK What crit? Am J Kidney Dis 1999 33(6):1177 79 10352212
Bommer J, Alexiou C, Muller-Buhl U, et al Recombinant human erythropoietin therapy in haemodialysis patients -- dose determination and clinical experience Nephrol Dial Transplant 1987 2(4):238 42 3118264
Bommer J, Huber W, Tewes G, et al. Treatment of polytransfused hemodialysis patients with recombinant human erythropoietin. Contrib Nephrol. 1988;66:131-8. [pmid: 3391027].
Bommer J, Kugel M, Schoeppe W, et al. Dose-related effects of recombinant human erythropoietin on erythropoiesis. Results of a multicenter trial in patients with end-stage renal disease. Contrib Nephrol. 1988;66:85-93. [pmid: 3292151].
Bommer J, Muller-Buhl E, Ritz E, et al Recombinant human erythropoietin in anaemic patients on haemodialysis Lancet 1987 1(8529):
Bommer J Hypertension under rhepo therapy Nieren-Hochdruckkr 1993 22(11):605 8
Bommer J Response to EPO therapy Przegl Lek 1992 49(1-2):36 7 1455003
Boning D, Maassen N, Jochum F, et al After-effects of a high altitude expedition on blood Int J Sports Med 1997 Apr 18(3):179 85 9187971
Boran M, Dalva I, Yazicioglu A, et al Correction of anaemia in haemodialysis patients with recombinant human erythropoietin Int Urol Nephrol 1993 25(2):197 203 8365853
Boratynska M, Magott M, Szewczyk Z [Treatment with human recombinant erythropoietin and nutritional status of patients on long term dialysis] Przegl Lek 1996 53(5):402 5 8754401
Boratynska M, Mazanowska O, Szewczyk Z [Treatment of anemia in patients after long term hemodialysis with human recombinant erythropoietin] Pol Merkuriusz Lek 1996 Nov 1(5):329 31 9273209
Boratynska M, Szewczyk Z, Szepietowski T, et al [Human recombinant erythropoietin in the treatment of anemia in patients on long-term hemodialysis] Przegl Lek 1990 47(11):741 5 2098840
Borgna-Pignatti C Hematopoietic disorders and growth factors Curr Opin Pediatr 1991 3(1):87 94
Borrego FJ, Miguel JL, Zamorano A, et al [The treatment of anemia in patients on hemodialysis with recombinant human erythropoietin] Med Clin (Barc) 1991 Nov 23 97(18):687 92 263984
Bozfakioglu S, Alptekin N, Seckin S, et al Red cell lipid peroxidation and antioxidant system in chronic renal failure patients treated with recombinant human erythropoietin Nephron 1992 61(2):228 9 1630552
Brandt JR, Avner ED, Hickman RO, et al Safety and efficacy of erythropoietin in children with chronic renal failure Pediatric Nephrol 1999 13(2):143 7
Branger B, Vecina F, Zabadani B, et al Subcutaneous erythropoietin administration in predialysis patients: a single centre prospective study Nephrol Dial Transplant 1995 10Suppl 6:36 9
Braumann KM. Improved physical performance after treatment of renal anemia with recombinant human erythropoietin. Nephron. 1991;58:129-34. [pmid: 1865966].
Brenner BM, Lazarus JM. Chronic renal failure. In: Harrisons:Principles and practice of internal medicine. 13th ed. Vol. 2. New York: McGraw-Hill Inc. Health Professions Division; 1994. p. 1274-81.
Briggs WA, Gimenez LF Clinical application of recombinant erythropoietin in predialysis renal failure Hematol Oncol Clin North Am 1994 Oct 8(5):927 32 7852215
Brown CD, Friedman EA. Clinical and blood rheologic stability in erythropoietin-treated predialysis patients. Am J Nephrol. 1990;10 Suppl 2:29-33. [pmid: 2260615].
Brown CD. Stable renal function and benign course in azotemic diabetics treated with erythropoietin for one year. Contrib Nephrol. 1991;88:182-9. [pmid: 2040181].
Brown JH, Maxwell AP, Doherty CC Subcutaneous erythropoietin therapy and hypertensive encephalopathy Nephrol Dial Transplant 1990 5(7):553 4
Brown TM, Brown RL Neuropsychiatric consequences of renal failure Psychosomatics 1995 36(3):244 53 7638311
Brown WS, Marsh JT, Wolcott D, et al Cognitive function, mood and P3 latency: effects of the amelioration of anemia in dialysis patients Neuropsychologia 1991 29(1):35 45 2017307
Brunet P, Berland Y, Merzouk T, et al Effect of recombinant human erythropoietin treatment in uremic patients on oxygen affinity of hemoglobin Nephron 1994 66(2):147 52 8139733
Brunkhorst R, Nonnast-Daniel B, Koch KM, et al. Hypertension as a possible complication of recombinant human erythropoietin therapy. Contrib Nephrol. 1991;88:118-25; discussion 126. [pmid: 2040173].
Buemi M, Allegra A, Aloisi C, et al Different answer to recombinant human erythropoietin in anephric and non-anephric haemodialyzed patients Nephron 1990 56(2):218 9 2243581
Buemi M, Allegra A, Aloisi C, et al Influence of the treatment with recombinant human erythropoietin on plasma concentration of interleukin-1-alpha and tumour necrosis factor-alpha in hemodialyzed subjects Nephron 1993 64(2):333 4 8321378
Buemi M, Allegra A, Corica F, et al Recombinant erythropoietin and the cardiovascular risk in uremia Recenti Progressi In Medicina 1998 89(9):456 8 9796377
Buemi M, Allegra A, Frisina N Erythropoietin: not only renal anaemia Giornale Italiano Di Nefrologia 1995 12(1):9 15
Bunn HF. Anemia associated with chronic disorders. In: Harrisons: Principles and practice of internal medicine. 13th ed., Vol. 2. New York: McGraw-Hill Inc. Health Professions Division; 1994b. p.1732-34.
Bunn HF. Pathophysiology of the anemias. In: Harrisons: Principles and practice of internal medicine. 13th ed., Vol. 2. New York: McGraw-Hill Inc. Health Professions Division; 1994a. p. 1717-21.
Burden R Management of chronic renal failure Practitioner 1991 235(1499):154 60 2034582
Burke JR Low-dose subcutaneous recombinant erythropoietin in children with chronic renal failure. Australian and New Zealand Paediatric Nephrology Association Pediatr Nephrol 1995 Oct 9(5):558 61 8580009
Burrows-Hudson S CQI and anemia management: maximizing positive outcomes. Case study of the anemic patient ANNA J 1997 Apr 24(2):254 60; quiz 261 9180430
Burtsev VI, Grankin VI, Briukhovetskii AG, et al [Some aspects of current treatment of patients with terminal chronic renal insufficiency] Klin Med (Mosk) 1993 Jan 71(1):33 6 358319
Butera E Case management of the anemic patient. Epoetin alfa: focus on quality of life ANNA J 1992 Aug 19(4):410 1 1520032
Buur T, Lundberg M Secondary effects of erythropoietin treatment on metabolism and dialysis efficiency in stable hemodialysis patients Clin Nephrol 1990 Nov 34(5):230 5 2268981
Cameron JS. European best practice guidelines for the management of anaemia in patients with chronic renal failure. Nephrol Dial Transplant. 1999;14:61-5. [pmid: 10334669].
Cameron JS. Towards the millennium: a history of renal anaemia and the optimal use of epoetin. Nephrology Dial Transplant. 1999;14:10-21.
Campistrus N, Gadola L, Gossio E, et al Acute leukemia and erythropoietin: cause or casual relationship? Nephron 1995 69(1):
Campos A, Garin EH Therapy of renal anemia in children and adolescents with recombinant human erythropoietin (rHuEPO) Clin Pediatr (Phila) 1992 Feb 31(2):94 9 358331 1544282
Canadian Erythropoietin Study Group Association between recombinant human erythropoietin and quality of life and exercise capacity of patients receiving haemodialysis BMJ 1990 Mar 3 300(6724):573 8
Canaud B, Bennhold I, Delons S, et al. What is the optimum frequency of administration of r-huepo for correcting anemia in hemodialysis patients?. Dial Transplant. 1995;4:306-9.
Canaud B, Bouloux C, Rivory JP, et al Erythropoietin-induced changes in protein nutrition: quantitative assessment by urea kinetic modeling analysis Blood Purif 1990 8(5):301 8 2091690
Canaud B, Polito-Bouloux C, Garred LJ, et al Recombinant human erythropoietin: 18 months' experience in hemodialysis patients Am J Kidney Dis 1990 Feb 15(2):169 75 2301388
Canaud B, Polito-Bouloux C, Rivory JP, et al [Recombinant human erythropoietin: 18 months of continuous use in substitution hemodialysis] Nephrologie 1990 11(1):5 10 2374643
Cannata-Andia JB Aluminium toxicity: its relationship with bone and iron metabolism Nephrol Dial Transplant 1996 11(Suppl 3):69 73 8840317
Cannella G, Paoletti E Clues for understanding the pathogenesis of left ventricular hypertrophy in chronic uremia [editorial] Int J Artif Organs 1998 Jul 21(7):378 83 9745991
Capelli JP, Kushner H, Camiscioli T, et al Factors affecting survival of hemodialysis patients utilizing urea kinetic modeling. A critical appraisal of shortening dialysis times Am J Nephrol 1992 12(4):212 23 1481868
Carlini R, Obialo CI, Rothstein M Intravenous erythropoietin (rHuEPO) administration increases plasma endothelin and blood pressure in hemodialysis patients Am J Hypertens 1993 Feb 6(2):103 7 8471228
Carlson HE, Graber ML, Gelato MC, et al Endocrine effects of erythropoietin Int J Artif Organs 1995 Jun 18(6):309 14 8593965
Carson JL, Duff A, Poses RM, et al Effect of anaemia and cardiovascular disease on surgical mortality and morbidity Lancet 1996 348(9034):1055 60 8874456
Caruso U, Leone L, Cravotto E, et al Effects of l-carnitine on anemia in aged hemodialysis patients treated with recombinant human erythropoietin: a pilot study Dialysis Transplant 1998 27(8):498 506
Casadevall N [Physiology of erythropoietin and its therapeutic use] Ann Pharm Fr 1996 54(4):151 6 8881101
Casadevall N Erythropoietin and autologous blood predeposit: from the physiological secretion to rational exogenic supplementation Nouvelle Revue Francaise D'hematologie 1995 37(Suppl. 1):S11 S15
Casadevall N Erythropoietin therapy Rev Med Interne 1991 12(6 Suppl.):
Catlin DH, Hatton CK. Use and abuse of anabolic and other drugs. Adv Intern Med. 1991;36:399-24. [pmid: 1673818].
Cavdar C, Camsari T, Semin I, et al Lipid peroxidation and antioxidant activity in chronic haemodialysis patients treated with recombinant human erythropoietin Scand J Urol Nephrol 1997 Aug 31(4):371 5 9290168
Cazzola M Erythropoietin: biology and clinical applications Forum Trends Exp Clin Med 1993 3(4):344 61
Cazzola M How and when to use erythropoietin Curr Opin Hematol 1998 5(2):103 8 9570702
Cengiz K, Islek I Does erythropoietin cause epilepsy Nephron 1996 73(2):320 1 8773367
Chagnac A, Weinstein T, Zevin D, et al Effects of erythropoietin on glucose tolerance in hemodialysis patients Clin Nephrol 1994 Dec 42(6):398 400 7882604
Chambers JK Case study of the anemic patient: epoetin alfa -- focus on blood pressure ANNA J 1994 Apr 21(2):154 7 8080316
Chambers JK Epoetin alfa: focus on inflammation and infection. Case study of the anemic patient ANNA J 1998 Jun 25(3):353 6 9801493
Chan WS, Okun N, Kjellstrand CM Pregnancy in chronic dialysis: a review and analysis of the literature Int J Artif Organs 1998 May 21(5):259 68 9684907
Chapman RF, Stray-Gundersen J, Levine BD Individual variation in response to altitude training J Appl Physiol 1998 Oct 85(4):1448 56 9760340
Cheng IK, Cy C, Chan MK, et al Correction of anemia in patients on continuous ambulatory peritoneal dialysis with subcutaneous recombinant erythropoietin twice a week: a long-term study Clin Nephrol 1991 May 5(5):207 12
Chiba S, Kikuchi M [Clinical significance of erythropoietin] Rinsho Byori 1985 Mar 33(3):323 9 4010004
Chmielewski CM Case study of the anemic patient: epoetin alfa -- focus on erythrokinetics ANNA J 1995 Aug 22(4):420 3 7654091
Churchill DN, Muirhead N, Goldstein M, et al Effect of recombinant human erythropoietin on hospitalization of hemodialysis patients Clin Nephrol 1995 Mar 43(3):184 8 7774076
Churchill DN, Muirhead N, Goldstein M, et al Probability of thrombosis of vascular access among hemodialysis patients treated with recombinant human erythropoietin J Am Soc Nephrol 1994 Apr 4(10):1809 13 8068879
Churchill DN, Taylor DW, Cook RJ, et al Canadian Hemodialysis Morbidity Study Am J Kidney Dis 1992 Mar 19(3):214 34 1553966
Churchill DN Results of the Canadian morbidity study in end-stage renal disease patients treated by hemodialysis Semin Nephrol 1990 Mar 10(2 Suppl 1):66 72 2356368
Clemens MR. Antioxidant therapy in hematological disorders. Adv Exp Med Biol. 1990;264:423-33. [pmid: 2244523].
Clyne N, Jogestrand T Effect of erythropoietin treatment on physical exercise capacity and on renal function in predialytic uremic patients Nephron 1992 60(4):390 6 1584314
Cohen JA, Brattich M Epoetin alfa: focus on maintaining a higher, stable, Hct. Case study of the anemic patient ANNA J 1997 Oct 24(5):574 80 9392740
College J Epoetin alfa -- focus on nutritional therapy. Case study of the anemic patient ANNA J 1996 Aug 23(4):416 9 8900689
Collins A, Hao W, Ebben J, et al. Hematocrit associated outcomes in incident peritoneal and hemodialysis patients. In: Abstracts, XVth International Congress of Nephrology, Buenos Aires, Argentina. May 2-6, 1999c. p. 70 (Abstract #280).
Collins A, Hao W, Ebben J, et al. Anemia correction in incident peritoneal dialysis patients is associated with lower hospitalization risk. J Am Soc Nephrol. 1999a;10.
Collins A, Hao W, Ebben J, et al. Higher hematocrit levels in incident hemodialysis patients are associated with lower hospitalization risks. J Am Soc Nephrol. 1999b;0:157A-158A.
Collins AJ, Ebben JP, Ma X. Clinical factors associated with changing hematocrit levels in hemodialysis patients. Semin Dialysis. 1999;12:S92-S96.
Collins AJ, Keane WF Higher haematocrit levels: do they improve patient outcomes, and are they cost effective? Nephrol Dial Transplant 1998 Jul 13(7):1627 9 9681700
Collins AJ, Ma JZ, Xia A, et al Trends in anemia treatment with erythropoietin usage and patient outcomes Am J Kidney Dis 1998 Dec 32(6 Suppl 4):S133 41 9892380
Coppo R, Porcellini MG, Bonaudo R, et al Providing the right stuff: feeding children with chronic renal failure J Nephrol 1998 Jul-Aug 11(4):171 6 9702867
Corea AL Case management of the anemic patient: epoetin alfa -- focus on cognitive function ANNA J 1993 Jun 20(3):350 3 8352632
Costagliola C, Romano L, Scibelli G, et al Anemia and chronic renal failure: a therapeutical approach by reduced glutathione parenteral administration Nephron 1992 61(4):404 8 1501736
Cotter DJ, Thamer M, Kimmel PL, et al Secular trends in recombinant erythropoietin therapy among the U. S. hemodialysis population: 1990-1996 Kidney International 1998 54(6):2129 39 9853279
Cotton SL, Holechek MJ Management of anemia using recombinant human erythropoietin in patients on chronic hemodialysis ANNA J 1989 Dec 16(7):463 8 2604448
Cuero CJ, Perez Guardia E, de Rivera C [Use of erythropoietin in patients with chronic renal insufficiency and in hemodialysis] Rev Med Panama 1996 Jan-May 21(1-2):55 9 8966240
Culp K, Flanigan M, Taylor L, et al Vascular access thrombosis in new hemodialysis patients Am J Kidney Dis 1995 26(2):341 6 7645539
Cutler M Administration of epoetin alfa. Case study of the anemic patient ANNA J 1997 Aug 24(4):459 65 9325701
Dabbagh S, Carroll CE, Fleishmann LE Recombinant human erythropoietin (rHuEPO) in pediatric pre-dialysis patients: a prospective study J Am Soc Nephrol 1991 2(3):
Dabbagh S, Ryckaert, Carroll CE, et al Long-term follow-up of the efficacy of recombinant human erythropoietin (rHuEPO) in children maintained on hemo- (HD) and continuous peritoneal dialysis (CCPD) J Am Soc Nephrol 1991 2(3):
Dainiak N The role of androgens in the treatment of anemia of chronic renal failure Semin Nephrol 1985 Jun 5(2):147 54 3843789
Dale GL, Alberio L Is there a correlation between raised erythropoietin and thrombotic events in sickle-cell anaemia? Lancet 1998 Aug 15 352(9127):566 7
Davenport A, King RF, Ironside JW, et al The effect of treatment with recombinant human erythropoietin on the histological appearance and glycogen content of skeletal muscle in patients with chronic renal failure treated by regular hospital haemodialysis Nephron 1993 64(1):89 94 8502342
Davenport A, Will EJ, Khanna SK, et al Blood lactate is reduced following successful treatment of anaemia in haemodialysis patients with recombinant human erythropoietin both at rest and after maximal exertion Am J Nephrol 1992 12(5):357 62 1489006
Davenport A The effect of treatment with recombinant human erythropoietin on skeletal muscle function in patients with end-stage renal failure treated with regular hospital hemodialysis Am J Kidney Dis 1993 Nov 22(5):685 90 8238014
Davison AM Management of pre-existing disorders in pregnancy: renal disease Prescribers' Journal 1997 37(1):46 53
Davison AM The dialysis patient today Nephrol Dial Transplant 1995 10(Suppl 10):2 6 8825425
de Fijter CW, Popp-Snijders C, Oe LP, et al Does additional treatment with fish oil mitigate the side effects of recombinant human erythropoietin in dialysis patients? Haematologica 1995 Jul-Aug 80(4):332 4 7590502
de Leeuwe JN [Risks and considerations in air travel for patients with lung or heart disorders] Ned Tijdschr Geneeskd 1985 129(26):1228 30 4022170
De Marchi S, Cecchin E, Falleti E, et al Long-term effects of erythropoietin therapy on fistula stenosis and plasma concentrations of PDGF and MCP-1 in hemodialysis patients J Am Soc Nephrol 1997 Jul 8(7):1147 56 9219165
De Paoli Vitali E, Guglielmini C, Casoni I, et al Serum erythropoietin in cross-country skiers Int J Sports Med 1988 9(2):99 101 3384528
de Sousa FT, Prata MM, Barbas JV, et al [Treatment of anemia in patients with chronic renal insufficiency undergoing hemodialysis with recombinant human erythropoietin: 12 months' experience] Acta Med Port 1990 Nov-Dec 3(6):347 52 2089856
Deamer RL, Prichard JG, Koenker N, et al Temafloxacin-induced hemolytic anemia and renal failure Clin Pharm 1993 12(5):380 2 8391409
Debska-Slizien A, Biedunkiewicz B, Rutkowski B [Effect of human recombinant erythropoietin (r-EPO) on behavior of iron status parameters in patients with chronic renal failure treated with dialysis] Pol Arch Med Wewn 1994 Sep 92(3):207 15 7808929
Debska-Slizien A, Rutkowski B, Niemierko J, et al [Subcutaneous administration of recombinant human erythropoietin (R-EPO) in the treatment of anemia in predialysis patients with chronic renal failure] Pol Arch Med Wewn 1991 Jun 85(6):334 40 1896396
Deierhoi MH, Barger BO, Hudson SL, et al The effect of erythropoietin and blood transfusions on highly sensitized patients on a single cadaver renal allograft waiting list Transplantation 1992 Feb 53(2):363 8 1738931
Delano BG, Lundin AP, Galonsky R, et al Dialyzer urea and creatinine clearances are not significantly altered in erythropoietin treated maintenance hemodialysis patients ASAIO Trans 1990 Jan-Mar 36(1):36 9 2306389
Delucchi A, Fuentes A, Rodriguez E, et al Recombinant erythropoietin in children under hemodialysis Rev Chil Pediatr 1992 63(6):303 7
Deniston OL, Luscombe FA, Buesching DP, et al Effect of long-term epoetin beta therapy on the quality of life of hemodialysis patients ASAIO Trans 1990 Jul-Sep 36(3):M157 60
DeOreo PB Treatment of anemia of chronic renal failure Dialysis Transplant 1997 26(12):842 4
Depner TA, Rizwan S, James LA Effectiveness of low dose erythropoietin: a possible advantage of high flux hemodialysis ASAIO Trans 1990 Jul-Sep 36(3):M223 5
deStrihou C. Should anaemia in subtypes of CRF patients be managed differently?. Nephrol Dial Transplant. 1999;14:37-45.
Dhondt AW, Vanholder RC, Ringoir SM Angiotensin-converting enzyme inhibitors and higher erythropoietin requirement in chronic haemodialysis patients Nephrol Dial Transplant 1995 Nov 10(11):2107 9 8643177
Di Iorio B, Terracciano V Bullous dermatosis in end-stage renal disease. Aluminum, iron and erythropoietin (1) Trace Elements And Electrolytes 1997 14(3):
Dickey LL, Griffith HM, Kamerow DB Put prevention into practice: preventive care for anemia. U.S. Department of Health and Human Services J Am Acad Nurse Pract 1994 Jun 6(6):267 9 7702942
Diez-Ruiz A, Weiss G, Artner-Dworzak E, et al Association between haemoglobin and neopterin concentrations in haemodialysis patients treated with erythropoietin Eur J Haematol 1993 Sep 51(3):175 6 8405333
Dine G, Boffa GA, Van Lierde F, et al Erythropoietin and physical training at mid altitude (2200 m) Sci Sports 1994 9(3):167 8
Djukanovic LJ, Lezaic V [Treatment of anemia in patients with chronic renal insufficiency with recombinant human erythropoietin] Srp Arh Celok Lek 1996 Mar-Apr 124(3-4):93 7 9102827
Dorhout Mees EJ, Ok E Erythropoietin hypertension: fact or fiction? Int J Artif Organs 1997 Aug 20(8):415 7 9323502
Drinovec J, Varl J Subcutaneous erythropoietin in the treatment of renal anaemia Przegl Lek 1992 49(1-2):38 40 1455004
Drueke T, Zins B, Bererhi L, et al [Use of recombinant erythropoietin in the treatment of anemia of chronic renal insufficiency] Presse Med 1989 Jun 24 18(25):1235 7
Drueke T, Zins B, Naret C, et al Erythropoietin and chronic renal failure Nouv Rev Fr Hematol 1989 31(2):97 8 2771635
Drueke TB, Barany P, Cazzola M, et al Management of iron deficiency in renal anemia: guidelines for the optimal therapeutic approach in erythropoietin-treated patients Clin Nephrol 1997 Jul 48(1):1 8 9247771
Duclos J, Olea C, Aguirre H, et al [Erythropoietin and transfusions in patients with anemia of chronic renal failure origin : an update view] Rev Med Chil 1995 Apr 123(4):451 5 8525189
Duclos J, Sieberth H G, Mann H [Is it necessary to supplement with folic acid patients in chronic dialysis treated with erythropoietin?] Rev Med Chil 1993 Jan 121(1):30 5 8235161
Duff DR, Golper TA, Sloan RS, et al Low-dose recombinant human erythropoietin therapy in chronic hemodialysis patients Am J Kidney Dis 1991 Jul 18(1):60 4 2063856
Dunn CJ, Markham A Epoetin beta. A review of its pharmacological properties and clinical use in the management of anaemia associated with chronic renal failure Drugs 1996 Feb 51(2):299 318 8808169
Dunn CJ, Wagstaff A J Epoetin alfa. A review of its clinical efficacy in the management of anaemia associated with renal failure and chronic disease and its use in surgical patients Drugs Aging 1995 Aug 7(2):131 56 7579784
Durand-Zaleski I, Goldfarb B, Blum-Boisgard C, et al Cost of treating predialysis patients with recombinant human erythropoietin Nephrol Dial Transplant 1993 8(4):311 4 8390004
Dy GR, Bloom EJ, Ijelu GK, et al. Effect of recombinant human erythropoietin on vascular access. ASAIO Trans 1991 Jul-Sep;37(3):M274-5.
Dyras P, Pietrzyk J A, Sancewicz-Pach K, et al [Clinical and metabolic effects of erythropoietin administration in hemodialyzed children] Przegl Lek 1996 53(11):793 6 9173441
Eckardt KU, Drueke T, Leski M, et al. Unutilized reserves: the production capacity for erythropoietin appears to be conserved in chronic renal disease. Contrib Nephrol. 1991;88:18-31; discussion 32-4. [pmid: 2040180].
Eckardt KU Cardiovascular consequences of renal anaemia and erythropoietin therapy Nephrol Dial Transplant 1999 4(5):1317 23 10344393
Eggers PW, Greer J, Jencks S The use of Health Care Financing Administration data for the development of a quality improvement project on the treatment of anemia Am J Kidney Dis 1994 Aug 24(2):247 54 8048432
Ehmer B, Messinger D, Scigalla P Influence of recombinant erythropoietin on transfusion need and iron metabolism variables in patients with end-stage renal failure Nieren-Hochdruckkr 1990 19(5):184 91
Ehrich JH, Loirat C, Brunner FP, et al Report on management of renal failure in children in Europe, XXII, 1991 Nephrol Dial Transplant 1992 7(Suppl. 2):36 48 1338120
Eicher ER Better dead than second J Lab Clin Med 1992 Sep 120(3):359 60 1517679
Eisele G, Bailie GR, Clement C, et al Erythropoietin in continuous ambulatory peritoneal dialysis: experience with subcutaneous administration Perit Dial Int 1992 12(1):34 6 1543777
Elisaf MS, Bairaktari E, Tzallas C, et al Atherogenic lipid and lipoprotein parameters in hemodialysis patients Dialysis Transplant 1995 24(11):642 6,648-50,660
Ellis PW EPO and renal nutrition-one year later. Evidence lacking in appetite improvement Nephrol News Issues 1990 Jun 4(6):
El-Reshaid K, Johny KV, Sugathan TN, et al End-stage renal disease and renal replacement therapy in Kuwait -epidemiological profile over the past 4one-half years Nephrol. Dial. Transplant 1994 9(5):532 8 8090333
Engfred K, Kjaer M, Secher NH, et al Hypoxia and training-induced adaptation of hormonal responses to exercise in humans Eur J Appl Physiol Occup Physiol 1994 68(4):303 9 8055887
Eridani S Erythropoietin. Chapter for the monograph on haemopoietic growth factors Biotherapy 1990 2(4):294 8
Ermolenko VM, Khvoinitskii VA, Suprun EK, et al [The effect of correcting anemia with recombinant erythropoietin on the central hemodynamic indices of patients on regular hemodialysis] Ter Arkh 1992 64(7):86 8
Ermolenko VM, Lashutin SV, Rudakov AG, et al [The effect of treatment with human recombinant erythropoietin on the functional status of patients on maintenance hemodialysis] Ter Arkh 1991 63(6):81 6
Erslev AJ, Besarab A Erythropoietin in the pathogenesis and treatment of the anemia of chronic renal failure [editorial] Kidney Int 1997 Mar 51(3):622 30 9067892
Erslev AJ Erythropoietin coming of age N Engl J Med 1987 316(2):101 3 3785351
Erslev AJ Erythropoietin N Engl J Med 1991 May 9 324(19):1339 44 2017231
Eschbach JW Erythropoietin-associated hypertension N Engl J Med 1990 323(14):999 1000 2402271
Eschbach JW The anemia of chronic renal failure: pathophysiology and the effects of recombinant erythropoietin [clinical conference] Kidney Int 1989 Jan 35(1):134 48 2651751
Eschbach JW, Abdulhadi MH, Browne JK, et al Recombinant human erythropoietin in anemic patients with end-stage renal disease. Results of a phase III multicenter clinical trial Ann Intern Med 1989 Dec 15 111(12):992 1000
Eschbach JW, Adamson JW Anemia of end-stage renal disease (ESRD) Kidney Int 1985 Jul 28(1):1 5 3900528
Eschbach JW, Adamson JW Guidelines for recombinant human erythropoietin therapy Am J Kidney Dis 1989 Aug 14(2 Suppl 1):2 8
Eschbach JW, Adamson JW. Modern aspects of the pathophysiology of renal anemia. Contrib Nephrol. 1988;66:63-70. [pmid: 3292149].
Eschbach JW, Aquiling T, Haley NR, et al The long-term effects of recombinant human erythropoietin on the cardiovascular system Clin Nephrol 1992 38Suppl 1:S98 103 1295715
Eschbach JW, Downing MR, Egrie JC, et al. USA multicenter clinical trial with recombinant human erythropoietin (Amgen). Results in hemodialysis patients. Contrib Nephrol. 1989;76:160-5. [pmid: 2684518].
Eschbach JW, Egrie JC, Downing MR, et al Correction of the anemia of end-stage renal disease with recombinant human erythropoietin. Results of a combined phase I and II clinical trial N Engl J Med 1987 Jan 8 316(2):73 8
Eschbach JW, Egrie JC, Downing MR, et al. The safety of epoetin-alpha: results of clinical trials in the United States. Contrib Nephrol. 1991;88:72-80. [pmid: 2040198].
Eschbach JW, Glenny R, Robertson T, et al. Normalizing the hematocrit (HCT) in hemodialysis patients (HDP) with EPO improves quality of life (Q/L) and is safe. J Am Soc Nephrol. 1993;4.
Eschbach JW, Kelly MR, Haley NR, et al Treatment of the anemia of progressive renal failure with recombinant human erythropoietin N Engl J Med 1989 Jul 20 321(3):158 63
Estrella R, Hercberg S, Maggy G, et al Evaluation of iron-deficiency anemia by an iron supplementation trial in children living at a 2,800-m altitude Clin Chim Acta 1987 Apr 15 164(1):1 6
Ettenger RB, Marik J, Grimm P The impact of recombinant human erythropoietin therapy on renal transplantation Am J Kidney Dis 1991 Oct 18(4 Suppl 1):57 61 1928081
Evans JH, Brocklebank JT, Bowmer CJ, et al Pharmacokinetics of recombinant human erythropoietin in children with renal failure Nephrol Dial Transplant 1991 6(10):709 14 1754107
Evans RW, Rader B, Manninen DL The quality of life of hemodialysis recipients treated with recombinant human erythropoietin. Cooperative Multicenter EPO Clinical Trial Group JAMA 1990 Feb 9 263(6):825 30
Evans RW Recombinant human erythropoietin and the quality of life of end-stage renal disease patients: a comparative analysis Am J Kidney Dis 1991 Oct 18(4 Suppl 1):62 70 1928082
Evans SJ Increased risk of cardiovascular disease with erythropoietin in chronic dialysis patients Nephron 1997 76(1):
Evens PE Update to Epogen information in article on future drug expenditures Am J Health Syst Pharm 1995 Jun 15 52(12):1348 9 7656127
Evers J Cardiac hemolysis and anemia refractory to erythropoietin: on anemia in dialysis patients Nephron 1995 71(1):
Ewing S, Crosby DL Renal transplantation for porphyria cutanea tarda N Engl J Med 1997 336(11):
Exeni R, Donato H, Rendo P, et al Low levels of serum erythropoietin in children with endemic hemolytic uremic syndrome Pediatric Nephrol 1998 12(3):226 30
Fabris F, Cordiano I, Girolami A Platelet count and volume in children with renal failure treated with human recombinant erythropoietin Platelets 1991 2(1):53 4 21043963
Faller B, Slingeneyer A, Waller M, et al Daily subcutaneous administration of recombinant human erythropoietin (rhEPO) in peritoneal dialysis patients: a European dose-response study Clin Nephrol 1993 Sep 40(3):168 75 8403573
Faller JP, Simon G, Rodier L, et al Acute renal failure, cholestatic jaundice, thrombocytopaenia and haemolytic anemia due to ajmaline hypersensitivity Ann Med Interne 1985 136(5):386 8
Farley DO Financing of end-stage renal disease care: past, present, and future Adv Ren Replace Ther 1994 Apr 1(1):24 31 7641085
Faulds D, Sorkin EM Epoetin (recombinant human erythropoietin). A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in anaemia and the stimulation of erythropoiesis Drugs 1989 Dec 38(6):863 99 2693045
Fazakas L, Taraba I, Hering A Anabolic steroids in the treatment of anemia in patients on hemodialysis Nieren Hochdruckkr 1986 15(11):502 4
Fearing MO Case management of the anemic patient. Epoetin alfa: focus on sexual dysfunction ANNA J 1992 Dec 19(6):570 1 1292419
Fellner SK, Lang RM, Neumann A, et al Cardiovascular consequences of correction of the anemia of renal failure with erythropoietin Kidney Int 1993 Dec 44(6):1309 15 8301932
Fernandez A, Hortal L, Rodriguez JC, et al Anemia in dialysis: its relation to acquired cystic kidney disease and serum levels of erythropoietin Am J Nephrol 1991 11(1):12 5 2048573
Fernandez A, Vega N, Jimenez F, et al Effect of recombinant human erythropoietin treatment on hemodynamic parameters in continuous ambulatory peritoneal dialysis and hemodialysis patients Am J Nephrol 1992 12(4):207 11 1481867
Ferrare, DeVita MV, Zabetakis PM, et al Bioelectric impedance and hemodynamic analysis in hemodialysis patients receiving rhuepo Dialysis Transplant 1993 22(11):668,672 5
Fillastre JP, Singlas E Pharmacokinetics of newer drugs in patients with renal impairment Clin Pharmacokin 1991 20(4):293 310
Fine RN. Subcutaneous recombinant human erythropoietin treatment of children undergoing peritoneal dialysis. Contrib Nephrol. 1991;89:186-9. [pmid: 1893725].
Fischer C, Scigalla P, Park W, et al. Influence of rhEPO therapy on the protein metabolism of hemodialysis patients with terminal renal insufficiency. Contrib Nephrol. 1989;76:250-6. [pmid: 2684526].
Fishbane S, Frei GL, Maesaka JK Reduction in recombinant human erythropoietin doses by the use of chronic intravenous iron supplementation Am J Kidney Dis 1995 26(1):41 6 7611266
Fishbane S, Kowalski EA, Imbriano LJ, et al The evaluation of iron status in hemodialysis patients J Am Soc Nephrol 1996 7(12):2654 7 8989744
Fishbane S, Lynn RI The efficacy of iron dextran for the treatment of iron deficiency in hemodialysis patients Clin Nephrol 1995 Oct 44(4):238 40 8575123
Fishbane S, Maesaka JK Iron management in end-stage renal disease Am J Kidney Dis 1997 Mar 29(3):319 33 9041207
Fisher JW Erythropoietin: physiologic and pharmacologic aspects Proc Soc Exp Biol Med 1997 216(3):358 69 9402140
Fitts SS, Guthrie MR, Blagg CR Exercise coaching and rehabilitation counseling improve quality of life for predialysis and dialysis patients Nephron 1999 82(2):115 21 10364702
Fivush BA, Jabs K, Neu AM, et al Chronic renal insufficiency in children and adolescents: the 1996 Annual Report of NAPRTCS. North American Pediatric Renal Transplant Cooperative Study Pediatr Nephrol 1998 May 12(4):328 37 9655366
Flechner SM Etiology and pathogenesis of renal failure Curr Opin Urol 1993 3(2):99 106
Foley RN, Parfrey PS, Harnett JD, et al The impact of anemia on cardiomyopathy, morbidity, and mortality in end-stage renal disease Am J Kidney Dis 1996 28(1):53 61 8712222
Foley RN, Parfrey PS, Morgan J, et al. A randomized controlled trial of complete vs. partial correction of anemia in hemodialysis patients with asymptomatic concentric LV hypertrophy or LV dilatation. J Am Soc Nephrol. 1998;9.
Foley RN, Parfrey PS Commentary: cardiomyopathy of anemia and the potential of erythropoietin Perit Dial Int 1997 Mar-Apr 17(2):117 8 9159828
Foley RN. A randomized controlled trial of complete vs. partial correction of anemia in hemodialysis patients with asymptomatic concentric LV hypertrophy or LV dilatation. J Am Soc Nephrol. 1998;9.
Foley RN The cardiovascular effects of r-huepo in end-stage renal disease Erythropoiesis: New dimensions in the treatment of anaemia 1995 6(1):3 7
Franke W, Scherhag Tolerability and efficacy of multidose formulations of epoetin beta Clinical Drug Investigation 1997 13(4):199 206
Frankenfield DL, Prowant BF, Flanigan MJ, et al. Trends in clinical indicators of care for adult peritoneal dialysis patients in the United States from 1995 to 1997. Kidney Int. 1999;55:1998-2010. [pmid: 10231465].
Frenken LA, Koene RA [Recombinant human erythropoietin] Ned Tijdschr Geneeskd 1988 Mar 5 132(10):432 4
Frenken LA, Koene RA [The use of erythropoietin] Ned Tijdschr Geneeskd 1991 Feb 2 135(5):163 6
Frenken LA, Verberckmoes R, Michielsen P, et al Efficacy and tolerance of treatment with recombinant-human erythropoietin in chronic renal failure (pre-dialysis) patients Nephrol Dial Transplant 1989 4(9):782 6 2516609
Friedlaender MM, Azem O, Rubinger D, et al Effect of human recombinant erythropoietin therapy on panel reactive antibodies in chronic dialysis patients Isr J Med Sci 1996 Sep 32(9):730 6 8865827
Friedlander MA, Hricik DE Optimizing end-stage renal disease therapy for the patient with diabetes mellitus Semin Nephrol 1997 Jul 17(4):331 45 9241718
Friedman EA, Delano BG Recombinant human erythropoietin in the diabetic patient Semin Nephrol 1990 Mar 10(2 Suppl 1):35 9 2192415
Frifelt JJ, Tvedegaard E, Bruun K, et al Efficacy of recombinant human erythropoietin administered subcutaneously to CAPD patients once weekly Perit Dial Int 1996 Nov-Dec 16(6):594 8 8981527
Fuchs J Case study of the anemic patient: epoetin alfa-focus on inflammation ANNA J 1994 Feb 21(1):78 81 8141637
Fukushima Y, Nakamoto Y, Miura AB, et al The inhibitory factors of hematopoiesis in chronic hemodialysis patients treated with recombinant human erythropoietin Tohoku J Exp Med 1990 161(3):217 25 2247892
Gabriel R Treating renal anaemia with erythropoietin Br Med J 1990 300(6728):
Gagnadoux MF, Loirat C, Bertheleme JP, et al [Treatment of anemia in hemodialyzed children using recombinant human erythropoietin (Eprex). Results of a French multicenter clinical trial] Nephrologie 1994 15(3):207 11 7969713
Gahl GM, Eckardt KU Erythropoietin 1997: a brief update Perit Dial Int 1997 17Suppl 2:S84 90 9163805
Garcia Martin F, Carrascosa Vallejo T, Martin Escobar E, et al [Treatment of anemia with recombinant human erythropoietin and the bone marrow response in uremic patients undergoing periodic hemodialysis] Rev Clin Esp 1990 May 186(9):419 22 2247677
Gareau R, Brisson GR, Chenard C, et al Possible discrimination between training in altitude and erythropoietin doping Science And Sports 1995 10(2):81 2
Gareau R, Gagnon MG, Ayotte C, et al rHuEPO increases urinary excretion of fibrin degradation products in haemodialysed patients Thromb Haemost 1993 Aug 2 70(2):373 4
Gerbase-DeLima M, Frugiuele PL, Lieber, et al Cellular immunity in multitransfused nonuremic patients Transplant Proc 1985 17(6):2432 34
Ghysen A Erythropoietin as medication of the future in renal failure Louvain Med 1989 108(5):315 320
Gibson SP, Cockwell P, Robinson BH, et al Responsiveness to recombinant human erythropoietin Nephrol Dial Transplant 1993 8(6):
Gillio AP Potential use of recombinant human hematopoietic growth factors in pediatrics Curr Opin Pediatr 1992 4(2):319 26
Gilman C Case management of the anemic patient. Epoetin alfa: focus on pediatric dialysis patients ANNA J 1992 Oct 19(5):496 7 1456798
Giorgianni V Anemia in association with chronic renal failure: treatment with recombinant erythropoietin Rass Med Interna 1990 11(5):295 8
Gokal R, Mallick NP Continuous ambulatory peritoneal dialysis Prescr J 1992 32(6):251 6
Goldberg N, Lundin AP, Delano B, et al Changes in left ventricular size, wall thickness, and function in anemic patients treated with recombinant human erythropoietin Am Heart J 1992 Aug 124(2):424 7 1386184
Goldwasser P, Avram MM, Collier JT, et al Correlates of vascular access occlusion in hemodialysis Am J Kidney Dis 1994 24(5):785 94 7977320
Golper TA The effect of recombinant erythropoietin on the early hematocrit rise after CAPD initiation Perit Dial Int 1992 12(1):37 9 1543778
Goodnough LT, Despotis GJ, Hogue CW Jr, et al On the need for improved transfusion indicators in cardiac surgery Ann Thorac Surg 1995 60(2):473 80 7646127
Goodnough LT. Recombinant human erythropoietin - Could it be used in a better way? In: Alternative Approaches to Human Blood Resources in Clinical Practice, CTS Sibinga, PC Das, JC Fratantoni, eds. Dordrecht: Kluwer Academic Publishers; 1998. p. 75-9.
Gore C, Craig N, Hahn A, et al Altitude training at 2690m does not increase total haemoglobin mass or sea level VO2max in world champion track cyclists J Sci Med Sport 1998 Sep 1(3):156 70 9783517
Graf H, Mayer G, Cada EM, et al Effectiveness of recombinant human erythropoietin in the treatment of transfusion dependent anaemia in patients on chronic haemodialysis Wien Klin Wochenschr 1987 99(24):855 9 3439185
Graf H Effectiveness and safety of recombinant human erythropoietin in predialysis patients J Am Soc Nephrol 1991 2(3):
Granolleras C, Branger B, Beau M C, et al. Experience with daily self-administered subcutaneous erythropoietin. Contrib Nephrol. 1989;76:143-7. [pmid: 2684516].
Granolleras C, Branger B, Deschodt G, et al. Daily self-administered subcutaneous erythropoietin: benefits in haemodialysis patients. Contrib Nephrol. 1990;82:49-54. [pmid: 2093526].
Granolleras C, Branger B, Deschodt G, et al Two years experience of daily self-administered subcutaneous erythropoietin Blood Purif 1990 8(5):268 71 2091686
Granolleras C, Branger B, Shaldon S, et al. Subcutaneous erythropoietin: a comparison of daily and thrice weekly administration. Contrib Nephrol. 1991;88:144-8; discussion 149-51. [pmid: 2040176].
Graudal N, Galloe AM, Nielsen OJ Erythropoietin in chronic obstructive pulmonary disease. Relationship between serum erythropoietin, blood hemoglobin and lung function -effect of the calcium antagonist isradipine on serum erythropoietin Respiration 1991 58(3-4):141 4 1836066
Gretz N, Lasserre JJ, Meisinger E, et al Potential side-effects of erythropoietin Lancet 1987 Jan 3 1(8523):
Grimm AM, Flaharty KK, Hopkins LE, et al Economics of epoetin therapy Clin Pharm 1989 8(11):807 10 2509130
Grunze M, Kohlmann M, Mulligan M, et al Mechanisms of improved physical performance of chronic hemodialysis patients after erythropoietin treatment Am J Nephrol 1990 10(Suppl 2):15 8; discussion 18-23 2124412
Grutzmacher P, Bergmann M, Low-Friedrich I, et al Cardiac effects of long-term treatment of renal anemia by recombinant erythropoietin Nieren-Hochdruckkr 1990 19(5):192 8
Grutzmacher P, Bergmann M, Weinreich T, et al. Beneficial and adverse effects of correction of anaemia by recombinant human erythropoietin in patients on maintenance haemodialysis. Contrib Nephrol. 1988;66:104-13. [pmid: 3292143].
Grutzmacher P, Scheuermann E, Low I, et al. Correction of renal anaemia by recombinant human erythropoietin: effects on myocardial function. Contrib Nephrol. 1988;66:176-84. [pmid: 3292146].
Grzeszczak W, Zukowska-Szczechowska E, Galwas B, et al [Concentrations of lead in blood of patients with chronic renal failure] Pol Arch Med Wewn 1994 Apr 91(4):247 56 8072884
Grzeszczak W, Zukowska-Szczechowska E [Circadian rhythm of pituitary-thyroid hormones in patients with chronic renal failure treated by hemodialysis] Pol Arch Med Wewn 1994 92(Spec No):21 30 7731896
Gunga HC, Frommhold M, Hildebrandt W, et al Erythropoietin production during flights with pressurised aircrafts Lancet 1996 Aug 10 348(9024):
Gunga HC, Kirsch K, Rocker L, et al Time course of erythropoietin, triiodothyronine, thyroxine, and thyroid-stimulating hormone at 2,315 m J Appl Physiol 1994 Mar 76(3):1068 72 8005846
Gunga HC, Rocker L, Behn C, et al Shift working in the Chilean Andes (> 3,600 m) and its influence on erythropoietin and the low-pressure system J Appl Physiol 1996 Aug 81(2):846 52 8872655
Guthrie M, Cardenas D, Eschbach JW, et al Effects of erythropoietin on strength and functional status of patients on hemodialysis Clin Nephrol 1993 Feb 39(2):97 102 8448925
Haberl M Erythropoietin Aust Nurses J 1990 Sep 20(2):
Haedersdal C, Mehlsen J, Stenver D, et al Erythropoietin treatment does not compromise cardiovascular function in chronic renal failure Angiology 1994 Mar 45(3):231 4 8129205
Halstenson CE, Macres M, Katz SA, et al Comparative pharmacokinetics and pharmacodynamics of epoetin alfa and epoetin beta Clin Pharmacol Ther 1991 Dec 50(6):702 12 1752115
Hanicki Z, Sulowicz W, Stepniewski M, et al [Recombinant human erythropoietin stimulates synthesis of fetal hemoglobin in patients with renal anemia treated by repeated hemodialysis] Pol Arch Med Wewn 1991 Jun 85(6):352 5 1716757
Hanicki Z, Sulowicz W, Stepniewski M, et al. Recombinant human erythropoietin stimulates synthesis of fetal haemoglobin in haemodialysed patients with anaemia due to end-stage kidney. Contrib Nephrol. 1990;87:11-4. [pmid: 1709603].
Hannah R, Levin NW, London R, et al Renal disease in the managed care setting: Selection and monitoring of outcome criteria Am J Kidney Dis 1999 33(4):S1 S24 10214346
Harnett JD, Kent GM, Foley RN, et al Cardiac function and hematocrit level Am J Kidney Dis 1995 Apr 25(4 Suppl 1):S3 7 7702071
Harnett JD, Le Cardiovascular effects of erythropoietin Dialysis Transplant 1993 22(9):
Harper G EPO -- one year later: a look at rehabilitation A patient perspective -- from patients. Nephrol News Issues 1990 Jun 4(6):
Harris DC, Chapman JR, Stewart JH, et al Low dose erythropoietin in maintenance haemodialysis: improvement in quality of life and reduction in true cost of haemodialysis Aust NZ J Med 1991 Oct 21(5):693 700
Harsfalvi J, Boda Z, Mikita J, et al Effect of recombinant human erythropoietin on plasma von Willebrand factor in chronic hemodialysis patients (4) Am. J. Hematol 1994 47(2):144 5 8092134
Harvengt C Drugs recently released in Belgium. Recombinant human erythropoietin-nizatidine Acta Clin Belg 1989 44(6):419 20 2576492
Hatch FE Reversing the anemia of renal failure Hosp Pract (Off Ed) 1990 Feb 28 25(2A):25 34 2105980
Hegbrant J, Thysell H, Ekman R Erythropoietin treatment and plasma levels of corticotropin-releasing hormone, delta sleep-inducing peptide and opioid peptides in hemodialysis patients Scand J Urol Nephrol 1992 26(4):393 6 1337953
Held PJ, Port FK, Webb RL, et al Excerpts from the USRDS 1995 annual data report Am J Kidney Dis 1995 26(4 Suppl.):S1 S186
Held PJ, Port FK, Webb RL, et al United States Renal Data System 1996 annual data report Am J Kidney Dis 1996 28(3 Suppl.):S1 S165
Hendrix WR Epoetin alfa -- focus on optimal hematocrit. Case study of the anemic patient ANNA J 1996 Feb 23(1):46 9 8702361
Henry DH, Spivak JL Clinical use of erythropoietin Curr Opin Hematol 1995 Mar 2(2):118 24 9371981
Henry DH Epoetin alfa and high-dose chemotherapy Semin Oncol 1998 Jun 25(3 Suppl 7):54 7 9671332
Hensley MK Case management of the anemic patient. Epoetin alfa: focus on nutrition management ANNA J 1990 Oct 17(5):390 1 2241257
Hisano S, Kaku Y, Ueda K, et al Human erythropoietin in children undergoing continuous ambulatory peritoneal dialysis Acta Paediatr Jpn 1992 Feb 34(1):36 41 1580151
Hoen B, Paul-Dauphin A, Hestin D, et al EPIBACDIAL: a multicenter prospective study of risk factors for bacteremia in chronic hemodialysis patients J Am Soc Nephrol 1998 9(5):869 76 9596085
Holechek MJ, Watson AJ Case management of the anemic patient. Focus on blood pressure and rHuEPO therapy ANNA J 1990 Feb 17(1):72 3 2317107
Holley JL, Schmidt RJ, Bender FH, et al Gynecologic and reproductive issues in women on dialysis Am J Kidney Dis 1997 29(5):685 90 9159301
Hood VL, Ingraham A Erythropoietin for chronic ambulatory peritoneal dialysis patients: once a week can be enough J Am Soc Nephrol 1992 Apr 2(10):1545 6 1600126
Horina JH, Fazekas F, Niederkorn K, et al Cerebral hemodynamic changes following treatment with erythropoietin Nephron 1991 58(4):407 12 1922604
Horina JH, Horn S, Silly H, et al Need for erythropoietin treatment in predialysis patients Lancet 1991 Mar 2 337(8740):
Horl WH, Schaefer RM Recombinant human erythropoietin therapy for renal anemia J. Nephrol 1989 2(4):277 90
Hortian B, Schmidt R, Wustenberg PW, et al [Ergometric results of r-erythropoietin treatment of hemodialysis patients] Z Gesamte Inn Med 1990 May 15 45(10):274 7
Hosokawa S, Yoshida O Effects of erythropoietin on trace elements in patients with chronic renal failure undergoing hemodialysis Nephron 1993 65(3):414 7 8289992
Hossli S Developing an anemia management protocol. Case study of the anemic patient ANNA J 1997 Dec 24(6):678 84; quiz 685 9444110
Hou CC, Wu SC, Wu SC, et al Serum transferrin receptor concentration is not indicative of erythropoietic activity in chronic hemodialysis patients with poor response to recombinant human erythropoietin Chin Med J (Taipei) 1998 61(8):456 62
Hou SH Frequency and outcome of pregnancy in women on dialysis Am J Kidney Dis 1994 Jan 23(1):60 3 8285199
House AA, Pham B, Page DE Transfusion and recombinant human erythropoietin requirements differ between dialysis modalities Nephrol Dial Transplant 1998 Jul 13(7):1763 9 9681725
Hsia CC Respiratory function of hemoglobin New England Journal Of Medicine 1998, 0122 1998 338(4):239 47
Huang TP, Lin CY Intraperitoneal recombinant human erythropoietin therapy: influence of the duration of continuous ambulatory peritoneal dialysis treatment and peritonitis Am J Nephrol 1995 15(4):312 7 7573189
Hughes RT, Cotes PM, Pippard MJ, et al Subcutaneous administration of recombinant human erythropoietin to subjects on continuous ambulatory peritoneal dialysis: an erythrokinetic assessment Br J Haematol 1990 Jun 75(2):268 73 2372513
Humphries JE Anemia of renal failure. Use of erythropoietin Med Clin North Am 1992 May 76(3):711 25 1578966
Huppmann M, Hief C, Schenk E, et al [Erythropoietin therapy in renal anemia. Effect on ergospirometry performance parameters] Wien Med Wochenschr Suppl 1989 104(suppl):48 50 2588635
Hussein MM, Bakir N, Roujouleh H Low-dose recombinant human erythropoietin in dialysis patients living at high altitude Nephrol Dial Transplant 1992 7(2):173 4
Hymes, Hawthorne, Clowers Impaired response to recombinant human erythropoietin therapy in children with peritonitis Dial Transplant 1994 23(8):462 3
Icardi A, Paoletti E, Molinelli G. Efficacy of recombinant erythropoietin after subcutaneous or intraperitoneal administration to patients on CAPD. Adv Perit Dial. 1990;6:292-5. [pmid: 1982830].
Ifudu O, Chan E, Paul H, et al Anemia severity and missed dialysis treatments in erythropoietin-treated hemodialysis patients ASAIO Journal 1996 42(3):146 9 8725679
Ifudu O, Dawood M, Homel P Erythropoietin-induced elevation in blood pressure is immediate and dose dependent Nephron 1998 Aug 79(4):486 7 9689173
Ifudu O, Friedman EA Economic implications of inadequate response to erythropoietin inpatients with end-stage renal disease Dial Transplant 1997 26(10):664 9
Ifudu O, Macey LJ, Friedman EA Resurgence of blood transfusion therapy in erythropoietin treated hemodialysis patients ASAIO J 1995 Jul-Sep 41(3):M426 30
Ifudu O, Paul H, Mayers JD, et al Pervasive failed rehabilitation in center-based maintenance hemodialysis patients Am J Kidney Dis 1994 Mar 23(3):394 400 8128941
Imarisio P, Biamino E, Bongiorno P, et al [Erythropoietin treatment in Piedmont and Valle d'Aosta] Minerva Urol Nefrol 1991 Jul-Sep 43(3):143 5 1817336
Imiela J, Korczak-Kowalska G, Malecki R, et al Immunomodulatory action of human recombinant erythropoietin in man Immunol Lett 1993 Mar 35(3):271 5 8514337
Isarangkura P, Chantarojanasiri T, Hathirat P, et al Pulmonary and platelet function in mild form of Hb H disease Southeast Asian J Trop Med Public Health 1993 24 p. 70(Suppl 1):210 2 7886577
Iseki K, Nishime K, Uehara H, et al Increased risk of cardiovascular disease with erythropoietin in chronic dialysis patients Nephron 1996 72(1):30 6 8903858
Ishiguro N [Effect of recombinant human erythropoietin on cytosolic free calcium concentration in platelets] Nippon Jinzo Gakkai Shi 1994 Mar 36(3):250 8 8196222
Ishimitsu T, Tsukada H, Ogawa Y, et al Genetic predisposition to hypertension facilitates blood pressure elevation in hemodialysis patients treated with erythropoietin Am J Med 1993 Apr 94(4):401 6 8475933
Ishimura E, Nishizawa Y, Okuno S, et al Diabetes mellitus increases the severity of anemia in non-dialyzed patients with renal failure J Nephrol 1998 Mar-Apr 11(2):83 6 9589379
Ismail N, Ikizler TA Erythropoietin-induced hypertension J Med Liban 1997 45(1):25 30 9421942
Ismail N Use of erythropoietin, active vitamin D3 metabolites, and alkali agents in predialysis patients Semin Nephrol 1997 Jul 17(4):270 84 9241713
Ito K, Hattori M [Erythropoietin treatment in children with chronic renal failure] Nippon Rinsho 1991 Dec 49(Suppl):688 94 1808336
Jaar B, Denis A, Viron B, et al Effects of long-term treatment with recombinant human erythropoietin on physiologic inhibitors of coagulation Am J Nephrol 1997 17(5):399 405 9382155
Jabs K, Harmon WE Recombinant human erythropoietin therapy in children on dialysis Adv Ren Replace Ther 1996 Jan 3(1):24 36 8620365
Jacobs C Normalization of haemoglobin: why not? Nephrol Dial Transplant 1999 14(suppl 2):75 9 10334671
Jacobs C Starting r-HuEPO in chronic renal failure: when, why, and how? Nephrol Dial Transplant 1995 10(suppl 2):43 7 7644105
Jacobs K, Shoemaker C, Rudersdorf R, et al. Isolation and characterization of genomic and cDNA clones of human erythropoietin. Nature. 1985;313:806-10. [pmid: 3838366].
Jacquot C, Berthelot JM, Chiappini-Judith D, et al [Treatment of anemia in chronic hemodialysis patients with recombinant human erythropoietin: long-term results in 15 patients] Nephrologie 1990 11(1):11 6 2374641
Jacquot C, Rossert J Does the normalization of hematocrit by recombinant erythropoietin increase the vascular and thrombotic risks in renal failure patients? Sang Thromb Vaiss 1990 2(5):271 3
Jacquot C. A drug for hospital use: recombinant erythropoietin. Rev Prat Med Gen. 1990;(89):11-3.
Janvier G, Roth C, Benillan N, et al [Blood transfusion in surgery: can it still be reduced by human recombinant erythropoietin]? Ann Fr Anesth Reanim 1996 15(8):1219 29 9636798
Jelkmann W [Recurrence of anemia after discontinuation of erythropoietin substitution.] Dtsch Med Wochenschr 1991 Jul 12 116(28-29):
Jelkmann W Erythropoietin: structure, control of production, and function Physiol Rev 1992 72(2):449 89 1557429
Jelkmann W Recombinant erythropoietin Pharm Ztg 1991 136(27):9 13
Jensen JD, Eiskjaer H, Bagger JP, et al Elevated level of erythropoietin in congestive heart failure relationship to renal perfusion and plasma renin J Intern Med 1993 Feb 233(2):125 30 8433072
Jensen JD, Madsen JK, Jensen LW, et al Pharmacokinetics of epoetin in dialysis patients before and after correction of the anaemia Drug Invest 1994 8(5):278 87
Jensen JD, Madsen JK, Jensen LW Comparison of dose requirement, serum erythropoietin and blood pressure following intravenous and subcutaneous erythropoietin treatment of dialysis patients. IV and SC erythropoietin Eur J Clin Pharmacol 1996 50(3):171 7 8737755
Ji SM, Li LS, Ji DX [Clinical studies of recombinant human erythropoietin in patients on long-term dialysis] Chung Hua Nei Ko Tsa Chih 1993 Feb 32(2):100 2 8404323
Jim RT Use of erythropoietin in Jehovah's Witness patients Hawaii Med J 1990 Jun 49(6):
Johnson CA, Rosowski E, Zimmerman SW. A prospective open-label study evaluating the efficacy and adverse reactions of the use of Niferex-150 in ESRD patients receiving EPOGEN. Adv Perit Dial. 1992;8:444-7. [pmid: 1361844].
Johnson WJ, McCarthy JT, Yanagihara T, et al Effects of recombinant human erythropoietin on cerebral and cutaneous blood flow and on blood coagulability Kidney Int 1990 Nov 38(5):919 24 2266676
Jones MA, Kingswood JC, Dallyn PE, et al Changes in diurnal blood pressure variation and red cell and plasma volumes in patients with renal failure who develop erythropoietin-induced hypertension Clin Nephrol 1995 Sep 44(3):193 200 8556836
Jones MA, Kingswood JC, Dallyn PE, et al Haemodynamic changes measured by transthoracic bioimpedance during treatment with recombinant human erythropoietin Clin Exp Hypertens 1996 Jan 18(1):51 64 8822233
Jonnalagadda V, Bloom E J, Raja R M. Importance of iron saturation for erythropoietin responsiveness in chronic peritoneal dialysis. Adv Perit Dial. 1997;13:113-5. [pmid: 9360662].
Jungers P, Joly D, Massy Z, et al. Effect of recombinant erythropoietin therapy on the rate of progression of chronic renal failure. J Am Soc Nephrol. 1998;9.
Junor BJ Hematocrit above 30% in continuous ambulatory peritoneal dialysis patients treated with erythropoietin is harmful Perit Dial Int 1993 13(Suppl 2):S535 7 8399658
Juric M, Rupcic V, Topuzovic N, et al Haemodynamic changes and exercise tolerance in dialysis patients treated with erythropoietin Nephrol Dial Transplant 1995 10(8):1398 404 8538932
Kaizu K, Uriu K, Eto S Effects of recombinant human erythropoietin (EPOCH) on the coagulation and fibrinolytic systems and platelet function in pre-dialysis patients with chronic renal failure Nippon Jinzo Gakkai Shi 1993 Aug 35(8):989 97 8255011
Kaizu K, Uriu K, Eto S Effects of recombinant human erythropoietin (epoch) on the coagulation and fibrinolytic systems and platelet function in pre-dialysis patients with chronic renal failure Jpn J Nephrol 1993 35(8):989 97
Kakuk G, Karpati I, Matyus J [Recombinant human erythropoietin in the therapy of anemia in hemodialyzed patients] Orv Hetil 1990 Oct 28 131(43):2365 6, 2369-71
Kamenetz Y, Beloosesky Y, Zeltzer C, et al Relationship between routine hematological parameters, serum IL-3, IL-6 and erythropoietin and mild anemia and degree of function in the elderly Aging (Milano) 1998 Feb 10(1):32 8 305699 9589749
Kameyama M, Kosugi E, Kobayashi Het al Effects of recombinant human erythropoietin on intractable leg edema in diabetic patients with predialysis chronic renal failure, and its mechanism Journal Of The Medical Society Of Toho University 1996 43(4):281 5
Kampf D Special drug treatment in dialysis patients Pharm Ztg 1993 138(47):9 13
Kaplan BS, Vedaranayanan VV Pathogenesis of the hemolytic uremic syndromes: current concepts Indian J Pediatr 1988 55(4):512 25 3049333
Kaufman JS, Reda DJ, Fye CL, et al Subcutaneous compared with intravenous epoetin in patients receiving hemodialysis. Department of Veterans Affairs Cooperative Study Group on Erythropoietin in Hemodialysis Patients N Engl J Med 1998 339(9):578 83 9718376
Kaupke CJ, Vaziri ND, Sampson JR, et al Effect of erythropoietin therapy on diet and dialysis clearances in hemodialysis patients Int J Artif Organs 1990 Apr 13(4):218 22 2373550
Kaupke CJ, Vaziri ND Effect of recombinant erythropoietin on electrolytes and nutrition in end-stage renal disease patients Int J Artif Organs 1993 Feb 16(2):59 62 8486413
Kavadias D, Fourtounas C, Tsouchnikas J, et al L-carnitine and erythropoietin requirements in hemodialysis patients Am J Kidney Dis 1996 Jul 28(1):
Keown PA. Quality of life in end-stage renal disease patients during recombinant human erythropoietin therapy. The Canadian Erythropoietin Study Group. Contrib Nephrol. 1991;88:81-6; discussion 87-9. [pmid: 2040199].
Kes P, Reiner Z, Starcevic B, et al Influence of erythropoietin treatment on dialyzer reuse Blood Purif 1997 15(2):77 83 9087814
Kessler M, Legrand E, Mertes M, et al Treatment of chronic renal failure anemia by recombinant erythropoietin and polycythemia following kidney transplantation Nephron 1992 62(3):370 1 1436359
Kinouchi T, Koide K, Shimizu N [Body fluids balance in chronic hemodialysis patients] Nippon Rinsho 1992 Jan 50(Suppl):465 74 1578725
Kinugasa E, Nabeshima K, Niikura K, et al [The effects of r-HuEPO on platelet function and coagulation factors in hemodialysis patients] Nippon Jinzo Gakkai Shi 1990 Oct 32(10):1109 16 2287103
Kirlin L Case management of the anemic patient. Epoetin alfa: focus on hematocrit ANNA J 1992 Feb 19(1):66 7 1546890
Kirlin LF Case management of the anemic patient: epoetin alfa-focus on iron supplementation ANNA J 1993 Dec 20(6):678 81 8267412
Kirlin LF Case study of the anemic patient: epoetin alfa-focus on iron management ANNA J 1995 Apr 22(2):192 5 7786067
Klahr S Anemia, dialysis, and dollars N Engl J Med 1996 Feb 15 334(7):461 3
Kleinman KS, Schweitzer SU, Perdue ST, et al The use of recombinant human erythropoietin in the correction of anemia in predialysis patients and its effect on renal function: a double-blind, placebo-controlled trial Am J Kidney Dis 1989 Dec 14(6):486 95 2688405
Kleinman KS, Schweitzer SU Human recombinant erythropoietin (rHuEPO) treatment of severe anemia associated with progressive renal failure may delay the need to initiate regular dialytic therapy Kid Int 1990 37(1):
Klinkmann H, Schmidt R, Wieczorek L, et al. Adverse events of subcutaneous recombinant human erythropoietin therapy. Contrib Nephrol. 1992;100:127-38. [pmid: 1458898].
Klinkmann H, Wieczorek L, Scigalla P Adverse events of subcutaneous recombinant human erythropoietin therapy: results of a controlled multicenter European study Artif Organs 1993 Apr 7(4):219 25
Koch KM, Koene RA, Messinger D, et al The use of epoetin beta in anemic predialysis patients with chronic renal failure Clin Nephrol 1995 Sep 44(3):201 8 8556837
Koch KM. [The treatment of renal anemia]. Verh Dtsch Ges Inn Med. 1989;95:246-8. [pmid: 2603482].
Koene RA, Frenken LA. Does treatment of predialysis patients with recombinant human erythropoietin compromise renal function?. Contrib Nephrol. 1990;87:105-12. [pmid: 2093536].
Koene RA, Frenken LA Starting r-HuEPO in chronic renal failure: when, why, and how? Nephrol Dial Transplant 1995 10(Suppl 2):35 42
Kohler M, Morsdorf S, Jung F, et al. [Recombinant human erythropoietin (rh-EPO) in chronic, dialysis-dependent renal failure: effects on macro- and microcirculation and hematologic parameters]. Beitr Infusionsther. 1990;26:89-95. [pmid: 1703909].
Koide K, Arai T [Erythropoietin-complications, side effects] Nippon Rinsho 1991 Dec 49(Suppl):679 87
Koide K, Sano M, Takeda F, et al [Anemia in acute renal failure and chronic renal failure] Nippon Rinsho 1991 Mar 49(3):685 9 2041197
Kokot F, Wiecek A, Grzeszczak W, et al [The effect of erythropoietin treatment on endocrine organ function in patients with terminal-stage kidney failure on hemodialysis] Ter Arkh 1991 63(6):86 9
Kokot F, Wiecek A, Grzeszczak W, et al Influence of erythropoietin treatment on function of the pituitary-adrenal axis and somatotropin secretion in hemodialyzed patients Clin Nephrol 1990 May 33(5):241 6 2162262
Kokot F, Wiecek A, Grzeszczak W, et al. Influence of erythropoietin treatment on glucose tolerance, insulin, glucagon, gastrin and pancreatic polypeptide secretion in haemodialyzed patients with end-stage renal failure. Contrib Nephrol. 1990;87:42-51. [pmid: 2093540].
Kokot F, Wiecek A, Schmidt-Gayk H, et al Influence of long-term erythropoietin therapy on endocrine abnormalities in haemodialyzed patients Przegl Lek 1992 49(1-2):43 9 1455006
Kokot F, Wiecek A. Evidence that the anemia of renal failure participates in overall uremic toxicity. Kidney Int Suppl. 1997 Nov;62:S83-6. [pmid: 9350689].
Konoshita T, Okamoto K, Koni I, et al Clinical characteristics of polycystic kidney disease with end-stage renal disease Clinical Nephrology 1998 50(2):113 7 9725783
Kooistra MP, van Es A, Marx JJ, et al Low-dose aspirin does not prevent thrombovascular accidents in low-risk haemodialysis patients during treatment with recombinant human erythropoietin Nephrol Dial Transplant 1994 9(8):1115 20 7800210
Kooistra MP, van Es A, Struyvenberg A, et al Iron metabolism in patients with the anaemia of end-stage renal disease during treatment with recombinant human erythropoietin Br J Haematol 1991 Dec 79(4):634 9 1772785
Kooman JP, Leunissen KM Malnutrition in patients with end-stage renal disease: diagnosis, pathophysiology and treatment Neth J Med 1997 50(3):120 32 9121596
Korbet SM, Vonesh EF, Firanek CA The effect of hematocrit on peritoneal transport Am J Kidney Dis 1991 Nov 18(5):573 8 1951337
Koury MJ Investigating erythropoietin resistance N Engl J Med 1993 Jan 21;328(3):205 6
Kovac A, Demes M, Gonzalvesova E, et al [Chronic renal insufficiency] Vnitr Lek 1996 Jul 42(7):503 6 8928431
Kovac A, Demes M, Pavlovic M, et al [Chronic renal insufficiency. Present views on pathogenesis, clinical aspects and treatment] Vnitr Lek 1996 Jan 42(1):49 53 8629361
Krantz SB Review of patients' responses to epoetin alfa therapy Pharmacotherapy 1990 Mar-Apr 10(2(Pt 2)):15S 21S 2189124
Krawczyk W, Dmoszynska A, Ledwozyw A, et al Human erythropoietin changes fatty acids composition of blood platelet phospholipids in hemodialyzed patients Nephron 1995 69(3):
Krawczyk W, Dmoszynska A, Ledwozyw A [The influence of recombinant human erythropoietin on platelet phospholipid fatty acid composition in patients on long term hemodialysis] Pol Merkuriusz Lek 1996 Dec 1(6):394 7 9273229
Krmar RT, Gretz N, Klare B, et al Renal function in predialysis children with chronic renal failure treated with erythropoietin Pediatr Nephrol 1997 Feb 11(1):69 73 9035175
Krug C, Messinger D, Scigalla P Influence of rhepo on renal anaemia and linear growth in children with end-stage renal disease Nieren-Hochdruckkr 1992 21(3):120 4
Kubasik A, Debska-Slizien A, Dudziak M, et al [Effect of treatment with erythropoietin (r-EPO) on hemodynamics of the cardiovascular system in patients with chronic renal failure (c.r.f.)] Pol Arch Med Wewn 1994 Sep 92(3):217 22 7808930
Kubiak W, Karwacki M, Mazur I Human recombinant erythropoietin: progress in clinical development Ann Univ Mariae Curie Sklodowska [Med] 1994 48(Suppl 3):39 50
Kubitscheck J German-Dutch multicenter study: no aggravation of kidney function due to therapy with erythropoietin Tw Urol Nephrol 1994 6(3):132 3
Kulzer P, Schaefer RM, Krahn R, et al Effectiveness and safety of recombinant human erythropoietin (r-HuEPO) in the treatment of anemia of chronic renal failure in non dialysis patients. European Multicentre Study Group Int J Artif Organs 1994 Apr 17(4):195 202 8070941
Kuo PC, Alfrey EJ, Scandling JD, et al Endovascular stenting of the abdominal aorta following renal transplantation Transplantation 1994 58(4):522 4 8073524
Kurihara S, Marumo F [Aluminum and iron deposition in dialysis patients] Nippon Rinsho 1992 Jan 50(Suppl):905 10 1578787
Kuriyama S, Hopp L, Yoshida H, et al Evidence for amelioration of endothelial cell dysfunction by erythropoietin therapy in predialysis patients Am J Hypertens 1996 May 9(5):426 31 8735172
Kuriyama S, Tomonari H, Yoshida H, et al Reversal of anemia by erythropoietin therapy retards the progression of chronic renal failure, especially in nondiabetic patients Nephron 1997 77(2):176 85 9346384
Kurtz A, Eckardt KU. Erythropoietin production in chronic renal disease before and after transplantation. Contrib Nephrol. 1990;87:15-25. [pmid: 2093537].
Kusunoki M, Kimura K, Nakamura M, et al Effects of hematocrit variations on cerebral blood flow and oxygen transport in ischemic cerebrovascular disease J Cereb Blood Flow Metabol 1981 1(4):413 7
Kutner NG, Cardenas DD, Bower JD Rehabilitation, aging and chronic renal disease Am J Phys Med Rehabil 1992 71(2):97 101 1558740
Lacombe C, Mayeux P, Casadevall N Erythropoietin: its role in the physiopathology of erythropoiesis and therapeutic applications Feuill. Biol 1991 32(182):11 5
Lambert KE Recombinant human erythropoietin Can Nurse 1990 Nov 86(10):27 8 2224810
Landar' VA, Sarycheva TG, Shemetov VD, et al Anemia in patients on systematic hemodialysis for chronic renal failure Urol Nefrol 1989 54(1):54 5
Landgraf H, Grutzmacher P, Garcia-Bartels C, et al Effect of erythropoietin treatment on tissue oxygenation in patients with severe transfusion dependent renal anaemia Eur J Med 1993 Aug-Sep 2(7):393 7 8258026
Lang SM, Schiffl H Losartan and anaemia of end-stage renal disease Lancet 1998 352(9141):
Lankiewicz M, Goodman W, Spivak JL The clinical promise of erythropoietin Im Int Med 1992 13(5):55 6,59,62-5
Lasserre JJ, Greger S, Kortsik C, et al Erythropoietin: a safe drug? Nieren-Hochdruckkr 1989 18(5):205 10
Lataste A, Chuet C, Finielz P, et al [Megakaryocytes in the blood of a patient treated with erythropoietin] Presse Med 1991 Oct 5 20(31):
Laupacis A, Wong C, Churchill D The use of generic and specific quality-of-life measures in hemodialysis patients treated with erythropoietin. The Canadian Erythropoietin Study Group Control Clin Trials 1991 Aug 12(4 Suppl):168S 179S 1663853
Laupacis A A randomized double-blind study of recombinant human erythropoietin in anaemic hemodialysis patients Transplant Proc 1991 23(2):1825 6 2053167
Laupacis A Changes in quality of life and functional capacity in hemodialysis patients treated with recombinant human erythropoietin. The Canadian Erythropoietin Study Group Semin Nephrol 1990 Mar 10(2 Suppl 1):11 9 2192412
Laurence A, Duley JA, Simmonds HA, et al. Erythrocyte CDP-choline accumulation in haemolytic anaemia and renal failure (RF). Adv Exp Med Biol. 1998;431:155-9. [pmid: 9598050].
Laville M, Fouque D. Muscular function in chronic renal failure. Adv Nephrol Necker Hosp. 1995;24:245-69. [pmid: 7572412].
Lawrence IG, Price DE, Howlett TA, et al Erythropoietin and sexual dysfunction Nephrol Dial Transplant 1997 Apr 12(4):741 7 9141005
Lazebnik N, Jaffa AJ, Peyeser MR Hemolytic-uremic syndrome in pregnancy. Review of the literature and report of a case Obstet Gynecol Surv 1985 40(10):618 21 3903577
Lebel M, Kingma I, Grose J H, et al Effect of recombinant human erythropoietin therapy on ambulatory blood pressure in normotensive and in untreated borderline hypertensive hemodialysis patients Am J Hypertens 1995 Jun 8(6):545 51 7662237
Leon-Velarde F, Monge CC, Vidal A, et al Serum immunoreactive erythropoietin in high altitude natives with and without excessive erythrocytosis Exp Hematol 1991 May 19(4):257 60 2055289
Leschke M, Gradaus F, Schoebel FC, et al Coronary heart disease in patients in terminal renal failure Deutsche Medizinische Wochenschrift 1997 122(31-32):976 82 9267338
Leski M The treatment of chronic renal insufficiency induced anemia with recombinant human erythropoietin Med Hyg 1990 48(1830):547 49
Levin A, Singer J, Thompson CR, et al Prevalent left ventricular hypertrophy in the predialysis population: identifying opportunities for intervention Am J Kidney Dis 1996 Mar 27(3):347 54 8604703
Levin A, Thompson CR, Ethier J, et al Left ventricular mass index increase in early renal disease: impact of decline in hemoglobin Am J Kidney Dis 1999 34(1):125 34 10401026
Levin A Prevalent left ventricular hypertrophy in the predialysis population: identifying opportunities for intervention Am J Kidney Dis 1996 27(3):347 54 8604703
Levin NW. How should anaemia be managed in pre-dialysis patients?. Nephrol Dial Transplant. 1999;14:66-74.
Levin NW Quality of life and hematocrit level Am J Kidney Dis 1992 Jul 20(1 Suppl 1):16 20 1626552
Levin NW, Lazarus JM, Nissenson AR National Cooperative rHu Erythropoietin Study in patients with chronic renal failure-an interim report. The National Cooperative rHu Erythropoietin Study Group Am J Kidney Dis 1993 Aug 22(2 Suppl 1):3 12 8352269
Levy JK, Leski M Erythropoietin in the treatment of anemia in hemodialysis patients Med. Hyg 1989 47(1783):561 6
Lewis NP, Macdougall IC, Willis N, et al The ventilatory cost of exercise compared in chronic heart failure and chronic renal anaemia Q J Med 1992 Jul 83(303):523 31 1484929
Lim VS Does correction of anemia with recombinant human erythropoietin accelerate the progression of renal insufficiency? Semin Nephrol 1990 Mar 10(2 Suppl 1):26 7 2356366
Lim VS Recombinant human erythropoietin in predialysis patients Am J Kidney Dis 1991 Oct 18(4 Suppl 1):34 7 1928077
Lim PS, Yeh CH, Hung TS Effects of recombinant human erythropoietin on echocardiographic findings in elderly dialysis patients Nephrology 1997 3(2):149 54
Lim VS, DeGowin RL, Zavala D, et al Recombinant human erythropoietin treatment in pre-dialysis patients. A double-blind placebo-controlled trial Ann Intern Med 1989 Jan 15 110(2):108 14
Lim VS, Fangman J, Flanigan MJ, et al Effect of recombinant human erythropoietin on renal function in humans Kidney Int 1990 Jan 37(1):131 6 2299799
Lim VS, Kirchner PT, Fangman J, et al The safety and the efficacy of maintenance therapy of recombinant human erythropoietin in patients with renal insufficiency Am J Kidney Dis 1989 Dec 14(6):496 506 2596476
Lin F-K, Suggs S, Lin C-H et al. Cloning and expression of the human erythropoietin gene. Proc Natl Acad Sci USA. 1985;82:7580-84. [pmcid: 391376]. [pmid: 3865178].
Linblad AS, Nolph KD Hematocrit values in the CAPD/CCPD population: a report of the National CAPD Registry Perit Dial Int 1990 10(4):275 8 2096927
Linde T, Wahlberg J, Wikstrom B, et al Outcome of renal transplantation in patients treated with erythropoietin Clin Nephrol 1992 May 37(5):260 3 1606776
Linde T, Wikstrom B, Andersson LG, et al Renal anaemia treatment with recombinant human erythropoietin increases cardiac output in patients with ischaemic heart disease Scand J Urol Nephrol 1996 Apr 30(2):115 20 8738056
Lipkin GW, Kendall R, Haggett P, et al Erythropoietin in acute renal failure Lancet 1989 May 6 1(8645):
Locatelli F, Conte F, Marcelli D The impact of haematocrit levels and erythropoietin treatment on overall and cardiovascular mortality and morbidity-the experience of the Lombardy Dialysis Registry Nephrol Dial Transplant 1998 Jul 13(7):1642 4 9681705
London G, Marchais S, Guerin A, et al Contributive factors to cardiovascular hypertrophy in renal failure Am J Hypertens 1989 2(11 Ii Suppl.):261s 265s 2530994
Lopez-Gomez JM, Jofre R, Moreno F, et al rHuEpo before dialysis and in dialysed patients Nephrol Dial Transplant 1995 10(Suppl 6):31 5 8524491
Lorch JA, Pollak VE Anemia management: one patient at a time Nephrol News Issues 1997 Sep 11(9):
Low I, Grutzmacher P, Bergmann M, et al Echocardiographic findings in patients on maintenance hemodialysis substituted with recombinant human erythropoietin Clin Nephrol 1989 Jan 31(1):26 30 2521587
Low-Friedrich I, Grutzmacher P, Marz W, et al Therapy with recombinant human erythropoietin reduces cardiac size and improves heart function in chronic hemodialysis patients Am J Nephrol 1991 11(1):54 60 1828650
Lowrie EG, Huang WH, Lew NL, et al. The relative contribution of measured variables to death risk among hemodialysis patients. In: Friedman EA, ed. Death on hemodialysis. Dordrecht: Kluwer Academic Publishers; 1994. Chapter 13, p. 121-41.
Lubrich-Birkner I, Schollmeyer P, Steinhauer HB. One year experience with subcutaneous human erythropoietin in CAPD: correction of renal anemia and increased ultrafiltration. Adv Perit Dial. 1990;6:302-7. [pmid: 1982833].
Ludwig H, Fritz E, Leitgeb C, et al Erythropoietin treatment for chronic anemia of selected hematological malignancies and solid tumors Ann Oncol 1993 Feb 4(2):161 7 8448084
Ludwig H, Pecherstorfer M, Leitgeb C, et al Quality of life in chronic anemia of cancer during treatment with recombinant human erythropoietin Cancer 1994 73(10):2535 42 8174050
Lue TF Normalization of serum prolactin levels in hemodialysis patients on recombinant human erythropoietin: editorial comment J Urol 1990 144(2 I):404 5
Lui SL 1996 Hong Kong renal registry report: central renal committee Nephrology 1997 3(6):577 581
Lundin AP, Akerman MJ, Chesler RM, et al Exercise in hemodialysis patients after treatment with recombinant human erythropoietin Nephron 1991 58(3):315 9 1910154
Lundin AP, Delano BG, Quinn-Cefaro R Perspectives on the improvement of quality of life with epoetin alfa therapy Pharmacotherapy 1990 Mar-Apr 10(2) Pt 2)):22S 26S 2345708
Lundin AP Finding logic in the hematocrit measurement audit Nephrol News Issues 1998 Jun 12(6):
Lundin AP Quality of life: subjective and objective improvements with recombinant human erythropoietin therapy Semin Nephrol 1989 Mar 9(1 Suppl 1):22 9 2648517
Ma JZ, Ebben J, Xia H, et al Hematocrit level and associated mortality in hemodialysis patients J Am Soc Nephrol 1999 10(3):610 9 10073612
Macdougall IC, Cavill I, Davies ME, et al. Subcutaneous recombinant erythropoietin in the treatment of renal anaemia in CAPD patients. Contrib Nephrol. 1989;76:219-26. [pmid: 2582780].
Macdougall IC, Davies ME, Hutton RD, et al Rheological studies during treatment of renal anaemia with recombinant human erythropoietin Br J Haematol 1991 Apr 77(4):550 8 2025581
Macdougall IC, Hutton RD, Cavill I, et al Poor response to treatment of renal anaemia with erythropoietin corrected by iron given intravenously BMJ 1989 Jul 15 299(6692):157 8
Macdougall IC, Lewis NP, Saunders MJ, et al Long-term cardiorespiratory effects of amelioration of renal anaemia by erythropoietin Lancet 1990 Mar 3 335(8688):489 93
Macdougall IC, McMahon LP Satellite symposium at XIVth international congress of nephrology, Sydney, Australia, 25 May, 1997, future challenges in optimizing the use of r-huEPO in CRF: Foreword Nephrol Dial Transplant 1998 13(Suppl. 2):
Macdougall IC, Ritz E. 2nd European Epoetin Symposium - Optimizing anaemia therapy in CRF - 17-19 April 1998 Crete, Greece - Foreword. Nephrol Dial Transplant. 1999;14.
Macdougall IC, Tucker B, Thompson J, et al A randomized controlled study of iron supplementation in patients treated with erythropoietin Kidney Int 1996 Nov 50(5):1694 9 8914038
Macdougall IC Meeting the challenges of a new millennium: optimizing the use of recombinant human erythropoietin Nephrol Dial Transplant 1998 13(Suppl 2):23 7 9566487
MacDougall IC Poor response to erythropoietin should be fully investigated and treated BMJ 1995 310(6992):1424 25 7613268
Macdougall IC Quality of life and anemia: the nephrology experience Semin Oncol 1998 Jun 25(3 Suppl 7):39 42 9671329
MacDougall IC. The Normal Haematocrit Trial in dialysis patients with cardiac disease: are we any the less confused about target haemoglobin?. Nephrol Dial Transplant. 1998;13:3030-3. [pmid: 9870460].
Macdougall IC Treatment of renal anemia with recombinant human erythropoietin Curr Opin Nephrol Hypertens 1992 Dec 1(2):210 9 1345620
Maddox N, Futral D, Boudreau FT Serologic investigation of fatal hemolytic anemia associated with a multiple drug history and rh-like autoantibody Immunohematology 1992 8(3):70 76 15946061
Madore F, Lowrie E G, Brugnara C, et al Anemia in hemodialysis patients: variables affecting this outcome predictor J Am Soc Nephrol 1997 Dec 8(12):1921 9 9402095
Mahler W Erythropoietin instead of transfusions Fortschr Med 1990 108(34):
Mahnensmith RL Advances in nephrology: a selected review of progress in care of the patient with renal failure R I Med J 1990 Nov 73(11):507 15 2263848
Mailloux LU, Haley WE Hypertension in the ESRD patient: pathophysiology, therapy, outcomes, and future directions Am J Kidney Dis 1998 32(5):705 19 9820438
Mairbaurl H, Schobersberger W, Hasibeder W, et al Increase in Hb-O2-affinity at moderate altitude (2000 m) in patients on maintenance hemodialysis Clin Nephrol 1989 31(4):198 203 2714024
Mairbaurl H Red blood cell function in hypoxia at altitude and exercise Int J Sports Med 1994 Feb 15(2):51 63 8157369
Majdan M, Ksiazek A, Koziol M, et al Comparison of plasma erythropoietin concentrations and iron status in hemodialyzed patients not requiring and requiring rHuEpo therapy Nephron 1996 73(3):425 9 8832602
Mak RH Correction of anemia by erythropoietin reverses insulin resistance and hyperinsulinemia in uremia Am J Physiol 1996 May 270(5 Pt 2):F839 44 8928846
Mak RH Effect of recombinant human erythropoietin on insulin, amino acid, and lipid metabolism in uremia J Pediatr 1996 Jul 129(1):97 104 8757568
Makil D, Gibel LJ, Tzamaloukas AH CAPD in patients with failure of hemodialysis vascular access Perit Dial Int 1998 18(5):534 6 9848635
Mall T, Schmitt HE, Widmer LK Arterial occlusions in iron deficiency anemia with thrombocytosis Vasa 1985 14(2):188 90 4013501
Malone M, Bailie GR, Eisele G The effect of recombinant human erythropoietin on the quality of life of CAPD patients J App Ther 1996 1(1):39 43
Malyszko J, Malyszko JS, Borawski J, et al A study of platelet functions, some hemostatic and fibrinolytic parameters in relation to serotonin in hemodialyzed patients under erythropoietin therapy Thromb Res 1995 Jan 15 77(2):133 43
Mann JF. What are the short-term and long-term consequences of anaemia in CRF patients?. Nephrol Dial Transplant. 1999;14:29-36. [pmid: 10334665].
Marichal JF, Brignon P, Fender M, et al Human recombinant erythropoietin: the new treatment of anaemia in hemodialysis patients. Practical sights J Med Strasbourg 1990 21(8):436 8
Marichal JF, Masson M [Correction of anemia with human recombinant erythropoietin in a pregnant woman with renal failure] Rev Med Interne 1994 Feb 15(2):149 50 8059125
Marisavljevic D, Djukanovic LJ, Lezajic V [The effect of recombinant human erythropoietin on erythrocyte lines in patients with anemia and chronic renal insufficiency] Srp Arh Celok Lek 1992 Sep-Oct 120(9-10):281 5 1306020
Markham A, Bryson HM Epoetin alfa. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic use in nonrenal applications Drugs 1995 49(2):232 54 7729331
Markowitz GS, Kahn GA, Feingold RE, et al An evaluation of the effectiveness of oral iron therapy in hemodialysis patients receiving recombinant human erythropoietin Clin Nephrol 1997 Jul 48(1):34 40 9247776
Marrades R M, Roca J, Campistol J M, et al Effects of erythropoietin on muscle O2 transport during exercise in patients with chronic renal failure J Clin Invest 1996 May 1 97(9):2092 100
Marrades RM, Alonso J, Roca J, et al Cellular bioenergetics after erythropoietin therapy in chronic renal failure J Clin Invest 1996 May 1 97(9):2101 10
Marsen TA, Pollok M, Baldamus CA [Erythropoietin: from established therapeutic procedures in renal anemia to future areas of use] Med Klin 1992 Apr 15 87(4):207 14
Marsh JT, Brown WS, Wolcott D, et al rHuEPO treatment improves brain and cognitive function of anemic dialysis patients Kidney Int 1991 Jan 39(1):155 63 2002629
Martin GR, Ongkingo JR, Turner ME, et al Recombinant erythropoietin (Epogen) improves cardiac exercise performance in children with end-stage renal disease Pediatr Nephrol 1993 Jun 7(3):276 80 8518098
Martin JF, Moncada S Blood pressure, erythropoietin, and nitric oxide Lancet 1988 1(8586):
Martin-Lester M Cognitive function in dialysis patients. Case study of the anemic patient ANNA J 1997 Jun 24(3):359 65; quiz 366 9238909
Martino, Vogel, O'Brien, et al Erythropoietin therapy improves graft patency with no increased incidence of thrombosis or thrombophlebitis J Am Coll Surg 1998 187(6):616 9 9849735
Martins Prata M, Teixeira de Sousa F, Barbas J, et al [Arterial hypertension in patients with chronic kidney insufficiency in hemodialysis with erythropoietin] Rev Port Cardiol 1990 Feb 9(2):119 23 2346662
Martins Prata M, Teixeira de Sousa F, Barbas J, et al Blood lipids in haemodialysis patients treated with erythropoietin Nephrol Dial Transplant 1990 5(6):
Mason K, McMahon LP. Normalization of haemoglobin in haemodialysis patients: A comparative study. 14th International Congress of Nephrology; 1997. S305.
Mason K, Skinner SL, Sangkabutra T, et al. Effects of erythropoietin on cardiac mass and function, ambulatory blood pressure and blood volumes at comparative levels of haemoglobin. 14th International Congress of Nephrology; 1997. S305.
Mat O, Stolear JC, Georges B Blood lipid profile in hemodialysis patients treated with human erythropoietin Nephron 1992 60(2):236 7 1553011
Mathers T Epoetin alfa-focus on the geriatric patient. Case study of the anemic patient ANNA J 1995 Oct 22(5):494 7 7487195
Mathur PC, Kumar N, Shanker A, et al Post exercise electrocardiographic changes in iron deficiency anaemia: effect of iron therapy Indian Heart J 1988 Nov-Dec 40(6):488 91 3248810
Mathur V, Bretan PN Jr, Tomlanovich S Management of end-stage renal disease: transplantation or dialysis? Curr Opin Urol 1994 4(2):95 99
Matsushita Y, Hara S [Glucose intolerance in patients with chronic renal failure] Nippon Rinsho 1998 Jan 56(Suppl 3):616 21 9513487
Matyus J, Ujhelyi L, Karpati I, et al Usefulness and risk of erythropoietin therapy in pregnancies of patients with chronic renal insufficiency Nephrol Dial Transplant 1996 Aug 11(8):1670 1 8856240
Mavromatidis K, Fytil C, Kynigopoulou P, et al Serum ferritin levels are increased in patients with acute renal failure Clin Nephrol 1998 May 49(5):296 8 9617492
Mayer G, Cada EM, Watzinger U, et al Hemodynamic effects of partial correction of chronic anemia by recombinant human erythropoietin in patients on dialysis Am J Kidney Dis 1991 17(3):286 9 1996570
Mayer G, Horl W H Cardiovascular effects of increasing hemoglobin in chronic renal failure Am J Nephrol 1996 16(4):263 7 8739276
Mayer G, Thum J, Graf H Anaemia and reduced exercise capacity in patients on chronic haemodialysis Clin. Sci 1989 76(3):265 8 2924518
McCarthy JT Anemia, cardiovascular disease, and erythropoietin therapy in chronic renal failure patients ACC Curr J Rev 1997 6(6):29 32
McEvoy GK, ed. Epoetin alfa. In: AHFS drug information 1999. Bethesda: American Society of Health-System Pharmacists; 1999.
McGonigle RJ, Boineau FG, Beckman B, et al Erythropoietin and inhibitors of in vitro erythropoiesis in the development of anemia in children with renal disease J Lab Clin Med 1985 Apr 105(4):449 58 3981057
McGregor E, Stewart G, Junor BJ, et al Successful use of recombinant human erythropoietin in pregnancy Nephrol Dial Transplant 1991 6(4):292 3 1881584
McMahon LP, Dawborn JK Experience with low dose intravenous and subcutaneous administration of recombinant human erythropoietin Am J Nephrol 1990 10(5):404 8 2080791
McMahon LP, Dawborn JK Subjective quality of life assessment in hemodialysis patients at different levels of hemoglobin following use of recombinant human erythropoietin Am J Nephrol 1992 12(3):162 9 1415377
McMahon LP, McKenna MJ, Sangkabutra T, et al Physical performance and associated electrolyte changes after haemoglobin normalization: A comparative study in haemodialysis patients Nephrol Dial Transplant 1999 14(5):1182 7 10344359
McMahon LP. Haemodynamic changes and physical performance at comparative levels of haemoglobin after long-term treatment with recombinant erythropoietin. Nephrol Dial Transplant. 1992;7:1199-206. [pmid: 1337160].
McMahon LP Towards an optimal level of haemoglobin in end-stage renal failure Erythropoiesis: New dimensions in the treatment of anaemia 1995 6(1):8 15
McNamee P, van Doorslaer E, Segaar R Benefits and costs of recombinant human erythropoietin for end-stage renal failure: a review. Benefits and costs of erythropoietin Int J Technol Assess Health Care 1993 Fall 9(4):490 504 8288425
Meier W, Paulitschke M, Lerche D, et al Action of rHuEpo on mechanical membrane properties of red blood cells in children with end-stage renal disease Nephrol Dial Transplant 1991 6(2):110 6 1857522
Meierhenrich R, Jedicke H, Voigt A, et al The effect of erythropoietin on lactate, pyruvate and excess lactate under physical exercise in dialysis patients Clin Nephrol 1996 Feb 45(2):90 7 8846536
Melappioni M, Giansanti R, Boemi M, et al Hemorheologic change before recombinant human erythropoietin treatment in chronic haemodialytic patients Minerva Urol Nefrol 1992 44(2):155 9 1411865
Merkus MP. Physical symptoms and quality of life in patients on chronic dialysis: results of the Netherlands Cooperative Study on Adequacy of Dialysis. Nephrol Dial Transplant. 1999;14:1163-70. [pmid: 10344356].
Metry G, Wikstrom B, Valind S, et al Effect of normalization of hematocrit on brain circulation and metabolism in hemodialysis patients J Am Soc Nephrol 1999 10(4):854 63 10203371
Michel C, Queffelou G, Hufnagel G, et al Recombinant human erythropoietin and chronic kidney failure Hematologie 1997 3(2 Suppl.):76 9
Micheloyannis S, Papadaki F, Jannopoulos A The effect of blood transfusion on alpha EEG activity in thalassemic patients Eur Neurol 1991 31(3):131 5 2044625
Mileto G, Mazzeo RS, Princi P, et al Subcutaneous erythropoietin in long term treatment of renal anemia G Ital Nefrol 1991 8(1):35 42
Mimura N [Treatment of patients with chronic kidney failure] Nippon Naika Gakkai Zasshi 1992 Mar 10 81(3):412 6 1607806
Minetti L Erythropoietin treatment in renal anemia. How high should the target hematocrit be? J Nephrol 1997 10(3):117 9 9238619
Mingardi G, Cornalba L, Cortinovis E, et al Health-related quality of life in dialysis patients. A report from an Italian study using the SF-36 Health Survey Nephrol Dial Transplant 1999 14(6):1503 10 10383015
Mittal SK, Maesaka JK, Fishbane S Diagnosis of iron deficiency in end-stage renal disease Seminars in Dialysis 1999 12(4):231 4
Mittman N Predictors of mortality in hemodialysis (HD): Analysis of serial data over six years J Am Soc Nephol 1993 Mar 3(9):1613 22
Mizuguchi T, Minakuchi J, Kawahara K, et al [Serum transferrin receptor level as an index of the response to erythropoietin therapy for anemia in pre-dialysis patients with chronic renal failure] Nippon Jinzo Gakkai Shi 1997 Jul 39(5):497 502 9283215
Mocks J, Franke W, Ehmer B, et al. Analysis of safety database for long-term epoetin-beta treatment: a meta-analysiscovering 3697 patients. Chapter 12, In: Koch KM, Stein G, eds Pathogenetic and Therapeutic Aspects of Chronic Renal Failure. New York, Marcel Dekker, Inc. 1997; p. 163-79.
Moczulski D, Grzeszczak W, Zukowska-Szczechowska EA, et al [The influence of recombinant human erythropoietin (rHu-EPO) on circadian rhythm of prolactin secretion in patients with chronic renal failure treated with hemodialysis] Pol Arch Med Wewn 1995 Jan 93(1):32 40 7479216
Mohini R Clinical efficacy of recombinant human erythropoietin in hemodialysis patients Semin Nephrol 1989 Mar 9(1 Suppl 1):16 21 2648516
Molzahn M Erythropoietin Dialysis Transplant 1986 15(10):564 8
Monge-C C, Arregui A, Leon-Velarde F Pathophysiology and epidemiology of chronic mountain sickness Int J Sports Med 1992 13(Suppl 1):S79 S81 1483802
Montagnac R, Ebikili B, Schillinger F [Autotransfusion using erythropoietin in patients under chronic hemodialysis. 2 cases] Presse Med 1996 Jun 22 25(22):
Montini G, Cazzin M, Suppiej A, et al Clinical results of anaemia treatment with recombinant human erythropoietin in children maintained by haemodialysis G Ital Nefrol 1990 7(4):259 66
Montini G, Zacchello G, Perfumo F, et al Pharmacokinetics and hematologic response to subcutaneous administration of recombinant human erythropoietin in children undergoing long-term peritoneal dialysis: a multicenter study J Pediatr 1993 Feb 122(2):297 302 8429450
Montloin A [Recombinant human erythropoietin] Rev Infirm 1990 Dec 40(19):33 4
Moore GE, Bertocci LA, Painter PL 31P-magnetic resonance spectroscopy assessment of subnormal oxidative metabolism in skeletal muscle of renal failure patients J Clin Invest 1993 Feb 1(2):420 4
Moore R Towards long-term graft survival in renal transplantation: the role of erythropoietin Nephrol Dial Transplant 1995 10(suppl 1):20 2 7617275
Moran LJ, Carey P, Johnson CA Cost-effectiveness of epoetin alfa therapy for anemia of end-stage renal disease Am J Hosp Pharm 1992 Jun 49(6):1451 4 1529988
Morduchowicz G, Boner G. Hospitalizations in dialysis end-stage renal failure patients. Nephron 1996:73(3):413-6.
Moreno F Quality of life in dialysis patients. A Spanish multicentre study Nephrol Dial Transplant 1996 11(suppl 2):125 129 8804012
Moreno F, Aracil FJ, Perez R, et al Controlled study on the improvement of quality of life in elderly hemodialysis patients after correcting end-stage renal disease-related anemia with erythropoietin Am J Kidney Dis 1996 Apr 27(4):548 56 8678066
Moreno F, Lopez-Gomez JM, Sanz-Guajardo D, et al Quality of life in dialysis patients. A Spanish multicentre study Nephrol Dial Transplant 1996 11(Suppl 2):125 9
Moreno F, Sanz-Guajardo D, Lopez-Gomez JM, et al Increasing the hematocrit has a beneficial effect on quality of life and is safe in selected hemodialysis patients. Spanish Cooperative Renal Patients Quality of Life Study Group of the Spanish Society of Nephrology J Am Soc Nephrol 2000 Feb 11(2):335 42 10665941
Morris K, Skinner J Growth-related changes in echocardiographic measurements Clin Nephrol 1991 Aug 36(2):
Morris KP, Sharp J, Watson S, et al Non-cardiac benefits of human recombinant erythropoietin in end stage renal failure and anaemia Arch Dis Child 1993 Nov 69(5):580 6 8257180
Morris KP, Skinner JR, Hunter S, et al Cardiovascular abnormalities in end stage renal failure: the effect of anaemia or uraemia? Arch Dis Child 1994 Aug 71(2):119 22 7944530
Morris KP, Skinner JR, Hunter S, et al Short term correction of anaemia with recombinant human erythropoietin and reduction of cardiac output in end stage renal failure Arch Dis Child 1993 May 68(5):644 8 8323333
Mourad G, Chong G, Cristol JP, et al [Post-transfusional anti-HLA hyperimmunization: importance of erythropoietin] Nephrologie 1993 14(2):91 4 8327032
Moynot A, Zins B, Naret C, et al [One-year treatment of 43 chronic hemodialysis patients with recombinant human erythropoietin] Presse Med 1990 Jan 27 19(3):111 5
Moynot A [Treatment of anemia in chronically dialyzed patients] Nephrologie 1998 19(3):125 7 9633055
Mrzljak V Recombinant human erythropoietin (r-huepo) in dialysis patients Diabetologia Croatica 1995 24(4):131 139
Muirhead N, Bargman J, Burgess E, et al Evidence-based recommendations for the clinical use of recombinant human erythropoietin Am J Kidney Dis 1995 Aug 26(2 Suppl 1):S1 S24
Muirhead N, Churchill DN, Goldstein M, et al Comparison of subcutaneous and intravenous recombinant human erythropoietin for anemia in hemodialysis patients with significant comorbid disease Am J Nephrol 1992 12(5):303 10 1488998
Muirhead N, Hodsman AB, Hollomby DJ, et al The role of aluminium and parathyroid hormone in erythropoietin resistance in haemodialysis patients Nephrol Dial Transplant 1991 6(5):342 5 1870750
Muirhead N, Hodsman AB Occult infection and resistance of anaemia to rHuEpo therapy in renal failure Nephrol Dial Transplant 1990 5(3):232 4 2113653
Muirhead N Renal disease. II. The clinical impact of recombinant human erythropoietin J R Coll Physicians Lond 1997 Mar-Apr 31(2):125 30 9131506
Muller R, Steffen HM, Brunner R, et al Changes in the alpha adrenergic system and increase in blood pressure with recombinant human erythropoietin (rHuEpo) therapy for renal anemia Clin Invest Med 1991 Dec 14(6):614 22 1665406
Muller-Wiefel DE, Scigalla P. Specific problems of renal anemia in childhood. Contrib Nephrol. 1988;66:71-84. [pmid: 3292150].
Muthny FA, Koch U Influence of epo-medication on quality of life of hemodialysis patients Nieren- Hochdruckkr 1993 22(8):375 80
Nagao K, Tsuchihashi K, Ura N, et al Appropriate hematocrit levels of erythropoietin supplementary therapy in end-stage renal failure complicated by coronary artery disease Can J Cardiol 1997 Aug 13(8):747 53 9284841
Nakamura S, Yang CL, Nakayama K, et al Study of the causes of recombinant human erythropoietin (rHuEPO)-derived hypertension in patients with chronic renal failure J Jpn Soc Dial Ther 1998 31(9):1251 1257
Narita M, Shibata A [The abnormalities of blood cells in chronic kidney failure with long-term dialysis] Nippon Rinsho 1992 Jan 50(Suppl):763 70
Nasu T, Mitui H, Shinohara Y, et al Effect of erythropoietin in continuous ambulatory peritoneal dialysis patients: comparison between intravenous and intraperitoneal administration Perit Dial Int 1992 12(4):373 7 1420496
National Institute of Diabetes and Digestive and Kidney Diseases. Healthy People 2010 Objectives: Chronic kidney disease draft chapter (Kidney Subcommittee). Available at: http://www.niddk.nih.gov/federal/kuhdic/kidsub/2010.htm. Last accessed March 2000.
Navarro JF, Teruel JL, Mateos M, et al Hepatitis C virus infection decreases the effective antibody response to hepatitis B vaccine in hemodialysis patients Clin Nephrol 1994 Feb 41(2):113 6 8004827
Navarro M, Alonso A, Avilla JM, et al Anemia of chronic renal failure: treatment with erythropoietin Child Nephrol Urol 1991 11(3):146 51 1777893
Navarro M Study and conservative treatment of chronic kidney failure in the child An Esp Pediat 1988 29(Suppl 33):137 42 3074685
Neff MS, Goldberg J, Slifkin RF, et al. Anemia in chronic renal failure. Acta Endocrinol Suppl (Copenh). 1985;271:80-6. [pmid: 3865483].
Nemecek K, Bartova V, Jachymova M, et al [Endothelin in patients with chronic kidney failure] Cas Lek Cesk 1995 Aug 23 134(16):511 3
Nemecek K, Bartova V, Jachymova M, et al Endothelin in patients with chronic renal failure Ren Fail 1995 Sep 17(5):559 63 8570868
Nielsen OJ, Thaysen JH Vital indication for erythropoietin in a chronic haemodialysis patient. A case report Dan Med Bull 1989 Dec 36(6):590 2 2612227
Nielsen OJ Recombinant human erythropoietin. Experimental and clinical applications Dan Med Bull 1991 38(5):355 70 1802621
Nieszporek T, Kokot F, Wiecek A, et al [Influence of long-term treatment with human recombinant erythropoietin on secretion of hormones regulating carbohydrate metabolism in hemodialyzed patients with chronic uremia] Pol Arch Med Wewn 1995 Dec 94(6):488 94 8618811
Nieszporek T, Kokot F, Wiecek A, et al [Influence of long-term human recombinant erythropoietin treatment on secretion of pancreatic polypeptide and gastrin in hemodialysed patients with chronic renal failure] Przegl Lek 1995 52(12):590 3 8834657
Nikolaev AI, Klepikov PV, Lashutin SV, et al [Individual differences in the efficacy of Recormon in patients with terminal kidney failure. The role of iron deficiency] Ter Arkh 1993 65(6):45 8
Nikolaev AI, Klepikov PV, Lashutin SV [The recovery of erythropoiesis after the short-term Recormon treatment of renal anemia] Ter Arkh 1992 64(6):90 1
Nishi S, Hirasawa Y [Dialysis-associated heart failure and the prevention and therapy] Nippon Rinsho 1992 Jan 50(Suppl):695 9 1578753
Nissenson AR, Besarab A, Bolton WK, et al Target haematocrit during erythropoietin therapy [editorial] Nephrol Dial Transplant 1997 Sep 12(9):1813 6 9306325
Nissenson AR, Pickett JL, Theberge WS, et al. Brain function is better in hemodialysis (HD) patients (PTS) when hematocrit (HCT) is normalized with erythropoietin (rHuEPO). J Am Soc Nephrol. 1996;7.
Nissenson AR, Rettig RA Medicare's end-stage renal disease program: current status and future prospects Health Aff (Millwood) 1999 Jan-Feb 18(1):161 79
Nissenson AR. Brain function is better in hemodialysis (HD) patients (PTS) when hematocrit (HCT) is normalized with erythropoietin (rHuEPO). J Am Soc Nephrol. 1996;7.
Nissenson AR Epoetin and cognitive function Am J Kidney Dis 1992 Jul 20(1 Suppl 1):21 4 1626553
Nissenson AR Erythropoietin treatment in peritoneal dialysis patients Perit Dial Int 1994 14(Suppl 3):S63 S69 7948280
Nissenson AR National cooperative rHu erythropoietin study in patients with chronic renal failure: a phase IV multicenter study. Report of National Cooperative rHu Erythropoietin Study Group Am J Kidney Dis 1991 Oct 18(4 Suppl 1):24 33 1928075
Nissenson AR Proceedings from the symposium on end-stage renal disease patient management: strategies for meeting the clinical and economic challenges Am J Kidney Dis 1993 22(2 Suppl. 1):1 2
Nissenson AR Recombinant human erythropoietin: impact on brain and cognitive function, exercise tolerance, sexual potency, and quality of life Semin Nephrol 1989 Mar 9(1 Suppl 2):25 31 2669083
NKF-DOQI clinical practice guidelines for the treatment of anemia of chronic renal failure National Kidney Foundation-Dialysis Outcomes Quality Initiative Am J Kidney Dis 1997 Oct 30(4 Suppl 3):S192 240 9339151
Nonnast-Daniel B, Creutzig A, Kuhn K, et al. Effect of treatment with recombinant human erythropoietin on peripheral hemodynamics and oxygenation. Contrib Nephrol. 1988;66:185-94. [pmid: 3292147].
Nonnast-Daniel B, Schaffer J, Frei U. Hemodynamics in hemodialysis patients treated with recombinant human erythropoietin. Contrib Nephrol. 1989;76:283-9; discussion 290-1. [pmid: 2684528].
Norris SH, Kurtzman NA Minimizing anemia in the chronic hemodialysis patient Int J Artif Organs 1986 9(4):199 206 3781644
Novick AC Renal medicine and renal transplantation Curr Opin Urol 1993 3(2):97 98
Novick AC Treatment of the anemia of progressive renal failure with recombinant human erythropoietin: editorial comment J Urol 1990 144(6):
Nowicki M Erythropoietin and hypertension J Hum Hypertens 1995 Feb 9(2):81 8 7752179
Nuss R, Loehr JP, Daberkow E, et al Cardiopulmonary function in men with sickle cell trait who reside at moderately high altitude J Lab Clin Med 1993 Oct 122(4):382 7 8228552
Obert Mak HK. Human recombinant erythropoietin (EPO) corrects insulin resistance and hyperlipidemia in patients on peritoneal dialysis (PD). J Am Soc Nephrol. 1996;7.
Obrador GT, Ruthazer R, Arora P, et al Prevalence of and factors associated with suboptimal care before initiation of dialysis in the United States J Am Soc Nephrol 1999 10(8):1793 800 10446948
Offner G, Hoyer PF, Latta K, et al One year's experience with recombinant erythropoietin in children undergoing continuous ambulatory or cycling peritoneal dialysis Pediatr Nephrol 1990 Sep 4(5):498 500 2242315
Ogden DA Introduction Semin Nephrol 1989 9(1 Suppl 2):1 2
Ogden DA Monitoring considerations in recombinant human erythropoietin therapy Semin Nephrol 1989 Mar 9(1 Suppl 2):12 5 2669080
Ohkubo M, Ishimitsu T, Kawaguchi T, et al [Efficacy and safety of long-term erythropoietin therapy in chronic hemodialysis patients with renal anemia] Nippon Jinzo Gakkai Shi 1993 Feb 35(2):171 7 8315880
Okada T, Takahashi T Effect of low doses of recombinant human erythropoietin on the anemia in hemodialyzed patients (22) Nephron 1991 59(4):689 690 1766524
Okundaye I, Abrinko P, Hou S Registry of pregnancy in dialysis patients Am J Kidney Dis 1998 May 31(5):766 73 9590185
Oliveira C, Boquinhas H, Gaspar A, et al [Assessment of iron requirements during treatment of anemia with recombinant human erythropoietin in patients with chronic renal insufficiency under hemodialysis] Acta Med Port 1992 Jul 5(7):351 7 1442178
Ongkingco JR, Ruley EJ, Turner ME, et al Efficacy of once- versus thrice-weekly subcutaneous recombinant human erythropoietin in children receiving continuous cycling peritoneal dialysis Am J Nephrol 1994 14(1):14 8 8017476
Ongkingco JR, Ruley EJ, Turner ME Use of low-dose subcutaneous recombinant human erythropoietin in end-stage renal disease: experience with children receiving continuous cycling peritoneal dialysis Am J Kidney Dis 1991 Oct 18(4):446 50 1928063
Ono K, Hisasue Y Is folate supplementation necessary in hemodialysis patients on erythropoietin therapy Clin Nephrol 1992 Nov 38(5):290 2 1451343
Ono K, Hisasue Y The rate of increase in hematocrit, humoral vasoactive substances and blood pressure changes in hemodialysis patients treated with recombinant human erythropoietin or blood transfusion Clin Nephrol 1992 Jan 37(1):23 7 1531789
Ortho-Biotech, Inc. Procrit^®^ (epoetin alfa) prescribing information. In: Physicians' desk reference. 53rd ed. Montvale: Medical Economics Press; 1999.
Osaka N, Kawaguchi Y [Anemia of end-stage renal disease (ESRD)] Ryoikibetsu Shokogun Shirizu 1997 17(Pt 2):58 61 9277860
Osorio FV, Teitelbaum I Treatment of congestive heart failure in patients with chronic renal insufficiency and end-stage renal disease Congestive Heart Failure 1996 2(6):11 24
Owczarzak MT, Debska-Slizien A, Biedunkiewicz B, et al Erythrocyte (RBC) Na-K-ATPase and Mg-ATPase activities in hemodialysis patients receiving recombinant erythropoietin (r-EPO) Annales Academiae Medicae Gedanensis 1995 25(Suppl 6):113 7
Owen WF, Lowrie EG C-reactive protein as an outcome predictor for maintenance hemodialysis patients Kidney Int 1998 Aug 54(2):627 36 9690231
Ozakgun R, Paydas S, Demirtas M, et al Effect of erythropoietin on systolic and diastolic left ventricular function in chronic renal failure with anemia Nephron 1995 71(1):103 4 8538829
Pacyk G, Grzeszczak W [The effect of recombinant human erythropoietin (rHu-EPO) on the autonomic nervous system in patients hemodialyzed for chronic kidney failure] Pol Arch Med Wewn 1997 Jan 97(1):22 9 9235548
Paganini EP, Abdulhadi MH, Garcia J, et al Recombinant human erythropoietin correction of anemia. Dialysis efficiency, waste retention, and chronic dose variables ASAIO Trans 1989 Jul-Sep 35(3):513 5 2688718
Paganini EP, Braun WE, Latham D, et al Renal transplantation: results in hemodialysis patients previously treated with recombinant human erythropoietin ASAIO Trans 1989 Jul-Sep 35(3):535 8 2688720
Paganini EP, Eschbach JW, Lazarus JM, et al Intravenous versus subcutaneous dosing of epoetin alfa in hemodialysis patients Am J Kidney Dis 1995 Aug 26(2):331 40 7645538
Paganini EP, Latham D, Abdulhadi M Practical considerations of recombinant human erythropoietin therapy Am J Kidney Dis 1989 Aug 14(2 Suppl 1):19 25
Paganini EP Adapting the dialysis unit to increased hematocrit levels Am J Kidney Dis 1995 Apr 25(4 Suppl 1):S12 7 7702070
Paganini EP In search of an optimal hematocrit level in dialysis patients: rehabilitation and quality-of-life implications Am J Kidney Dis 1994 Jul 24(1 Suppl 1):S10 6; discussion S31-2 8023833
Painter P, Carlson L Case study of the anemic patient: epoetin alfa!focus on exercise ANNA J 1994 May 21(3):304 7 7998811
Painter P, Moore GE The impact of recombinant human erythropoietin on exercise capacity in hemodialysis patients Adv Ren Replace Ther 1994 Apr 1(1):55 65 7641089
Painter P The importance of exercise training in rehabilitation of patients with end-stage renal disease Am J Kidney Dis 1994 Jul 24(1 Suppl 1):S2 9; discussion S31-2 8023835
Pan D, Hsu K, Ray S C Ecchymoses and eschars at sites of injection Lancet 1997 May 10 349(9062):
Panas N, Turkowa M, Zgheib A, et al [Revolution in the treatment of chronic renal insufficiency anemia: the role of recombinant erythropoietin] Rev Med Liege 1990 Jun 45(6):280 5 2367758
Parfrey PS, Harnett JD, Foley RN Heart failure and ischemic heart disease in chronic uremia Current Opinion In Nephrology And Hypertension 1995 4(2):105 110 7600039
Parfrey PS, Harnett JD Clinical aspects of cardiomyopathy in dialysis patients Blood Purif 1994 12(4-5):267 76 7865186
Parfrey PS Cardiac and cerebrovascular disease in chronic uremia Am J Kidney Dis 1993 Jan 21(1):77 80 8418631
Park CW, Shin YS, Shin MJ, et al Pyoderma gangrenosum and spinal epidural abscess after subcutaneous administration of recombinant human erythropoietin Nephrol Dial Transplant 1997 12(7):1506 1508 9249800
Park JS, Kim SB, Park SK, et al Effect of recombinant human erythropoietin on muscle energy metabolism in patients with end-stage renal disease: a 31P-nuclear magnetic resonance spectroscopic study Am J Kidney Dis 1993 Jun 21(6):612 8 8503414
Parker KP, Sands JM Weekly subcutaneous erythropoietin maintains hematocrit in chronic hemodialysis patients J Am Soc Nephrol 1993 Apr 3(10):1717 8 8318688
Parsons DS, Harris DC A review of quality of life in chronic renal failure Pharmacoeconomics 1997 12(2):140 160 10169667
Pascual J, Teruel JL, Marcen R, et al Hemodynamic and cardiac effects of erythropoietin in patients on regular dialysis Int J Artif Organs 1992 Jun 15(6):349 53 1639526
Pascual J, Teruel JL, Moya JL, et al Regression of left ventricular hypertrophy after partial correction of anemia with erythropoietin in patients on hemodialysis: a prospective study Clin Nephrol 1991 Jun 35(6):280 7 1831414
Pascual JF, Lopez JD, Molina M Hemofiltration in children with renal failure Pediatr Clin North Am 1987 34(3):803 818 3295728
Patte D [Quality of life of patients treated for terminal chronic renal failure] Presse Med 1998 Oct 3 27(29):1499 505 9798471
Pena Amaro MP, Garcia Lopez J, Camacho Romera M [Erythropoietin in renal anemia] Rev Enferm 1992 Mar 15(163):67 70
Perez R, Anaya F, Garcia de Vinuesa MS, et al Evolution of panel reactive anti-HLA cytotoxic antibodies (PRA) in patients on dialysis (D) treated with erythropoietin (EPO) Nefrologia 1994 14(3):333 340
Perkins SL. Normal blood and bone marrow values in humans. In: Lee GR, et al., eds. Wintrobe's clinical hematology. 10th ed. Baltimore: Williams and Wilkins; 1999. Appendix A.
Petersen-Lehmann J, Hilbig WP, Morck H The treatment of endocrine diseases Pharm. Ztg 1991 136(5):26 37
Pfaffl W, Gross HJ, Neumeier D, et al. Lymphocyte subsets and delayed cutaneous hypersensitivity in hemodialysis patients receiving recombinant human erythropoietin. Contrib Nephrol. 1988;66:195-204. [pmid: 3391032].
Piccoli A, Puggia RM, Fusaro M, et al A decision analysis comparing three dosage regimens of subcutaneous epoetin in continuous ambulatory peritoneal dialysis Pharmacoeconomics 1995 7(5):444 456 10155331
Pickett JL Normalizing hematocrit in dialysis patients improves brain function Am J Kid Dis 1999 33(6):1122 1130 10352201
Pickett JL, Theberge DC, Brown WS, et al Normalizing hematocrit in dialysis patients improves brain function Am J Kidney Dis 1999 Jun 33(6):1122 30 10352201
Pietrzak I, Baczyk K, Kubiak W Recombinant human erythropoietin administration improves thiamin content in blood and erythrocytes transketolase activity in pre-dialyzed patients Ann Univ Mariae Curie Sklodowska [Med] 1994 48(Suppl 3):29 37
Pietrzyk JA, Dyras P, Smolnik T, et al [Effect of using recombinant human erythropoietin on the effectiveness of hemodialysis in children with terminal renal failure] Przegl Lek 1992 49(1-2):61 5 1280842
Pietrzyk JA, Smolnik T, Szymowska M, et al [Effect of recombinant human erythropoietin-rHu-EPO on the metabolism of children treated by long-term hemodialysis] Przegl Lek 1992 49(1-2):55 60 1455008
Pincus T, Olsen NJ, Russell IJ, et al Multicenter study of recombinant human erythropoietin in correction of anemia in rheumatoid arthritis Am J Med 1990 Aug 89(2):161 8 2200263
Pinevich AJ, Petersen J Erythropoietin therapy in patients with chronic renal failure West J Med 1992 Aug 157(2):154 7 1441466 1011236
Polenakovic M, Sikole A Is erythropoietin a survival factor for red blood cells? J Am Soc Nephrol 1996 Aug 7(8):1178 82 8866410
Pollok M, Bommer J, Gurland HJ, et al. Effects of recombinant human erythropoietin treatment in end-stage renal failure patients. Results of a multicenter phase II/III study. Contrib Nephrol. 1989;76:201-11; discussion 212-8. [pmid: 2684523].
Porsius AJ Simply aluminium to achieve a phosphate-free environment and an acceptable hormone concentration (ii) Tijdschr Ther Geneesm Onderz 1992 17(5):121 125
Port RE, Ding RW, Fies T, et al Predicting the time course of haemoglobin in children treated with erythropoietin for renal anaemia Br J Clin Pharmacol 1998 46(5):461 466 9833599
Portoles J, Torralbo A, Martin P, et al Cardiovascular effects of recombinant human erythropoietin in predialysis patients Am J Kidney Dis 1997 Apr 29(4):541 8 9100042
Powe N R, Eggers P W, Johnson CB Early adoption of cyclosporine and recombinant human erythropoietin: clinical, economic, and policy issues with emergence of high-cost drugs Am J Kidney Dis 1994 Jul 24(1):33 41 8023822
Powe NR, Griffiths RI, Anderson GF, et al Medicare payment policy and recombinant erythropoietin prescribing for dialysis patients Am J Kidney Dis 1993 Oct 22(4):557 67 8213796
Powe NR, Griffiths RI, Bass B Cost implications to Medicare of recombinant erythropoietin therapy for the anemia of end-stage renal disease J Am Soc Nephrol 1993 Apr 3(10):1660 71 8318682
Powe NR, Griffiths RI, de Lissovoy G, et al Access to recombinant erythropoietin by Medicare-entitled dialysis patients in the first year after FDA approval JAMA 1992 268(11):1434 1440 1512912
Powe NR, Griffiths RI, Greer JW, et al Early dosing practices and effectiveness of recombinant human erythropoietin Kidney Int 1993 May 43(5):1125 33 8510392
Powe NR, Griffiths RI, Watson AJ, et al Effect of recombinant erythropoietin on hospital admissions, readmissions, length of stay, and costs of dialysis patients J Am Soc Nephrol 1994 Jan 4(7):1455 65 8161727
Pradella M, Cavill I, d'Onofrio G Assessing erythropoiesis and the effect of erythropoietin therapy in renal disease by reticulocyte counting Clin Lab Haematol 1996 Dec 18(Suppl 1):35 7
Prata MM, de Sousa FT, Barbas JV, et al [Treatment of anemia in patients with chronic kidney insufficiency in hemodialysis with erythropoietin] Acta Med Port 1990 May-Jun 3(3):149 53 2220424
Prichard S, Sniderman A, Cianflone K, et al Cardiovascular disease in peritoneal dialysis Perit Dial Int 1996 16(Suppl 1):S19 S22 8728157
Pugh M, Saylor G Case management of the anemic patient. Focus on hemodynamics ANNA J 1991 Jun 18(3):316 7 2064457
Quarello F, Martina G, Beltrame G, et al [Effects of erythropoietin on the cardiovascular system and the intradialytic hemodynamic behavior] Minerva Urol Nefrol 1991 Jul-Sep 43(3):125 30 1817333
Rachmilewitz EA, Aker M. The role of recombinant human erythropoietin in the treatment of thalassemia. Ann N Y Acad Sci. 1998 Jun 30;850:129-38.
Radermacher J, Koch KM Treatment of renal anemia by erythropoietin substitution. The effects on the cardiovascular system Clin Nephrol 1995 Nov 44(Suppl 1):S56 S60 8608665
Raine AE, Margreiter R, Brunner FP, et al Report on management of renal failure in Europe, XXII, 1991 Nephrol Dial Transplant 1992 7(Suppl 2):7 35 1338121
Raine AE, Roger SD Effects of erythropoietin on blood pressure Am J Kidney Dis 1991 Oct 18(4 Suppl 1):76 83 1928084
Raine AE Hypertension, blood viscosity, and cardiovascular morbidity in renal failure: implications of erythropoietin therapy Lancet 1988 Jan 16 1(8577):97 100 2891990
Raman GV The nature and management of advanced diabetic renal disease Pract. Diabetes 1992 9(4):146 148
Ramello A, Malcangi U, Bruno M, et al. Treatment of anaemia in CAPD patients with recombinant human erythropoietin. Adv Perit Dial. 1990;6:308-11. [pmid: 1982834].
Ramello A, Perosa P, Bruno M, et al [Utilization of EPO in CAPD] Minerva Urol Nefrol 1991 Jul-Sep 43(3):137 41 1817335
Ramirez B, Flores A, Perez F, et al Human recombinant erythropoietin (rHuEPO) in the treatment of anemia in patients with chronic renal failure (CRF): experience with a group of patients on chronic haemodialysis treatment Transplant Proc 1991 Apr 23(2):1833 4 2053170
Ramirez G, Bittle PA, Sanders H, et al The effects of corticotropin and growth hormone releasing hormones on their respective secretory axes in chronic hemodialysis patients before and after correction of anemia with recombinant human erythropoietin J. Clin. Endocrinol. Metab 1994 78(1):63 69 8288716
Rao DS, Shih MS, Mohini R Effect of serum parathyroid hormone and bone marrow fibrosis on the response to erythropoietin in uremia N Engl J Med 1993 Jan 21 328(3):171 5
Rapoport I, Engelhardt I, Drung I, et al Influence of erythropoietin treatment on 2,3-bisphosphoglycerate and O2-affinity of red blood cells in children with renal anemia Biomed Biochim Acta 1990 49(2-3):S280 3 2386518
Rault R, Magnone M The effect of parathyroidectomy on hematocrit and erythropoietin dose in patients on hemodialysis ASAIO Journal 1996 42(5):M901 M903 8945016
Reddingius RE, de Boer AW, Schroder CH, et al Increase of the bioavailability of intraperitoneal erythropoietin in children on peritoneal dialysis by administration in small dialysis bags Perit Dial Int 1997 Sep-Oct 17(5):467 70 9358528
Reisdorff EJ, Prodinger RJ Sudden cardiac death in the athlete Emerg Medicine Clin North Am 1998 16(2):281 294
Rendo P, Biscigniano L, Turconi A, et al [Treatment of anemia in children undergoing chronic hemodialysis with recombinant human erythropoietin] Medicina (B Aires) 1994 54(5 Pt 1):392 8 198880 7658972
Revicki DA, Brown RE, Feeny DH, et al Health-related quality of life associated with recombinant human erythropoietin therapy for predialysis chronic renal disease patients Am J Kidney Dis 1995 Apr 25(4):548 54 7702049
Revicki DA Relationship between health utility and psychometric health status measures Med Care 1992 May 30(5 Suppl):MS274 82 1583939
Riabov SI, Shostka GD, Petrova NN, et al [The effect of Recormon therapy on the quality of life of patients on hemodialysis treatment] Ter Arkh 1996 68(8):43 6
Richalet JP, Souberbielle JC, Antezana AM, et al Control of erythropoiesis in humans during prolonged exposure to the altitude of 6,542 m Am J Physiol 1994 Mar 266(3 Pt 2):R756 64
Riedel E. Total correction of renal anemia improves malnutrition and amino acid (AA) metabolism in hemodialysis (HD) patients. J Am Soc Nephrol. 1996;7.
Riedel E, Hampl H, Nundel M, et al. Total correction of renal anemia improves malnutrition and amino acid (AA) metabolism in hemodialysis (HD) patients. J Am Soc Nephrol. 1996;7.
Riedel E, Hampl H, Scigalla P, et al. Correction of amino acid metabolism by recombinant human erythropoietin therapy in hemodialysis patients. Kidney Int Suppl. 1989 Nov;27:S216-S221. [pmid: 2636662].
Riedel E, Hampl H, Scigalla P, et al Anemia and amino acid homoeostasis in hemodialysis patients Nieren- Hochdruckkr 1990 19(5):199 204
Rigalleau V, Pommereau A, Martin L, et al Acute anemia, renal failure and disseminated gastric adenocarcinoma Revue De Medecine Interne 1995 16(Suppl 2):287s 288s
Ritz E The conservative treatment of chronic kidney failure: the prevention of late complications Therapiewoche 1991 41(9):530, 531 534
Robbins KC, Senger JM, Kerhulas S, et al Iron management in ESRD and the role of the nephrology nurse ANNA J 1997 Apr 24(2):265 72; quiz 273-4 9180431
Roberts GW, Zoanetti GD Clobazam and n-desmethylclobazam serum concentrations in endstage renal failure and hemodialysis Ann Pharmacother 1994 28(7-8):966 967 7949528
Roberts M 2nd annual international symposium on daily home hemodialysis Dialysis And Transplantation 1996 25(6):361, 365 366
Robertson HT, Haley NR, Guthrie M, et al Recombinant erythropoietin improves exercise capacity in anemic hemodialysis patients Am J Kidney Dis 1990 Apr 15(4):325 32 2321645
Robertson JS, Graves J The end stage renal disease program N Engl J Med 1993 329(2):139 141
Rockel A, Abdelhamid S, Menth M Secondary manifestations in endstage renal failure and their treatment Med Welt 1992 43(1):55 60
Rodriguez RA Use of the medical differential diagnosis to achieve optimal end-stage renal disease outcomes Adv Ren Replace Ther 1997 Apr 4(2):97 111 9113226
Roger SD, Baker LR, Raine AE Autonomic dysfunction and the development of hypertension in patients treated with recombinant human erythropoietin (r-HuEPO) Clin Nephrol 1993 Feb 39(2):103 10 8448912
Roth D, Smith RD, Schulman G, et al Effects of recombinant human erythropoietin on renal function in chronic renal failure predialysis patients Am J Kidney Dis 1994 Nov 24(5):777 84 7977319
Rousseau P [Financial impact of anemia in patients with chronic renal insufficiency undergoing hemodialysis at centers] Nephrologie 1990 11(3):147 52 2234271
Royer B, Arock M [Therapeutic use of hematopoietic growth factors. I. Erythropoietin and thrombopoietin] Ann Biol Clin (Paris) 1998 Mar-Apr 56(2):143 52 9754239
Rozental' RL, Zezina LI, Spudass AV [The use of recombinant erythropoietin with patients on programmed hemodialysis] Ter Arkh 1991 63(12):110 3
Rud'ko IA, Balashova TS, Kubatiev AA, et al [The effect of recombinant human erythropoietin during hemodialysis on the thrombocyte and erythrocyte functions of patients with chronic kidney failure] Ter Arkh 1994 66(6):57 60
Rud'ko IA, Pokrovskii IuA, Ermolenko VM, et al [The effect of recombinant human erythropoietin on thrombocyte aggregation capacity and on the blood prostanoid level in patients with chronic kidney failure on hemodialysis] Ter Arkh 1991 63(10):128 30
Ruedin P Correction of anemia related to chronic renal insufficiency. Practical guideline of recombinant human erythropoietin treatment Medcine Et Hygiene 1997 55(2152):373 377
Ruedin P Ten-year of experience with human recombinant erythropoietin Med Hyg 1995 53(2060):405 8
Ruedin P Treatment of renal anaemia in predialysis Med Hyg 1998 56(2229):2081 4
Rusko HR New aspects of altitude training Am J Sports Med 1996 24(Suppl):S48 S52 8947429
Rutkowski B, Gora E, Barlik J, et al [Histidine in the treatment of anemia in patients with chronic renal failure treated by hemodialysis] Pol Tyg Lek 1987 Aug 24 42(34):1031 4
Rutkowski B [Practical aspects of erythropoietin treatment-state of current knowledge] Przegl Lek 1995 52(3):
Saatci U, Topaloglu R, Ozen S, et al Does erythropoietin have a beneficial effect on calcium, phosphorus and parathyroid hormone levels in pediatric hemodialysis patients? Nephron 1994 67(3):
Sadler JH, Levin GV, Painter, et al Discussion Am J Kidney Dis 1994 24(1 Suppl):S31 S32
Sadler JH Race and access to erythropoietin by patients on hemodialysis JAMA 1994 Dec 21 272(23):1818 9 7990207
Sagales T, Gimeno V, Planella MJ, et al Effects of rHuEPO on Q-EEG and event-related potentials in chronic renal failure Kidney Int 1993 Nov 44(5):1109 15 8264143
Sakai O [Physiopathology and therapy of chronic kidney failure] Nippon Naika Gakkai Zasshi 1995 Mar 10 84(3):480 4 7751793
Sakiewicz P, Paganini E The use of iron in patients on chronic dialysis: mistake and misconceptions J Nephrol 1998 Jan-Feb 11(1):5 15 9561479
Salaman JR Kidney transplantation Curr Pract Surg 1992 4(4):195 200
Saldanha LF, Weiler EW, Gonick HC Effect of continuous ambulatory peritoneal dialysis on blood pressure control Am J Kidney Dis 1993 Feb 21(2):184 8 8430680
Saleh A, Krane NK, Caballero M, et al. Once weekly subcutaneous erythropoietin is an effective maintenance therapy in the treatment of anemia of end stage renal disease in patients on CAPD. Adv Perit Dial. 1991;7:288-91. [pmid: 1680448].
Salive ME, Cornoni-Huntley J, Guralnik JM, et al Anemia and hemoglobin levels in older persons: relationship with age, gender, and health status J Am Geriatr Soc 1992 40(5):489 496 1634703
Saltissi D, Sauvage D, Westhuyzen J Comparative response to single or divided doses of parenteral iron for functional iron deficiency in hemodialysis patients receiving erythropoietin (epo) Clin Nephrol 1998 49(1):45 48 9491286
Salvarani C, Lasagni D, Casali B, et al Recombinant human erythropoietin therapy in patients with rheumatoid arthritis with the anemia of chronic disease J Rheumatol 1991 Aug 18(8):1168 71 1941817
Salvati F, Liani M, La Torre M, et al Immunological effects of recombinant human erythropoietin on end-stage renal disease pediatric and adult patients Nephron 1994 68(4):510 1 7870240
Salvati F, Liani M Erythropoietin and thrombotic events Lancet 1998 Oct 31 352(9138):
Samtleben W, Baldamus CA, Bommer J, et al. Blood pressure changes during treatment with recombinant human erythropoietin. Contrib Nephrol. 1988;66:114-22. [pmid: 3292144].
Samtleben W, Baldamus CA, Bommer J, et al. Indications and contraindications for recombinant human erythropoietin treatment. Results in hemodialysis patients. Contrib Nephrol. 1989;76:193-200; discussion 212-8. [pmid: 2684521].
Samtleben W, Ehmer B, Lutz-Knochenhauer I, et al. Side effects during recombinant human erythropoietin therapy in 2,000 ESRD patients. Contrib Nephrol. 1991;88:107-16; discussion 117. [pmid: 2040172].
Samuels MA, Thalinger K Cerebrovascular manifestations of selected hematologic diseases Semin Neurol 1991 11(4):411 418 1811296
Sanders HN, Rabb HA, Bittle P, et al Nutritional implications of recombinant human erythropoietin therapy in renal disease J Am Diet Assoc 1994 Sep 94(9):1023 9 8071484
Sanderson JE Pathogenesis of oedema in chronic severe anaemia: studies of body water and sodium, renal function, haemodynamic variables and plasma hormones Br Heart J 1994 May 71(5):
Sasagawa I, Nakada T, Hashimoto T, et al Change in haemoglobin concentration, haematocrit and vasoactive hormones in haemodialysis patients with erythropoietin-associated hypertension Int Urol Nephrol 1994 26(2):237 43 8034437
Satoh K, Ikeda Y, Kurokawa S, et al [Effect of recombinant human erythropoietin administration on cardiovascular system in patient with chronic renal failure: an analysis of the blood pressure upward] Kokyu To Junkan 1989 Mar 37(3):313 9 2734509
Satoh K, Ikeda Y, Kurokawa S, et al Effect of recombinant human erythropoietin administration on cardiovascular system in patients with chronic renal failure: an analysis of the blood pressure upward Respir Circ 1989 37(3):313 9
Saul F, Lederle RM, Klaus D, et al The influence of erythropoietin on hemodynamics, left ventricular performance and neurohumoral factors in end-stage renal failure Clin. Exp. Hypertens. Part A Theory Pract 1990 12(3):
Savica V, Costantino G, Monardo P, et al Subcutaneous low doses of recombinant human erythropoietin in predialysis patients do not interfere with the progression of renal failure Am. J. Nephrol 1995 15(1):10 14 7872358
Savourey G, Garcia N, Besnard Y, et al Pre-adaptation, adaptation and de-adaptation to high altitude in humans: cardio-ventilatory and haematological changes Eur J Appl Physiol 1996 73(6):529 35
Sawka MN, Young AJ, Rock PB, et al Altitude acclimatization and blood volume: effects of exogenous erythrocyte volume expansion J Appl Physiol 1996 Aug 81(2):636 42 8872628
Sayinalp N, Erdem Y, Ilhami Ozcebe O, et al Recombinant human erythropoietin increases platelet aggregation in chronic hemodialysis patients Thromb Res 1998 May 15 90(4):195 8
Schaefer RM, Heidland A Efficient therapy of renal anemia by recombinant human erythropoietin Nieren Hochdruckkr 1989 18(11):501 505
Schaefer RM, Kokot F, Kuerner B, et al Normalization of serum prolactin levels in hemodialysis patients on recombinant human erythropoietin Int J Artif Organs 1989 Jul 12(7):445 9 2767790
Schaefer RM, Kokot F, Wernze H, et al Improved sexual function in hemodialysis patients on recombinant erythropoietin: a possible role for prolactin Clin Nephrol 1989 Jan 31(1):1 5 2914405
Schaefer RM, Kuerner B, Zech M, et al Clinical experience with recombinant human erythropoietin in hemodialysis patients Pol Arch Med Wewn 1988 Oct 80(4):213 20 3078210
Schaefer RM, Kurner B, Zech M, et al [Therapy of renal anemia with recombinant human erythropoietin] Dtsch Med Wochenschr 1988 Jan 29 113(4):125 9
Schaefer RM, Leschke M, Strauer B E, et al Blood rheology and hypertension in hemodialysis patients treated with erythropoietin Am J Nephrol 1988 8(6):449 53 3218658
Schaefer RM, Schaefer L Management of iron during rhepo therapy Annales Academiae Medicae Gedanensis 1995 25(Suppl 6):69 73
Schaefer RM. Impact of recombinant erythropoietin on sexual function in hemodialysis patients. Contrib Nephrol. 1989;76:273-282. [pmid: 2684527].
Schaller R, Sperschneider H, Thieler H, et al Differences in intravenous and subcutaneous application of recombinant human erythropoietin: a multicenter trial Artif Organs 1994 Aug 18(8):552 8 7993190
Schardin KE Case management of the anemic patient: epoetin alfa-focus on ventricular function ANNA J 1993 Feb 20(1):96 9 8431032
Scharer K, Klare B, Braun A, et al Treatment of renal anemia by subcutaneous erythropoietin in children with preterminal chronic renal failure Acta Paediatr 1993 Nov 82(11):953 8 8111177
Schiffl H, Lang SM Hypertension induced by recombinant human erythropoietin (rHU-EPO) can be prevented by indomethacin. Pathogenetic role of cytosolic calcium Eur J Med Res 1997 Mar 24 2(3):97 100
Schillinger F, Dubot Ph, Cabanne JF, et al Acquired cystic kidney disease in renal insufficiency: a multicentre study Eur J Med 1993 2(8):457 460 8258045
Schiro KB EPO!one year later. Effects of EPO on nutritional status in CRF Nephrol News Issues 1990 May 4(5):
Schmidt G, Stamminger G, Daniel A, et al Evaluation of indicators of erythropoiesis stimulated by recombinant human erythropoietin in renal anemia Biomed Biochim Acta 1990 49(2-3):S275 9 2386517
Schmidt R, Lerche D, Dorp E, et al. Changes in red blood cell volume under recombinant human erythropoietin therapy. Contrib Nephrol. 1990;87:52-8. [pmid: 2093541].
Schmidt RJ, Holley JL Fertility and contraception in end-stage renal disease Adv Ren Replace Ther 1998 Jan 5(1):38 44 9477214
Schonhofer B, Wenzel M, Geibel M, et al Blood transfusion and lung function in chronically anemic patients with severe chronic obstructive pulmonary disease Crit Care Med 1998 Nov 26(11):1824 8 9824074
Schwartz A Commentary on "the use of the artificial kidney in the treatment of uremia" J Urban Health 1998 75(4):919 21
Schwartz AB, Orquiza CS The effects of recombinant human erythropoietin on mean corpuscular volume in patients with the anemia of chronic renal failure Clin Nephrol 1995 Apr 43(4):256 9 7606880
Schwartz AB, Prior JE, Mintz GS, et al Cardiovascular hemodynamic effects of correction of anemia of chronic renal failure with recombinant-human erythropoietin Transplant Proc 1991 Apr 23(2):1827 30 2053168
Schwenk MH, Halstenson CE Recombinant human erythropoietin DICP 1989 Jul-Aug 23(7-8):528 36 2669369
Scigalla P, Bonzel KE, Bulla M, et al. Therapy of renal anemia with recombinant human erythropoietin in children with end-stage renal disease. Contrib Nephrol. 1989;76:227-40; discussion 240-1. [pmid: 2684524].
Scigalla P, Ehmer B, Herrmann Z, et al Subcutaneous application of recombinant human erythropoietin!the optimal route of administration Nieren-Hochdruckkr 1992 21(3):114 9
Scigalla P, Ehmer B, Woll EM, et al Reasons for individual responses to recombinant human erythropoietin inpatients with end-stage renal failure Nieren-Hochdruckkr 1990 19(5):178 83
Scigalla P, Wieczorek L, Hirth P Recombinant erythropoietin - a new drug for the treatment of renal anemia Nieren-Hochdruckkr 1987 16(11):487 2
Scigalla P. Effect of recombinant human erythropoietin treatment on renal anemia and body growth of children with end-stage renal disease. The European Multicenter Study Group. Contrib Nephrol. 1991;88:201-11; discussion 212-4.
Scott LL, Ramin SM, Richey M, et al Erythropoietin use in pregnancy: two cases and a review of the literature Am J Perinatol 1995 Jan 12(1):22 4 7710570
Seguias LF, Zilleruelo G Transferrin saturation in pediatric hemodialysis Pediatr Nephrol 1998 12(7):
Seidel C, Schaefer F, Walther U, et al The application of knemometry in renal disease: preliminary observations Pediatr Nephrol 1991 Jul 5(4):467 71 1911123
Selcuk Y, San A, Sahin M, et al Effects of treatment with recombinant human erythropoietin on hemodynamic functions and vasoactive hormones in renal anemia Turk J Med Sci 1994 22(4):271 275
Selmaier A, Samtleben W, Lorenz B, et al Screening of intestinal iron absorption in end-stage renal disease Nieren-Hochdruckkr 1994 23(2):77 83
Sennesael JJ, Demanet CG, Verbeelen DL Serum soluble interleukin 2 receptor in hemodialysis patients treated with recombinant human erythropoietin Blood Purif 1995 Nov-Dec 13(6):347 56 8821199
Shaheen EA, Mansuri, NA Al-Shaikh AM, et al Effect of erythropoietin treatment on hearing loss in anemic patients on hemodialysis Annales Academiae Medicae Gedanensis 1995 25(Suppl 6):103 6
Shaheen FA, Mansuri NA, al-Shaikh AM, et al Reversible uremic deafness: is it correlated with the degree of anemia? Ann Otol Rhinol Laryngol 1997 May 106(5):391 3 9153103
Shanahan M, Walton S Developing an epoetin alfa medication protocol to improve patient care and foster collaboration ANNA J 1995 Oct 22(5):471 6 7487190
Shand BI, Buttimore AL, Hurrell MA, et al Hemorheology and fistula function in home hemodialysis patients following erythropoietin treatment: a prospective placebo-controlled study Nephron 1993 64(1):53 7 7880205
Shand BI, Buttimore AL, Lynn KL, et al Effect of hemodialysis and recombinant human erythropoietin on determinants of blood viscosity Ren Fail 1994 16(3):407 13 8059023
Shannon JS, Lappin TR The anaemia of chronic renal failure: a potentially treatable catabolic phenomenon? Med Hypotheses 1986 20(1):29 36 3523174
Shannon KM Recombinant erythropoietin in pediatrics: a clinical perspective Pediatr Ann 1990 Mar 19(3):197 206 2181391
Shaver TR Golper TA Clinical applications of iron management in peritoneal dialysis patients Semin Dialysis 1999 12(4):257 261
Sheingold S, Churchill D, Muirhead N, et al The impact of recombinant human erythropoietin on medical care costs for hemodialysis patients in Canada Soc Sci Med 1992 May 34(9):983 91 1631611
Sheingold SH, Churchill DN, Muirhead N, et al Recombinant human erythropoietin: factors to consider in cost-benefit analysis [editorial] Am J Kidney Dis 1991 Jan 17(1):86 92 1898836
Shepherd JD, Eaves AC Recombinant human erythropoietin: current potential applications Ann R Coll Physicians Surg Can 1990 23(1):25 28
Sheridan W, Foote MA. Thrombopoietic growth factors. Emerging Drugs. 1998;3:261-9.
Shih YC, Kauf TL Reconciling decision models with the real world - An application to anaemia of renal failure Pharmacoeconomics 1999 15(5):481 493 10537965
Shimosaka A. Pharmacokinetics and application of erythropoietin therapy: overview of epoetin alfa studies in Japan. Ann N Y Acad Sci. 1994 Apr 15;718:111-22. [pmid: 8185220].
Shinzato T, Nakai S, Akiba T, et al Current status of renal replacement therapy in Japan: results of the annual survey of the Japanese Society for Dialysis Therapy [news] [corrected and republished article originally printed in Nephrol Dial Transplant 1996 Nov;11(11):2143-50] Nephrol Dial Transplant 1997 May 12(5):889 98 9175040
Shrivastava D, Rao TK, Sinert R, et al The efficacy of erythropoietin in human immunodeficiency virus-infected end-stage renal disease patients treated by maintenance hemodialysis Am J Kidney Dis 1995 Jun 25(6):904 9 7771487
Sieniawska M, Roszkowska-Blaim M [Dosage of erythropoietin in children treated with hemodialysis and continuous ambulatory peritoneal dialysis] Pediatr Pol 1995 Dec 70(12):1023 8 8649941
Sieniawska M, Roszkowska-Blaim M Recombinant human erythropoietin dosage in children undergoing hemodialysis and continuous ambulatory peritoneal dialysis Pediatr Nephrol 1997 Oct 11(5):628 30 9323294
Sikole A, Polenakovic M, Spirovska V, et al Analysis of heart morphology and function following erythropoietin treatment of anemic dialysis patients Artif Organs 1993 Dec 17(12):977 84 8110072
Sikole A, Stojanovic A, Polenakovic M, et al How erythropoietin affects bone marrow of uremic patients Am J Nephrol 1997 17(2):128 36 9096443
Silberberg J, Racine N, Barre P, et al Regression of left ventricular hypertrophy in dialysis patients following correction of anemia with recombinant human erythropoietin Can J Cardiol 1990 Jan-Feb 6(1):1 4 2138048
Silverberg D, Blum M, Peer G, et al Anemia during the predialysis period: A key to cardiac damage in renal failure Nephron 1998 Sep 80(1):1 5 9730696
Silverberg DS, Blum M, Peer G, et al Intravenous ferric saccharate as an iron supplement in dialysis patients Nephron 1996 72(3):413 7 8852489
Silverberg DS, Blum M, Schwartz, et al Iron management in predialysis patients Seminars in Dialysis 1999 12(4):262 266
Silverberg DS, Iaina A, Peer G, et al Intravenous iron supplementation for the treatment of the anemia of moderate to severe chronic renal failure patients not receiving dialysis Am J Kidney Dis 1996 Feb 27(2):234 8 8659499
Simon P, Ang KS, Benziane A, et al [Isolated systolic hypertension in uremic hemodialyzed patients] Arch Mal Coeur Vaiss 1991 Aug 84(8):1205 10 1835361
Simon P [Development of extrarenal complications of chronic renal insufficiency in patients treated by peritoneal dialysis] Nephrologie 1995 16(1):77 83 7700424
Simon P [Erythropoietin and arterial hypertension in patients with chronic renal insufficiency] Rev Med Interne 1995 16(6):457 61 7652230
Sinai-Trieman L, Salusky IB, Fine RN Use of subcutaneous recombinant human erythropoietin in children undergoing continuous cycling peritoneal dialysis J Pediatr 1989 Apr 114(4 Pt 1):550 4 2926567
Singh AB, Singh M, Palekar S, et al The effects of recombinant human erythropoietin on the cell mediated immune response of renal failure patients J Med 1992 23(5):289 302 1469332
Sinnassamy P, Andre J L, Treize G, et al [Effect of the treatment with human recombinant erythropoietin on anemia in children with end-stage kidney failure. French multicenter study] Arch Fr Pediatr 1993 Mar 50(3):201 8 8338412
Sisk JE, Gianfrancesco FD, Coster JM Recombinant erythropoietin and Medicare payment JAMA 1991 Jul 10 266(2):247 52
Sivak L, Scuteri RM, Cavalli NH, et al [The correction of anemia with a high requirement for transfusion in patients on maintenance hemodialysis by conventional and reduced doses of recombinant human erythropoietin] Medicina (B Aires) 1992 52(6):516 22 198880 1340900
Sleasman JW, Scott GB Pediatric HIV infection. An update J Fla Med Assoc 1991 78(10):673 677 1753232
Slingeneyer A, Faller B, Laroche B, et al Self-administered daily subcutaneous recombinant human erythropoietin: an open randomised dose-finding study in ESRD patients receiving peritoneal dialysis Contrib Nephrol 1991 88(159-68).
Smans KA, Van Landeghem FG, D'Haese PC, et al Is there a link between erythropoietin therapy and adynamic bone disease? Nephrol Dial Transplant 1996 Jul 11(7):1248 9 8672017
Smith BR Use of erythropoietin in AIDS and hematologic disorders Hosp Formul 1991 26(8):655 661
Smith DA, Perry PJ The efficacy of ergogenic agents in athletic competition. Part II: Other performance-enhancing agents Ann Pharmacother 1992 May 26(5):653 9 1591427
Smith PS Management of end-stage renal disease in children Ann Pharmacother 1998 32(9):929 939 9762381
Sobota JT. Recombinant human erythropoietin in patients with anemia due to end-stage renal disease. US multicenter trials. Contrib Nephrol. 1989;76:166-78; discussion 212-8. [pmid: 2684519].
Solozabal C, Maduell F, Unzue J, et al Low-dose human erythropoietin in chronic hemodialysis patients Nephron 1991 57(4):483 4 2046835
Sommerburg O, Grune T, Hampl H, et al Does long-term treatment of renal anaemia with recombinant erythropoietin influence oxidative stress in haemodialysed patients? Nephrol Dial Transplant 1998 13(10):2583 7 9794564
Spinowitz B The practical aspects of therapy with rHuEPO Am J Nephrol 1990 10(Suppl 2):24 8 2260614
Spinowitz BS EPO!one year later: a look at rehabilitation. The impact of long-term epoetin beta therapy on ESRD patient quality of life Nephrol News Issues 1990 Jun 4(6):35 7 2205809
Spivak J Preface Hematol Oncol Clin North Am 1994 8(5):Ix Xi
Sreedhara R, Avram MM, Patel N, et al Correlates of very long term survival in peritoneal dialysis (PD) patients (pts) J Am Soc Nephrol 1996 7(9):
Standage BA, Schuman ES, Ackerman D, et al Does the use of erythropoietin in hemodialysis patients increase dialysis graft thrombosis rates? Am J Surg 1993 May 165(5):650 4 8488954
Stasiecki P, Pollok M, Baldamus CA [Erythropoietin as a therapeutic agent. II: Indications, side effects and dangers] Med Klin 1989 84(4):216 218
Stefanidis C J, Koulieri A, Siapera D, et al. Effect of the correction of anemia with recombinant human erythropoietin on growth of children treated with CAPD. Adv Perit Dial. 1992;8:460-3. [pmid: 1361848].
Stefenelli T, Boszotta A, Kaliman JF, et al Digital vascular reactivity in patients on haemodialysis treated with human recombinant erythropoietin Vasa 1991 20(1):70 3 2031404
Steffen HM, Brunner R, Muller R, et al. Peripheral hemodynamics, blood viscosity, and the renin-angiotensin system in hemodialysis patients under therapy with recombinant human erythropoietin. Contrib Nephrol. 1989;76:292-8. [pmid: 2582783].
Steffensen G, Aunsholt NA, Ahlbom G Comparative crossover study of intravenously and subcutaneously administered recombinant human erythropoietin in hemodialysis patients Blood Purif 1992 10(5-6):241 247
Steffensen G, Aunsholt NA, Povlsen JV Evidence that treatment of ESRD patients with recombinant human erythropoietin induces immunosuppression without affecting the distribution of peripheral blood mononuclear cell subpopulations Clin Nephrol 1996 Feb 45(2):98 103 8846537
Steffensen G, Aunsholt NA Impact of human recombinant erythropoietin on plasminogen activator inhibitor, and protein C and S activity Am J Nephrol 1996 16(5):453 4 8886186
Stein RS, Abels RI, Krantz SB Pharmacologic doses of recombinant human erythropoietin in the treatment of myelodysplastic syndromes Blood 1991 Oct 1 78(7):1658 63
Steinhauer HB, Lubrich-Birkner I, Dreyling KW, et al Increased ultrafiltration after erythropoietin-induced correction of renal anemia in patients on continuous ambulatory peritoneal dialysis Nephron 1989 53(1):91 2 2779711
Stenver D, Nielsen B, Jeppesen LL, et al Erythropoietin and fibrinolysis effects on platelet activity Lancet 1993 Feb 20 341(8843):495 6
Stenver DI, Nielsen B [Erythropoietin treatment of dialysis patients] Ugeskr Laeger 1994 Apr 25 156(17):2589 91
Stephens R, Williams A, McKnight T, et al Effects of self-monitored exercise on selected blood chemistry parameters of end-stage renal disease patients Am J Phys Med Rehabil 1991 Jun 70(3):149 53 2039617
Stevens J M, Auer J, Strong C A, et al Stepwise correction of anaemia by subcutaneous administration of human recombinant erythropoietin in patients with chronic renal failure maintained by continuous ambulatory peritoneal dialysis Nephrol Dial Transplant 1991 6(7):487 94 1922910
Stevens ME, Summerfield GP, Hall AA, et al Cost benefits of low dose subcutaneous erythropoietin in patients with anaemia of end stage renal disease BMJ 1992 Feb 22 304(6825):474 7
Stevenson K, Binkley LS EPO!one year later: a look at rehabilitation. Does EPO impact on rehabilitation of the dialysis patient? A nursing perspective Nephrol News Issues 1990 Jun 4(6):30 1
Stifter S, Graf H Treatment of renal anaemia by recombinant human erythropoietin Pol Arch Med Wewn 1991 Jun 85(6):329 33 1896395
Stivelman JC Injectable medications for hemodialysis patients Am J Nephrol 1996 16(1):73 8 8719768
Stojcheva-Taneva OO, Polenakovic MH Autonomic neuropathy in hemodialysis patients treated with recombinant human erythropoietin Int J Artif Organs 1996 Oct 19(10):574 7 8946232
Stone WJ, Graber SE, Krantz SB, et al Treatment of the anemia of predialysis patients with recombinant human erythropoietin: a randomized, placebo-controlled trial Am J Med Sci 1988 Sep 296(3):171 9 3177433
Strauss MJ, Port FK, Somen C, et al An estimate of the size of the US predialysis population with renal insufficiency and anemia Am J Kidney Dis 1993 Mar 21(3):264 9 8447302
Strauss RG Current issues in neonatal transfusions Vox Sang 1986 51(1):1 9 3526725
Stray-Gundersen J, Sams B, Goodkin D, et al. Improvement in functional capacity in dialysis patients with regular exercise and correction of anemia. J Am Soc Nephrol. 1997;8.
Stummvoll HK, Schindl R, Aigner K, et al [Physiologic respiratory parameters in erythropoietin treatment of patients with chronic renal failure] Wien Med Wochenschr Suppl 1989 104(suppl):50 2 2588636
Sulkova S Erythropoietin, an update, and where to in the future? EDTNA-ERCA Journal 1998 24(3):30 32
Sulowicz W, Dubiel J, Hanicki Z, et al Influence of recombinant human erythropoietin therapy on selected echocardiographic indices and exercise capacity in patients on maintenance haemodialysis Przegl Lek 1991 48(12):741 4
Sulowicz W, Hanicki Z, Lisiewicz J, et al [Activity of selected neutrophil enzymes of patients maintained on hemodialysis and treated with erythropoietin (rHu EPO)] Pol Arch Med Wewn 1991 Jun 85(6):391 5 1896403
Sundal E, Businger J, Kappeler A Treatment of transfusion-dependent anaemia of chronic renal failure with recombinant human erythropoietin. A European multicentre study in 142 patients to define dose regimen and safety profile Nephrol Dial Transplant 1991 6(12):955 65 1798595
Sundal E, Kaeser U Correction of anaemia of chronic renal failure with recombinant human erythropoietin: safety and efficacy of one year's treatment in a European multicentre study of 150 haemodialysis-dependent patients Nephrol Dial Transplant 1989 4(11):979 87 2516891
Sunder-Plassmann G, Horl WH Comparative look at intravenous iron agents: Pharmacology, efficacy, and safety of iron dextran, iron saccharate, and ferric gluconate Sem Dial 1999 12(4):243 248
Sunder-Plassmann G, Horl WH Erythropoietin and iron Clin Nephrol 1997 Mar 47(3):141 57 9105761
Sunder-Plassmann G, Horl WH Safety aspects of parenteral iron in patients with end-stage renal disease Drug Saf 1997 Oct 17(4):241 50 9352960
Sunder-Plassmann G, Horl WH Iron and erythropoietin Klinisches Labor 1996 42(4):269 77
Sungur C, Akpolat T, Ozkuyumcu C, et al False-positive HIV antibody test following alpha-interferon therapy in a chronic hemodialysis patient Nephron 1994 67(2):
Suppiej A, Montini G, Casara G, et al Evoked potentials before and after anemia correction with recombinant human erythropoietin in end-stage renal disease Child Nephrol Urol 1992 12(4):197 201 1473092
Suzuki M [Countermeasure for patients with anemia due to hemodialysis] Nippon Naika Gakkai Zasshi 1995 Oct 10 84(10):1663 7 8537721
Suzuki M Normalization of hematocrit with recombinant human erythropoietin in chronic hemodialysis patients does not fully improve their exercise tolerance abilities Artif Organs 1995 19(12):1258 61 8967885
Suzuki H, Murakami M, Ichihara A, et al Alterations in sex hormones and sexual function of patients with renal failure treated with recombinant human erythropoietin Jpn J Nephrol 1992 34(1):79 84
Suzuki M, Hirasawa Y, Hirashima K, et al. Dose-finding, double-blind, clinical trial of recombinant human erythropoietin (Chugai) in Japanese patients with end-stage renal disease. Research Group for Clinical Assessment of rhEPO. Contrib Nephrol. 1989;76:179-92; discussion 212-8. [pmid: 2684520].
Suzuki M, Tsutsui M, Yokoyama A, et al Normalization of hematocrit with recombinant human erythropoietin in chronic hemodialysis patients does not fully improve their exercise tolerance abilities Artif Organs 1995 Dec 19(12):1258 61 8967885
Svara F, Spicka I, Sulkova S, et al Erythropoietin (r-HuEPO) for the treatment of anaemia in patients with multiple myeloma and end-stage renal failure Nephrol Dial Transplant 1995 Dec 10(12):2374 5
Svara F, Sulkova S, Kvasnicka J, et al [Iron supplementation during erythropoietin therapy in patients on hemodialysis] Vnitr Lek 1996 Dec 42(12):849 52 9072885
Szewczuk J, Mazerska M, Malyszko J, et al Increase in fibrinolytic activity after erythropoietin therapy (4) Thromb. Haemostasis 1992 67(2):
Szolkiewicz M, Manitius J, Kopecka L, et al [Some clinical aspects of erythropoietin action used at doses not affecting erythropoiesis in hemodialysed patients] Pol Arch Med Wewn 1994 92(Spec No):78 84 7731903
Szurkowski M, Wiecek A, Kokot F, et al Safety and efficiency of recombinant human erythropoietin treatment in anemic pregnant women with a kidney transplant Nephron 1994 67(2):242 3 8072619
Taaning E, Morling N, Mortensen SA, et al Hemolytic anemia due to graft-derived anti-b production after lung transplantation Transplant Proc 1994 26(3):
Tagawa H [Hypertension in dialysis patients] Nippon Rinsho 1992 May 50(Suppl):610 5 1355139
Takasaki M, Tsurumi N, Konjiki O, et al [Causes, diagnosis, and treatment of anemia in the elderly] Nippon Ronen Igakkai Zasshi 1997 34(3):171 9 9155190
Tan A. Recombinant human erythropoietin (r-HuEPO): quality of life and other considerations. J CANNT. 1990;Summer:13-4. [pmid: 2202375].
Tanabe R [Numerical and functional alterations in T and B lymphocyte subpopulations in CAPD patients treated with recombinant human erythropoietin] Nippon Jinzo Gakkai Shi 1994 Oct 36(10):1159 68 7815748
Tang IY, Vrahnos D, Valaitis D, et al Vascular access thrombosis during recombinant human erythropoietin therapy ASAIO J 1992 Jul-Sep 38(3):M528 31
Tang WW, Stead RA, Goodkin DA Effects of Epoetin alfa on hemostasis in chronic renal failure [editorial] Am J Nephrol 1998 18(4):263 73 9653828
Tarng DC, Huang TP Uraemic pericarditis: a reversible inflammatory state of resistance to recombinant human erythropoietin in haemodialysis patients Nephrol Dial Transplant 1997 12(5):1051 1054 9175071
Tassies D, Reverter JC, Cases A, et al Effect of recombinant human erythropoietin treatment on circulating reticulated platelets in uremic patients: association with early improvement in platelet function Am J Hematol 1998 Oct 59(2):105 9 9766793
Taylor J, Mactier RA, Stewart WK, et al Effect of erythropoietin on anaemia in patients with myeloma receiving haemodialysis BMJ 1990 Sep 8 301(6750):476 7
Taylor JE, Belch JJ, McLaren M, et al Effect of erythropoietin therapy and withdrawal on blood coagulation and fibrinolysis in hemodialysis patients Kidney Int 1993 Jul 44(1):182 90 8355460
Taylor JE, Henderson IS, Mactier RA, et al Effects of withdrawing erythropoietin BMJ 1991 Feb 2 302(6771):272 3
Taylor JE, Henderson IS, Stewart WK, et al Erythropoietin and spontaneous platelet aggregation in haemodialysis patients Lancet 1991 Nov 30 338(8779):1361 2
Taylor JE, Henderson IS, Stewart WK, et al Platelet aggregation in erythropoietin treated dialysis patients Platelets 1992 3(1):47 52 21043900
Taylor JE, Peat N, Porter C, et al Regular low-dose intravenous iron therapy improves response to erythropoietin in haemodialysis patients Nephrol Dial Transplant 1996 Jun 11(6):1079 83 8671972
Taylor JE Haemostasis and vascular disease in dialysis patients receiving erythropoietin therapy Vasc Med Rev 1993 4(3):171 182
Teehan BP, Benz RL, Sigler MH, et al Early intervention with recombinant human erythropoietin therapy Semin Nephrol 1990 Mar 10(2 Suppl 1):28 34 2192414
Teehan BP, Sigler MH, Brown, et al Hematologic and physiologic studies during correction of anemia with recombinant human erythropoietin in predialysis patients Transplant Proc 1989 21(6 Suppl 2):63 6 2545019
Teehan BP Double-blind, placebo-controlled study of the therapeutic use of recombinant human erythropoietin for anemia associated with chronic renal failure in predialysis patients Am J Kid Dis 1991 18(1):50 59 2063855
Teruel JL, Aguilera A, Avila C, et al Effects of androgen therapy on prostatic markers in hemodialyzed patients Scand J Urol Nephrol 1996 Apr 30(2):129 31 8738058
Teruel JL, Fernandez Juarez G, Marcen R, et al Effect of angiotensin-converting enzyme inhibitors on anemia in hemodialyzed patients Nephron 1996 73(1):
Thamer M, Richard C, Ray NF, et al The effect of insurance status on use of recombinant erythropoietin therapy among end-stage renal disease patients in three states Am J Kidney Dis 1996 Aug 28(2):235 49 8768919
The US Recombinant Human Erythropoietin Predialysis Study Group Double-blind, placebo-controlled study of the therapeutic use of recombinant human erythropoietin for anemia associated with chronic renal failure in predialysis patients Am J Kidney Dis 1991 Jul 18(1):50 9 2063855
Toffelmire EB, Barrett BJ, Fenton SS, et al. Chapter 2: Clinical practice guidelines for the management of anemia coexistent with chronic renal failure. J Am Soc Nephrol. 1999;10:S292-S296. [pmid: 10425612].
Toffelmire EB Iron management in patients using r-HuEPO J CANNT 1994 Fall 4(4):20 3 7612402
Tomoda F, Takata M, Izumino K, et al Effects of erythropoietin treatment on thyroid dysfunction in hemodialysis patients with renal anemia Nephron 1994 66(3):307 11 8190183
Tomson CR End stage renal disease in sickle cell disease: Future directions Postgrad Med J 1992 68(804):775 8 1461848
Tomura S, Nakamura Y, Tachibana K, et al Enhanced coagulation and fibrinolysis during treatment with recombinant human erythropoietin in patients undergoing chronic hemodialysis Blood Purif 1993 11(6):370 7 8043258
Tomura S [Effect of recombinant human erythropoietin on hemodynamics in chronic hemodialysis patients] Nippon Rinsho 1991 Dec 49(Suppl):695 701 1808338
Trbojevic J, Zivkovic M [Quality of life in chronic renal insufficiency: the effect of disease development and various method of therapy] Srp Arh Celok Lek 1997 Jul-Aug 125(7-8):223 7 9304236
Trembecki J, Kokot F, Wiecek A, et al [Improvement of sexual function in hemodialyzed male patients with chronic renal failure treated with erythropoietin (rHuEPO)] Przegl Lek 1995 52(9):462 6 8834648
Trembecki J, Kokot F, Wiecek A, et al [Influence of long-term erythropoietin (rHuEPO) therapy on the function of the pituitary-gonadal axis in hemodialyzed male patients with end stage renal failure] Pol Arch Med Wewn 1995 Aug 94(2):144 52 8596749
Tufts DA, Haas JD, Beard JL, et al Distribution of hemoglobin and functional consequences of anemia in adult males at high altitude Am J Clin Nutr 1985 Jul 42(1):1 11 4014058
Turi S, Nemeth I, Varga I, et al The effect of erythropoietin on the cellular defence mechanism of red blood cells in children with chronic renal failure Pediatr Nephrol 1992 Nov 6(6):536 41 1482641
Ucok K, Gokbel H, Yeksan M, et al The effects of rHuEPO administration on pulmonary functions in haemodialysis patients Int J Artif Organs 1996 Jun 19(6):336 8 8814495
Uehlinger DE, Frey FJ [Erythropoietin, a milestone in the history of nephrology] Ther Umsch 1995 Oct 52(10):672 7 7482378
Uhl D [Erythropoietin] Med Monatsschr Pharm 1990 May 13(5):130 1 2192242
Urabe A, Kitamura T, Takaku F Clinical application of erythropoietin Nippon Ketsueki Gakkai Zasshi 1988 Dec 51(8):1355 9 3073611
Urabe A, Takaku F, Mizoguchi H, et al Effect of recombinant human erythropoietin on the anemia of chronic renal failure Int J Cell Cloning 1988 May 6(3):179 91 3397592
Uthayanaka Y, Jirajan B, Krairithichai U, et al The clinical effects of recombinant human erythropoietin for the treatment of anemia in end stage renal disease patients on dialysis Southeast Asian J Trop Med Public Health 1993 Sep 24(3):577 82 8160072
Valderrabano F, Jones EH, Mallick NP Report on management of renal failure in Europe, XXIV, 1993 Nephrol Dial Transplant 1995 10(Suppl 5):1 25
Valderrabano F [Erythropoietin in the treatment of anemia in chronic renal insufficiency] An Med Interna 1991 Jun 8(Suppl 2):22 3 1878467
Valderrabano F Erythropoietin in chronic renal failure Kidney Int 1996 Oct 50(4):1373 91 8887302
Valderrabano F Recombinant erythropoietin: 10 years of clinical experience Nephrol Dial Transplant 1997 12(Suppl 1):2 9 9075222
Valeri CR, Crowley JP, Loscalzo J. Indications for red blood cell transfusion. In: Alternative Approaches to Human Blood Resources in Clinical Practice, CTS Sibinga, PC Das, JC Fratantoni, eds. Dordrecht: Kluwer Academic Publishers; 1998. p. 209-214.
Vallance P, Benjamin N, Collier J Erythropoietin, haemoglobin, and hypertensive crises Lancet 1988 1(8594):
Van Damme-Lombaerts R, Broyer M, Businger J, et al A study of recombinant human erythropoietin in the treatment of anaemia of chronic renal failure in children on haemodialysis Pediatr Nephrol 1994 Jun 8(3):338 42 7917862
Van Damme-Lombaerts R, Herman J Erythropoietin treatment in children with renal failure Pediatric Nephrol 1999 13(2):148 152
Van De Voorde J The endocrine functions of the kidney. Iii. Erythropoietin Tijdschr. Geneeskd 1992 48(23):1763 1768
Van Demark RE Sr Erythropoietin S D J Med 1990 Apr 43(4):
Van der Linden P, Vincent JL Reevaluation of blood transfusion strategies Minerva Anestesiol 1997 May 63(5):143 7 9339090
Van der Niepen P, Sennesael J, Verbeelen D r-HuEPO treatment of anemia associated with multiple myeloma and ESRD Clin Nephrol 1993 Feb 39(2):
Van Loo A, Vanholder R, Bernaert P, et al Recombinant human erythropoietin corrects anaemia during the first weeks after renal transplantation: a randomized prospective study Nephrol Dial Transplant 1996 Sep 11(9):1815 21 8918628
Van Stone JC Who should receive recombinant human erythropoietin? Semin Nephrol 1989 Mar 9(1 Suppl 2):3 7 2669084
Van Wyck D Efficacy and adverse effects of oral iron supplements Semin Dialysis 1999 12(4):235 236
Vanrenterghem Y, Khamis S The management of the failed renal allograft Nephrol Dial Transplant 1996 11(6):955 958 8671948
Vanrenterghem Y, Vanwalleghem J Benefits and concerns of treating pre-dialysis and renal transplant patients with recombinant human erythropoietin Nephrol Dial Transplant 1998 13(Suppl 2):13 5 9566485
Vanrenterghem Y, Vanwalleghem J Benefits and concerns of treating pre-dialysis and renal transplant patients with recombinant human erythropoietin Nephrol Dial Transplant 1998 13(Suppl 2):13 15 9566485
VanwalleghemY, Vanrenterghem J The role of epoetin in predialysis and renal transplantation Erythropoiesis: New dimensions in the treatment of anaemia 1997 8(2):43 8
Vasquez EM, Pollak R Effect of pretransplant erythropoietin therapy on renal allograft outcome Transplantation 1996 62(7):1026 1028 8878400
Vaziri ND Mechanism of erythropoietin-induced hypertension Am J Kidney Disease 1999 33(5):821 828 10213636
Velasquez MT, Lew SQ, von Albertini B, et al Control of hypertension is better during hemodialysis than during continuous ambulatory peritoneal dialysis in ESRD patients Clin Nephrol 1997 Dec 48(6):341 5 9438091
Velasquez MT, von Albertini B, Lew SQ, et al Equal levels of blood pressure control in ESRD patients receiving high-efficiency hemodialysis and conventional hemodialysis Am J Kidney Dis 1998 Apr 31(4):618 23 9531177
Vella JP, O'Neill D, Atkins N, et al Sensitization to human leukocyte antigen before and after the introduction of erythropoietin Nephrol Dial Transplant 1998 13(8):2027 2032 9719159
Venkatesan J, Henrich WL Anemia, hypertension, and myocardial dysfunction in end-stage renal disease Semin Nephrol 1997 17(4):257 269 9241712
Verbeelen D, Hauglustaine D, Sennesael J Treatment of the anaemia of end-stage renal disease with recombinant human erythropoietin Neth J Med 1988 Aug 33(1-2):60 7 3247012
Veys N Clinical administration of erythropoietin in nephrology Tijdschr Geneeskd 1993 49(9):632 6
Viale S, Nori G, Magarini C, et al Erytropoietin and hemostasys in uraemic patients G Ital Angiol 1993 13(4):213 6
Villa MP, Rotili PL, Santamaria F, et al Physical performance in patients with thalassemia before and after transfusion Pediatr Pulmonol 1996 Jun 21(6):367 72 8927463
Villaverde M, PerezGarcia R, Verde E, et al High-flux polysulfone improves the response to recombinant human erythropoietin (RH-EPO) in patients on long term hemodialysis (HD) Nefrologia 1999 19(2):161 167
Virot JS, Janin G, Guillaumie J, et al Must erythropoietin be injected by the subcutaneous route for every hemodialyzed patient? Am J Kidney Dis 1996 Sep 28(3):400 8 8804239
Vlassopoulos D, Sonikian M, Dardioti V, et al Target haematocrit during erythropoietin treatment in dialysis patients. Which value is "true-functional haematocrit"? Nephrol Dial Transplant 1999 14(5):1340 1 10344405
Volpe M, Tritto C, Testa U, et al Blood levels of erythropoietin in congestive heart failure and correlation with clinical, hemodynamic, and hormonal profiles Am J Cardiol 1994 Sep 1 74(5):468 73
Vora M, Gruslin A Erythropoietin in obstetrics Obstet Gynecol Surv 1998 53(8):500 508 9702790
Vreugdenhil G, Schrey G, van Es PN, et al Erythropoietin production in hypertensive patients with and without renal artery stenosis Nephron 1995 70(1):137 8 7617109
Vreugdenhil G, Swaak AJ The role of erythropoietin in the anaemia of chronic disease in rheumatoid arthritis Clin Rheumatol 1990 Mar 9(1):22 7 2185909
Wahr JA Myocardial ischaemia in anaemic patients Br J Anaesth 1998 81(Suppl 1):10 5 10318982
Wakeen M, Zimmerman SW Association between human recombinant EPO and peripheral vascular disease in diabetic patients receiving peritoneal dialysis Am J Kidney Dis 1998 Sep 32(3):488 93 9740167
Warady B, Watkins SL Current advances in the therapy of chronic renal failure and end stage renal disease Semin Nephrol 1998 May 18(3):341 54 9613874
Warady BA, Jabs K New hormones in the therapeutic arsenal of chronic renal failure. Growth hormone and erythropoietin Pediatr Clin North Am 1995 Dec 42(6):1551 77 8614600
Warady BA, Sabath RJ, Smith CA, et al Recombinant human erythropoietin therapy in pediatric patients receiving long-term peritoneal dialysis Pediatr Nephrol 1991 Nov 5(6):718 23 1768585
Wasielewski S The therapeutic possibilities for children with kidney failure Krankenhauspharmazie 1993 14(7):333 334
Watson AJ, Gimenez LF, Cotton S, et al Treatment of the anemia of chronic renal failure with subcutaneous recombinant human erythropoietin Am J Med 1990 Oct 89(4):432 5 2220877
Watson AJ Adverse effects of therapy for the correction of anemia in hemodialysis patients Semin Nephrol 1989 Mar 9(1 Suppl 1):30 4 2648519
Watson AR Chronic renal failure in childhood Br J Hosp Med 1996 Mar 20-Apr 2 55(6):329 31 8696626
Weil C Case study of the anemic patient: epoetin alfa!focus on improving ventricular function ANNA J 1995 Jun 22(3):338 41 7786083
Welch TR Renal failure in children Curr Opin Pediatr 1991 3(2):264 7
Welch TR Treatment options for end-stage renal disease in children: where have we been; where are we; and where are we going? Clin Transplant 1991 5(2 Ii):146 9
Wells GA, Coyle D, Lee KM, et al. Quality of life effects of normalization of hemoglobin in asymptomatic hemodialysis patients. J Am Soc Nephrol. 1998;9.
Wheby MS Preface Med Clin North Am 1992 76(3):
White JD A view of the future of end-stage renal disease care: the patient's perspective Advances In Renal Replacement Therapy 1998 5(4):309 314 9792086
Widmer LK [Acute anemia and angina] Ann Fr Anesth Reanim 1994 13(1):
Wiecek A, Kokot F, Marcinkowski W, et al [Treatment of anemia with erythropoietin (rhuEPO) in patients with chronic kidney failure who are not yet in need of dialysis therapy] Pol Arch Med Wewn 1992 Nov 88(5):310 23 1300551
Wiecek A, Kokot F, Spiechowicz U, et al [Requirement for blood in hemodialyzed patients with chronic renal failure in the period before and after introduction to erythropoietin (r-HuEPO) treatment] Przegl Lek 1996 53(12):866 9 9163010
Wiecek A, Kokot, F Marcinkowski W, et al Effectiveness and safety of recombinant human erythropoietin (rhuepo)in the treatment of anaemia in predialysis uraemic patients. Polish multicenter study Ann Acad Med Gedanensis 1995 25(Suppl 6):75 81
Wiecek A [Use of human recombinant erythropoietin (rHuEPO) for treatment of anemia in patients with chronic kidney failure who don't require additional dialysis therapy] Przegl Lek 1995 52(3):93 4 7644683
Wiesholzer M, Kitzwogerer M, Harm F, et al Prevalence of preterminal pulmonary thromboembolism among patients on maintenance hemodialysis treatment before and after introduction of recombinant erythropoietin Am J Kidney Dis 1999 33(4):702 708 10196012
Wiklund I. The Nottingham Health Profile!a measure of health-related quality of life. Scand J Prim Health Care Suppl. 1990;1:15-8. [pmid: 2100359].
Williams C Haemoglobin!is more better? Nephrol Dial Transplant 1995 10(Suppl 2):48 55 7644106
Winchester JF, Rakowski TA End-stage renal disease and its management in older adults Clin Geriatr Med 1998 14(2):255 265 9536104
Winearls CG, Oliver DO, Pippard MJ, et al Effect of human erythropoietin derived from recombinant DNA on the anaemia of patients maintained by chronic haemodialysis Lancet 1986;Nov 22 2(8517):1175 8
Winearls CG Historical review on the use of recombinant human erythropoietin in chronic renal failure Nephrol Dial Transplant 1995 10(Suppl 2):3 9 7644103
Winearls CG Treatment of anaemia in renal failure Prescr J 1992 32(6):238 244
Winearls CG Treatment of the anaemia of chronic renal failure with recombinant human erythropoietin Drugs 1989 Sep 38(3):342 5 2806134
Wingard RL, Parker RA, Ismail N, et al Efficacy of oral iron therapy in patients receiving recombinant human erythropoietin Am J Kidney Dis 1995 Mar 25(3):433 9 7872321
Winslow RM, Chapman KW, Gibson CC, et al Different hematologic responses to hypoxia in Sherpas and Quechua Indians J Appl Physiol 1989 Apr 66(4):1561 9 2732148
Wirtz JJ, van Esser JW, Hamulyak K, et al The effects of recombinant human erythropoietin on hemostasis and fibrinolysis in hemodialysis patients Clin Nephrol 1992 Nov 38(5):277 82 1451341
Wish JB Economic issues and future directions in iron management Seminars in Dialysis 1999 12(4):267 270
Wizemann V. Follow-up of cardiac changes induce by anemia compensation in normotensive hemodialysis patients with left-ventricular hypertrophy. Nephron. 1993;64:202-6. [pmid: 8321352].
Wolcott DL, Marsh JT, La Rue A, et al Recombinant human erythropoietin treatment may improve quality of life and cognitive function in chronic hemodialysis patients Am J Kidney Dis 1989 Dec 14(6):478 85 2596475
Wolfe RA, Held PJ, Hulbert-Shearon TE, et al A critical examination of trends in outcomes over the last decade Am J Kidney Dis 1998 Dec 32(6 Suppl 4):S9 S15 9892361
Wolfson M, Mundt DJ, Hawley GG Recombinant human erythropoietin utilization in department of veterans affairs dialysis units Am J Kidney Dis 1994 24(2):184 91 8048423
Wong W-Y, Elliott-Mills D, Powars D Renal failure in sickle cell anemia Hematology/Oncology Clinics Of North America 1996 10(6):1321 1331 8956019
Working Party for European Best Practice Guidelines for the Management of Anaemia in Patients with Chronic Renal Failure The European best practice guidelines for the management of anaemia in patients with chronic renal failure Nephrol Dial Transplant 1999 14(Suppl 5):1 50
Xia H, Ebben J, Ma JZ, et al Hematocrit levels and hospitalization risks in hemodialysis patients J Am Soc Nephrol 1999 10(6):1309 16 10361870
Yagil Y Proposed therapeutic algorithm for the treatment of anemia of chronic renal failure in pre-dialysis patients with low dose once weekly subcutaneous r-HuEPO. Multicenter Study Group, Israel Isr J Med Sci 1997 Jan 33(1):36 44 9203516
Yagil Y Treatment of anemia of CRF in the pre-dialysis stage with low dose once-a-week S.C. erythropoietin (EPO) Nephrol Dial Transplant 1995 10(6):
Yalcinkaya F, Tumer N, Cakar N, et al Low-dose erythropoietin is effective and safe in children on continuous ambulatory peritoneal dialysis Pediatr Nephrol 1997 Jun 11(3):350 2 9203190
Yamazaki C, Itoh A, Yamamoto N, et al [Pharmacokinetics and clinical effect of recombinant human erythropoietin on the anemia of predialysis patients] Nippon Jinzo Gakkai Shi 1992 Jun 34(6):701 10 1479710
Yamazaki C, Itoh A, Yamamoto N, et al Pharmacokinetics and clinical effect of recombinant human erythropoietin on the anemia of predialysis patients Jpn J Nephrol 1992 34(6):701 710
Yamazaki C, Watanabe Y, Sakamoto N Pharmacokinetic study of recombinant human erythropoietin treatment in pre-dialysis end stage renal disease patients Nippon Jinzo Gakkai Shi 1993 Nov 35(11):1233 42 8139135
Yaqoob M, Ahmad R, McClelland P, et al Resistance to recombinant human erythropoietin due to aluminium overload and its reversal by low dose desferrioxamine therapy Postgrad Med J 1993 Feb 69(808):124 8 8506193
Yepez R, Estevez E, Galan P, et al Validity of criteria used to define high-altitude anemia Cah Sante 1994 4(1):9 13
Yepez R, Estrella R, Galan P, et al Hemoglobin response to an iron supplementation trial in schoolchildren living at high altitude Nutr Rep Int 1988 38(3):629 633
York S Current perspectives: iron management during therapy with recombinant human erythropoietin ANNA J 1993 Dec 20(6):645 50 8267408
Yoshida Y, Ohmori S, Tohyama K, et al Erythropoietic changes in chronic hemodialysis patients undergoing recombinant human erythropoietin therapy Nippon Ketsueki Gakkai Zasshi 1988 Sep 51(6):1092 6 3201902
Zachee P, Ferrant A, Daelemans R, et al Oxidative injury to erythrocytes, cell rigidity and splenic hemolysis in hemodialyzed patients before and during erythropoietin treatment Nephron 1993 65(2):288 93 8247195
Zachee P Controversies in selection of epoetin dosages. Issues and answers Drugs 1995 Apr 49(4):536 47 7789287
Zarifian A Case study of the anemic patient: epoetin alfa-focus on sexual function ANNA J 1994 Oct 21(6):368 71 7993143
Zehnder C, Blumberg A [The treatment of anemia of hemodialysis patients using recombinant human erythropoietin: comparison between intravenous and subcutaneous administration] Schweiz Med Wochenschr 1990 Feb 17 120(7):217 20
Zehnder C, Blumberg A Recombinant human erythropoietin in anemic patients on hemodialysis: benefits and risks Schweiz Med Wochenschr 1989 119(9):269 275 2711161
Zehnder C, Zuber M, Sulzer M, et al Influence of long-term amelioration of anemia and blood pressure control on left ventricular hypertrophy in hemodialyzed patients Nephron 1992 61(1):21 5 1388250
Zein ZA, Assefa M The prevalence of anaemia among populations living at different altitudes in north-western Ethiopia Ethiop Med J 1987 Jul 25(3):105 11 3609004
Zezina L, Britcina N, Adamsone I, et al Influence of recombinant human erythropoietin on central haemodynamics in haemodialysis patients Annales Academiae Medicae Gedanensis 1995 25(Suppl 6):151 8
Zhang QY, Zhang JY, Wu QW [Clinical and experimental study of kidney tonics plus whole embryo extract in treatment of renal anemia] Chung Kuo Chung Hsi I Chieh Ho Tsa Chih 1996 Jun 16(6):330 2 9387758
Zheng FL, Bi ZQ, Li RS [The effect of low doses of recombinant human erythropoietin on renal anemia in predialysis patients with chronic renal failure] Chung Hua Nei Ko Tsa Chih 1993 Jul 32(7):440 3 8275819
Zins B, Drueke T, Zingraff J, et al Erythropoietin treatment in anaemic patients on haemodialysis Lancet 1986 Dec 6 2(8519):
Zins B, Hannedouche D, Kleinknecht T, et al Effects of erythropoietin treatment on renal function of predialytic uremic patients J Am Soc Nephrol 1991 2(3):
Zoellner K, Schmidt G, Devaux S The influence of recombinant human erythropoietin on renal anemia in polytransfused children on chronic hemodialysis Nieren-Hochdruckkr 1990 19(5):211 214
Zorsky PE Erythropoietin Drug Ther 1990 20(9):50, 55 7