# Future Research

- The published literature does not provide strong or consistent support that maintaining Hct above 36 percent is beneficial to patients with CRF. The most suggestive evidence is from studies of adult CRF patients not yet on dialysis and from studies of dialysis patients without severe comorbidity. These data are from cross-sectional analyses that show an association between higher Hct and lower LVMI. In addition, several small intervention studies report improvement in physiologic measures of exercise performance when Hct is maintained at higher levels. The potential for benefit should be tested in well-designed interventional studies.

Epoetin offers patients with anemia of CRF the potential to increase Hct to a level considered normal for a healthy individual; yet the benefits and risks of such a management strategy have not been well established in the published literature. A broad spectrum of disease severity and associated comorbidity is represented in the CRF population. Subgroups of this heterogenous population may differ with respect to the potential benefits and adverse effects of using epoetin to maintain Hct above 36 percent.

Evidence of a favorable association between higher Hct and lower LVMI was derived from populations of CRF patients who were not yet on dialysis. In contrast, an RCT found no reduction in cardiac events in hemodialysis patients with documented congestive heart failure or ischemic cardiac disease who were maintained at Hct above 36 percent. A question of interest is whether maintaining higher Hct in patients early in the course of disease to prevent LVH might prove more effective than trying to reverse existing LVH in chronic dialysis patients. The single study that tested this hypothesis is limited by the relatively short duration of followup and uncertainty as to whether the cardiac parameters reported are significant predictors of LVH and clinically evident cardiac events.

Statistically significant improvements have been reported in physiologic measures of exercise performance, physiologic measures of cognitive function, laboratory sleep patterns, and some quality of life measures in small studies of highly selected CRF patients maintained at Hct above 36 percent. In particular, physiologic measures of physical performance obtained using cycle ergometry report statistically significant changes in peak oxygen consumption, peak work rate, and work done. The clinical significance of these favorable changes in outcome measures needs to be established in larger populations of CRF patients.

- Well-designed, large trials that incorporate strong control measures such as masking and randomization are required to assess the outcomes of using epoetin to increase Hct above 36 percent and into the normal range, as compared with maintaining Hct in the NKF-DOQI™ recommended target range between 33 and 36 percent. The populations of primary interest are adult CRF patients not yet on dialysis and dialysis patients without overt cardiac disease (i.e., ischemia or congestive heart failure).

Methodologic weaknesses inherent in much of the existing literature might produce results that overestimate the magnitude of effect attributed to raising Hct above 36 percent. In particular, the use of a pre/postcontrol design in the absence of double-masking is problematic when looking at outcome measures that depend on patient effort and/or familiarity with the testing instruments used to assess outcome.

Future studies should focus on relatively healthy populations of CRF patients without severe comorbidity. Studies should include large samples and prospectively identify relevant subgroups for stratified analysis in order to understand any differential effects in various groups of CRF patients. Methodologically strong control designs using randomization are preferable to minimize confounding influences. Outcome measures should be carefully selected and well validated to maximize clinical relevance and reliability of findings.

Evidence suggesting improvements in neurophysiologic measures of cognitive function when Hct is raised from a mean of 31.6 percent to a mean of 42.8 percent was derived from a single-arm, unmasked interventional study. However, repeated exposure to the outcome testing situation might produce a training effect resulting in improved test performance regardless of Hct level.

In a similar fashion, pre/poststudies of exercise performance are subject to patient motivation and the effects of physical training and conditioning. A single study controlled for training effect reported that approximately two-thirds of the observed improvement was attributable to physical conditioning and only one-third was attributable to correction of anemia.

Improvement in the relevant scales of a validated quality of life instrument, such as the SF-36, would substantiate the clinical significance of the physiologic measures of cognitive function and exercise performance reported in several small intervention studies. Assessment of quality of life requires well-designed trials to control for potential sources of bias. Relevant design features include double-masking, rigorous protocols for administration of the quality of life instrument, methods for minimizing and handling missing data, and prospective definition of effect sizes that are considered clinically significant.

- If benefits in physical performance, cognitive function, and prevention of cardiac disease when anemia is eliminated are confirmed in adults, it will be of utmost importance to perform similar studies in children with CRF.

The pediatric CRF population has specific issues related to growth and development that do not exist in adult CRF populations. If benefits in physical performance, cognitive function, and prevention of organ damage when anemia is eliminated are confirmed in adults, it will be of utmost importance to perform similar studies in children. Outcomes specific to children include growth and school performance. Because there is considerable normal variation in growth and development and many factors may influence these outcomes, randomized trials are preferred to minimize confounding of results. Studies of growth and development would necessitate large samples because of the wide normal variation in these outcomes and because prospective stratification would be useful to investigate the influence of factors such as age, severity of renal disease, and comorbidity.