# Appendix C. Acronyms and Abbreviations

ANOVA: analysis of variance

APLMS: arousing periodic leg movements of sleep

CAPD: continuous ambulatory peritoneal dialysis

CI: confidence interval

CRF: chronic renal failure

CVA: cerebrovascular accident

dCPT: difficult Continuous Performance Task

EEG: electroencephalogram

ERA-EDTA: European Renal Association/European Dialysis and Transplantation Association

ERP: event-related potential

ESRD: endstage renal disease

FDA: Food and Drug Administration

Hb: hemoglobin

Hct: hematocrit

HPLC: high-performance liquid chromatography

HUI: Health Utilities Index

iv: intravenous

KDQ: Kidney Disease Questionnaire

KS: Karnofsky Scale

LVCVI: left ventricular cavity volume index

LVD: left ventricular dilatation

LVH: left ventricular hypertrophy

LVMI: left ventricular mass index

MeSH: Medical Subject Heading

MI: myocardial infarction

NFK-DOQI™: National Kidney Foundation's Dialysis Outcomes Quality Initiative

NHP: National Health Profile

OR: odds ratio

PD: peritoneal dialysis

PLMS: periodic leg movements of sleep

PMMIS: Program Management and Medical Information System

RCT: randomized controlled trial

REM: rapid eye movement

RR: relative risk

sc: subcutaneous

sCPT: simple Continuous Performance Task

SD: standard deviation

SF-36: Short Form 36-Item Health Survey

SIP: Sickness Impact profile

TAG: Technical Advisory Group

TIA: transient ischemic attack

tw: text word

U: Units