# Appendix B. Data Abstraction Forms: Renal

## Patient Population Information

Age (descriptive statistics) Age subgroup analysis in paper: yes/no Gender subgroup analysis in paper: yes/no Race subgroup analysis in paper: yes/no Total number of patients in analysis Type of dialysis population: #pre-dialysis, #dialysis (percentages will be automatically calculated cells) Type of dialysis - # HD, #PD

Patient inclusion exclusion criteria - to be provided to TAG only for information

## Treatment information

EPO yes/no IV iron yes/no Oral iron yes/no Androgen yes/no Transfusion yes/no Other free text

Pediatric studies: Nutritional supplementation yes/no [when defined as nutrition given by IV, NGT (nasogastric tube), NJT (nasojejunal tube), G-tube (gastrostomy tube), J-tube (jejunostomy tube)] Growth hormone yes/no

## Group Hematocrit description table

Summary hematocrit value Hematocrit summary statistic (mean versus median) SD hematocrit Range Number of patients in group

## Outcome information

- Functional Status - issues of various outcome assessment tools used and appropriate intermediate outcomes
- Quality of life - KD QOL etc
- Survival
- Blood transfusions - various ways of reporting % pts requiring transfusion number of transfusions needed (units)
- Hospitalization - various dimensions of this outcome to consider Number of hospital days Number of overall hospitalizations Number of hospitalizations for a specific problem
- Treatment related morbidity - rate of new or worsened hypertension, vascular access thrombosis, cardiovascular events, any others? (seizures, etc...)
- Growth - height, weight, percentile, standard deviation score, head circumference
- Development - Stanford-Binet score, Bailey score, normal vs. delayed
- School Performance - within normal limits vs. special needs Regularly attend school - able vs. unable vs. part-time