# Appendix A: Technical Advisory Group, External Reviewers, and Medical Advisory Panel

## Technical Advisory Group

- Joseph W. Eschbach, MD
- University of Washington

- Alan E. Lichtin, MD
- Hematology/Oncology
- Cleveland Clinic Foundation and Co-Chair, ASH/ASCO Expert Panel on the Use of Erythropoietin

- Allen R. Nissenson, MD
- University of California in Los Angeles

- Earl Steinberg, MD, MPP
- Covance Health Economics and Outcomes Services, Inc.

## Task Order Officer

- Martin Erlichman, MS
- Center for Health Care Technology
- AHRQ

## Health Care Financing Administration Liaison

- John Whyte, MD, MPH
- Medical Officer
- HCFA

## External Expert Reviewers/Advisors

- John W. Adamson, MD
- Blood Research Institute

- Tom Anderson, MD
- Division of Hematology/Oncology
- Medical College of Wisconsin

- Barbara Alving, MD
- Director, Division of Blood Diseases and Resources
- National Heart, Lung and Blood Institute

- Hanan S. Bell, PhD
- Independent Consultant; formerly Clinical Policies Analyst/Co-Director
- American Academy of Family Physicians

- Allan J. Collins, MD, FACP
- Associate Professor of Medicine
- Division of Nephrology, University of Minnesota

- Helen Danko, MS, RN, CNN
- Winthrop Hospital, Minneola, New York

- Peter DeOreo, MD
- Associate Clinical Professor of Medicine
- Case Western Reserve University, Division of Nephrology
- University Hospitals of Cleveland

- Steve Fishbane, MD
- Director, Dialysis Services
- Winthrop University Hospital, Minneola, New York

- Thomas Golper, MD
- Professor of Medicine
- Division of Nephrology, University of Arkansas for Medical Sciences

- David Goodkin, MD
- Amgen, Inc.

- Lawrence Goodnough, MD
- Division of Laboratory Medicine
- Washington University

- Paul Kimmel, MD
- Nephrology Program Director
- National Institute of Diabetes and Digestive and Kidney Diseases
- National Institutes of Health

- Carolyn E. Latham, President
- American Nephrology Nurses' Association

- Glenn Ramsey, MD
- Northwestern Memorial Hospital Blood Bank

- Mitchell Slavin, PharmD
- Ortho Biotech, Inc.

- Alice Thurston, Esq.
- Patient Advocate
- American Association of Kidney Patients

- Neil Powe, MD, MPH, MBA
- Johns Hopkins University
- School of Hygiene and Public Health

- Fernando Valderrabano, MD
- Chief, Department of Nephrology
- Hospital General Universitario
- Gregorio Maranon
- Madrid, Spain

- David van Wyck, MD
- Tucson, Arizona

- Sandra L. Watkins, MD
- Department of Pediatrics
- University of Washington Children's Hospital

- Jay Wish, MD
- Coordinator, Patient-based Program of Hemodialysis Services
- University Hospital, Division of Nephrology, Cleveland, Ohio

## Blue Cross and Blue Shield Association Medical Advisory Panel

- Peter C. Albertsen, MD
- University of Connecticut Health Center
- Division of Urology

- James. O. Armitage, MD
- Internal Medicine
- University of Nebraska Medical Center

- Wade Aubry, MD (Chair)
- Blue Cross and Blue Shield Association
- National Medical Consultant

- J. Lawrence Colley, MD
- Corporate Medical Director
- Trigon BlueCross BlueShield

- Helen Darling, MA
- Practice Leader, Group Benefits & Health Care
- Watson Wyatt & Company

- David M. Eddy, MD, PhD
- Kaiser Permanente
- Southern California Region
- Scientific Advisor for Health Policy and Management

- Alan M. Garber, MD, PhD
- Director, PCOR and CHP
- Stanford University

- Michael A. Hattwick, MD
- Woodburn Internal Medicine Associates, Ltd.

- I. Craig Henderson, MD
- University of California, San Francisco
- Professor of Medicine, Chief of Oncology

- Albert R. Jonsen, PhD
- University of Washington
- Department of Medical History and Ethics

- Peter A. Margolis, MD, PhD
- Assistant Professor, Department of Pediatrics
- Clinical Assistant Professor, Department of Epidemiology
- Children's Primary Care Research Group

- Barbara J. McNeil, MD, PhD
- Ridley-Watts Professor and Head of Health Care Policy
- Harvard Medical School

- Richard G. Roberts, MD, JD
- Department of Family Medicine
- University of Wisconsin School of Medicine

- Earl P. Steinberg, MD, MPP
- Covance Health Economics and Outcomes Services, Inc.

- Clifford Waldman, MD
- Medical Director
- Anthem BlueCross & BlueShield

- Paul J. Wallace, MD
- Kaiser Permanente Northwest

- Les Zendle, MD
- Associate Medical Director
- Kaiser Permanente Southern California