# Appendixes

Appendix A: Technical Advisory Group, External Reviewers, and Medical Advisory Panel

Appendix B. Data Abstraction Forms: Renal

Appendix C. Acronyms and Abbreviations