# Supplemental Analyses

## Supplemental Analysis 1: Practice Variation in the Evaluation of Secondary Causes of Osteoporosis

A preliminary literature search of MEDLINE identified no studies of strategies to diagnose secondary causes of osteoporosis in postmenopausal women who have low bone density or fragility fractures. A review of published practice guidelines and expert opinions about diagnostic strategies for secondary osteoporosis confirmed this finding, because there were no publications cited as background or evidence. Based on this investigation, we determined that evidence supporting an appropriate evaluation for secondary causes in women with osteoporosis was lacking. To determine how physicians actually conduct these evaluations in clinical practice in the absence of evidence, we next performed a supplemental analysis based on responses to a questionnaire (Appendix S1-1). Support for this separate project was provided by the Outcomes Management Group, Division of Medical Informatics and Outcomes Research, Oregon Health & Science University. The principal investigator of the project was Cynthia Morris, Ph.D.

### Methods

We designed a mailed, self-administered questionnaire to measure the following: (1) frequency of use of bone density testing in postmenopausal women, and characteristics influencing the decision to order it; (2) frequency of evaluation for secondary causes of osteoporosis for women with confirmed low bone density; (3) referral patterns for women diagnosed with osteoporosis; (4) principal secondary causes of osteoporosis considered in the evaluation; (5) factors influencing the decision to evaluate secondary causes; and (6) laboratory tests used routinely and selectively as indicated by history and physical examination in women with confirmed osteoporosis.

We used the American Medical Association (AMA) list of U.S. practitioners to identify physicians in active practice who are not in military service; both members and nonmembers of the AMA are contained in this list. To enable a comparison of primary care practitioners to specialists (endocrinologists), 500 physicians each in internal medicine, family practice, and obstetrics and gynecology were randomly selected using a nationwide sampling strategy. One thousand endocrinologists were similarly chosen nationwide. Questionnaires were mailed to subjects in January 2000. Because this was intended as a pilot project, additional mailings were not provided. Responses were accepted up until April 1, 2000. Analysis included descriptive frequencies only.

### Results

A total of 367 of the 2,500 mailed questionnaires (15 percent) were completed and returned. The average age of physician respondents was 47.3±10.9 years. Thirty-two percent of the sample was female and 68 percent male. Ninety-three percent of respondents were in practice full-time and 7 percent part-time. Private or group practice types predominated in the sample (76 percent) compared with 10 percent who work in an academic medical center, 5 percent in an HMO, and 6 percent in other settings. Fifty-five percent of respondents practiced in a large city (>200,000 population), 35 percent in a midsized city (25,000-200,000 population), and 10 percent in a small town or rural environment.

Thirty-five percent of the respondents recommended bone density testing for the majority (>75 percent) of all postmenopausal women; 42 percent recommended it for 25 to 75 percent; 22 percent recommended it for less than 25 percent; and 2 percent recommended it for none (Table S1-1). Internists and endocrinologists recommended testing for a larger proportion of postmenopausal women than did obstetricians/gynecologists or family practitioners. This recommendation was similar to the reported frequency of ordering bone density tests. More internists, endocrinologists, and obstetricians/gynecologists order bone density tests on a weekly basis than do family practitioners (Table S1-2). Overall, 58 percent of respondents said they ordered more than one bone density test per week, 33 percent more than one test per month, 8 percent more than one test per year, and one percent never ordered this test.

After the diagnosis of osteoporosis was made by bone density testing in a postmenopausal woman, endocrinologists evaluated women for secondary causes of osteoporosis more frequently than other practitioners (Table S1-3). Fifty-four percent of endocrinologists reported that they evaluate more than 75 percent of all women with osteoporosis for a secondary cause. The majority of internists, family practitioners, and obstetricians/gynecologists reported that they occasionally or rarely evaluate women for secondary causes and rarely refer women to a specialist. This would indicate that the majority of women with osteoporosis diagnosed in a primary care setting are not undergoing investigations for secondary causes of osteoporosis.

Three factors were cited as strongly influential in the decision to evaluate a woman for secondary causes by more than 90 percent of the responding physicians: no response to 1 year of treatment for osteoporosis, very low bone density, and osteoporosis in a premenopausal woman. When asked which age group they would most likely evaluate for secondary causes, respondents most often cited the youngest group, women 45-54 years of age. Concomitant serious medical illness, history of an atraumatic fracture, and unwillingness to undergo treatment for osteoporosis were modestly influential in the decision to evaluate osteoporosis in a woman, cited at least half the time by respondents.

Hyperthyroidism and hyperparathyroidism were selected by more than 60 percent of the sample as the most common secondary causes of osteoporosis, followed by hypogonadism and vitamin D deficiency, which were noted by about one-third of respondents. Tests to evaluate these disorders were cited by respondents who were asked to indicate which laboratory tests they routinely order in this situation (Table S1-4). (Thirty-four respondents noted that they did not evaluate for secondary causes, and did not respond to this question.) The majority of physicians reported routinely ordering a metabolic panel, complete blood count, and thyroid-stimulating hormone to rule out a secondary cause of osteoporosis. A sizeable sample noted that measures of calcium metabolism -- bspecifically 24-hour urinary calcium, ionized calcium, parathyroid hormone, and 25-OH vitamin D -- were ordered either routinely or selectively if indicated by history and physical examination.

### Conclusions

The results of our analysis of physician practice pattern variation in the evaluation of secondary causes of osteoporosis in women indicated a lack of consensus. Physician test-ordering behavior differed among primary care practitioners and specialists. Family practitioners less frequently recommended bone density tests for postmenopausal women, obtained bone density tests, and underwent evaluations for secondary causes than did internists, endocrinologists, and obstetricians/gynecologists. Endocrinologists more frequently evaluated patients for secondary causes than did other practitioners. Thyroid-stimulating hormone, chemistry battery, and complete blood count were the most frequently ordered tests cited by respondents. These also were the most frequently recommended tests in our review of expert guidelines.

These data are limited by the low response rate and may not be representative of true practice variation that would be observable only within a large data set. Respondents likely represented a physician community most interested in osteoporosis, as evidenced by the higher response rate (21 percent) of endocrinologists, and may not reflect actual community practice.

Table S1-1. Proportion of postmenopausal women for which bone density testing is recommended*

Table S1-1. Proportion of postmenopausal women for which bone density testing is recommended*

| Internists | Family Practitioners | Endocrinologists | Obstetricians/Gynecologists
>75% | 22 (42%) | 9 (20%) | 80 (42%) | 15 (23%)
25-75% | 20 (38%) | 19 (42%) | 83 (43%) | 25 (38%)
<25% | 8 (15%) | 16 (36%) | 27 (14%) | 26 (39%)
None | 2 (4%) | 1 (2%) | 2 (1%) | 0

*Percentages may not equal 100 because of rounding

Table S1-2. How often do you obtain bone density measurements for your postmenopausal women patients?*

Table S1-2. How often do you obtain bone density measurements for your postmenopausal women patients?*

| Internists | Family Practitioners | Endocrinologists | Obstetricians/Gynecologists
Frequently (>1 patient/wk) | 31 (60%) | 15 (33%) | 128 (66%) | 35 (53%)
Occasionally (>1 patient/mo) | 17 (33%) | 20 (44%) | 59 (31%) | 22 (33%)
Rarely (>1 patient/yr) | 3 (6%) | 10 (22%) | 4 (2%) | 9 (14%)
Never | 1 (2%) | 0 | 2 (1%) | 0

*Percentages may not equal 100 because of rounding

Table S1-3. How often do you evaluate a woman with osteoporosis for secondary causes?*

Table S1-3. How often do you evaluate a woman with osteoporosis for secondary causes?*

| Internists | Family Practitioners | Endocrinologists | Obstetricians/Gynecologists
Frequently (>1 patient/wk) | 10 (20%) | 4 (9%) | 104 (54%) | 12 (18%)
Occasionally (>1 patient/mo) | 17 (33%) | 11 (24%) | 66 (35%) | 10 (15%)
Rarely (>1 patient/yr) | 22 (43%) | 28 (62%) | 20 (10%) | 34 (52%)
Never | 2 (4%) | 2 (4%) | 1 (1%) | 9 (14%)

*Percentages may not equal 100 because of rounding

Table S1-4. Laboratory tests ordered to assess secondary causes of osteoporosis

Table S1-4. Laboratory tests ordered to assess secondary causes of osteoporosis

| Routinely | Only if indicated by history & exam
TSH - Thyroid-stimulating hormone | 92% | 6%
Chemistry battery | 87% | 9%
Complete blood count | 69% | 20%
24-hour urine calcium | 44% | 37%
Parathyroid hormone | 43% | 45%
Urinalysis | 42% | 33%
25-OH vitamin D | 41% | 40%
Serum protein electrophoresis | 37% | 48%
Ionized calcium | 32% | 43%
T3/T4 - Thyroxine or T3 | 31% | 47%
Erythrocyte sedimentation rate | 24% | 50%
Bone-specific alkaline phosphatase | 18% | 52%
Serum or urinary collagen crosslinks | 18% | 50%
Urine pH | 18% | 50%
Cortisol | 16% | 63%
1,25(OH)2D3 | 16% | 57%
24-hour creatinine clearance | 15% | 52%
Spinal X-ray or CT scan | 10% | 60%
Osteocalcin | 7% | 56%
Blood gas | 0.6% | 62%
Bone biopsy | 0.3% | 64%

## Appendix S1-1. Survey form: Practice Variation

[Form goes here]

## Supplemental Analysis 2: Model-Based Economic Comparison of Diagnostic Alternatives

### Background

Our review of the literature on bone measurement tests indicates that dual-energy X-ray absorpiometry of the femoral neck (DXN-FN) or total hip is the best predictor of hip fractures (see section on Bone Measurement Tests, p. 48, above). Clinicians use this approach for making diagnosis and treatment decisions about osteoporosis. Women with T-scores less than -2.5 are considered osteoporotic and may be offered treatment.^ 1 ^ Women with T-scores between -1 and -2.5 are considered ostepenic and may be monitored more closely for additional loss of bone density. Diagnosis with DXA-FN requires a relatively large and expensive instrument and a relatively high degree of operator skill to correctly position the target area. DXA is usually performed at a hospital or larger medical center and is often done on a referral basis.

Over the last few years, several newer diagnostic approaches, such as quantitative ultrasound (QUS) and peripheral DXA, have become more available. These approaches require less costly equipment and less space than DXA and are becoming more common in primary care offices and smaller clinics. As part of our evidence review, we met with a local technical expert panel (Appendix A). They suggested that a sequential diagnostic approach may become common in primary care. With this approach, a newer and more available diagnostic tool such as QUS is used in a primary care setting. If a woman is identified as being at higher risk of osteoporosis, she is then referred to DXA-FN for a definitive diagnosis. Also, as these diagnostic tools become more available in the primary care setting, clinicians may choose to use one of these newer methods alone.

We developed a simple economic model to compare both the sequential diagnostic approach and diagnosis with QUS alone to diagnosis with DXA-FN alone. This simple model is intended to evaluate potential differences in cost per fracture prevented among these three diagnostic approaches. These results may support a more detailed economic evaluation beyond the scope of this evidence report.

We chose QUS to be representative of the newer and more available diagnostic tools because there are published reports from two cohort studies^ 2 ^,^ 3 ^ that compare hip fracture rates following diagnosis with DXA and with QUS. In addition to these published reports, the investigators of the Study of Osteoporotic Fractures (SOF)^ 4 ^ provided data on women in the SOF cohort who received both DXA-FN and QUS and were followed for subsequent fractures.

The World Health Organization^ 1 ^ and other groups recommend that osteoporotic women be defined as those with DXA T-scores less than -2.5. However, there are no such guidelines for QUS broadband ultrasound attenuation (QUS/BUA). We therefore performed a series of analyses using the SOF cohort data with various QUS/BUA cut points used to define women at high risk of fractures.

### Objective

The objective of this economic evaluation is to use a relatively simple economic model to predict, for alternative diagnostic approaches, the total direct medical costs (from a payer/provider perspective) and number of hip fractures in a cohort of 1,000 older women. Data for this analysis was obtained from published studies of the Epidemiologie de l'Osteoporose (EPIDOS) cohort^ 2 ^ and unpublished data from the SOF cohort.^ 3 ^ We developed this model to assess the potential for reduced cost per hip fracture prevented using either a sequential diagnostic approach (QUS followed by DXA-FN in those at higher risk of osteoporosis) or QUS alone relative to DXA alone.

### Methods

#### Economic Model

We used a cost-effectiveness approach to estimate the cost per hip fracture prevented. We used a decision tree (Figure S2-1) to estimate costs per hip fracture prevented for three diagnostic approaches. The audience for this economic evaluation includes providers and payers of healthcare. Only direct medical costs (from a payer or provider perspective) are considered.

The target population for these analyses is the same as that for the EPIDOS^ 2 ^ and SOF^ 3 ^ studies -- that is, older white women. The EPIDOS study consisted of 5,541 French women (out of 7,575 in the original cohort) with a mean age of 80 years. The original SOF cohort^ 3 ^ (U.S. women age 65 years or more) had been followed for about 5 years when the period for this study began. Of those alive at that time, 5,993 (72 percent) were included in this study, with a mean age of 76 years. In both studies, some centers lacked the QUS instruments at the time the diagnostic tests were taken; thus, not all women in the cohorts were included in these two studies. The fracture data in the reports on the EPIDOS and SOF cohorts had an average follow-up time of about 2 years. While this period is shorter than the period of most clinical trials of therapy to reduce fracture rates, we have used this 2-year time horizon for our analyses.

We considered three alternative diagnostic approaches: DXA-FN alone, QUS alone, and a sequential approach where QUS is used first and, for those at high risk, DXA-FN also is performed. Because there are no recommended cut points for QUS/BUA that define high risk of fracture, we compared the alternative diagnostic approaches across a series of QUS/BUA cut points (from 50 to 85 dB/MHz in steps of 5 dB/MHz). These approaches are summarized in Table S2-1 with respect to test(s) performed and subsequent treatment (based on the test results). Figure S2-2 illustrates which women would be treated given these alternatives based on whether test values are above or below the cut point for DXA-FN and/or for QUS. With each approach, all women diagnosed as osteoporotic (that is, at high risk of fracture) receive treatment. While treatment is not the focus of this report, differences among treatments with respect to reductions of risk of hip fracture and costs of the treatments may affect the cost per fracture prevented. The diagnostic approaches are compared within treatments but not across treatments. We restricted our economic evaluation to a one-time diagnostic test (no follow-up monitoring).

We used number of hip fractures as the only outcome of interest. We did not explicitly model sequelae of hip fractures (such as death or admission to a nursing home), although the costs of these sequelae were included in the cost of a hip fracture.

#### Model Assumptions

For these analyses, we defined a base case scenario in terms of the cohort (EPIDOS or SOF), the diagnostic approach (DXA alone, QUS alone, or sequential), the treatment provided to women diagnosed as osteoporotic (alendronate, hormone replacement therapy [HRT], or calcium and vitamin D) and, for analyses using SOF data only, a particular QUS/BUA cut point defining high risk of fracture. The full list of model parameters (with sensitivity values) is included in Table S2-2.

As the base case risk reductions for the three treatments, we used 50 percent (alendronate), 25 percent (HRT), and 10 percent (calcium and vitamin D). These values are based on the more conservative estimates of treatment effects and the ranges of uncertainty cited in a 1998 report by the National Osteoporosis Foundation.^ 4 ^ We then estimated the number of women in a hypothetical cohort of 1,000 who were diagnosed as osteoporotic and received treatment. The number of hip fractures was estimated for osteoporotic women using the risk reduction for the treatment used, and for nonosteoporotic women. This total number of hip fractures was subtracted from the number of fractures without any diagnosis or treatment (the number of hip fractures per 1,000 women observed in the cohort used) to estimate the number of fractures prevented by diagnosis and treatment. We allowed the total fracture rate to be increased (up to tenfold) or decreased (by up to 50 percent) to represent populations with higher or lower overall fracture risk. We also allowed fracture risk reduction in those diagnosed using QUS alone to be reduced by a percentage (by 10 percent, 20 percent, and 30 percent) compared to those diagnosed with DXA-FN alone. There are no clinical trials of therapies leading to reduction in fracture rates that have used QUS/BUA at baseline as a risk predictor.

#### Costs

We used three sets of direct medical costs in this economic model. The first set of costs are the costs of diagnosis. For DXA or QUS alone, the costs of diagnosis are 1,000 (the number in the cohort) times the cost of the diagnostic test. For the base case, the test cost for DXA is $133 and for QUS is $34. In sensitivity analyses, these costs range from $99 to $183 for DXA and $30 to $54 for QUS. We used Medicare reimbursement rates (median, lower, and upper quartiles) for 2000^ 6 ^ for CPT code 76075 for DXA (hip and spine) and 76977 for QUS (any site) for these cost estimates.

The second cost is for treatment of fractures. We used cost estimates for hip fractures from the U.S. Congress Office of Technology Assessment.^ 7 ^ We inflated these costs to 1999 values (multiplier of 1.147) using medical inflation data from the U.S. Department of Commerce.^ 8 ^

The third set of costs are for the three treatment regimens -- alendronate, HRT, and calcium and vitamin D. HRT assumes treatment with both estrogen and progestin. In practice, women without an intact uterus would receive only the estrogen, lowering the cost for this regimen. We used the cost for the combination regimen for all analyses. We used the annual cost estimates from the NOF report^ 4 ^ inflated to 1999 dollars (using a multiplier of 1.147). Because the EPIDOS and SOF cohorts had different mean ages, the treatment costs differ slightly because of differences in mortality in the first year. Treatment costs were summed for year 1 and, after discounting and adjusting for mortality in year 1, for year 2. We assumed the cohort experienced mortality in the second year corresponding to the average mortality in females in the United States for a group with age equal to the mean cohort age.^ 9 ^

The three sets of costs (diagnosis, fractures, and treatment) were summed to obtain a total cost. We used base case plus or minus 30 percent for sensitivity analyses on costs of fractures and costs of treatments. From this total cost we subtracted the cost of treating fractures in the cohort, assuming no diagnosis or treatment, to obtain the final (incremental) total cost. Thus, the total cost is the incremental cost of performing a diagnosis and treating women diagnosed as osteoporotic.

Neither of the reports on the EPIDOS and SOF cohorts reported 1-year hip fracture rates, only fracture rates for the total follow-up period. Thus, we were unable to discount either fractures prevented or cost for fractures for these analyses. We discounted the second year of treatment costs by 3 percent. Given the 2-year time horizon we used, any impact of not discounting all costs and outcomes is likely to be relatively small.

#### Sensitivity Analyses

We performed univariate sensitivity analyses for the parameters with ranges listed in Table S2-2. Sensitivity analyses were reviewed primarily to determine if the order of the alternatives changed across the sensitivity analyses although the magnitudes of the incremental cost-effectiveness ratios also were reviewed.

#### Implementation

We programmed two versions of this model. The first version was developed in Excel 97^®^ for Windows 95^®^. The second version was programmed in SAS^®^ Version 7.0 for Windows 95^®^. For a given scenario, we omit discussion of diagnostic alternatives that are either dominated or show extended dominance compared to another alternative. Economic dominance occurs in three situations: one alternative may cost more and prevent more fractures than a second; one alternative may cost as much and prevent more fractures; an alternative may cost less and prevent the same number of fractures. Extended dominance occurs when the incremental cost-effectiveness of an alternative with lower cost is greater than the incremental cost-effectiveness of a second alternative that has higher cost. For a more complete discussion of dominance and extended dominance, we refer the reader to the report by the Panel of Cost-Effectiveness in Health and Medicine.^ 10 ^

### Results

#### EPIDOS Cohort

In the report on the EPIDOS cohort,^ 2 ^ the overall fracture rate was 2.07 percent over the followup period. These authors selected a cut point for QUS/BUA of 100.9 dB/MHz. This value was approximately the median value of QUS/BUA in this cohort. For DXA-FN, the T-score of -2.5 also was approximately the median. Thus, for diagnosis with either DXA alone and QUS alone, approximately 50 percent of women would have been diagnosed as osteoporotic and received treatment. For the sequential diagnostic approach, only 31 percent of women would have been diagnosed as osteoporotic and received treatment under our model. Table S2-3 summarizes the percentage of women diagnosed as osteoporotic for both cohorts. The EPIDOS cohort fracture rates are summarized in Table S2-4.

#### Base Case

The results for cost per hip fracture prevented are summarized in Table S2-5. For the base case the sequential diagnostic approach is the most cost-effective option for treatment with either alendronate ($77,837 per hip fracture prevented) or HRT ($107,621 per hip fracture prevented). The incremental cost per hip fracture prevented for DXA is 50 percent (for HRT) to 61 percent (for alendronate) higher than the incremental cost per hip fracture for the sequential approach. QUS is eliminated by the principle of extended dominance for both of these treatments. For treatment with calcium and vitamin D, QUS alone is the most cost-effective alternative ($39,307 per hip fracture prevented). The incremental cost per fracture prevented is over 10 times the cost per hip fracture prevented for QUS alone and the sequential approach is dominated in this scenario.

#### Sensitivity Analyses

In all but two of the sensitivity analysis scenarios, the sequential approach had the lowest cost per hip fracture prevented, DXA alone prevented more hip fractures at a higher cost per hip fracture prevented, and QUS alone was dominated. If women diagnosed as osteoporotic are treated with HRT and if either the higher cost of DXA ($183) or the lower cost of HRT is used, QUS alone has an incremental cost-effectiveness ratio only slightly higher than that for the sequential approach. For high-cost DXA (or low-cost HRT), the incremental cost-effectiveness ratios are about $116,000 ($78,000) for the sequential approach, about $129,000 ($79,000) for QUS alone, and about $235,000 ($149,000) for DXA alone. While the magnitude of the incremental cost-effectiveness ratios varies across the other sensitivity scenarios, the sequential procedure consistently has the lower cost-effectiveness ratio. DXA alone will prevent additional hip fractures, but at an increased incremental cost per hip fracture prevented at least 43 percent higher across scenarios with alendronate treatment and at least 26 percent higher across scenarios with HRT treatment.

#### SOF Cohort

We used SOF data^ 5 ^ to evaluate the cost per hip fracture prevented using several cut points for QUS/BUA. The overall fracture rate in this cohort is 0.90 percent across the followup period. We used a T-score of less than or equal to -2.5 as the definition of osteoporosis for diagnosis with DXA-FN. Table S2-3 summarizes the percentage of women diagnosed as osteoporotic for each QUS/BUA cut point we considered. For diagnosis with DXA-FN alone, about 28 percent of the women are diagnosed as osteoporotic. For diagnosis with QUS alone, the proportion of women diagnosed as osteoporotic covers a broad range (16 percent to 87 percent). For diagnosis with the sequential procedure, the proportion of women diagnosed as osteoporotic covers a more narrow range (9 percent to 27 percent). SOF cohort fracture rates are summarized by QUS/BUA cut points in Table S2-6.

#### Base Case

For treatment with alendronate, the results are summarized in Figure S2-3 and Appendix S2-1. In the top panel of Figure S2-3 (and subsequent Figures), the diagnostic alternatives are in the same order across QUS/BUA cut points. The alternative with the lowest incremental cost-effectiveness ratio (i.e., the most cost-effective) is compared to no diagnosis and no treatment. The alternative with the next higher incremental cost-effectiveness ratio is compared to the alternative with the next lower incremental cost-effectiveness ratio. For example, at 65 dB/MHz, the most cost-effective alternative is the sequential approach, DXA alone the next most cost-effective, and QUS alone the least cost-effective. Also, the incremental cost-effectiveness ratio is not included for alternatives that are dominated (including dominated by extended dominance), but the total direct medical costs and hip fractures prevented are displayed for all alternatives.

Appendix S2-1 summarizes results for all diagnostic alternatives, including those that are dominated. The sequential diagnostic approach has the lowest incremental cost per fracture prevented compared to no diagnosis and treatment. For QUS/BUA cut points of 70 dB/MHz or less, DXA is the next most cost-effective alternative, but the incremental cost per fracture prevented of DXA over the sequential option is substantial, at least 50 percent greater in relative terms or more than $85,500 per hip fracture prevented in absolute terms. At QUS/BUA cut points of 75 dB/MHz or greater, DXA alone is dominated. QUS alone is not a cost-effective alternative at cut points of 75 dB/MHz or greater. The cost per hip fracture prevented is around three times as great or greater as the cost per hip fracture for the sequential approach.

For HRT, the results are summarized in Figure S2-4 and Appendix S2-1. The sequential approach is again the most cost-effective option except at a QUS/BUA cut point of 85 dB/MHz, where DXA alone is the most cost-effective alternative. The next most cost-effective options, either DXA alone in four cases or QUS alone in three cases, have substantially higher costs per fracture prevented (at least 40 percent higher).

If calcium and vitamin D were used as a treatment, QUS alone is the most cost-effective alternative (cost per fracture prevented ranging from about $118,000 to $130,000 across the cut points). DXA alone is the only other nondominated alternative, but only for cut points of 60 dB/MHz or less, and the incremental cost per fracture prevented is about four times or more greater than for QUS alone. Results are summarized in Appendix S2-1.

#### Sensitivity Analyses

This summary will focus primarily on scenarios in which the order of the diagnostic alternatives changes from the base case. For scenarios not discussed, the magnitudes of the incremental cost-effectiveness ratios may differ across alternatives, but the order is the same as the base case. In some cases, the change in magnitude of the incremental cost-effectiveness ratios indicates that an alternative may become relatively cost-effective for certain sensitivity parameters. These cases also are cited.

The analyses are relatively insensitive to the cost of alendronate treatment. The only scenario in which the order differed from the base case is at 50 dB/MHz with the low cost of alendronate. In this case, QUS alone is not dominated, and the incremental cost per hip fracture prevented ($153,464) is intermediate between that of the sequential approach ($87,066) and that of DXA alone ($194,493). For sensitivity analyses on the cost of HRT, the results are summarized for low and high HRT costs for cut points of 50, 55, and 60 dB/MHz in Figure S2-5. At low HRT costs, QUS alone is the most cost-effective alternative at a cut point of 50 dB/MHz (the sequential approach is dominated), and QUS has only a slightly higher incremental cost-effectiveness ratio at 55 dB/MHz than the sequential approach, which is the most cost-effective alternative at this cost and cut point combination.

For sensitivity analyses for cost of DXA and treatment of osteoporotic women with alendronate, there is only one substantive deviation from the base case. At the high value of DXA cost ($183), the incremental cost per hip fracture prevented for QUS alone (about $230,716) is intermediate between the incremental cost-effectiveness ratio for the sequential approach ($123,400) and for DXA alone ($294,312). For treatment with HRT, there are several differences between the base case and the sensitivity scenarios at QUS/BUA cut points of 50, 55 or 60 dB/MHz. These are plotted in Figure S2-6 by QUS cut point and by cost of DXA. Finally, for high-cost DXA at QUS/BUA cut point of 85 dB/MHz, the sequential diagnostic approach replaces DXA alone as the most cost-effective alternative, and DXA alone is dominated for this scenario. Thus, the results are somewhat sensitive to DXA costs, especially the high cost for DXA, when HRT treatment is used for osteoporotic women.

Sensitivity analyses for cost of QUS showed no substantive changes for the analyses with alendronate treatment. For treatment with HRT, at QUS/BUA cut points of 70 and 80 dB/MHz, in the scenarios using the higher cost for QUS ($54), DXA alone dominated the sequential procedure. At QUS/BUA cut point of 85 dB/MHz, in the scenario of low cost for QUS ($30), the sequential diagnostic approach dominated DXA alone.

Finally, we performed sensitivity analyses on reduction in the degree of risk reduction achieved by therapy in women diagnosed as osteoporotic using QUS alone. For treatment with alendronate, QUS alone was the least cost-effective alternative at QUS/BUA cut points of 65 and 70 dB/MHz. With 5 percent reduction in risk reduction, QUS alone became dominated at 65 dB/MHz, and with 15 percent reduction, it was dominated at 70 dB/MHz. At QUS/BUA cut point of 75 dB/MHz, DXA was a more cost-effective alternative than QUS diagnosis (DXA was dominated in the base case) with 10 percent or greater reduction in risk reduction. At cut points of 80 and 85 dB/MHz, there was no substantive difference between sensitivity and base case scenarios up to a reduction in risk reduction of 30 percent.

For treatment with HRT at QUS/BUA cut points of 50 and 65 dB/MHz, QUS alone -- not dominated in the corresponding base case scenarios -- is a dominated alternative with even a 5 percent risk reduction. At a cutpoint of 70 dB/MHz, QUS alone is dominated if the reduction in risk reduction is 15 percent. At a cut point of 75 dB/MHz, diagnosis with DXA alone, which is dominated in the corresponding base case scenario, is not dominated with even a 5 percent reduction in risk reduction and QUS alone is dominated with a 30 percent reduction in risk reduction. For all cut points except 85 dB/MHz, however, the sequential approach remained the most cost-effective alternative.

For treatment with calcium and vitamin D, QUS alone was the only nondominated alternative for QUS/BUA cut points of 65 dB/MHz or greater. If the reduction in risk reduction was at least 5 percent at 65 dB/MHz or at least 15 percent at 70 dB/MHz, then DXA alone is a nondominated alternative, although with a relatively high incremental cost-effectiveness ratio for most reductions in risk reduction. At QUS/BUA cut point of 75 dB/MHz, DXA alone is the only nondominated alternative for a 30 percent reduction in risk.

Sensitivity analyses for costs of calcium and vitamin D, risk reduction in response to treatment (alendronate, HRT, or calcium plus vitamin D), costs to treat fractures, and fracture rates did not show any changes in the order of the alternatives with respect to incremental cost-effectiveness ratios. The magnitude of cost-effectiveness ratios did change somewhat across these sensitivity analyses.

QUS alone in the base case is only cost-effective for treatment with calcium and vitamin D. As noted in the National Osteoporosis Foundation report,^ 4 ^ this is an alternative in which diagnosis may not be worth performing, because the cost and adverse experiences of both calcium and vitamin D are so low as to be relatively negligible. For treatment with alendronate, QUS alone is not dominated for cut points of 70 dB/MHz or higher. While diagnosis with QUS alone prevents the most fractures in these scenarios, the incremental cost-effectiveness ratios are all around $500,000 per fracture prevented or greater. One could ask whether, in a higher-risk population than the SOF cohort, diagnosis with QUS alone would be more cost-effective.

To address this question, we performed a series of analyses in which the risk of fractures in the population was increased by five-, seven- , and tenfold. In these scenarios, the order of alternatives is the same as in the base case. However, for higher-risk groups the incremental cost per hip fracture prevented drops for all alternatives. In particular, the incremental cost per hip fracture prevented for QUS alone is below $100,000 for several scenarios. For example, with alendronate treatment at 70 dB/MHz and a tenfold increase in fracture risk, the incremental cost per hip fracture prevented is $2,937 saved per hip fracture prevented for the sequential approach, $5,618 per hip fracture prevented for DXA alone, and $81,954 for QUS alone. QUS alone prevented 4.17 more fractures than DXA alone. Similarly, the incremental cost per hip fracture prevented following diagnosis with QUS alone at 75 dB/MHz given a 5-fold increase in fracture risk is $93,997 -- and for a 10-fold increase, $35,933. In these cases, almost 6 and more than 12 additional hip fractures are prevented, respectively, compared to the sequential approach. Similar results are observed for higher QUS/BUA cut points with alendronate and for treatment with HRT for QUS/BUA cut points of 70 dB/MHz or greater. Thus, QUS alone may be a cost-effective alternative in higher-risk populations.

#### Discussion

These analyses have shown that the sequential diagnostic approach may be a cost-effective alternative to DXA. Further, in a higher-risk population, QUS alone may also be a cost-effective alternative. The results for diagnosis with QUS alone are sensitive to the reduction of risk reduction following diagnosis with QUS. If reduction in fracture risk reduction is as little as 5 percent less than diagnosis with DXA, QUS alone may be dominated by other alternatives.

Quality-adjusted life year (QALY), rather than hip fractures prevented, is the recommended outcome measure for economic comparisons.^ 10 ^ By using fractures prevented, policymakers cannot compare diagnoses with one of the approaches considered to other healthcare interventions. An analysis using QALYs would facilitate such a comparison. Our approach does allow one to make comparisons among diagnostic alternatives included within our model. Cost per QALY would also allow incremental cost-effectiveness ratios (comparisons among alternatives) to be placed into a context related to other economic healthcare decisions. Our primary purpose for this project, however, was to assess the potential for less expensive and more readily available diagnostic approaches (the sequential diagnostic approach and QUS alone) to provide a cost-effective alternative to diagnosis with DXA-FN. If the sequential approach, for example, were not cost-effective compared to DXA-FN in this simple approach, it would not be likely to be more cost-effective with a more complex model. These results support additional research to estimate differences in cost per QALY among these diagnostic alternatives.

We have made an assumption about the treatment-related reduction of fracture rates following diagnosis of osteoporosis with QUS/BUA. To date, clinical trials that have assessed the impact of reduction in risk of fracture have all used diagnosis with DXA-FN. One may question whether a woman diagnosed using either the sequential approach or QUS alone would experience the same reduction in fracture risk as a woman diagnosed with DXA. For diagnosis with the sequential approach, this should not be an issue. All women diagnosed by the sequential approach as osteoporotic will have both a QUS/BUA value less than the specified point and a DXA T-score less than -2.5. Since QUS/BUA has been shown to be a statistically significant risk factor for fracture rates in a multivariable model containing DXA-FN T-scores,^ 3 ^ the fracture risk in this group would be expected to be at least as high as that for women with a DXA-FN T-score less than -2.5 alone. To the extent that women identified as osteoporotic by the sequential approach have a higher fracture risk than women diagnosed with DXA alone, our analyses are conservative with respect to the sequential diagnostic approach. That is, the true fracture rates in women diagnosed as osteoporotic by the sequential approach will be higher than we have used, meaning that the corresponding incremental cost-effectiveness ratios will be lower than those reported here. For diagnosis with QUS alone, however, no clinical trials support similar reductions in hip fracture risk as following diagnosis with DXA alone. The sensitivity of our results to potential reduction in risk reduction following diagnosis with QUS alone suggests that further research is needed to determine if such as reduction in risk occurs using diagnosis with QUS alone.

Our economic analyses have proved robust to the reductions in hip fracture risk following any of the treatment regimens. That is, the order of the cost-effectiveness ratios did not change across the sensitivity analyses of treatment-related risk reductions. However, the magnitude of the incremental cost-effectiveness ratios decreases as the treatment-related risk reduction increases. Similarly, the sensitivity analyses for costs of care for fractures did not change the order of the alternatives. As fracture costs increase, the incremental cost-effectiveness ratios decrease, although changes are relatively minor over the range of fracture costs considered. Finally, when the sensitivity analyses are performed for the proportion of fractures (across all women), the order of alternatives does not change. As the rate of fractures increases, the incremental cost-effectiveness ratios decrease.

#### Other Considerations

One aspect that complicates our analyses is the lack of an agreed-upon cut point for QUS/BUA. That is, the literature does not provide a recommendation for a QUS/BUA cut point that will either indicate sufficient risk to either require treatment or warrant further diagnosis using DXA. The EPIDOS report used a cut point that approximated the median of the observed distribution of QUS/BUA. Using the SOF data, if we were to define sensitivity and specificity in terms of fracture outcomes and plot a receiver operating characteristic (ROC) curve, an optimal QUS/BUA cut point would not be obvious. Thus, we have performed the economic analyses for each of a series of cut points (from 50 to 85 dB/MHz with increases of 5 dB/MHz). We have made no attempt to select one QUS/BUA cut point. As the cut point increases, so do the numbers of fractures prevented, the numbers of patients diagnosed as osteoporotic, and the total costs. Additional research to determine QUS/BUA cut points would allow economic evaluation to be more focused.

The two cohorts, EPIDOS and SOF, differ, especially in the proportion of women with DXA-FN T-scores of -2.5 or less. The EPIDOS cohort has older women with almost 50 percent diagnosed as osteoporotic using DXA-FN. Only 28 percent of the SOF cohort is osteoporotic by DXA-FN. Also, the EPIDOS results are very robust across scenarios whereas SOF results are sensitive to the QUS/BUA cut point used and to several other variables as well.

The incremental cost per fracture prevented as estimated by our model appears to be very high, with most much higher than $100,000 per hip fracture prevented for most scenarios. There are at least two reasons why these values may be inflated. First, we used a relatively short time horizon of 2 years for this evaluation. This period corresponds to the mean follow-up time in both cohorts simplifying the analyses. However, the time in which to accrue benefits is relatively short, even for women in this elderly population. If fractures over remaining lifetime were modeled, the cost per fracture prevented would likely decrease, perhaps substantially. Second, this evaluation has ignored other risk factors. Use of additional risk factors might reduce the magnitude of these cost-effectiveness ratios by better identifying women at high risk of hip fractures. Thus, a more complex economic model that included other clinical risk factors would provide more definitive comparisons among these alternatives.

#### Future Research

Several areas of future research needs have been mentioned so far in this section. Studies are needed to choose cut points for QUS/BUA to either define women at high risk of fracture or define women who should receive further diagnostic testing with DXA. The SOF cohort may provide some guidance to address this question, but additional studies are likely to be needed also. Second, a more detailed economic evaluation should be performed. A future economic evaluation should, at a minimum, use QALY as an outcome measure, include lifetime costs and benefits, and target other age groups in addition to the elderly. Also, if such an economic evaluation can include other risk factors, the cost per hip fracture prevented for these diagnostic approaches is likely to decrease. Third, research should evaluate whether or not the treatment-related reduction in risk of hip fracture is the same in a woman diagnosed with QUS alone as in one diagnosed with DXA-FN alone. Fourth, a randomized clinical trial that compares a sequential diagnostic approach to diagnosis with DXA-FN alone would be useful. Women would be randomly allocated to one or the other of the two diagnostic approaches and treated if diagnosed to be at high risk. This study would require agreed-upon QUS/BUA cut points.

### Overall Conclusion

Overall, the sequential diagnostic approach may provide a cost-effective alternative to diagnosis with DXA-FN alone. Further, in a population with a much higher overall fracture risk than SOF, QUS alone may also be cost-effective. However, the results for diagnosis with QUS alone are sensitive to any reduction in efficacy following diagnosis with QUS. As diagnostic tools such as QUS become more readily available in the primary care setting, research that provides guidance to clinicians as to the best use of such tools is required. Based on the conclusion of the simple model presented here, use of QUS either for diagnosis of osteoporosis or to determine which women should receive DXA-FN may be appropriate and cost-effective.

Figure S2-1. Decision tree used in economic comparison among diagnosis with DXA alone, sequential diagnosis (QUS followed by DXA only in those below QUS/BUA cut point), and diagnosis with QUS/BUA alone

DXA = Dual-energy X-ray absorptiometry

QUS = Quantitative ultrasound

DXA = Dual-energy X-ray absorptiometry

Figure S2-2. Comparison of three treatment alternatives. Population is divided into four groups (all combinations of DXA <-2.5 or DXA >-2.5 and QUS < cut point or QUS > cut point). Shaded cells are those diagnosed as osteoporotic by each diagnostic approach

QUS = Quantitative ultrasound

DXA = Dual-energy X-ray absorptiometry

Figure S2-3. Summary of base case economic evaluation when osteoporotic women are treated with alendronate^*^ * Cost per hip fracture prevented (excluding dominated scenarios), total direct medical costs and number of fractures prevented, for various QUS/BUA cut points

BUA = Broad band ultrasound attenuation

QUS = Quantitative ultrasound

BUA = Broad band ultrasound attenuation

Figure S2-4. Summary of base case economic evaluation when osteoporotic women are treated with HRT^*^ * Cost per hip fracture prevented (excluding dominated scenarios), total direct medical costs and number of fractures prevented, for various QUS/BUA cut points

DXA = Dual-energy X-ray absorptiometry

QUS = Quantitative ultrasound

BUA = Broadband ultrasound attenuation

Figure S2-5. Sensitivity analyses for HRT cost when osteoporotic women are treated with HRT^*^ * Cost per hip fracture prevented (excluding dominated scenarios) for QUS/BUA cut points for which there are substantive differences between low HRT cost ($957) and high HRT costs ($1,633)

HRT=Hormone replacement therapy

DXA=dual-energy X-ray absorptiometry

QUS=quantitative ultrasound

BUA=broadband ultrasound attenuation

Figure S2-6. Sensitivity analyses for DXA cost when osteoporotic women are treated with HRT^*^ * Cost per hip fracture prevented (excluding dominated scenarios) for QUS/BUA cut points for which there are substantive differences between low DXA cost ($99) and high DXA costs ($183)

HRT=Hormone replacement therapy

DXA=dual-energy X-ray absorptiometry

QUS=quantitative ultrasound

BUA=broadband ultrasound attenuation

Table S2-1. Summary of three diagnostic approaches (DXA alone, QUS alone, and Sequential) compared in this economic evaluation

Approach | Step 1 | Result | Step 2 | Result | Treat
DXA-FN | DXA-FN | High Risk | | | Yes
DXA-FN | DXA-FN | Low Risk | | | No
QUS | QUS | High Risk | | | Yes
QUS | QUS | Low Risk | | | No
Sequential | QUS | High Risk | DXA-FN | High Risk | Yes
Sequential | QUS | | | Low Risk | No
Sequential | QUS | Low Risk | | | No

DXA-FN = Dual-energy X-ray absorptiometry

QUS = Quantitative ultrasound

Table S2-2. Table of parameters (base case and values for sensitivity analyses) used in cost-effectiveness analyses

Parameter | Base case | Lower value | Upper value | Source
Time horizon | 2 years | N/A | N/A | Hans (1996)^ 2 ^ and Bauer (1997)^ 3 ^
Fracture risk reduction with treatment: alendronate | 50% | 25% | 75% | NOF (1998)^ 5 ^
Fracture risk reduction with treatment: HRT | 25% | 15% | 50% | NOF (1998)^ 5 ^
Fracture risk reduction with treatment: calcium/vitamin D | 10% | 1% | 20% | NOF (1998)^ 5 ^
Multiplier of overall fracture risk | 100% | 50% | 100% | hypothetical range
Reduction in efficacy (fracture rate reduction) following diagnosis with QUS alone | 100% | 70% | 100% | hypothetical range
Cost of DXA-FN test | $133 | $99 | $183 | HFCA, (2000)^ 6 ^
Cost of QUS test | $34 | $54 | $30 | HFCA, (2000)^ 6 ^
Cost of fractures | $22,130 | $15,461 | $28,768 | U.S. Congress, OTA (1994)^ 7 ^
Cost of treatment: alendronate treatment (using EPIDOS mean age) | $1,632.75 | $1,142.93 | $2,122.58 | NOF (1998)^ 5 ^
Cost of treatment: alendronate treatment (using SOF mean age) | $1,646.27 | $1,152.39 | $2,140.16 | NOF (1998)^ 5 ^
Cost of treatment: HRT (using EPIDOS mean age) | $948.76 | $664.13 | $1,233.39 | NOF (1998)^ 5 ^
Cost of treatment: HRT (using SOF mean age) | $956.62 | $669.63 | $1,243.60 | NOF (1998)^ 5 ^
Cost of treatment: calcium/vitamin D treatment (using EPIDOS mean age) | $110.32 | $77.22 | $143.42 | NOF (1998)^ 5 ^
Cost of treatment: calcium/vitamin D treatment (using SOF mean age) | $111.23 | $77.86 | $144.61 | NOF (1998)^ 5 ^
Discount rate (treatment only) | 3% | N/A | N/A | Gold (1996)^ 10 ^

DXA-FN = Dual-energy X-ray absorptiometry of the femoral neck

QUS = Quantitative ultrasound

SOF = Study of Osteoporotic Fractures

HRT = Hormone replacement therapy

EPIDOS = Epidemiologie de l'Osteoporose

NOF = National Osteoporosis Foundation

HCFA = Health Care Financing Administration

OTA = Office of Technology Assessment

Table S2-3. Percentages diagnosed as osteoporotic (and therefore treated) in EPIDOS and SOF cohorts*

Cohort | QUS cut point | Percentage diagnosed as osteoporotic
Cohort | QUS cut point | DXA-FN alone | QUS alone | Sequential approach
EPIDOS | 100.9 dB/MHz | 49.4% | 49.2% | 31.2%
SOF | 50 dB/MHz | 28.1% | 16.3% | 9.4%
SOF | 55 dB/MHz | 28.1% | 26.4% | 13.3%
SOF | 60 dB/MHz | 28.1% | 37.3% | 16.8%
SOF | 65 dB/MHz | 28.1% | 49.2% | 19.9%
SOF | 70 dB/MHz | 28.1% | 60.5% | 22.2%
SOF | 75 dB/MHz | 28.1% | 71.3% | 24.3%
SOF | 80 dB/MHz | 28.1% | 80.3% | 25.7%
SOF | 85 dB/MHz | 28.1% | 86.9% | 26.6%

DXA-FN = Dual-energy X-ray absorptiometry of the femoral neck

QUS = Quantitative ultrasound

SOF = Study of Osteoporotic Fractures

EPIDOS = Epidemiologie de l'Osteoporose

2 Data from EPIDOS and SOF^4^

*For the SOF cohort, percentages at high risk of fracture are estimated for eight QUS/BUA cut points

Table S2-4. Fracture rates from EPIDOS comparison of DXA-FN and QUS*

Test 1 | Risk assessed | Test 2 | Risk assessed | Number of fractures | Number at risk | Fracture rate
DXA-FN | high | | | 93 | 2,735 | 0.0340
DXA-FN | low | | | 22 | 2,806 | 0.0078
QUS | high | | | 80 | 2,725 | 0.0294
QUS | low | | | 35 | 2,816 | 0.0124
DXA-FN | high | QUS | high | 68 | 1,730 | 0.0393
DXA-FN | high | QUS | low | 25 | 1,005 | 0.0249
DXA-FN | low | QUS | high | 12 | 995 | 0.0121
DXA-FN | low | QUS | low | 10 | 1,811 | 0.0055

DXA-FN = Dual-energy X-ray absorptiometry of the femoral neck

QUS = Quantitative ultrasound

EPIDOS = Epidemiologie de l'Osteoporose

2 *Risk is based on cut points defined by authors and described in text of this report. Hans (1996)

Table S2-5. Summary of base case cost-effectiveness analysis using data from EPIDOS cohort

Treatment | Parameter | Lowest total cost | Intermediate total cost | Highest total cost
Alendronate | Diagnostic approach | Sequential | QUS alone | DXA alone
Alendronate | Total cost | $441,590 | $635,284 | $702,562
Alendronate | Hip fractures prevented | 5.67 | 6.67 | 7.76
Alendronate | Incremental cost-effectiveness ratio | $77,837 | Dominated (extended) | $125,121
HRT | Diagnostic approach | Sequential | QUS alone | DXA alone
HRT | Total cost | $305,283 | $392,555 | $473,684
HRT | Hip fractures prevented | 2.84 | 3.34 | 3.88
HRT | Incremental cost-effectiveness ratio | $101,621 | Dominated (extended) | $161,476
Calcium /Vitamin D | Diagnostic approach | QUS alone | Sequential | DXA alone
Calcium /Vitamin D | Total cost | $52,470 | $98,909 | $139,389
Calcium /Vitamin D | Hip fractures prevented | 1.335 | 1.13 | 1.55
Calcium /Vitamin D | Incremental cost-effectiveness ratio | $39,307 | Dominated | $400,694

DXA = Dual-energy X-ray absorptiometry

QUS = Quantitative ultrasound

EPIDOS = Epidemiologie de l'Osteoporose

Table S2-6. Fracture rates from SOF comparison of DXA and QUS*1

QUS/BUA cut point (dB/MHz ^2^ ) | Test 1 | Risk assessed | Test 2 | Risk assessed | Number of fractures | Number at risk | Fracture rate
| DXA-FN | high | | | 35 | 1,686 | 0.0208
| DXA-FN | low | | | 19 | 4,307 | 0.0044
50 | QUS | high | | | 22 | 979 | 0.0225
50 | QUS | low | | | 32 | 5,014 | 0.0064
50 | DXA-FN | high | QUS | high | 18 | 563 | 0.0320
50 | DXA-FN | high | QUS | low | 17 | 1,123 | 0.0151
50 | DXA-FN | low | QUS | high | 4 | 416 | 0.0096
50 | DXA-FN | low | QUS | low | 15 | 3,891 | 0.0039
55 | QUS | high | | | 27 | 1,580 | 0.01709
55 | QUS | low | | | 27 | 4,413 | 0.0061
55 | DXA-FN | high | QUS | high | 21 | 798 | 0.0263
55 | DXA-FN | high | QUS | low | 14 | 888 | 0.0158
55 | DXA-FN | low | QUS | high | 6 | 782 | 0.0077
55 | DXA-FN | low | QUS | low | 13 | 3,525 | 0.0037
60 | QUS | high | | | 32 | 2,234 | 0.0143
60 | QUS | low | | | 22 | 3,759 | 0.0059
60 | DXA-FN | high | QUS | high | 25 | 1,004 | 0.0249
60 | DXA-FN | high | QUS | low | 10 | 682 | 0.0147
60 | DXA-FN | low | QUS | high | 7 | 1,230 | 0.0057
60 | DXA-FN | low | QUS | low | 12 | 3,077 | 0.0039
65 | QUS | high | | | 36 | 2,949 | 0.0122
65 | QUS | low | | | 18 | 3,044 | 0.0059
65 | DXA-FN | high | QUS | high | 28 | 1,190 | 0.0235
65 | DXA-FN | high | QUS | low | 7 | 496 | 0.0141
65 | DXA-FN | low | QUS | high | 8 | 1,759 | 0.0045
65 | DXA-FN | low | QUS | low | 11 | 2,548 | 0.0043
70 | QUS | high | | | 40 | 3,627 | 0.0110
70 | QUS | low | | | 14 | 2,366 | 0.0059
70 | DXA-FN | high | QUS | high | 30 | 1,332 | 0.0225
70 | DXA-FN | high | QUS | low | 5 | 354 | 0.0141
70 | DXA-FN | low | QUS | high | 10 | 2,295 | 0.0044
70 | DXA-FN | low | QUS | low | 9 | 2,012 | 0.0045
75 | QUS | high | | | 48 | 4,272 | 0.0112
75 | QUS | low | | | 6 | 1,721 | 0.0035
75 | DXA-FN | high | QUS | high | 34 | 1,458 | 0.0233
75 | DXA-FN | high | QUS | low | 1 | 228 | 0.0044
75 | DXA-FN | low | QUS | high | 14 | 2,814 | 0.0050
75 | DXA-FN | low | QUS | low | 5 | 1,493 | 0.0033
80 | QUS | high | | | 53 | 4,812 | 0.0110
80 | QUS | low | | | 1 | 1,181 | 0.0008
80 | DXA-FN | high | QUS | high | 35 | 1,541 | 0.0227
80 | DXA-FN | high | QUS | low | 0 | 145 | 0
80 | DXA-FN | low | QUS | high | 18 | 3,271 | 0.0055
80 | DXA-FN | low | QUS | low | 1 | 1,036 | 0.0010
85 | QUS | high | | | 54 | 5,207 | 0.0104
85 | QUS | low | | | 0 | 786 | 0
85 | DXA-FN | high | QUS | high | 35 | 1,594 | 0.0220
85 | DXA-FN | high | QUS | low | 0 | 92 | 0
85 | DXA-FN | low | QUS | high | 19 | 3,613 | 0.0053
85 | DXA-FN | low | QUS | low | 0 | 694 | 0

DXA-FN = Dual-energy X-ray absorptiometry of the femoral neck

QUS = Quantitative ultrasound

SOF = Study of Osteoporotic Fractures

BUA = Broadband ultrasound attenuation

4 *Bauer (2000)

1 Risk is based on cut points defined by authors and described in text of this report.

2 dB/MHz = decibels/mega-hertz

Appendix S2-1. Summary of base case cost-effectiveness analyses using fracture rate data from SOF cohort (results presented by treatment and QUS/BUA cut point)

Treatment | QUS/BUA Cut Point | Parameter | Lowest Total Cost | Intermediate Total Cost | Highest Total Cost
alendronate | 50 db/MHz | Diagnostic Approach | Sequential | QUS alone | DXA alone
alendronate | 50 db/MHz | Total Cost | $177,148 | $262,311 | $531,521
alendronate | 50 db/MHz | Hip Fractures Prevented | 1.5 | 1.84 | 2.92
alendronate | 50 db/MHz | Incremental Cost-Effectiveness Ratio | $117,961 | Dominated (extended) | $249,854
alendronate | 55 db/MHz | Diagnostic Approach | Sequential | QUS alone | DXA alone
alendronate | 55 db/MHz | Total Cost | $249,501 | $418,173 | $531,521
alendronate | 55 db/MHz | Hip Fractures Prevented | 1.75 | 2.25 | 2.92
alendronate | 55 db/MHz | Incremental Cost-Effectiveness Ratio | $142,406 | Dominated (extended) | $241,449
alendronate | 60 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
alendronate | 60 db/MHz | Total Cost | $313,218 | $531,521 | $588,595
alendronate | 60 db/MHz | Hip Fractures Prevented | 2.09 | 2.92 | 2.67
alendronate | 60 db/MHz | Incremental Cost-Effectiveness Ratio | $150,169 | $261,658 | Dominated
alendronate | 65 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
alendronate | 65 db/MHz | Total Cost | $374,640 | $531,521 | $777,619
alendronate | 65 db/MHz | Hip Fractures Prevented | 2.34 | 2.92 | 3
alendronate | 65 db/MHz | Incremental Cost-Effectiveness Ratio | $160,373 | $268,624 | $2,949,734
alendronate | 70 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
alendronate | 70 db/MHz | Total Cost | $425,002 | $531,521 | $956,480
alendronate | 70 db/MHz | Hip Fractures Prevented | 2.5 | 2.92 | 3.34
alendronate | 70 db/MHz | Incremental Cost-Effectiveness Ratio | $169,802 | $255,348 | $1,018,711
alendronate | 75 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
alendronate | 75 db/MHz | Total Cost | $466,543 | $531,521 | $1,118,890
alendronate | 75 db/MHz | Hip Fractures Prevented | 2.84 | 2.92 | 4
alendronate | 75 db/MHz | Incremental Cost-Effectiveness Ratio | $164,470 | Dominated (extended) | $558,503
alendronate | 80 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
alendronate | 80 db/MHz | Total Cost | $499,480 | $531,521 | $1,257,996
alendronate | 80 db/MHz | Hip Fractures Prevented | 2.92 | 2.92 | 4.42
alendronate | 80 db/MHz | Incremental Cost-Effectiveness Ratio | $171,051 | Dominated | $505,087
alendronate | 85 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
alendronate | 85 db/MHz | Total Cost | $522,805 | $531,521 | $1,364,655
alendronate | 85 db/MHz | Hip Fractures Prevented | 2.92 | 2.92 | 4.51
alendronate | 85 db/MHz | Incremental Cost-Effectiveness Ratio | $179,038 | Dominated | $531,074
HRT | 50 db/MHz | Diagnostic Approach | Sequential | QUS alone | DXA alone
HRT | 50 db/MHz | Total Cost | $128,977 | $169,961 | $369,814
HRT | 50 db/MHz | Hip Fractures Prevented | 0.75 | 0.92 | 1.46
HRT | 50 db/MHz | Incremental Cost-Effectiveness Ratio | $171,769 | $245,617 | $368,528
HRT | 55 db/MHz | Diagnostic Approach | Sequential | QUS alone | DXA alone
HRT | 55 db/MHz | Total Cost | $177,057 | $261,279 | $369,814
HRT | 55 db/MHz | Hip Fractures Prevented | 0.88 | 1.13 | 1.46
HRT | 55 db/MHz | Incremental Cost-Effectiveness Ratio | $202,115 | Dominated (extended) | $330,054
HRT | 60 db/MHz | Diagnostic Approach | Sequential | QUS alone | DXA alone
HRT | 60 db/MHz | Total Cost | $220,761 | $361,056 | $369,814
HRT | 60 db/MHz | Hip Fractures Prevented | 1.04 | 1.33 | 1.46
HRT | 60 db/MHz | Incremental Cost-Effectiveness Ratio | $211,683 | Dominated (extended) | $357,310
HRT | 65 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
HRT | 65 db/MHz | Total Cost | $263,549 | $369,814 | $471,494
HRT | 65 db/MHz | Hip Fractures Prevented | 1.17 | 1.46 | 1.5
HRT | 65 db/MHz | Incremental Cost-Effectiveness Ratio | $225,635 | $363,912 | $2,437,486
HRT | 70 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
HRT | 70 db/MHz | Total Cost | $299,415 | $369,814 | $576,026
HRT | 70 db/MHz | Hip Fractures Prevented | 1.25 | 1.46 | 1.67
HRT | 70 db/MHz | Incremental Cost-Effectiveness Ratio | $239,253 | $337,518 | $988,664
HRT | 75 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
HRT | 75 db/MHz | Total Cost | $330,149 | $369,814 | $671,597
HRT | 75 db/MHz | Hip Fractures Prevented | 1.42 | 1.46 | 2
HRT | 75 db/MHz | Incremental Cost-Effectiveness Ratio | $232,775 | Dominated (extended) | $584,656
HRT | 80 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
HRT | 80 db/MHz | Total Cost | $354,459 | $369,814 | $753,178
HRT | 80 db/MHz | Hip Fractures Prevented | 1.46 | 1.46 | 2.21
HRT | 80 db/MHz | Incremental Cost-Effectiveness Ratio | $242,774 | Dominated | $531,005
HRT | 85 db/MHz | Diagnostic Approach | Sequential | DXA alone | QUS alone
HRT | 85 db/MHz | Total Cost | $369,814 | $371,685 | $815,306
HRT | 85 db/MHz | Hip Fractures Prevented | 1.46 | 1.46 | 2.25
HRT | 85 db/MHz | Incremental Cost-Effectiveness Ratio | $253,291 | Dominated | $562,070
cal_vitD | 50 db/MHz | Diagnostic Approach | QUS alone | Sequential | DXA alone
cal_vitD | 50 db/MHz | Total Cost | $44,046 | $59,529 | $151,368
cal_vitD | 50 db/MHz | Hip Fractures Prevented | 0.37 | 0.3 | 0.58
cal_vitD | 50 db/MHz | Incremental Cost-Effectiveness Ratio | $119,986 | Dominated | $494,752
cal_vitD | 55 db/MHz | Diagnostic Approach | QUS alone | Sequential | DXA alone
cal_vitD | 55 db/MHz | Total Cost | $53,355 | $76,121 | $151,368
cal_vitD | 55 db/MHz | Hip Fractures Prevented | 0.45 | 0.35 | 0.58
cal_vitD | 55 db/MHz | Incremental Cost-Effectiveness Ratio | $118,428 | Dominated | $734,242
cal_vitD | 60 db/MHz | Diagnostic Approach | QUS alone | Sequential | DXA alone
cal_vitD | 60 db/MHz | Total Cost | $63,647 | $92,981 | $151,368
cal_vitD | 60 db/MHz | Hip Fractures Prevented | 0.53 | 0.42 | 0.58
cal_vitD | 60 db/MHz | Incremental Cost-Effectiveness Ratio | $119,198 | Dominated | $1,752,380
cal_vitD | 65 db/MHz | Diagnostic Approach | QUS alone | Sequential | DXA alone
cal_vitD | 65 db/MHz | Total Cost | $75,440 | $111,193 | $151,368
cal_vitD | 65 db/MHz | Hip Fractures Prevented | 0.6 | 0.47 | 0.58
cal_vitD | 65 db/MHz | Incremental Cost-Effectiveness Ratio | $125,586 | Dominated | Dominated
cal_vitD | 70 db/MHz | Diagnostic Approach | QUS alone | Sequential | DXA alone
cal_vitD | 70 db/MHz | Total Cost | $86,547 | $128,136 | $151,368
cal_vitD | 70 db/MHz | Hip Fractures Prevented | 0.67 | 0.5 | 0.58
cal_vitD | 70 db/MHz | Incremental Cost-Effectiveness Ratio | $129,668 | Dominated | Dominated
cal_vitD | 75 dB/MHz | Diagnostic Approach | QUS alone | Sequential | DXA alone
cal_vitD | 75 dB/MHz | Total Cost | $95,564 | $143,312 | $151,368
cal_vitD | 75 dB/MHz | Hip Fractures Prevented | 0.8 | 0.57 | 0.58
cal_vitD | 75 dB/MHz | Incremental Cost-Effectiveness Ratio | $119,315 | Dominated | Dominated
cal_vitD | 80 db/MHz | Diagnostic Approach | QUS alone | DXA alone | Sequential
cal_vitD | 80 db/MHz | Total Cost | $103,740 | $151,368 | $156,467
cal_vitD | 80 db/MHz | Hip Fractures Prevented | 0.88 | 0.58 | 0.58
cal_vitD | 80 db/MHz | Incremental Cost-Effectiveness Ratio | $117,304 | Dominated | Dominated
cal_vitD | 85 db/MHz | Diagnostic Approach | QUS alone | DXA alone | Sequential
cal_vitD | 85 db/MHz | Total Cost | $110,702 | $151,368 | $166,217
cal_vitD | 85 db/MHz | Hip Fractures Prevented | 0.9 | 0.58 | 0.58
cal_vitD | 85 db/MHz | Incremental Cost-Effectiveness Ratio | $122,858 | Dominated | Dominated

DXA-FN = Dual-energy X-ray absorptiometry of the femoral neck

QUS = Quantitative ultrasound

SOF = Study of Osteoporotic Fractures

HRT = Hormone replacement therapy

BUA = Broadband ultrasound attenuation

dB/MHz = decibels/mega-hertz

## References

1 Assessment of fracture risk and its application to screening for postmenopausal osteoporosis. WHO Technical Report Series 843. Geneva: World Health Organization; 1994.
2 Hans D, Dargent-Molina P, Schott AM, et al Ultrasonographic heel measurements to predict hip fracture in elderly women: the EPIDOS prospective study Lancet 1996 348(9026):511 4 8757153
3 Bauer DC, Gluer CC, Cauley JA, et al Broadband ultrasound attenuation predicts fractures strongly and independently of densitometry in older women. A prospective study. Study of Osteoporotic Fractures Research Group Arch Intern Med 1997 157(6):629 34 9080917
4 Osteoporosis: Review of the evidence for prevention, diagnosis, and treatment and cost-effectiveness analysis Osteoporos Int 1998Suppl 4:S7 S88
5 Bauer DC. Personal communication; 2000.
6 National Physician Fee Schedule Payment Amount File; 2000.
7 Hip fracture outcomes in people age 50 and over. Background paper. Washington, DC: U.S. Government Printing Office; 1994. Report No.: OTA-BP-H-120.
8 Survey of current business. Monthly reports for January 1995-August 1999. Washington, DC: U.S. Government Printing Office; 1999.
9 United States Life Tables; 1997.
10 Gold MR, Siegel JE, Russell LB, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.