# Evidence Tables

Evidence Table 1. Risk factors for hip fracture: studies reporting multiple factors

Author/yr | Study design | Population | N | Mean age | Outcome | Predictors studied | Statistical models | Significant predictors in multivariate | RR or OR | Quality ^a^
Cummings (1995)^ 54 ^ | Prospective (ave. 4.1 years followup) | Community-dwelling U.S. white women age 65 and over without previous hip fractures (Study of Osteoporotic Fractures) | 9,516 | 72 | Hip fracture assessed 4-month intervals and validated by X-rays (n=192) | Significant predictors in multivariate models (next page) Significant predictors in age-adjusted models only: current smoking, alcohol use, current thyroid therapy, functional-status score, fall in the previous year, gait speed, current weight Not significant in age-adjusted models: hair color, North vs South European ancestry, maternal fracture other than hip, children breast-fed, natural menopause before age 45, bilateral oophorectomy, past smoking, calcium intake, osteoarthritis, cataracts, short-acting benzo, aluminum antacid, estrogen use, thiazide use, current height, Modified Mini-Mental State score, poor vision, orthostatic hypotension | Multivariable models based on proportional-hazards analysis with backwards stepwise elimination model tested with and without adding history of fracture and calcaneal bone density Use of anticonvulsant drugs becomes nonsignificant when using full model* | | Relative Risk (CI) | Good
Cummings (1995)^ 54 ^ | Prospective (ave. 4.1 years followup) | Community-dwelling U.S. white women age 65 and over without previous hip fractures (Study of Osteoporotic Fractures) | 9,516 | 72 | Hip fracture assessed 4-month intervals and validated by X-rays (n=192) | | | Age (per 5 years) History of maternal hip fracture Increase in weight since age 25 (per 20%) Height at age 25 (per 6 cm) Self-rated health (per 1-point decrease) Previous hyperthyroidism Current use of long-acting benzo Current use of anticonvulsant drugs Current caffeine intake (per 190 mg/day) Walking for exercise On feet <=4 hrs/day Inability to rise from a chair Lowest quartile for distant depth percept Low-freq contrast sens (per 1 SD decr) Resting pulse rate >80 beats/min. Any fracture since age 50 Calcaneal BMD (per 1 SD decrease) | 1.4 (1.2-1.6) 1.8 (1.2-2.7) 0.8 (0.6-0.9) 1.3 (1.1-1.5) 1.6 (1.2-2.1) 1.7 (1.2-2.5) 1.6 (1.1-2.4) 2.0 (0.8-4.9)* 1.2 (1.0-1.5) 0.7 (0.5-1.0) 1.7 (1.2-2.4) 1.7 (1.1-2.7) 1.4 (1.0-1.5) 1.2 (1.0-1.5) 1.7 (1.2-2.4) 1.5 (1.1-2.0) 1.6 (1.3-1.9) | Good
Graafmans (1996)^ 58 ^ | Prospective (median 3.5 years followup) | Non-nursing home elderly age 70 and older in Amsterdam | 1,916 | | Hip fracture reported by subject's practitioner based on X-rays (n=93 for women; 149/1,000 person-yrs) | Age, gender, mobility, frequency of going outdoors | Multivariable models based on proportional-hazards analysis with backwards stepwise elimination (p<0.01) All variables in next column were included in adjusted models | | Relative Risk (CI) | Good
Graafmans (1996)^ 58 ^ | Prospective (median 3.5 years followup) | Results for women reported separately from men | 74% female | | Hip fracture reported by subject's practitioner based on X-rays (n=93 for women; 149/1,000 person-yrs) | Age, gender, mobility, frequency of going outdoors | Multivariable models based on proportional-hazards analysis with backwards stepwise elimination (p<0.01) All variables in next column were included in adjusted models | Age (per 5 years) 70-75 >75-80 >80-85 >85 | 1.0 1.9 (0.8-4.7) 3.5 (1.5-8.2) 5.3 (2.2-12.8) | Good
Graafmans (1996)^ 58 ^ | Prospective (median 3.5 years followup) | Results for women reported separately from men | 74% female | | Hip fracture reported by subject's practitioner based on X-rays (n=93 for women; 149/1,000 person-yrs) | Age, gender, mobility, frequency of going outdoors | Multivariable models based on proportional-hazards analysis with backwards stepwise elimination (p<0.01) All variables in next column were included in adjusted models | Female gender Mobility: 2 (moderately impaired) 1 (severely impaired) | 1.9 (1.0-3.4) 1.8 (1.1-2.8) | Good
Graafmans (1996)^ 58 ^ | Prospective (median 3.5 years followup) | Results for women reported separately from men | 74% female | | Hip fracture reported by subject's practitioner based on X-rays (n=93 for women; 149/1,000 person-yrs) | Age, gender, mobility, frequency of going outdoors | Multivariable models based on proportional-hazards analysis with backwards stepwise elimination (p<0.01) All variables in next column were included in adjusted models | Outdoor score: 3 (>=3 times/weekly) 2 (1 or 2 times/week) 1 (<1 time/week) | 1.7 (0.9-3.5) 1.0 1.0 (0.6-1.7) | Good
Graafmans (1996)^ 58 ^ | Prospective (median 3.5 years followup) | Results for women reported separately from men | 74% female | | Hip fracture reported by subject's practitioner based on X-rays (n=93 for women; 149/1,000 person-yrs) | Age, gender, mobility, frequency of going outdoors | Multivariable models based on proportional-hazards analysis with backwards stepwise elimination (p<0.01) All variables in next column were included in adjusted models | Residence: | 0.5 (0.3-0.9) | Good
Fujiwara (1997)^ 72 ^ | Prospective | Subjects of Adult Health Study in Japan examined in 1978-80 and followed until 1992 Results for women reported separately from men | 2,987 | 58.6 yrs at baseline | Hip fracture diagnosed by physician and validated by charts and X-rays (n=49) | Age, BMI, milk intake, alcohol use, age of menarche, number of children, vertebral fracture, self-rated health, marital status, food preference, tofu intake, fish, coffee, tea, smoking, exposure to atomic-bomb radiation, baseline diseases | Mulivariable models based on Poisson regression included variables age, BMI, milk intake, alcohol intake, age at menarche, parity, vertebral fracture | Age (per 5 years) Low BMI (kg/m2) Regular alcohol use Vertebral fracture 5 or more children | Relative Risk (CI) 1.7 (1.4-2.0) 1.1 (1.0-1.2) 1.4 (1.3-4.4) 2.1 (1.0-4.1) 2.5 (1.1-6.7) | Good
Meyer (1993)^ 77 ^ | Prospective (ave. followup 10.9 years) | Women who attended a cardiovascular screening during 1974-78 when age 35-49 were followed until 1990 for hip fracture | 25,298 | | Hospital information about hip fractures identified cases (n=177; 5.23/10,000 person-yrs) | Variables on next page as well as menopause status | Multivariate models based on Cox proportional hazard regression Variables in model include age, height, BMI, diabetes, disability status, marital status, physical activity at work (not sedentary/sedentary), physical activity leisure (not sedentary/sedentary), cerebral stroke (yes/no), smoking status, number of cigarettes/day | Age (per 5 years) Height (per 0.1 m) BMI in kg/m2 (per 10) Diabetes mellitus (yes/no) Disability pension (yes/no) Unmarried (vs others) | Relative Risk (CI) 1.94 (1.55-2.42) 1.58 (1.18-2.12) 0.58 (0.36-0.92) 9.17 (3.38-24.92) 3.79 (2.15-6.68) 2.16 (1.28-3.64) | Good
Wolinsky (1994)^ 88 ^ | Prospective | Men and women respondents to the Longitudinal Study on Aging (LSOA) in the U.S. | 7,527 | | Hip fracture between 1984-91 (n=368; 4.9%) | Kin social supports; perceived health status; walking up 10 steps; sitting for 2 hours; stooping, crouching, or kneeling; shaking hands; using fingers to grasp; ever had osteoporosis; ever had a stroke; ever had arthritis; and variables in regression model (next column) | Multivariate models based on hierarchical logistic regression Variables in model include rural residence, southern residence, age, female gender, white race, lives alone, non-kin social supports, hospitalized in year prior to baseline, visual problems, hearing problems, dizziness, walking 1/4 mile, standing for 2 hours, reaching over the head, carrying 25 pounds, ever had diabetes, fell in year prior to baseline, body mass, had a hip fracture prior to baseline | Age Female gender White race Hospitalized in year prior to baseline Fell in year prior to baseline Body mass | Odds Ratios (p) 1.1 (0.0001) 2.0 (0.0001) 2.6 (0.002) 1.3 (0.05) 1.4 (0.007) 0.95 (0.0002) | Good
Jacqmin-Gadda (1998)^ 245 ^ | Prospective (5-year followup) | Men and women >=65 years living in the community in SW France | 3,216 57.90% female | 74.8 years | Hip fracture requiring hospitalization and confirmed by physician; 5.2/1,000 person-yrs. | Age, sex, weight, height, tobacco consumption, current participation in sports, profession, visual and auditory impairment, medication use, fluoride content of water | Logistic regression analysis | Age over 85 years Female sex Daily alcohol consumption Antidepressant use Anxiolytic use Fluoride level 0.11-0.25 mg/liter | Odds Ratios (CI) 9.9 (5.10-19.2) 1.93 (1.01-3.68) 5.41 (1.78-16.4) 2.53 (1.05-6.12) 2.25 (1.31-3.88) 2.43 (1.11-5.33) | Good
Grisso (1991)^ 89 ^ | Case-control | Women admitted with a first hip fracture to study hospitals in New York and Philadelphia | 174 cases | Median 80 years | Hip fracture during 1987-89 supported by hospital records | Included in model | Conditional logistic regression models with the patient's hospital as the conditional variable, and controlled for age, estrogen use, use of thiazide diuretics, smoking, number of chronic illnesses, moderate cognitive impairment, lower-extremity dysfunction, loss of distant vision, previous stroke, and BMI | | Odds Ratio (CI) | Good
Grisso (1991)^ 89 ^ | Case-control | Controls were matched by age and hospital and selected from general surgical or orthopedic surgical services during 1987-89 Information was obtained by interview | 174 controls | Median 80 years | Hip fracture during 1987-89 supported by hospital records | Included in model | | Loss of distant vision | 4.8 (1.4-16.2) | Good
Grisso (1991)^ 89 ^ | Case-control | Controls were matched by age and hospital and selected from general surgical or orthopedic surgical services during 1987-89 Information was obtained by interview | 174 controls | Median 80 years | Hip fracture during 1987-89 supported by hospital records | Included in model | | Previous stroke | 4.6 (1.5-13.5) | Good
Grisso (1991)^ 89 ^ | Case-control | Controls were matched by age and hospital and selected from general surgical or orthopedic surgical services during 1987-89 Information was obtained by interview | 174 controls | Median 80 years | Hip fracture during 1987-89 supported by hospital records | Included in model | | BMI (kg/m2) in quintiles Lowest Second Third Fourth Highest | 1.0 0.6 (0.3-1.2) 0.4 (0.2-0.9) 0.2 (0.1-0.4) 0.2 (0.1-0.5) | Good
Grisso (1994)^ 71 ^ | Case-control | Black women admitted with a first hip fracture to study hospitals in New York and Philadelphia | 144 cases | | Hip fractures were confirmed by 1 of 30 study hospitals during 1987-98 | BMI, estrogen therapy lasting >=1 year, years since last estrogen therapy, duration of estrogen therapy, alcohol consumed in the past year (drinks/wk), thiazide diuretic use, smoking (none, former, current; <1 pack/day; >=1 pack/day; use before or after menopause), nulliparity, presence of disease or disability, use of psychotropic drugs, number of chronic illnesses | Conditional logistic-regression models controlled for age, zip code, or telephone exchange, number of chronic diseases, BMI, estrogen therapy lasting >=1 year, alcohol consumed in the past year (drinks/wk), history of stroke, and use of ambulatory aids | | Odds Ratio (CI) | Good
Grisso (1994)^ 71 ^ | Case-control | Controls were obtained from the community and matched by age and zip code or telephone exchange and from a hospital population matched by age and hospital | 218 community controls | | Hip fractures were confirmed by 1 of 30 study hospitals during 1987-98 | | | BMI (kg/m2) in quintiles <=22.6 22.7-24.4 24.5-27.2 27.3-31.5 >=31.6 | 13.5 (4.2-43.3) 4.2 (1.3-14.0) 3.5 (1.2-10.3) 1.5 (0.4-5.3) 1.0 | Good
Grisso (1994)^ 71 ^ | Case-control | Information was collected by interviews | 181 hospital controls | | Hip fractures were confirmed by 1 of 30 study hospitals during 1987-98 | | | Estrogen therapy lasting >=1 year Women < 75 years old Women >75 years old | 0.1 (<0.1-0.5) 1.1 (0.2-6.3) | Good
Grisso (1994)^ 71 ^ | Case-control | Information was collected by interviews | 181 hospital controls | | Hip fractures were confirmed by 1 of 30 study hospitals during 1987-98 | | | Alcohol consumed, past year (dr/wk) <=1 2-6 >=7 | 1.0 2.0 (0.8-5.0) 4.6 (1.5-14.1) | Good
Grisso (1994)^ 71 ^ | Case-control | Information was collected by interviews | 181 hospital controls | | Hip fractures were confirmed by 1 of 30 study hospitals during 1987-98 | | | History of stroke (vs none) | 3.1 (1.2-8.1) | Good
Grisso (1994)^ 71 ^ | Case-control | Information was collected by interviews | 181 hospital controls | | Hip fractures were confirmed by 1 of 30 study hospitals during 1987-98 | | | Use of ambulatory aids (vs none) | 5.6 (2.7-11.5) | Good
Cumming (1994)^ 192 ^ | Case-control | Women 65 years or older living in Sydney, Australia during 1990-91 | 174 cases | | Hip fracture diagnosed by physician and identified by hospital admissions data during the study period | Smoking status; cigarettes per day; weight; height; BMI at ages 20, 50, and current age; alcohol; caffeine; dairy product use at age 20, 50, and current age; physical activity at different ages | Multivariable regression models, proxy responses not included Variables in model include: age, sex, country of birth, current weight, smoking, current physical activity, psychotropic drugs, cognitive state, dairy consumption at age 20 and currently, physical activity at age 20, weight at 20 | | Odds Ratios (CI) | Fair
Cumming (1994)^ 192 ^ | Case-control | Cases recruited from 12 hospitals, controls from area probability sampling method 27% required proxy respondents | 137 controls | | Hip fracture diagnosed by physician and identified by hospital admissions data during the study period | Smoking status; cigarettes per day; weight; height; BMI at ages 20, 50, and current age; alcohol; caffeine; dairy product use at age 20, 50, and current age; physical activity at different ages | | Weight at age 20 (trend p=0.001) highest quintile | 5.9 (1.7-20.1) | Fair
Cumming (1994)^ 192 ^ | Case-control | Cases recruited from 12 hospitals, controls from area probability sampling method 27% required proxy respondents | 137 controls | | Hip fracture diagnosed by physician and identified by hospital admissions data during the study period | Smoking status; cigarettes per day; weight; height; BMI at ages 20, 50, and current age; alcohol; caffeine; dairy product use at age 20, 50, and current age; physical activity at different ages | | Weight at current age (trend p=0.03) highest quintile | 0.3 (0.1-0.9) | Fair
Kreiger (1982)^ 438 ^ | Case-control | Women age 45-74 years, cases had hip hospital admission for hip fractures at four hospitals in Connecticut 1977-79; two control groups | 98 cases 83 trauma controls 801 controls | not given | Hip fracture confirmed by X-ray | Demographic data, height, weight, menstrual reproductive history, estrogen use, comorbidities | Multivariable regression models including age, BMI, breastfeeding, oophorectomy, HRT use | BMI (kg/m2) (0.01 increase) oophorectomy HRT | 0.4 (0.3-0.6) 1.9 (0.9-3.5) 0.5 (0.2-0.9) | Fair
Meyer (1995)^ 167 ^ | Case-control | All noninstitutionalized persons 50 years or older living in catchment area of two hospitals in Oslo, Norway | 246 cases | 79.9 | Hip fractures identified from hospital admission lists and verified by medical records during 1992-93 | Triceps skinfold thickness, BMI, weight reduction in the previous year, height, number of meals/day, eating dinner every day, slices of bread/day, dietary vitamin D, vitamin D supplements, total vitamin D intake, calcium supplements, outdoor walking, climbing stairs, grip strength, history of fall in the previous year, dependent on gait support, previous fracture, diabetes, hospital admissions in previous 2 years, daylight exposure, length of education, current daily smoker, age at menopause, parity, hysterectomy, estrogen use | Conditional logistic-regression models for matched pairs controlled for diabetes, current smoking, years of education, and triceps skinfold thickness | | Odds Ratio (CI) | Good
Meyer (1995)^ 167 ^ | Case-control | Cases were patients admitted for hip fracture during a 1-year period; controls were randomly selected from study population matched for age and sex | 246 controls 78% females | 79.8 females | Hip fractures identified from hospital admission lists and verified by medical records during 1992-93 | | Conditional logistic-regression models for matched pairs controlled for diabetes, current smoking, years of education, and triceps skinfold thickness | Triceps skinfold thickness (mm) <=12.7 12.8- 17.6- >23 | 9.54 (4.41-20.6) 4.31 (2.17-8.55) 2.90 (1.46-5.74) 1.00 | Good
Meyer (1995)^ 167 ^ | Case-control | Cases were patients admitted for hip fracture during a 1-year period; controls were randomly selected from study population matched for age and sex | 246 controls 78% females | 79.8 females | Hip fractures identified from hospital admission lists and verified by medical records during 1992-93 | | Conditional logistic-regression models for matched pairs controlled for diabetes, current smoking, years of education, and triceps skinfold thickness | BMI (kg/m2) <=20.2 20.3-22.5 <3 meals/day | 5.86 (2.68-21.8) 2.81 (1.24-6.35) 6.76 (2.61-17.5) | Good
Meyer (1995)^ 167 ^ | Case-control | Cases were patients admitted for hip fracture during a 1-year period; controls were randomly selected from study population matched for age and sex | 246 controls 78% females | 79.8 females | Hip fractures identified from hospital admission lists and verified by medical records during 1992-93 | | Conditional logistic-regression models for matched pairs controlled for diabetes, current smoking, years of education, and triceps skinfold thickness | Not eating dinner every day <=2 slices/bread per day <2.5 microgr/day vitamin D No stair climbing Grip strength <=14 kg Fell >=3 times in previous year >=2 hospital admissions/2 years <15 min/day daylight exposure <=7 years of education Current daily smoker | 2.63 (1.39-4.97) 3.61 (1.82-7.17) 3.95 (1.67-9.32) 3.43 (1.58-7.42) 3.27 (1.54-6.97) 4.13 (1.68-10.1) 2.21 (1.03-4.76) 5.31 (2.06-13.6) 2.66 (1.45-4.89) 2.05 (1.17-3.58) | Good
Bean (1995)^ 439 ^ | Case-control | Consecutive noninstitutionalized women with hip fracture admitted to a hospital in Nottingham, UK between 12/90 and 6/91. | 50 cases | 79.5 | Hip fractures identified from hospital admissions and records | Weight, demispan, dominant handgrip, nondominant handgrip, CAPE score | Stepwise multiple linear regression including variables demispan (hand to sternum length), CAPE score, dominant handgrip | | R2 (p-value) | Poor (small sample)
Bean (1995)^ 439 ^ | Case-control | Controls did not have previous hip fractures and were randomly selected from an earlier aging study and matched for age | 50 controls | 79.6 | Hip fractures identified from hospital admissions and records | Weight, demispan, dominant handgrip, nondominant handgrip, CAPE score | Stepwise multiple linear regression including variables demispan (hand to sternum length), CAPE score, dominant handgrip | Dominant handgrip CAPE score | 0.35 (0.0001) 0.44 (0.0003) | Poor (small sample)
Elliot (1992)^ 168 ^ | Case-control | Patients with hip fracture admitted to Christchurch Hospital, New Zealand, from 8/88 to 11/88 age 65 or over, without previous fracture, community dwelling, without dementia | 36 cases (78% female) | 79.1 | Hip fractures identified from hospital admissions and records | Height, weight, BMI, total number of medications, blood pressure, number of previous fractures, number of falls, mobility index, handgrip strength, midthigh circumference | Logistic regression included all variables in previous column except BMD | Grip strength Mobility Falls | R2 (p-value) 0.14 (0.003) 0.24 (0.016) 0.37 (0.017) | Poor (small sample)
Elliot (1992)^ 168 ^ | Case-control | Controls were from a community study of the elderly; 2 age and sex-matched per case | 72 controls (76% female) | 78.4 | Hip fractures identified from hospital admissions and records | Height, weight, BMI, total number of medications, blood pressure, number of previous fractures, number of falls, mobility index, handgrip strength, midthigh circumference | Logistic regression included all variables in previous column except BMD | Grip strength Mobility Falls | R2 (p-value) 0.14 (0.003) 0.24 (0.016) 0.37 (0.017) | Poor (small sample)
Johnell (1995)^ 196 ^ | Case-control | Women 50 years or older from Portugal, Spain, France, Italy, Greece, Turkey (MEDOS study) over a 1-year period | 2,086 cases | | Hip fracture cases obtained by surveillance of hospitals | Breastfeeding; parity; menarche <12 years; menopause >44; tea, coffee, alcohol, and milk use; smoking; sunlight exposure; recreational physical activity; nonsedentary job; BMI >25 kg/m2; dementia; imperfect mental score | Multivariable models based on unconditional logistic regression Variables in model included age, center, BMI, and all other significant predictors shown in column | Recreational physical activity (any) Milk intake (highest 90%) Mental score (perfect score) BMI (>25 kg/m2) Menarche (<12 years) Menopause (>44 years) Sunlight exposure (above median) Tea consumption (any) | Relative Risk (CI) 0.85 (0.72-0.99) 0.71 (0.58-0.87) 0.58 ( 0.49-0.68) 0.45 (0.39-0.53) 0.76 (0.61-0.95) 0.88 (0.73-1.06) 0.86 (0.73-1.00) 0.71 (0.60-0.83) | Good
Johnell (1995)^ 196 ^ | Case-control | Controls selected from neighborhood or population registries | 3,532 controls | | Hip fracture cases obtained by surveillance of hospitals | | Multivariable models based on unconditional logistic regression Variables in model included age, center, BMI, and all other significant predictors shown in column | | Relative Risk (CI) 0.85 (0.72-0.99) 0.71 (0.58-0.87) 0.58 ( 0.49-0.68) 0.45 (0.39-0.53) 0.76 (0.61-0.95) 0.88 (0.73-1.06) 0.86 (0.73-1.00) 0.71 (0.60-0.83) | Good
Suzuki (1997)^ 73 ^ | Case-control | Hip fractures in men and women age 65-89 years old in Japan admitted to study hospitals for fracture | 249 cases | 79 | Hip fracture diagnosed by hospital admissions data | Urban/rural location, activity level of work, BMI, sleep disturbance, stroke with hemiplegia, diabetes, coffee use, alcohol use, milk intake, fish intake, sun exposure, exercise in adulthood, immobilization, green tea use, able to bathe self, type of bed (Japanese vs western) | Multivariable conditional logistic regression model includes variables significant in the first model listed in previous column | Lived in rural area in the past BMI 18.5-20.7 (compared to <=18.4) 20.8-23.0 23.1 or more Sleep disturbance Stroke with hemiplegia 3 or more cups of coffee/day <27 g/day of alcohol Eating fish 3-4 times per week Use of western bed | Odds Ratios (CI) 2.7 (1.5-4.8) 0.4 (0.2-0.7) 0.5 (0.3-0.8) 0.2 (0.1-0.4) 2.6 (1.3-5.2) 3.7 (1.1-12.5) 3.6 (1.5-8.9) 0.5 (0.3-0.9) 0.6 (0.4-0.9) 2.0 (1.3-2.9) | Good
Suzuki (1997)^ 73 ^ | Case-control | Controls were selected from the same community as cases and matched by ethnicity, sex, age, and residential area | 498 controls 83% female | 78.3 | Hip fracture diagnosed by hospital admissions data | | Multivariable conditional logistic regression model includes variables significant in the first model listed in previous column | | Odds Ratios (CI) 2.7 (1.5-4.8) 0.4 (0.2-0.7) 0.5 (0.3-0.8) 0.2 (0.1-0.4) 2.6 (1.3-5.2) 3.7 (1.1-12.5) 3.6 (1.5-8.9) 0.5 (0.3-0.9) 0.6 (0.4-0.9) 2.0 (1.3-2.9) | Good
Ribot (1993)^ 121 ^ | Case-control | Cases: Residents of Toulouse, France, >=50 years old with hip fractures not related to secondary pathology | 419 cases | 80 | Hip fracture determined by hospital evaluation | 56 demographic and health variables | Multiple stepwise regression including 56 variables | Weight above 1 SD Moderate alcohol intake High calcium intake Loss of autonomy Height above 1 SD Psychotropic drugs Previous fractures Mental deterioration | Odds Ratios (CI) 0.82 (0.71-0.94) 0.56 (0.3-0.75) 0.55 (0.3-0.75) 2.24 (1.27-3.93) 1.76 (1.4-2.22) 1.82 (1.56-2.45) 1.77 (1.17-2.7) 1.76 (1.02-3.02) | Good
Ribot (1993)^ 121 ^ | Case-control | Controls: 2 per case matched by sex and age from the community (MEDOS study) | 915 controls 80.8% female | 80 | Hip fracture determined by hospital evaluation | 56 demographic and health variables | Multiple stepwise regression including 56 variables | Weight above 1 SD Moderate alcohol intake High calcium intake Loss of autonomy Height above 1 SD Psychotropic drugs Previous fractures Mental deterioration | Odds Ratios (CI) 0.82 (0.71-0.94) 0.56 (0.3-0.75) 0.55 (0.3-0.75) 2.24 (1.27-3.93) 1.76 (1.4-2.22) 1.82 (1.56-2.45) 1.77 (1.17-2.7) 1.76 (1.02-3.02) | Good
Turner (1998)^ 440 ^ | Cross-sectional | Women age 50 and over interviewed in NHANES III who lived in the southern region of the U.S. | 953 | 68.8 | Hip fracture by self-report | Age, race, maternal history of osteoporosis or hip fracture, BMI, physical activity, smoking status, alcohol use, dairy product intake | Multivariable models based on stepwise logistic regression | Black race Hispanic race Age >= 65 years BMI (<20) | Odds Ratios (CI) 0.06 (0.01-0.24) 0.43 (0.19-1.0) 7.45 (2.95-18.8) 1.95 (1.16-3.29) | Fair

a Quality rating described in Methods and Appendix

Evidence Table 2. Risk factors for low bone density: studies reporting multiple factors

Author/yr | Study design | Population | N | Mean age | Outcome | Predictors studied | Statistical models | Significant predictors in multivariate | RR or OR | Quality ^a^
Smeets-Goevaers (1998)^ 441 ^ | Cross-sectional | White Dutch women born from 1941-47 living in Eindhoven, the Netherlands, were invited to participate in the study, 77% agreed to participate during 1995-95 | 6,262 | 50 | DXA of the lumbar spine Low BMD defined as T-score <1 SD | Listed in next column | Multivariate logistic regression analysis: hormonal use, age, BMI, hysterectomy, menopausal status, age at menarche, pregnancies, smoking, drinking, and milk consumption before and after the age of 25 years | | OddsRatio (CI) | Good
Smeets-Goevaers (1998)^ 441 ^ | Cross-sectional | White Dutch women born from 1941-47 living in Eindhoven, the Netherlands, were invited to participate in the study, 77% agreed to participate during 1995-95 | 6,262 | 50 | DXA of the lumbar spine Low BMD defined as T-score <1 SD | Listed in next column | | Age BMI Bilateral oophorectomy Perimenopause Menopause Parity Smoking Current alcohol consumption | 1.13 (1.09-1.17) 1.13 (1.09-1.17) 2.25 (1.44-3.52) 1.72 (1.34-2.19) 4.91 (3.77-6.40) 0.95 (0.91-1.00) 1.25 (1.08-1.44) 0.71 (0.61-0.83) | Good
Kroger (1994)^ 442 ^ | Cross-sectional | Women age 47-56 years in Finland who responded to a postal recruitment during 1989 | 1,600 | 53.2 | Single-photon absorptiometry scans Low BMD defined as T-score <1 SD | Listed in next two columns | Multiple regression analysis included significant factors in next column as well as nulliparity, smoking, lifetime tobacco, coffee consumption | Significant correlations in multivariate analysis: age, weight, height, BMI, grip strength, and menopausal status. | | Good
Kroger (1994)^ 442 ^ | Cross-sectional | Women age 47-56 years in Finland who responded to a postal recruitment during 1989 | 1,600 | 53.2 | Single-photon absorptiometry scans Low BMD defined as T-score <1 SD | Listed in next two columns | Multiple regression analysis included significant factors in next column as well as nulliparity, smoking, lifetime tobacco, coffee consumption | Significant odds ratios include: | Odds Ratio (CI) | Good
Kroger (1994)^ 442 ^ | Cross-sectional | Women age 47-56 years in Finland who responded to a postal recruitment during 1989 | 1,600 | 53.2 | Single-photon absorptiometry scans Low BMD defined as T-score <1 SD | Listed in next two columns | Multiple regression analysis included significant factors in next column as well as nulliparity, smoking, lifetime tobacco, coffee consumption | for femoral neck- low calcium intake (<520 mg/day) low physical activity | 1.6 (1.2-2.2) 1.3 (1.0-1.8) | Good
Kroger (1994)^ 442 ^ | Cross-sectional | Women age 47-56 years in Finland who responded to a postal recruitment during 1989 | 1,600 | 53.2 | Single-photon absorptiometry scans Low BMD defined as T-score <1 SD | Listed in next two columns | Multiple regression analysis included significant factors in next column as well as nulliparity, smoking, lifetime tobacco, coffee consumption | for spine- high alcohol consumption (>6dl/day) | 0.6 (0.3-1.0) | Good
Bauer (1993)^ 65 ^ | Cross-sectional | Community-dwelling, ambulatory nonblack U.S. women, age 65 years or older; data collected from 1986-88 (SOF) | 9,704 | 71.1 | Single-photon absorptiometry scans of distal radius, midradius, and calcaneus Results report distal radius because all were correlated | All variables in the next column as well as those not associated with BMD in univariate analysis: education level, N European ancestry, blond hair, ever breastfed, paternal fracture, hip fracture in mother or sister, total calcium intake, walking in past year, cigarettes smoked in lifetime, alcohol intake in lifetime, alcohol dr/wk, good health, history of hyperthyroid, use of progestins, estrogen cream, oral contraceptives, calcium supplements, TUMS, antacids, vitamin D, nonthiazide, diuretics, thyroid hormone, seizure med | Variables significant in univariate analysis examined in multivariate models including: age, weight, height, grip strength, waist-to-hip ratio, age at menopause, surgical menopause, parity, maternal fracture after age 50, NIDDM, gastric surgery, rheumatoid arthritis, calcium-food, calcium-milk age 18-50, current smoker, lifetime caffeine intake, lifetime activity, estrogen use >2 years, thiazide use >5 years, steroid use >1 year | Effect size >3% change in distal radius BMI per unit change in variable: weight (10 kg), grip strength (5 kg), gastric surgery, estrogen use >2 yrs, NIDDM, thiazide use > 5 years Effect size 1-3%: age (5 years), age at menopause (5 years), height (10 cm), maternal fracture, current smoker Effect size <1%: lifetime caffeine, current dietary calcium (400 mg/d) | N/A | Good
Ribot (1992)^ 269 ^ | Cross-sectional | Peri- and postmenopausal women selected from women referred to menopause clinic in France | 1,565 | 54 | BMD at L2-L4 by dual photon absorp-tiometry Low BMD defined as T-score <2 | Age, height, weight, age at menarche, use and duration of oral contraceptives, parity, breastfeeding and duration, menopause, family history osteoporosis, arthritis of the spine, Heberden's nodes, immobilization, smoking status, pack-years, psychotropic drugs, thyroid supplements | Multiple stepwise logistic regression with predictors in previous column | | Odds Ratio (CI) | Fair
Ribot (1992)^ 269 ^ | Cross-sectional | Peri- and postmenopausal women selected from women referred to menopause clinic in France | 1,565 | 54 | BMD at L2-L4 by dual photon absorp-tiometry Low BMD defined as T-score <2 | | Multiple stepwise logistic regression with predictors in previous column | Per 1 SD below mean of variable: Age Height Weight Age at menarche Years since menopause Menopause Osteoarthritis | 1.33 (1.1-1.6) 1.14 (1.0-1.3) 1.88 (1.6-2.2) 1.11 (1.0-1.3) 1.42 (1.2-1.7) 2.66 (1.6-4.4) 1.65 (1.1-2.4) | Fair
Blaauw (1994)^ 443 ^ | Case-control | Men and women with diagnosed osteoporosis based on DXA from a metabolic unit in South Africa matched by age and sex to controls without osteoporosis | 39 cases 98 controls (females) | 61 60 | DXA of lumbar spine and hip | Significantly different factors: low body mass, fair complexion, family history of osteoporosis, no breastfeeding, smoking, fat distribution around the waist | N/A | N/A | N/A | Poor (small sample)
Parra-Cabrera (1996)^ 444 ^ | Cross-sectional | Women in a private osteoporosis clinic in Mexico City age 26-83 years old | 313 | 55.1 | DXA of lumbar spine and hip | Listed in next column | Multiple regression models with backwards elimination included: age, BMI, exercise and sedentary indexes, parity, menopause, estrogen use, and smoking | Significant for spine BMD: age, BMI, exercise score, parity, estrogen use Significant for femoral BMD: age, BMI, exercise score, estrogen use >1 year | N/A | Poor
Shaw (1993)^ 445 ^ | Cross-sectional | Healthy volunteers including men and women age 15-83 years old living in Taiwan | 404 266 (females) | | DPA of lumbar spine Low BMD defined as below 1 g/cm2 | Age, education, BMI, smoking status, milk consumption, seaweed diet, exercise, diabetes, breastfeeding, years since menopause, frequency of pregnancy, menarche | Multiple logistic regression model included age, years since menopause, diabetes, seaweed diet, and gender | | Odds Ratio (CI) | Fair
Shaw (1993)^ 445 ^ | Cross-sectional | Healthy volunteers including men and women age 15-83 years old living in Taiwan | 404 266 (females) | | DPA of lumbar spine Low BMD defined as below 1 g/cm2 | Age, education, BMI, smoking status, milk consumption, seaweed diet, exercise, diabetes, breastfeeding, years since menopause, frequency of pregnancy, menarche | Multiple logistic regression model included age, years since menopause, diabetes, seaweed diet, and gender | Age >=6 years since menopause Diabetes BMI | 1.04 (1.01-1.07) 4.93 (1.86-13.06) 5.37 (1.52-18.92) 0.85 (0.77-0.95) | Fair
Orwoll (1996)^ 64 ^ | Cross-sectional | Community-dwelling, ambulatory nonblack U.S. women, age 65 years or older; data collected from 1986-88 (SOF) | 7,963 | 73.8 | DXA of lumbar spine and proximal femur | Many variables tested, too long to list | Multivariable models tested associations of a long list of variables and spine and femoral BMD | Spine: age, weight, height, age at menopause, age at menarche, fracture in mother, arthritis, lifetime activity, alcoholic drinks, thiazide use, estrogen use, nonthiazide use Femoral neck: age, weight, height, quadriceps strength, age at menopause, fracture in mother, wrist fracture in sister, NIDDM, calcium, high activity, any thiazide use, current estrogen use | NA provided % change in bone density per unit adjusted for multiple variables | Good

a Quality rating discussed in Methods and Appendix

BMI = Body Mass Index

Evidence Table 3. Risk factors for bone loss: studies reporting multiple factors

Author/yr | Study design | Population | N | Mean age | Outcome | Predictors studied | Statistical models | Significant predictors in multivariate | RR or OR | Quality ^a^
Sowers (1992)^ 446 ^ | Prospective (5 years) | Women age 22-80 years living in a single rural community in the U.S. recruited in 1984 and re-examined in 1989 | 217 | 40.4 | Radial BMD by single-photon absorptiometry obtained at baseline and 5 years later (% change) | Factors not associated with BMD or bone loss: BMI, muscle area, number of lost pregnancies, ever breastfed, calcium intake, physical activity, and alcohol intake | Stepwise multiple regression included age, estrogen status, parity, age at first pregnancy, and weight | Factors associated with lower BMD: menopause without HRT, nulliparity, smoking, age at first pregnancy Factors associated with bone loss: menopause without HRT, smoking, duration of oral contraceptive use, age | N/A | Poor (wide age range)
Brot (1997)^ 447 ^ | Prospective (2 years) | Menopausal women age 45-58 years enrolled in Danish Osteoporosis Prevention Study (DOPS) in Copenhagen | 433 baseline 87 followup | 50.9 | Whole body BMC by DXA Outcome measured as % change/yr | Age, height, weight, age at menopause, number of fertile years, parity, breastfeeding menopausal symptoms, family history of fractures, physical or occupational activity, smoking, caffeine, alcohol use | Multiple linear regression with stepwise backwards elimination | Predictors of BMD: age, weight, height, smoking (pack-yrs), reproductive period (years), family history of fracture, working capacity Predictors of bone loss (% per yr): baseline weight, weight changes | N/A | Poor (small sample)
Nguyen (1998)^ 360 ^ | Prospective (2.7 years) | Women enrolled in the Dubbo Osteoporosis Epidemiology Study (DOES) in Australia age >=60 as of 1989 | 827 | >=60 | DXA of femoral neck Outcome measured as % change/yr | Age, weight, weight change, physical activity, quadriceps strength, and dietary calcium intake | Multiple regression with all variables included | Predictors of BMD loss (% per yr): age, baseline BMD< weight, weight change, physical activity | N/A | Good
Burger (1998)^ 362 ^ | Prospective (2 years) | Men and women age 55 years and over from the Rotterdam Study, a population-based cohort study in the Netherlands during 1990-93 | 2,452 females | >=55 | Hip DXA Outcome measured as % change/yr | Age, BMI, lower limb disability, current smoking, dietary calcium intake, alcohol use | Multiple regression adjusted for age and sex | Predictors of BMD loss (% per yr) for women: increasing age, lower BMI, smoking | N/A | Good

a Quality rating described in Methods and Appendix.

Evidence Table 4. Risk assessment tools

Author, yr | Risk factors included | Risk score | Performance | Quality score ^a^
Fracture Outcomes
van Hemert (1990)^ 260 ^ | (%), BMI (kg/m2), height (cm), diameter of forearm (mm), diameter of knee (mm), age at menarche (years), age at menopause (years), smoking (cigarettes/day), number of children, period of lactation (months) | used to calculate individual risk scores; upper quintile of population considered high risk; N=1,014; 9-year followup | specificity 84% Osteoporotic fractures: sensitivity 48%, specificity 82%
Ranstam (1996)^ 261 ^ | Mental-functional risk score (points given if unable to perform): knowledge of the day of week (10 points), knowledge of age (6 points), ability to wash (3 points), ability to dress (3 points) | Subjects in MEDOS (2,810 cases; 4,664 controls) were found to have 4 functional predictors significantly associated with hip fracture; points were assigned that correspond to RR of fracture | Hip fracture: a less than perfect score had a sensitivity 46%, specificity 79% | Fair
Burger (1999)^ 262 ^ | Model with BMD: age (5 yrs), gender, height (per 5 cm), use of a walking aid, current smoking, BMD of femoral neck Model without BMD: age (5 yrs), gender, height (per 5 cm), use of a walking aid, current smoking, weight | Subjects in the Rotterdam Study (N=5,208); risk factors determined at baseline, hip fractures counted 3.8 yrs later; risk points assigned from beta coefficients of models | Model with BMD: ROC area 0.88 (CI 0.84-0.92); sensitivity 70%, specificity 84% Model without BMD: ROC area 0.83 (CI 0.77-0.89); sensitivity 70%, specificity 83% | Fair
Tromp (1998)^ 263 ^ | Recurrent falls: urinary incontinence, impaired mobility, use of analgesics, use of antiepileptic drugs Fractures: female gender, living alone, past fractures, inactivity, height, use of analgesics | 1,469 elderly community dwelling men and women followed for 38 months; predictors for falls and fractures obtained at baseline and found significant by regression | Probabilities of recurrent falls: 0 predictors = 4.7% 4 predictors = 59.2% Probabilities of fractures: 0 predictors = 0% 6 predictors = 12.9% | Fair
Johnell (1995)^ 156 ^ | Late menarche, poor mental score, low BMI, low physical activity, low exposure to sunlight, and low consumption of calcium and tea | Case-control study (MEDOS) risk factors determined to be significant by regression were used to compute a score based on the log of the RR; highest 33% were classified as cases | For hip fracture: sensitivity 55%, specificity 65% | Fair
Wolinsky (1994)^ 88 ^ | White race, female gender, living in southern U.S., age, having been hospitalized in the previous year, previous fall, body mass | Older adults in Longitudinal Study on Aging; risk factors significant by regression were introduced into a predictive model (N=368 with fracture) | Best model for hip fracture: ROC .71; sensitivity 64.7%, specificity 65.7% | Fair
Kleerekoper (1989)^ 264 ^ | Model 1: total months of lactation, family history of osteoporosis, years postmenopause, weight Model 2: breastfed, surgical menopause, age at menarche, age, smoking status (e.g., current) | Women with vertebral fractures were compared to two different comparison groups without osteoporosis; best predictors used in models; N=663 | Model 1: ROC area (SE) 0.55 (0.07); sensitivity 56%, specificity 54% Model 2: ROC area (SE) 0.51 (0.042); sensitivity 63%, specificity 39% | Fair
Cooper (1991)^ 63 ^ | Variables from discriminant function resulting from backwards stepwise elimination: age (yrs), height (cm), broken bone in back after age 45, age of last menstrual period (yrs), number of children, ever used oral corticosteroids | 1,012 women were evaluated for vertebral fractures and risk factors; cases compared with controls; scores assigned from standardized coefficients of models using discriminant analysis | Vertebral fractures: sensitivity 51%, specificity 69% | Fair
Bone Density Outcomes
Falch (1992)^ 265 ^ | Low body weight, reduced renal phosphate reabsorption, smoking | Significant predictors of bone loss were identified from a 10-year study of 73 Norwegian women; an index was developed and validated using data from a 10-year study of 86 Dutch women | Bone loss: sensitivity 36%, specificity 89%, PPV 74% | Poor (small sample)
Verhaar (1998)^ 266 ^ | Arm span-height difference of at least 3 cm (criteria used in the Netherlands for suspecting osteoporosis) Arm span-height difference, age above or below 70, and whether arm span was below or above 160 cm | Criteria tested in a group of 36 women with established osteoporosis and 25 without | Arm span only: sensitivity 58%, specificity 56% Arm span, age, arm span length: sensitivity 81%, specificity 64% | Poor (small sample)
Elliot (1993)^ 267 ^ | Spine BMD: age, weight, smoking status, age at menarche Femoral neck BMD: age, weight, family history, activity, smoking status | Significant predictors of spine and femoral neck BMD were identified from 320 women; an equation for predicting BMD was developed and validated on 107 other women | Lumbar spine BMD: sensitivity 86%, specificity 32% Femoral neck BMD: sensitivity 89%, specificity 25% | Fair
Michaelsson (1996)^ 83 ^ | Weight >70kg | Risk factors were evaluated in a cross-sectional study (N=175); weight was the strongest body measure to consider for screening purposes | BMD<2.5 SD for femoral neck: sensitivity 94%, specificity 36%, PPV 21%, NPV 97% | Fair
Ballard (1998)^ 268 ^ | Referral criteria: osteoporotic from radiologic and clinical findings, medical condition predisposing to osteoporosis, on oral corticosteroids, menopause <45 years old, positive family history in first degree relative Regression model: age, age at menopause, height, weight, gravidity, parity, current use of steroids, current HRT | 1,158 women were assessed for risk factors and BMD; compared performance of regression generated risk with UK clinical referral criteria | Osteoporosis by BMD of femoral neck and/or spine-regression model: ROC area 0.73 (SD=0.0198) Referral criteria: sensitivity 58%, specificity 60% (below ROC) | Fair
Ribot (1992)^ 269 ^ | Weight, menopause, duration of menopause | Cross-sectional study of 1,565 women from menopause clinic, risk factors significant in multiple regression were added to model | Vertebral BMD 2 SD below normal young adult value: correct classification of 73% with low BMD, 66% of those with normal BMD | Fair
Slemenda (1990)^ 270 ^ | Age, height, weight, calcium intake, caffeine intake, alcohol and tobacco use, urinary markers of bone turnover | 124 perimenopausal women, those with low bone mass were compared to those without; scores assigned according to strength of predictors in general linear models | Correct classification of midshaft radius BMD: 68% low BMD, 77% high BMD Lumbar spine BMD: 61% low BMD, 45% high BMD Femoral neck BMD: 66% low BMD, 53% high BMD | Poor (small sample)
Lydick (1998)^ 271 ^ | Age (3 times first digit in age), weight (-1 times weight divided by 10 and truncated to integer), race (5 points if not black), estrogen (1 if never received estrogen therapy), rheumatoid arthritis (4 if has), history of fractures (4 for each type of nontraumatic fracture after age 45 with maximum score of 12); total points is SCORE; threshold of 6 used in study | 1,279 peri- and postmenopausal women from community were asked about risk factors and provided with BMD; scores were assigned according to coefficients in the model relative to the coefficient for weight; model then tested in a validation group (n=259) | Femoral neck BMD: sensitivity 89%, specificity 50% ROC area 0.81 Performance in validation group: sensitivity 91%, specificity 40% | Good
Goemaere (1999)^ 272 ^ | 18-item questionnaire on risk factors for osteoporosis (race, height loss, age [50-70; >70], weight [55-60 kg; <55 kg], smoking, coffee, alcohol, dairy products, activity, family history, existence of comorbidities, history of wrist fracture, menopause before 45 years, corticosteroid use) | 300 postmenopausal women seeking general medical care; points summed for positive answers to obtain score; regression used to determine strength of associations with BMD | Lumbar spine BMD: ROC area 0.66 Femoral neck BMD: ROC area 0.69 Hip BMD: ROC area 0.76 | Fair

a Quality criteria described in Methods and Appendix

Evidence Table 5. Prospective studies of bone measurement tests and fracture prediction (hip DXA and heel QUS)

Cohort | Age group range or mean | Length of follow-ups | N | Probability of hip fracture | Mean BMD-FN g/cm | Cutoff values | DXA of the hip | | | | | | QUS of the heel
Cohort | Age group range or mean | Length of follow-ups | N | Probability of hip fracture | Mean BMD-FN g/cm | Cutoff values | Hip fracture | | | All nonspine fracture | | | Hip fracture | | | All nonspine fracture
Cohort | Age group range or mean | Length of follow-ups | N | Probability of hip fracture | Mean BMD-FN g/cm | Cutoff values | RR per 1 SD (CI) | Prob if "low risk" ^a^ | Prob if "high risk" ^b^ | RR per 1 SD(CI) | Prob if "low risk" | Prob if "high risk" | RR per 1 SD (CI) | Prob if "low risk" | Prob if "high risk" | RR per 1 SD (CI) | Prob if "low risk" | Prob if "high risk"
SOF | > 65 | 1.8 to 2.9 yrs | 5,236-8,134 | .009 | 0.63 | Lowest quartile | 2.6 (1.9, 3.8) | .005 ^c^ | .023 | 1.3 (1.1, 1.5) | | | 2.0 (1.5, 2.7) | .006 | .018 | 1.3 (1.2, 1.5)
SOF | > 65 | 1.8 to 2.9 yrs | 5,993 | | | QUS 50 | | | | | | | | .006 | .023
SOF | 65-79 | 2.9 yrs | | | 0.66 | | 2.9 (2.2, 3.9) | | | 1.5 (1.4, 1.6)
SOF | > 80 | | | | 0.59 | | 2.1 (1.4, 3.2) | | | 1.9 (1.6, 2.4)
SOF | 65-69 | 1.8 yrs | 2,371 | .003 | | Age-specific quartiles | | .0028 | .005
SOF | 70-74 | | 3,013 | .0076 | | | | .005 | .016
SOF | 75-79 | | 1,728 | .007 | | | | .003 | .019
SOF | 80-84 | | 731 | .018 | | | | .007 | .049
SOF | > 85 | | 291 | .024 | | | | .014 | .028
EPIDOS | > 75 | 2 yrs | 5,656 | .02 | 0.69-0.72 | <0.703 g/cm2 | 1.9 (1.6, 2.4) | .033 | .008 | | | | 2.0 (1.6, 2.4) | .012 | .029
EPIDOS | < 80 | | 3,982 | .013 | 0.73 | -2.5 SD | | .002 | .025
EPIDOS | > 80 | | 3,616 | .028 | 0.67-0.71 | -2.5 SD | | .006 | .04
Aberdeen (Porter) | > 70 | 2 yrs | 1,414 | .052 | | Median | | | | | | | | .037 | .077
Aberdeen (Stewart) | 45-49 | 2 yrs | 790 | N/A | 0.89 | Not specified | | | | 1.43 ^d^ (1.3, 2.4) | .017 ^d^ | .024 | | | | 1.43d (1.2, 2.4) | .017 | .024
HOS | 73.9 | 2.7 yrs | 560 | N/A | | | | | | | | | | | | 1.89d (1.3, 2.9)
Rotterdam | > 55 | 3.8 yrs | 3,078 | .013 | | Risk function ^g^ | 2.5 (1.8, 3.6) | .007 | .069
Kuopio | 53.4 | 2.4 yrs | 3,122 | | .928 | Quartiles | | | | 1.39 ^d^ (1.2, 1.6) | .048 | .07

Duboeuf (1997)292, Schott (1998)298, Garnero (1998)293, Hans (1996)294, Black (1992)285, Cummings (1993)44, Nevitt (1994)297, Bauer (1997)290, Porter (1990)57, de Laet (1998)291, Huang (1998)45, Kroger (1995)295, Mele (1997)296, Stewart (1996)299

a Probability of hip fracture if the BMD test was classified as "low risk."

b Probability of hip fracture if the BMD test was classified as "high risk."

c Based on 48 hip fractures.

d Estimate based on investigator calculations.

e Probability of hip fracture if the BMD test was classified as "low risk."

f Probability of hip fracture if the BMD test was classified as "high risk."

g Regression equation using age and BMD.

Evidence Table 6. Prospective studies of bone measurement tests and fracture prediction (spine, hand, forearm)

Cohort | Age | DXA-Spine | | | | | | Hand ^a^
Cohort | Age | Hip fracture | | | All non-spine fracture | | | Hip fracture | | | All non-spine fracture
Cohort | Age | RR per 1 SD (CI) | Prob if "low risk" ^b^ | Prob if "high risk" ^c^ | RR per 1 SD (CI) | Prob if "low risk" | Prob if "high risk" | RR per 1 SD (CI) | Prob if "low risk" | Prob if "high risk" | RR per 1 SD (CI) | Prob if "low risk" | Prob if "high risk"
SOF ^d^ | > 65 | 1.6 (1.2, 2.2) | .006 | .014
SOF ^d^ | 65-79 | 1.5 (1.2, 1.9) | | | 1.4 (1.2, 1.5)
SOF ^d^ | > 80 | 1.8 (1.2, 2.8) | | | 1.5 (1.2, 1.8)
SOF ^d^ | 65-79 | | .002 | .008
SOF ^d^ | > 80 | | .005 | .015
SOF ^d^ | 75-79 | | .006 | .009
SOF ^d^ | 80-84 | | .01 | .033
SOF ^d^ | > 85 | | .018 | .027
Aberdeen | 45-49 | | | | 2.14 ^e^ (1.2, 3.8) | .014 | .028
HOS | 73.9 | | | | | | | | | | 1.5 ^e^ (0.9, 2.6)
Rotterdam | > 55
Kuopio | 53.4 | | | | 1.5 | .045 | .078
Modena | 52 | | | | | | | | | | 1.5 ^e^ (1.1, 1.7)
DOM | 57 | | | | | | | | | | 2.4 ^f^ | .029 ^g^ | .096

a Radiographic absorptiometry or quantitative densitometry.

b Probability of hip fracture if the BMD test was classified as "low risk."

c Probability of hip fracture if the BMD test was classified as "high risk."

d SOF: Black (1992)285, Cummings (1993)44, Nevitt (1994)297, Bauer (1997)290; Aberdeen: Stewart (1996)299, HOS: Huang (1998)45, Rotterdam: de Laet (1998)291, Kuopio: Kroger (1995)295, Modena: Mele (1997)296:

e Odds ratio.

f Hazards ratio.

g High risk group includes lowest 2 quartiles.

Evidence Table 7. Effect of agreement between tests or sites and classification using T-scores

Study, year | Setting and sample | Prevalence of osteoporosis based on T-score <2.5
Study, year | Setting and sample | DXA-spine | DXA of the hip | DXA-hip sites | DXA-distal radius | DXA-lateral spine | QCT-radius | QCT-spine | QUS-BUA | QUS-stiffness
Arlot (1997) ^ 304 ^ | Population-based, cross-sectional study of 479 postmenopausal women; Lyon, France | 0.18 | 0.12 | | 0.37 | 0.31
Arlot (1997) ^ 304 ^ | Women > 69 years old | 0.22 | 0.24 | | 0.60
Arlot (1997) ^ 304 ^ | Women 60-69 years old | 0.25 | 0.12 | | 0.42
Arlot (1997) ^ 304 ^ | Women 50-59 years old | 0.10 | 0.03 | | 0.15
Faulkner (1999) ^ 10 ^ | Data from NHANES III survey for 60-year-old women | 0.14 | | 0.06 | 0.12 | 0.38 | 0.50 | | 0.03
Grampp (1999) ^ 305 ^ | 342 consecutive patients with postmenopausal osteoporosis referred to a university clinic | 0.32 | 0.42 | 0.23 | | | | | | 0.49
Kroger (1999) ^ 306 ^ | Patients referred for assessment of suspected vertebral osteoporosis (13 centers)
Kroger (1999) ^ 306 ^ | Women with spine fracture | 0.71 | 0.34 | | | | 0.18 | 0.94
Kroger (1999) ^ 306 ^ | Women with hip fracture | 0.49 | 0.53
Kroger (1999) ^ 306 ^ | Healthy controls | 0.11 | 0.03 | | | | 0.02 | 0.41
Varney (1999) ^ 307 ^ | 115 consecutive patients with postmenopausal osteoporosis referred to a clinic at Beth Israel Deaconess Hospital, Boston | 0.20 | 0.17 | 0.06 | 0.27 | | | | 0.17

Evidence Table 8. Studies of agreement between different bone measurement tests

Studies of ultrasound vs. DXA | Inception cohort ^a^ | Osteoporotic | | | Type of QUS | Other | vs. DXA of the spine | | | vs. DXA of the hip
Author, year, location | Inception cohort ^a^ | Controls | No fracture | Vertebral fracture | Type of QUS | Other | r | Sens | Spec | r | Sens | Spec
Agren (1991)^ 333 ^ Univ. of Mass | | 17 | 21 | 20 | BUA | | 0.606 | 0.93 | 0.41 | 0.684
Alenfeld (1998)^ 334 ^ Heidelberg | | 15 | | 24 | AD-SOS | | 0.11 | 0.9 | 0.8 | 0.35 | 0.5 | 1
Cunningham (1996)^ 335 ^ Univ. of Bristol | 89 | | | | SOS | | | | | 0.498
Cunningham (1996)^ 335 ^ Univ. of Bristol | | | | | BUA | | | | | 0.537
Cunningham (1996)^ 335 ^ Univ. of Bristol | | | | | stiffness | | | | | 0.546
Faulkner (1994)^ 336 ^ Portland, OR | | 170 | | | BUA | | | | | 0.26-0.6
Faulkner (1994)^ 336 ^ Portland, OR | | | | | SOS | | | | | 0.48-0.5
Faulkner (1994)^ 336 ^ Portland, OR | | | | | stiffness | | | | | 0.43-0.6
Formica (1998)^ 337 ^ W. Haverstraw, NY | | 118 | | 47 | | pQCT | 0.46
Graafmans (1996)^ 338 ^ Amsterdam | | | 42 | | BUA | | | | | 0.56 | 0.47 | 1
Graafmans (1996)^ 338 ^ Amsterdam | | | | | BUA | | 0.57 | 0.93 | 0.67
Graafmans (1996)^ 338 ^ Amsterdam | | | | | SOS | | 0.48 | | | 0.38
Grampp (1997)^ 448 ^ UCSF | | 38 | | 97 | | pQCT-arm | | | | 0.39-0.4
Greenspan (1997)^ 325 ^ Boston and Oregon | 53 | | 52 | 56 | BUA | | 0.58-0.6
Greenspan (1997)^ 325 ^ Boston and Oregon | | | | | BUA | | | | | 0.7
Langton (1997)^ 46 ^ Hull, UK | 107
Laval-Jeantet (1995)^ 340 ^ Paris | | 90 | | 81 | | DXA-heel | 0.49
Laval-Jeantet (1995)^ 340 ^ Paris | | | | | | QCT | 0.48
Martin (1996)^ 341 ^ UK | 216 | | | | | pQCT-arm | 0.39
Martin (1996)^ 341 ^ UK | | | | | BUA | | 0.34
Martin (1996)^ 341 ^ UK | | | | | SOS | | 0.14
Martin (1996)^ 341 ^ UK | | | | | BUA | | | | | 0.32
Martin (1996)^ 341 ^ UK | | | | | | pQCT-arm | | | | 0.46
Massie (1993)^ 342 ^ UK | 328 | | | | BUA | | | | | 0.42
Massie (1993)^ 342 ^ UK | | | | | BUA | | 0.32
Naganathan (1999)^ 343 ^ Australia | 326 | | | | BUA
Naganathan (1999)^ 343 ^ Australia | | | | | Stiffness
Pocock (1996)^ 344 ^ Australia | 143 | | | | BUA | | | | | 0.44
Pocock (1996)^ 344 ^ Australia | | | | | BUA | | 0.48
Rosenthall (1995)^ 345 ^ Montreal | | | | | BUA | | 0.55 | 0.75 | 0.64 | 0.55 | 0.9 | 0.35
Roux (1993)^ 346 ^ Paris | | 240 | | 37 | BUA | | 0.55 | | | 0.4
Salamone (1994)^ 347 ^ | | 259 | | | BUA | | 0.43 | | | 0.43
Schott (1995)^ 348 ^ Lyon | | 86 | | 43 | BUA | | | | | 0.49
Schott (1995)^ 348 ^ Lyon | | | | | Stiffness | | | | | 0.4
Schott (1995)^ 348 ^ Lyon | | | | | SOS | | | | | 0.46
Tromp (1999)^ 349 ^ Amsterdam | | | | | BUA | | | | | 0.54
Tromp (1999)^ 349 ^ Amsterdam | | | | | SOS | | | | | 0.4
Tromp (1999)^ 349 ^ Amsterdam | | | | | BUA | | 0.48
Tromp (1999)^ 349 ^ Amsterdam | | | | | SOS | | 0.3
Turner (1995)^ 350 ^ Indiana | 325 | | | 22 | SOS | | | | | 0.54
Young (1993)^ 351 ^ Sutton, UK | 578 | | | | BUA | | | | | 0.35
Sutton, UK

a Blank cells indicate other sampling strategies.

Evidence Table 9. Recent studies of bone density change at the hip with treatment

Author | Study design | N | Age | Test | Time of evaluation | Change in bone density (hip) | | Density used to assess compliance or adjust therapy?
Author | Study design | N | Age | Test | Time of evaluation | Treated group (% change) | Difference between groups | Density used to assess compliance or adjust therapy?
Chesnut (1995)^ 281 ^ | RCT (alendronate) in PO | 188 | 63 | DXA | 2 years | 7.0% | 8.2% | No
Blake (1996)^ 316 ^ | RCT (etidronate) in PO | 152 | | DXA | 2 years | 1.6% | 1.7% | No
Shiraki (1998)^ 448 ^ | RCT (alendronate) in PO | 101 | | DXA | 36 weeks | 5.6% | | No
Wimalawansa (1998)^ 363 ^ | RCT (etidronate+estrogen) in PO | 72 | 64.9 | DXA | 2 years | 4.7% | 6.9% | No
Wimalawansa (1998)^ 363 ^ | RCT (etidronate+estrogen) in PO | 72 | 64.9 | DXA | 4 years | 7.0% | 11.4%
Braga de Castro Machado (1999)^ 364 ^ | RCT (alendronate+calcium) in high-risk women with T-score <-2.5 | 26 | | DXA | 6 months | 4.6% | 4.3% | No
Parviainen (1999)^ 450 ^ | RCT (estrogen+calcium) in PO | 33 | 50-75 | DXA | 6 months | 1.8% | ns
Parviainen (1999)^ 450 ^ | RCT (estrogen+calcium) in PO | 33 | 50-75 | DXA | 2 years | 3.4% | ns | No
Ravn (1999)^ 451 ^, Hosking (1998)^ 452 ^ | RCT (alendronate+estrogen) in PN | 1,609 | 45-59 | DXA | 4 years | 1.4% | 4.3% | No
Ravn (1999)^ 451 ^, Hosking (1998)^ 452 ^ | RCT (alendronate+estrogen) in PN | 1,609 | 45-59 | DXA | 4 years | 0.1% | ns | No
Ravn (1999)^ 451 ^, Hosking (1998)^ 452 ^ | RCT (alendronate+estrogen) in PN | 1,609 | 45-59 | DXA | 2 years | 2.1% | 3.3% | No
Hochberg (1999)^ 366 ^ | RCT (alendronate) in PO | 2,984 | 68.6 | DXA | 1 year | 2.0% | | No
Hochberg (1999)^ 366 ^ | RCT (alendronate) in PO | 2,984 | 68.6 | DXA | 3 years | 2.9% | | No

Note: When multiple doses were administered, the table shows results for the group that had the best response.

Evidence Table 10. Diagnostic accuracy studies of the agreement between markers and bone density

Study, year | Population, setting | Markers* | Reference test | Definition of + BMD test | Cutoff for + marker test | sensitivity | specificity | Positive predictive value | Negative predictive value | False positive rate | False negative rate | Positive likelihood ratio | Negative likelihood ratio | Quality rating
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | HPR | spine or hip BMD | osteoporotic (>2 standard deviations below mean BMD of control group) | >.03 mmol/mmol HPR/Cr | 0.45 | 0.79 | 0.60 | 0.68 | 0.21 | 0.55 | 2.18 | 0.69 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | HPR | spine or hip BMD | osteoporotic (>2 standard deviations below mean BMD of control group) | >.02 mmol/mmol HPR/Cr | 0.90 | 0.28 | 0.46 | 0.80 | 0.72 | 0.10 | 1.24 | 0.36 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | HPR | spine or hip BMD | osteopenic (1-2 standard deviations below mean BMD of control group) | >.03 mmol/mmol HPR/Cr | 0.29 | 0.79 | 0.45 | 0.66 | 0.21 | 0.71 | 1.42 | 0.89 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | HPR | spine or hip BMD | osteopenic (1-2 standard deviations below mean BMD of control group) | >.02 mmol/mmol HPR/Cr | 0.82 | 0.28 | 0.40 | 0.73 | 0.72 | 0.18 | 1.14 | 0.64 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | PYR | spine or hip BMD | osteoporotic | >26 nm/mm | 0.55 | 0.83 | 0.69 | 0.73 | 0.17 | 0.45 | 3.19 | 0.54 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | PYR | spine or hip BMD | osteoporotic | >15 nm/mm | 0.90 | 0.14 | 0.42 | 0.67 | 0.86 | 0.10 | 1.04 | 0.73 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | PYR | spine or hip BMD | osteopenic | >26 nm/mm | 0.24 | 0.83 | 0.44 | 0.65 | 0.17 | 0.76 | 1.36 | 0.92 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | PYR | spine or hip BMD | osteopenic | >15 nm/mm | 0.82 | 0.28 | 0.40 | 0.73 | 0.72 | 0.18 | 1.14 | 0.64 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | ICTP | spine or hip BMD | osteoporotic | >4 ng/l | 0.10 | 0.66 | 0.17 | 0.51 | 0.34 | 0.90 | 0.29 | 1.37 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | ICTP | spine or hip BMD | osteoporotic | >2.5 ng/l | 0.95 | 0.14 | 0.43 | 0.80 | 0.86 | 0.05 | 1.10 | 0.36 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | ICTP | spine or hip BMD | osteopenic | >4 ng/l | 0.18 | 0.66 | 0.23 | 0.58 | 0.34 | 0.82 | 0.51 | 1.26 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | ICTP | spine or hip BMD | osteopenic | >2.5 ng/l | 0.88 | 0.14 | 0.38 | 0.67 | 0.86 | 0.12 | 1.02 | 0.85 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | CTX | spine or hip BMD | osteoporotic | >200 ng/mmol | 0.75 | 0.85 | 0.79 | 0.81 | 0.15 | 0.25 | 4.88 | 0.30 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | CTX | spine or hip BMD | osteoporotic | >100 ng/nmol | 1.00 | 0.27 | 0.51 | 1.00 | 0.73 | 0.00 | 1.37 | 0.00 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | CTX | spine or hip BMD | osteopenic | >200 ng/mmol | 0.31 | 0.85 | 0.56 | 0.67 | 0.15 | 0.69 | 2.03 | 0.81 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Guerrero (1996)^ 378 ^ | Spain, 20 women with osteoporosis, 29 healthy controls at one institution | CTX | spine or hip BMD | osteopenic | >100 ng/mmol | 0.94 | 0.27 | 0.44 | 0.88 | 0.73 | 0.06 | 1.28 | 0.23 | Poor: reference standard not independent of screening test, very small sample size, narrow selected spectrum of patients
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | OC | spine BMD | osteoporotic (BMD >2.5 standard deviations below young normal mean) | >6.3 ng/ml | 0.52 | 0.52 | 0.15 | 0.87 | 0.48 | 0.48 | 1.10 | 0.91 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | OC | spine BMD | osteoporotic or low (BMD >1 standard deviation below young normal mean) | | 0.56 | 0.62 | 0.65 | 0.52 | 0.38 | 0.44 | 1.46 | 0.72 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | BALP | spine BMD | osteoporotic | >23.1 U/l | 0.70 | 0.58 | 0.21 | 0.92 | 0.42 | 0.30 | 1.66 | 0.52 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | BALP | spine BMD | osteoporotic or low | | 0.51 | 0.60 | 0.62 | 0.49 | 0.40 | 0.49 | 1.27 | 0.82 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | PICP | spine BMD | osteoporotic | >100.7 ng/ml | 0.22 | 0.88 | 0.23 | 0.88 | 0.12 | 0.78 | 1.83 | 0.89 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | PICP | spine BMD | osteoporotic or low | | 0.17 | 0.92 | 0.73 | 0.47 | 0.08 | 0.83 | 2.09 | 0.90 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | PYR | spine BMD | osteoporotic | 3.4 nmol/l glomerular filtrate | 0.52 | 0.44 | 0.13 | 0.85 | 0.56 | 0.48 | 0.93 | 1.09 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | PYR | spine BMD | osteoporotic or low | | 0.61 | 0.52 | 0.62 | 0.51 | 0.48 | 0.39 | 1.28 | 0.74 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | D-PYR | spine BMD | osteoporotic | .50 nmol/l glomerular filtrate | 0.43 | 0.53 | 0.13 | 0.85 | 0.47 | 0.57 | 0.93 | 1.06 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | D-PYR | spine BMD | osteoporotic or low | | 0.48 | 0.56 | 0.58 | 0.46 | 0.44 | 0.52 | 1.10 | 0.92 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | NTX | spine BMD | osteoporotic | 3.2 nmol/l glomerular filtrate | 0.57 | 0.67 | 0.22 | 0.91 | 0.33 | 0.43 | 1.72 | 0.65 | Good
Melton (1997)^ 379 ^ | Rochester, MN, random sample, 166 postmeno-pausal women not on estrogen | NTX | spine BMD | osteoporotic or low | | 0.51 | 0.82 | 0.78 | 0.57 | 0.18 | 0.49 | 2.84 | 0.60 | Good
Minisola (1998)^ 380 ^ * | Italy, 34 postmeno-pausal women, relatives of medical students at one institution | TRAP | spine BMD | osteoporotic (>2.5 standard deviations below young adult mean) | >16 U/L | 0.25 | 0.94 | 0.75 | 0.65 | 0.06 | 0.75 | 4.50 | 0.79 | Poor: small sample size
Minisola (1998)^ 380 ^ * | Italy, 34 postmeno-pausal women, relatives of medical students at one institution | TRAP | spine BMD | osteoporotic (>2.5 standard deviations below young adult mean) | >12 U/L | 0.83 | 0.17 | 0.40 | 0.60 | 0.83 | 0.17 | 1.00 | 1.00 | Poor: small sample size
Minisola (1998)^ 380 ^ * | Italy, 34 postmeno-pausal women, relatives of medical students at one institution | ALP | spine BMD | osteoporotic (>2.5 standard deviations below young adult mean) | >95 U/L | 0.42 | 0.86 | 0.63 | 0.72 | 0.14 | 0.58 | 2.92 | 0.68 | Poor: small sample size
Minisola (1998)^ 380 ^ * | Italy, 34 postmeno-pausal women, relatives of medical students at one institution | ALP | spine BMD | osteoporotic (>2.5 standard deviations below young adult mean) | >60 U/L | 1.00 | 0.05 | 0.41 | 1.00 | 0.95 | 0.00 | | 0.00 | Poor: small sample size
Minisola (1998)^ 380 ^ * | Italy, 34 postmeno-pausal women, relatives of medical students at one institution | a | spine BMD | osteoporotic (>2.5 standard deviations below young adult mean) | >115 pmoles/cr | 0.27 | 0.95 | 0.75 | 0.71 | 0.05 | 0.73 | 5.73 | 0.76 | Poor: small sample size
Minisola (1998)^ 380 ^ * | Italy, 34 postmeno-pausal women, relatives of medical students at one institution | a | spine BMD | osteoporotic (>2.5 standard deviations below young adult mean) | >70 pmoles/cr | 0.64 | 0.62 | 0.47 | 0.76 | 0.38 | 0.36 | 1.67 | 0.59 | Poor: small sample size
Pansini (1992)^ 377 ^ | Italy, 78 postmeno-pausal women at one institution | OC | | osteopenic (>2 standard deviations below young normal mean) | >14.6 ng/ml | 0.24 | 0.87 | 0.57 | 0.61 | 0.13 | 0.76 | 1.82 | 0.87 | Fair: moderate sample size
Pansini (1992)^ 377 ^ | Italy, 78 postmeno-pausal women at one institution | OC | | osteopenic (>2 standard deviations below young normal mean) | > 8 ng/ml | 0.91 | 0.32 | 0.51 | 0.82 | 0.68 | 0.09 | 1.34 | 0.28 | Fair: moderate sample size
Pansini (1992)^ 377 ^ | Italy, 78 postmeno-pausal women at one institution | CA | | osteopenic | >150 | 0.21 | 0.71 | 0.35 | 0.55 | 0.29 | 0.79 | 0.73 | 1.11 | Fair: moderate sample size
Pansini (1992)^ 377 ^ | Italy, 78 postmeno-pausal women at one institution | CA | | osteopenic | >50 | 0.84 | 0.22 | 0.42 | 0.67 | 0.78 | 0.16 | 1.07 | 0.74 | Fair: moderate sample size
Taguchi (1998)^ 381 ^ | Japan, 1100 healthy volunteers at 2 instit., 272 premeno., 828 postmeno. | NTX | | osteoporotic (>2.5 standard deviations below peak bone mass standard) | 30 bone collagen equivalents/nmol cr | 0.61 (given) | 0.52 (given) | | | | | | | Good
Taguchi (1998)^ 381 ^ | Japan, 1100 healthy volunteers at 2 instit., 272 premeno., 828 postmeno. | NTX | | osteoporotic | 31 bone collagen equivalents/nmol cr | 0.59 (given) | 0.5 (given) | | | | | | | Good

* Our analysis excludes patients who had a history of fracture; See Table 13.

Evidence Table 11. Prospective studies of markers to predict fracture in women not on treatment for osteoporosis

Study, year | Population/Setting | Age (years) | Definition of abnormal marker | Length of followup | Fracture type | Results by Odds Ratio or Relative Risk (*significant or NS non-significant) | | | | | | | | | | | | Quality Rating
Study, year | Population/Setting | Age (years) | Definition of abnormal marker | Length of followup | Fracture type | ALP | BALP | Ca | Oc | Hydroxy-proline | PYR | D-PYR | ICTP | NTX | CTX | P1CP | TRAP | Quality Rating
Akesson (1995)^ 383 ^ | Sweden, population-based sample of 328 women of Scandinavian background, one city, urban, randomly selected from city population files | 40-80 | Decrease of 1 standard deviation of PICP and ICTP, independent of age and BMC | 5 years | All | | | | OR = 1.3 NS | | | | OR = 1.9* | | | OR = 1.8* | | Good
Garnero (1996)^ 385 ^ | 5 French cities, volunteers from population-based listing, nested case-control study, EPIDOS cohort, 109 patients with hip fracture, 292 controls | >74 | Above upper limit of premenopausal range | Mean 22 months | Hip | | OR = 1.1 NS | | OR = 1.0 NS | | | OR =1.9 | | OR = 1.4 NS | OR = 2.2* | | | Good
Vergnaud (1997)^ 387 ^ | EPIDOS cohort, 104 patients with hip fracture, 255 controls | >74 | Highest quartile of controls | Mean 22 months | Hip | | | | Total: 1.3* (p = 0.39) undercarboxylated: 2.0* (p< 0.008)
Ross (2000)^ 384 ^ | Hawaii, 512 community dwelling, postmenopausal women | 43-80 | 1 standard deviation increase in baseline marker | Mean 2.7 years | All | | 1.53* | | | | | | | | 1.54*
Szulc (1993)^ 382 ^ | France, 195 elderly institutionalized women | 70-101 | >1.65 ng/ml | 18 months | Hip and other non-vertebral | | | | RR = 5.9* (95% CI 1.5-22.7) | | | | | | | | | Fair. Groups not comparable (some received calcium supplements), also, not generalizable
van Daele (1996)^ 386 ^ | Residents of one district of Rotterdam, nested case-control study, Rotterdam cohort, 36 women with hip fracture, 163 without hip fracture | > 55 | < median for OC and ALP, > median for other markers | Median 2.4 years | Hip | | | | RR = 3.1 NS | | Total: RR = 3.3* Free: RR = 3.0* | Total: RR = 1.4 NS Free: RR = 1.8 NS | | | | | | Good

Note: When multiple doses were administered, the table shows results for the group that had the best response.

Evidence Table 12. Diagnostic accuracy of markers to predict fracture in women not on treatment for osteoporosis

Study, year | Marker* | Outcome | Cutoff for + marker test | sensitivity | specificity | Positive predictive value | Negative predictive value | False positive rate | False negative rate | Positive likelihood ratio | Negative likelihood ratio | Quality Rating
Szulc (1993)^ 382 ^ | undercarb-oxylated Oc | Hip fracture | >1.65 ng/ml | 0.53 | 0.79 | 0.18 | 0.95 | 0.21 | 0.47 | 2.59 | 0.59 | Fair. Groups not comparable (some received calcium supplements), also, not generalizable
Garnero (1996)^ 385 ^ | CTX | Hip fracture | > 2 standard deviations above mean for premenopausal women | 0.36 | 0.81 | 0.41 | 0.77 | 0.19 | 0.64 | 1.90 | 0.79 | Good
Garnero (1996)^ 385 ^ | D-PYR | Hip fracture | > 2 standard deviations above mean for premenopausal women | 0.30 | 0.81 | 0.38 | 0.76 | 0.19 | 0.70 | 1.61 | 0.86

*See Table 13

Evidence Table 13. Prospective studies of markers to predict bone loss in women not on treatment for osteoporosis

Study, year | Population, setting | Age (years) | Time since menopause | Marker comparison measures | Bone loss comparison measure | Results (correlation coefficients for marker results and bone loss measures) *significant or NS non-significant | | | | | | | | | | | Quality Rating
Study, year | Population, setting | Age (years) | Time since menopause | Marker comparison measures | Bone loss comparison measure | ALP | BALP | Ca | Oc | Hydroxy-proline | PYR | D-PYR | ICTP | NTX | CTX | P1CP | Quality Rating
Bauer (1999)^ 397 ^ | Subset of 295 white women participating in population-based study of risk factors for fracture (SOF), 4 clinical centers (OR, MN, MD, PA) | Mean 73 (67-89) | Not given | At baseline, above median, and highest quartile | Annual % change in BMD by hip DXA; mean follow-up 3.8 years (range 3.3 to 5.1 years) | | 0.08 NS | | 0.12* | | 0.09* | 0.13* | | 0.15* | 0.08* | | Good
Cosman (1996)^ 393 ^ | New York, 30 women recruited from local community through one institution | Mean 62.4 (standard deviation 1.5, range 48-86) | Mean = 18 years (standard deviation 2.2, range 1-52) | At baseline, at least 1 standard deviation above the mean young normal | DPA, rate of BMD change (% bone rate change) over 3 years high bone losers defined as >1% loss/year (note: results are from a stepwise regression model that included multiple markers) | | spine: 0.11* | | Hip: 0.12* | spine: 0.15* | | | spine: 0.09-.015* hip: 0.13* | | | | Poor. Groups not comparable (some with osteoporosis, prior fracture), small size, not blinded assessment of outcomes. Correlation coefficients estimated from a stepwise regression (Table 6 of article).
Christiansen (1990)^ 388 ^ | Denmark, 70 participants selected by questionnaires and medical screening, one institution | 45-54 | 6 months to 3 years | Baseline value | % bone loss over 2 years, BMC of forearms, spine, total body bone mineral content | | | | | Regression equation using 4 markers (OC, ALP, CA, HPR): proximal forearm: 0.76* ultradistal forearm: 0.32* spine: 0.07 NS total body: 0.21 NS
Keen (1996)^ 394 ^ | UK, 141 normal volunteers participating in an ovarian cancer screening program | 45-62 | Within 5 years | Baseline value | Annual % change in BMD over 4 years, DPA spine and hip | Spine: -0.12 NS | | Spine: -0.04 NS | | Spine: 0.15 NS | Spine: 0.05 NS | Spine: 0.02 NS | | | | | Poor. Not blinded assessment of outcomes, groups not comparable, not same BMD measurements on all
Keen (1996)^ 394 ^ | UK, 141 normal volunteers participating in an ovarian cancer screening program | 45-62 | Within 5 years | Baseline value | Annual % change in BMD over 4 years, DPA spine and hip | Hip: -0.13 NS | | Hip: -0.11 NS | | Hip: -0.04 NS | Hip: -0.00 NS | Hip: -0.07 NS | | | | | Poor. Not blinded assessment of outcomes, groups not comparable, not same BMD measurements on all
Garnero (1999)^ 399 ^ | France, 305 women from population-based study of determinants of bone loss (OFELY), from one health insurance company | 50-88 | 1-39 years | Baseline value, highest quartile | Annual % change in midradius BMD over 4 years, DXA, highest quartile | | -0.06 NS | | -0.23* | | | | | -0.20* | -0.21* | -0.07 NS
Miura (1995)^ 390 ^ | Japan, "sports-loving" volunteers, one institution, 51 premenopausal, 30 postmenopausal | Premenopausal: 28-59 Postmenopausal: 42-59, mean 52 | Mean = 2.5 years | Baseline value | Rate of bone loss over 3 years, DXA of spine annually | 0.28 NS | | | 0.21 | | 0.45 NS | 0.34NS Free D-PYR: 0.17 NS | | | | 0.48* | Poor. Not blinded assessment of outcomes, not comparable groups (some women perimenopausal), confounders not adjusted for
Nordin (1993)^ 389 ^ | Australia, 307 normal volunteers | Mean 59 (39-72) | 10 years (range 1-37) | Baseline value | % change in forearm BMD at 5-year followup | not given, NS | | r = -0.16 | | r = -0.31* | | | | | | | Good
Reeve (1995)^ 391 ^ | UK, 64 women attending 6 NHS family practices for routine care | At followup, mean 57 (standard deviation 2.4, range 49.3-60.5) | 9-36 months | Baseline value | Low spinal bone mass after 5 years, DPA | | | | NS? | NS? | | | | | | | Fair. Not blinded assessment of outcomes, DXA not used
Reginster (1997)^ 395 ^ | Belgium, 92 healthy white women, obese women excluded, untreated cohort of participants in clinical trial of bone loss prevention | Not reported | < 36 months | Change in markers after 6 months | Change in BMD of lumbar spine (DPA) at 3 years | not given, NS | not given, NS | r = -0.23* | | not given, NS | | | | | | | Fair. Low follow-up rate (63%), confounders not adjusted for
Rosso (1995)^ 392 ^ | Italy, 45 healthy women attending "Mineral Metabolism Service" at one institution | Mean 52.4 years (standard deviation 4.1) | Within 3 years | Baseline value | % yearly bone loss, BMD of ultradistal forearm, follow-up period not clear | -0.30* | | not given, NS | not given, NS | not given, NS | | | | | | | Fair. Not all had same outcome assessments, not blinded outcome assessment
Sinigaglia (1997)^ 396 ^ | Italy, 42 women recruited by questionnaire, one institution | Mean 52.3 (standard deviation 2.6) | 6 months to 3 years | Baseline value | Bone loss by spine DXA at 1 year follow up: higher than 4% or not | | | | | | serum: not given, NS | serum: -0.36* | | | | | Poor. High loss to followup, not blinded assessment of outcomes, no adjustment for confounders
Sinigaglia (1997)^ 396 ^ | Italy, 42 women recruited by questionnaire, one institution | Mean 52.3 (standard deviation 2.6) | 6 months to 3 years | Baseline value | Bone loss by spine DXA at 1 year follow up: higher than 4% or not | | | | | | urine: not given, NS | urine: not given, NS | | | | | Poor. High loss to followup, not blinded assessment of outcomes, no adjustment for confounders
Yoshimura (1999)^ 398 ^ | Japan, 50 women from one town, randomly selected from participants in a health survey | Mean 59.2 (standard deviation 11.5) | Not given | Baseline value | Annual change rate in BMD over 3 years by spine and hip DXA | Spine: 0.11 NS | | Spine: 0.02 NS | Spine: -0.08 NS | | Spine: 0.12 NS | Spine: 0.03 NS | Spine: 0.11 NS | | | Spine: 0.04 NS | Poor. Small sample, not blinded assessment of outcomes, no adjustment for confounders
Yoshimura (1999)^ 398 ^ | Japan, 50 women from one town, randomly selected from participants in a health survey | Mean 59.2 (standard deviation 11.5) | Not given | Baseline value | Annual change rate in BMD over 3 years by spine and hip DXA | Hip: 0.14 NS | | Hip: 0.14 NS | Hip: 0.14 NS | | Hip: 0.10 NS | Hip: .16* | Hip: 0.05 NS | | | Hip: .19* | Poor. Small sample, not blinded assessment of outcomes, no adjustment for confounders

Evidence Table 14. Studies of the diagnostic accuracy of markers to predict bone loss

Study, year | Markers | Outcome | Cutoff for + marker test | sensitivity | specificity | Positive predictive value | Negative predictive value | False positive rate | False negative rate | Positive likelihood ratio | Negative likelihood ratio | Quality Rating
Bauer (1999)^ 397 ^ | CTX | Bone loss > 1.1% per year (highest tertile) | above median | 0.68 | 0.49 | 0.39 | 0.76 | 0.51 | 0.32 | | | Good
Bauer (1999)^ 397 ^ | CTX | Bone loss > 1.1% per year (highest tertile) | 4th quartile | 0.33 | 0.74 | 0.38 | 0.69 | 0.26 | 0.67 | | | Good
Bauer (1999)^ 397 ^ | D-PYR | Bone loss > 1.1% per year | above median | 0.56 | 0.55 | 0.38 | 0.72 | 0.45 | 0.44 | | | Good
Bauer (1999)^ 397 ^ | D-PYR | Bone loss > 1.1% per year | 4th quartile | 0.28 | 0.78 | 0.38 | 0.68 | 0.22 | 0.72 | | | Good
Bauer (1999)^ 397 ^ | NTX | Bone loss > 1.1% per year | above median | 0.72 | 0.50 | 0.42 | 0.79 | 0.50 | 0.28 | | | Good
Bauer (1999)^ 397 ^ | NTX | Bone loss > 1.1% per year | 4th quartile | 0.38 | 0.78 | 0.46 | 0.71 | 0.22 | 0.62 | | | Good
Bauer (1999)^ 397 ^ | PYR | Bone loss > 1.1% per year | above median | 0.63 | 0.56 | 0.42 | 0.71 | 0.44 | 0.37 | | | Good
Bauer (1999)^ 397 ^ | PYR | Bone loss > 1.1% per year | 4th quartile | 0.30 | 0.79 | 0.41 | 0.69 | 0.21 | 0.70 | | | Good
Bauer (1999)^ 397 ^ | BALP | Bone loss > 1.1% per year | above median | 0.59 | 0.46 | 0.35 | 0.69 | 0.54 | 0.41 | | | Good
Bauer (1999)^ 397 ^ | BALP | Bone loss > 1.1% per year | 4th quartile | 0.29 | 0.74 | 0.36 | 0.68 | 0.26 | 0.71 | | | Good
Bauer (1999)^ 397 ^ | OC | Bone loss > 1.1% per year | above median | 0.63 | 0.47 | 0.37 | 0.72 | 0.53 | 0.37 | | | Good
Cosman (1996)^ 393 ^ | HPR, ICTP, BALP | > 0% annual change in spine BMD | Predicted spine BMD using regression equation with 3 markers + calcium intake | 0.97 | 0.29 | 0.86 | 0.67 | 0.71 | 0.03 | 1.36 | 0.11 | Poor. Groups not comparable (some with osteoporosis, prior fracture), small size, not blinded assessment of outcomes
Cosman (1996)^ 393 ^ | HPR, ICTP, BALP | >3% annual change in spine BMD | Predicted spine BMD using regression equation with 3 markers + calcium intake | 0.57 | 0.82 | 0.40 | 0.90 | 0.18 | 0.43 | 3.14 | 0.52 | Poor. Groups not comparable (some with osteoporosis, prior fracture), small size, not blinded assessment of outcomes
Cosman (1996)^ 393 ^ | ICTP, OC | >0% annual change in hip BMD | Predicted hip BMD using regression equation with 2 markers + body mass index | 0.96 | 0.67 | 0.85 | 0.89 | 0.33 | 0.04 | 2.87 | 0.07 | Poor. Groups not comparable (some with osteoporosis, prior fracture), small size, not blinded assessment of outcomes
Cosman (1996)^ 393 ^ | ICTP, OC | >3% annual change in hip BMD | Predicted hip BMD using regression equation with 2 markers + body mass index | 0.17 | 0.97 | 0.50 | 0.85 | 0.03 | 0.83 | 4.83 | 0.86 | Poor. Groups not comparable (some with osteoporosis, prior fracture), small size, not blinded assessment of outcomes
Christiansen (1990)^ 388 ^ | ALP, CA, HPR | Fast losers (see Christiansen 87 for defs) | Predicted loss using regression equation with 3 markers + fat mass | 0.64 | 0.83 | 0.67 | 0.81 | 0.17 | 0.36 | 3.73 | 0.44
Christiansen (1990)^ 388 ^ | ALP, CA, HPR | Fast + borderline losers | Predicted loss using regression equation with 3 markers + fat mass | 0.88 | 0.61 | 0.80 | 0.74 | 0.39 | 0.13 | 2.24 | 0.21
Christiansen (1990)^ 388 ^ | BGP, ALP, CA, HPR | Fast losers | Predicted loss using regression equation with 4 markers | 0.70 | 0.87 | 0.73 | 0.85 | 0.13 | 0.30 | 5.45 | 0.35
Christiansen (1990)^ 388 ^ | BGP, ALP, CA, HPR | Fast + borderline losers | Predicted loss using regression equation with 4 markers | 0.91 | 0.74 | 0.88 | 0.81 | 0.26 | 0.09 | 3.51 | 0.12
Garnero (1999)^ 399 ^ | OC | Annual % midradius bone loss over 4 years, highest tertile | 2 standard deviations above the premenopausal mean | 0.36 | 0.82 | 0.49 | 0.72
Garnero (1999)^ 399 ^ | BALP | Annual % midradius bone loss over 4 years, highest tertile | 2 standard deviations above the premenopausal mean | 0.39 | 0.79 | 0.48 | 0.71 | 0.21 | 0.61
Garnero (1999)^ 399 ^ | PICP | Annual % midradius bone loss over 4 years, highest tertile | 2 standard deviations above the premenopausal mean | 0.16 | 0.91 | 0.48 | 0.68 | 0.09 | 0.84
Garnero (1999)^ 399 ^ | Urinary NTX | Annual % midradius bone loss over 4 years, highest tertile | 2 standard deviations above the premenopausal mean | 0.59 | 0.66 | 0.46 | 0.76 | 0.34 | 0.41
Garnero (1999)^ 399 ^ | Urinary CTX | Annual % midradius bone loss over 4 years, highest tertile | 2 standard deviations above the premenopausal mean | 0.40 | 0.78 | 0.48 | 0.72 | 0.22 | 0.60
Garnero (1999)^ 399 ^ | Serum CTX | Annual % midradius bone loss over 4 years, highest tertile | 2 standard deviations above the premenopausal mean | 0.37 | 0.85 | 0.56 | 0.76 | 0.15 | 0.63
Keen (1996)^ 394 ^ | OC, ALP, Ca, HPR, PYR, D-PYR (individual results not given) | | | 0.33 to 0.58 | 0.50 to 0.72 | | | 0.28 to 0.50 | 0.42 to 0.67 | | | Poor. Not blinded assessment of outcomes, groups not comparable, not same BMD measurements on all
Miura (1995)^ 390 ^ | PICP, D-PYR, Oc | > 0.05 g/cm2 bone loss | Predicted bone loss Using regression equation using 3 markers and initial BMD | 0.78 | 0.80 | 0.88 | 0.67 | 0.20 | 0.22 | 3.89 | 0.28 | Poor. Not blinded assessment of outcomes, not comparable groups (some women perimenopausal), no adjustment for confounders
Reeve (1995)^ 391 ^ | HPR, Oc | | | ROC analysis: area under the curve close to 50% | | | | | | | | Fair. Not blinded assessment of outcomes, DXA not used
Reginster (1997)^ 395 ^ | CA | >10% loss in spine BMD change at 36 months ("fast losers") | > 0.05 mg/dl change at 6 months | 1.00 | 0.24 | 0.29 | 1.00 | 0.76 | 0.00 | 1.32 | 0.00 | Fair. Low follow-up rate (63%), confounders not adjusted for
Reginster (1997)^ 395 ^ | CA | > 3.4% loss in spine BMD at 36 months ("fast" + "slow" losers) | > 0.05 mg/dl change at 6 months | 0.83 | 0.21 | 0.65 | 0.40 | 0.79 | 0.17 | 1.04 | 0.84 | Fair. Low follow-up rate (63%), confounders not adjusted for
Rosso (1995)^ 392 ^ | ALP | > 3% yearly bone loss | > 80 iu/l at baseline | 0.30 | 0.63 | 0.40 | 0.52 | 0.38 | 0.70 | 0.80 | 1.12 | Fair. Not all had same outcome assessments, not blinded outcome assessment
Rosso (1995)^ 392 ^ | ALP | > 1% yearly bone loss | > 80 iu/l at baseline | 0.39 | 0.77 | 0.80 | 0.34 | 0.23 | 0.61 | 1.68 | 0.80 | Fair. Not all had same outcome assessments, not blinded outcome assessment
Rosso (1995)^ 392 ^ | ALP | > 3% yearly bone loss | >55 iu/l at baseline | 0.85 | 0.25 | 0.49 | 0.67 | 0.75 | 0.15 | 1.13 | 0.60 | Fair. Not all had same outcome assessments, not blinded outcome assessment
Rosso (1995)^ 392 ^ | ALP | > 1% yearly bone loss | >55 iu/l at baseline | 0.81 | 0.23 | 0.71 | 0.33 | 0.77 | 0.19 | 1.05 | 0.84 | Fair. Not all had same outcome assessments, not blinded outcome assessment
Rosso (1995)^ 392 ^ | ALP | > 3% yearly bone loss | >95 iu/l at baseline | 0.15 | 0.92 | 0.60 | 0.56 | 0.08 | 0.85 | 1.80 | 0.93 | Fair. Not all had same outcome assessments, not blinded outcome assessment
Rosso (1995)^ 392 ^ | ALP | > 1% yearly bone loss | >95 iu/l at baseline | 0.16 | 1.00 | 1.00 | 0.33 | 0.00 | 0.84 | #DIV/0! | 0.84 | Fair. Not all had same outcome assessments, not blinded outcome assessment
Nordin (1993)^ 389 ^ | HPR | >5% bone loss at 5-year follow-up | > 14.3 /mmol (highest quintile) at baseline | 1.00 | 0.49 | 0.75 | 1.00 | 0.51 | 0.00 | -- | 0.00 | Good, but individual data were not reported. We estimated "best case" sensitivity and specificity from means and standard errors (Figure 3 of article.)
Nordin (1993)^ 389 ^ | HPR | >5% bone loss at 5-year follow-up | > 20.1 /mmol (2 highest quintiles) at baseline | 0.66 | 1.00 | 1.00 | 0.66 | 0.00 | 0.34 | -- | 0.34 | Good, but individual data were not reported. We estimated "best case" sensitivity and specificity from means and standard errors (Figure 3 of article.)

Evidence Table 15. Prospective studies of markers to monitor or predict response to therapy in women on treatment for osteoporosis

Study, year | Population/Setting | Age (years) | Time since menopause | Treatment | Bone loss comparison measures | Marker comparison measures | Results (correlation coefficients for marker results and bone loss measures) *significant or NS non-significant | | | | | | | | | | | Quality Rating
Study, year | Population/Setting | Age (years) | Time since menopause | Treatment | Bone loss comparison measures | Marker comparison measures | ALP | BALP | CA | OC | HPR | PYR | D-PYR | ICTP | NTX | CTX | PICP | Quality Rating
Women on Alendronate Therapy
Garnero (1999)^ 404 ^ | France, 307 women with osteoporosis | 45-78 (mean 64, standard deviation 7) | At least 5 years (mean = 17.6 years, standard deviation 8) | Alendronate 10 mg | % change from baseline at 24 months, DXA spine | % change from baseline at 6 months | -0.54* | | | | | | | | | | | Good
Garnero (1994)^ 402 ^ | France, 85 women with osteoporosis | 43-74 (mean 63, standard deviation 6.4) | At least 5 years (mean = 15.9, standard deviation 6.8 years) | Alendronate 5 or 10 mg | Change at 24 months | Change at 3 months | -0.67* | -0.63* | | -0.21 NS | | -0.20* | -0.53* | | -0.67* | | | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Greenspan (1998)^ 282 ^ | Boston, 120 healthy, ambulatory community-dwelling women | > 64 (mean 71, standard deviation 7) | | Alendronate 5 mg, then 10 mg in final year | Change at 30 months | Change at 6 months | | Lateral spine: -0.06 NS hip: -0.17 NS total body: -0.02 NS forearm: -0.05 NS | | Lateral spine: -0.32* hip: -0.31* total body: -0.26 NS forearm: -0.20 NS | Lateral spine: -0.00 NS hip:0.24 NS total body: 0.11 NS forearm: 0.10 NS | | Lateral spine: -0.26 NS hip: -0.28* total body: -0.34* forearm: -0.02 NS | | | | | Fair. Not clear if blinded assessment of outcomes, <80% followup
Kyd (1998)^ 403 ^ | UK, 35 women | mean 67 (range 52-82) | Median 21 years (range 1-62 years) | Alendronate 10 mg | Change after 1 year of treatment, DXA of spine and hip | Baseline, and change from baseline at 6 months | baseline marker: spine: r = 0.13 NS hip: 0.25 NS change in marker at 6 months: spine:r = -0.24 NS hip: r = -0.09 NS | | | | | | | | | | | Fair. Not clear if blinded assessment of outcomes.
Ravn (1999)^ 374 ^ | 4 clinical centers (Denmark, UK, HI, OR), 794 women | 45-59 | At least 6 months | Alendronate 5 mg | Change from baseline at 24 months, DXA of spine, hip, total body, forearm | Change from baseline at 6 months | | Spine: -0.25* hip: -0.18* total body: -0.16* forearm: -0.17* | | | | | Spine: -0.31* hip: -0.30* total body: -0.28* forearm: -0.12* | | | | | Fair. Not clear if blinded assessment of outcomes.
Ravn (1999)^ 405 ^ | Denmark, 67 women, cohort of multicenter study, from 8 cities in 1 Copenhagen County | 40-59 | 6 months-3 years | Alendronate 1 mg, 5 mg, 10 mg, or 20 mg | Change from baseline at 24 months, DXA of spine, hip, total body | Change from baseline at 6 months | spine: -0.32* hip: -0.17 NS total body: -0.17 NS | Spine: -0.59* hip: -0.39* total body: -0.33* | | | spine: 0.10 NS hip: -0.02 NS total body: 0.11 NS | | spine: -0.45* hip: -0.27* total body: -0.20 NS | | | | | Fair. Not clear if blinded assessment of outcomes.

Evidence Table 15. Prospective studies of markers to monitor or predict response to therapy in women on treatment for osteoporosis

Study, year | Population/Setting | n | Age (years) | Time since menopause | Treatment | Bone loss comparison measures | Marker comparison measures | Results (correlation coefficients for marker results and bone loss measures) *significant or NS non-significant | | | | | | | | | | | Quality Rating
Study, year | Population/Setting | n | Age (years) | Time since menopause | Treatment | Bone loss comparison measures | Marker comparison measures | ALP | BALP | CA | OC | HPR | PYR | D-PYR | ICTP | NTX | CTX | PICP | Quality Rating
Women on Hormone Replacement Therapy
Chen (1996)^ 375 ^ | Japan, 36 women diagnosed with osteoporosis or osteopenia | 36 | mean = 53.1 (standard deviation = 3.5) | | HRT | change at 12 months | change at 3 months | 0.41 NS | | 0.17 NS | N-terminal OC: 0.58* OC: 0.14 NS | 0.20 NS | 0.11 NS | 0.32 NS | | | | | Fair. Not specified if blinded outcome assessment, followup rate not clear
Chesnut (1997)^ 408 ^ | US, 227 women, multicenter | 227 | 40-58 | 6 months-3 years | estrogen/progesterone | change at 1 year | change at 6 months | | -0.32* | | -0.11 NS | -0.20* | | | | -0.39* | | | Poor. Not specified if blinded outcome assessment, not intention-to-treat
Delmas (2000)^ 415 ^ | France, 388 postmenopausal women enrolled in clinical trials, one university hospital | 388 | 40-60 mean = 53.1 (standard deviation = 20.3 months) | 6 months-6 years mean = 39.3 months (standard deviation = 20.3) | transdermal estradiol | % change at 2 years, spine DXA | change at 3 or 6 months | | 3 months: -0.12* 6 months: -0.13* | | 3 months: -0.12* 6 months: -0.11 | | | | | | 3 months: -0.32* (serum) -0.38* (urine) 6 months: -0.48* (serum)
Dresner-Pollak (2000)^ 416 ^ | Israel, 63 early postmenopausal women at one university hospital | 63 | 43-54 mean = 49.1 (standard deviation = 2.7) | 12 months or less | Sequential estrogen/progestin Continuous estrogen/progestin Estrogen alone | % change at 2 years, spine or hip DXA | change at 6 months
Gonnelli (1997)^ 409 ^ | Italy, one center, 90 consecutive patients with osteoporosis | 90 | 46-66 | at least 2 years | transdermal estradiol | | | 0.57* | | | 0.66* | 0.59* | 0.67* | | | | | | Fair. Not specified if blinded outcome assessment
Heikkinen (1997)^ 410 ^ | Finland, population-based, 69 women in one province | 69 | 47-56 | 6-24 months | estradiol | Change at 2.5 years, spine and hip DXA | change at 1 year | | spine: -0.34* hip: -0.36* | | spine: -0.24 NS hip: -0.35* | | | | spine: -0.26* hip: -0.36* | | | | Poor. Not specified if blinded outcome assessment, not intention-to-treat
Marcus (1999)^ 6 ^ | RCT, 293 women at 3 clinical centers (CA, DC) | 293 | 45-64 | 1-10 years | conjugated estrogen plus progesterone | % change from baseline to 3 years, spine DXA | % change from baseline | | spine: 0.30 NS hip: 0.20 NS | | spine: 0.23 NS hip: 0.15 NS | | spine: 0.13 NS hip: 0.07 NS | spine: 0.13 NS hip: 0.08 NS | | spine: 0.19 NS hip: 0.09 NS | | | Good
Riis (1995)^ 407 ^ | 119 randomly selected postmenopausal women | 119 | 45-55 (mean = 51, 2.2) | 6 months - 3 years (mean = 21.1 months, 9) | HRT | % change over 2 years | change at 6 months | forearm: 0.60* spine: 0.46* | | | forearm: 0.48* spine: 0.44* | forearm: 0.36* spine: 0.25 NS | | | | | | | Fair. Not specified if blinded outcome assessment
Masahashi (1999)^ 413 ^ | Japan, 21 women with surgically induced menopause (hysterectomy with oophorectome for benign disease) | 21 | mean = 47.3 (6.8) | mean = 20.2 months (20.7 months) | estrogen | Annual % change from baseline, DXA lumbar spine | change from baseline | | | | R not given, (p = 0.04) | | R not given, (p = < 0.01) | R not given (p < 0.01) | | | | | Poor. Small size, not specified if blinded outcome assessment, no adjustment for confounders.
Hesley (1998)^ 412 ^ | Women with bilateral oophorectomy | | > 39 | 6 weeks to 2 years | transdermal estradiol | change at 12 months | change at 6 months | | | | | | | spine: 0.47* | | | | | Poor. Not specified if blinded outcome assessment, DXA not used, followup rate not clear
Rosen (1997)^ 411 ^ | US, 8 clinical research sites, 227 women | 227 | 40-58 (mean = 51) | 6 months-3 years | estrogen/progesterone | gain or loss in BMD at 1 year | increase of 1 | | OR = 1.9* 1.03-3.45) | | OR = 6.4* (2.6-9.99) | | | OR = 1.2 NS (0.80-1.73) | | OR = 5.4* (1.95-15.2) | | | Fair. Not clear if blinded outcome assessment, may have been substantial noncompliance
Zhan (1999)^ 414 ^ | Japan, 33 postmenopausal women with osteoporosis | 33 | 47-74 mean = 55.9 (standard deviation 8.4) | 7.8 years (standard deviation 4.1) | estrogen/progesterone and alfacalcidol | Total body DXA, lumbar spine DXA, hip DXA | % change at 6 months | | | | | | spine: -0.52* NS at total body and hip | spine: -0.43* NS at total body and hip | | | | | Poor. Not randomized (patients chose treatment), not blinded assessment of outcomes, <80% followup

Evidence Table 16. Diagnostic accuracy of markers in women on treatment for osteoporosis

Study, year | Markers | Cutoff for + marker test (non-response) | Definition of non-response | sensitivity | specificity | Positive predictive value | Negative predictive value | False positive rate | False negative rate | Positive likelihood ratio | Negative likelihood ratio | Quality Rating
Women on Alendronate Treatment
Garnero (1994)^ 402 ^ | Intact OC | <20% decrease from baseline | decrease in BMD | 0.92 | 0.76 | 0.44 | 0.98 | 0.24 | 0.08 | 3.82 | 0.10 | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Garnero (1994)^ 402 ^ | Intact OC | <10% decrease from baseline | decrease in BMD | 0.77 | 0.84 | 0.50 | 0.95 | 0.16 | 0.23 | 4.77 | 0.28 | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Garnero (1994)^ 402 ^ | PICP | <20% decrease from baseline | decrease in BMD | 0.75 | 0.85 | 0.57 | 0.93 | 0.15 | 0.25 | 4.92 | 0.30 | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Garnero (1994)^ 402 ^ | PICP | <10% decrease from baseline | decrease in BMD | 0.56 | 0.90 | 0.60 | 0.88 | 0.10 | 0.44 | 5.53 | 0.49 | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Garnero (1994)^ 402 ^ | D-PYR | <50% decrease from baseline | decrease in BMD | 0.87 | 0.42 | 0.28 | 0.93 | 0.58 | 0.13 | 1.50 | 0.31 | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Garnero (1994)^ 402 ^ | D-PYR | <0% decrease from baseline | decrease in BMD | 0.60 | 0.86 | 0.53 | 0.89 | 0.14 | 0.40 | 4.43 | 0.46 | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Garnero (1994)^ 402 ^ | NTX | <40% decrease from baseline | decrease in BMD | 0.67 | 0.77 | 0.43 | 0.90 | 0.23 | 0.33 | 2.87 | 0.43 | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Garnero (1994)^ 402 ^ | NTX | <20% decrease from baseline | decrease in BMD | 0.40 | 0.88 | 0.46 | 0.84 | 0.13 | 0.60 | 3.20 | 0.69 | Fair. Not clear if blinded assessment of outcomes, followup rate not clear.
Garnero (1999)^ 404 ^ | BALP | >9.5 ng/l at 6 months | <3% increase in spine BMD after 2 years | 0.59 | 0.90 | 0.84 | 0.73 | 0.10 | 0.41 | 5.90 | 0.46 | Good
Garnero (1999)^ 404 ^ | BALP | >38.2% increase at 6 months | <3% increase in spine BMD after 2 years | 0.61 | 0.90 | 0.83 | 0.74 | 0.10 | 0.39 | 6.10 | 0.43 | Good
Ravn (1999)^ 374 ^ | NTX | < 40% decrease at 6 months | decrease in spine BMD at 24 months | 0.46 | 0.85 | 0.32 | 0.91 | 0.15 | 0.54 | 3.07 | 0.64 | Fair. Not clear if blinded assessment of outcomes.
Ravn (1999)^ 374 ^ | OC | < 20% decrease at 6 months | decrease in spine BMD at 24 months | 0.54 | 0.78 | 0.27 | 0.92 | 0.22 | 0.46 | 2.45 | 0.59 | Fair. Not clear if blinded assessment of outcomes.
Ravn (1999)^ 405 ^ | total OC | < 50% decrease at 6 months | decrease in spine BMD | 0.57 | 0.98 | 0.92 | 0.82 | 0.02 | 0.43 | 28.50 | 0.44 | Fair. Not clear if blinded assessment of outcomes.
Ravn (1999)^ 405 ^ | serum CTX | <50% decrease at 6 months | decrease in spine BMD | 1.00 | 0.80 | 0.71 | 1.00 | 0.20 | 0.00 | 5.00 | 0.00 | Fair. Not clear if blinded assessment of outcomes.
Ravn (1999)^ 405 ^ | urine CTX | <50% decrease at 6 months | decrease in spine BMD | 0.71 | 0.88 | 0.75 | 0.86 | 0.22 | 0.29 | 3.23 | 0.33 | Fair. Not clear if blinded assessment of outcomes.
Ravn (1999)^ 405 ^ | NTX | <50% decrease at 6 months | decrease in spine BMD | 0.81 | 0.78 | 0.61 | 0.90 | 0.22 | 0.19 | 3.68 | 0.24 | Fair. Not clear if blinded assessment of outcomes.
Women on Hormone Replacement Therapy
Chen (1996)^ 375 ^ | N-terminal OC | increase at 3 months | decrease in spine BMD at 12 months | 0.43 | 0.76 | 0.30 | 0.85 | 0.24 | 0.57 | 1.78 | 0.75
Chen (1996)^ 375 ^ | N-terminal OC | increase at 6 months | decrease in spine BMD at 12 months | 0.71 | 0.07 | 0.16 | 0.50 | 0.93 | 0.29 | 0.77 | 4.14
Chen (1996)^ 375 ^ | N-terminal OC | <40% decrease at 3 months | decrease in spine BMD at 12 months | 0.14 | 0.69 | 0.10 | 0.77 | 0.31 | 0.86 | 0.46 | 1.24
Chen (1996)^ 375 ^ | N-terminal OC | <40% decrease at 6 months | decrease in spine BMD at 12 months | 0.14 | 0.52 | 0.07 | 0.71 | 0.48 | 0.86 | 0.30 | 1.66
Chesnut (1997)^ 408 ^ | NTX | <25% decrease at 6 months | decrease in spine BMD at 12 months | 0.55 | 0.80 | 0.38 | 0.89 | 0.20 | 0.45 | 2.72 | 0.56
Chesnut (1997)^ 408 ^ | NTX | < 50% decrease at 6 months | decrease in spine BMD at 12 months | 0.85 | 0.56 | 0.30 | 0.94 | 0.44 | 0.15 | 1.94 | 0.27

Evidence Table 17. Cost studies

Author/year | Population | Study Type | Perspective | 6 Components of Quality score ^a^ | | | | | | Quality Scorea | Comparisons | Primary outcome | Cost Data Sources | Discount Rate (base case) | Results | Sensitivity Analyses
Author/year | Population | Study Type | Perspective | Perspective stated | Describe program benefit | COST: Diagnosis/Morbidity/Averted/Induced | Discount costs/benefits | Sensitivity analyses | C/E ratio estimated | Quality Scorea | Comparisons | Primary outcome | Cost Data Sources | Discount Rate (base case) | Results | Sensitivity Analyses
Epstein (1998)^ 275 ^ | Hypothetical U.S. cohort of post-menopausal women age 60+ | CBA, CEA, and CUA models | Payer? | N | Y | Y/Y/Y/N | Y | Y | Y | 5 of 6 | Hip DXA: treat with T <-2 or Tm <-2.5. With or without SCORE prescreen | Number needed to treat (CBA), $/LYG (CEA), $/QALY | Literature from U.S. | 5% (benefits and risks) | Use of score reduced costs of diagnosis. | Various, similar results
National Osteoporosis Foundation (1998)^ 8 ^ | Individual women in U.S. | Cost-effectiveness (balance sheets) | Patient | Y | Y | Y/Y/Y/N | N | Y | N | 4 of 6 | Given age and number of other risk factors, when should BMD be assessed? | Decisions to assess BMD and to treat, include QALYs | U.S. national data | "Analyses not sensitive to discount rate" | Provides nomograms based on age and numbers of risk factors (of family history of osteoporosis, thinness, and current smoking) to aid decision on whether or not to assess BMD. | Various, including wrist fractures
Abbott (1999)^ 12 ^ | Cohort of 392 post-menopausal women in U.S. | CEA model | Provider | Y | Y | Y/N/N/N | N/A | One cost only | Y | <6 of 6 | DXA hip+spine, DXA hip, DXA spine, pDXA, DXA all 3, same+SCORE, SCORE+pDXA+DXA hip+spine (for all non-osteoporotic or only osteopenic) | $/sensitivity (number identified of 100) | Arbitrary U.S. values | N/A | SCORE only avoided testing in 84 of 392 (21%) of this sample. | Cost of DXA hip+spine only
Langton, Ballard, Langton, et al. (1997)^ 421 ^ | 107 women age 60-69 referred for DXA in UK | CEA | Payer? | N | Y | Y/N/N/N | N/A | N | N | 2 of 6 | QUS (BUA and SOS at various thresholds) versus clinical criteria to determine which women to send for DXA | Cost per osteoporotic (and osteopenic) women detected | UK payer | N/A | BUA at 60 dB MHz provides lowest cost per case detected among various alternatives and thresholds. | None
Langton (1999)^ 422 ^ | 599 women age 50-54 in UK | CEA | Payer? | N | Y | Y/N/N/N | N/A | Y | N | 3 of 6 | QUS (BUA and SOS at various thresholds) versus clinical criteria to determine which women to send for DXA | Cost per osteoporotic (and osteopenic) women detected | UK payer | N/A | To identify osteoporotic (osteopenic and osteoporotic) women compensated for prevalence, QUS/BUA is more cost-effective (similarly cost-effective) than clinical criteria. | If DXA costs >4 times QUS costs, QUS/BUA more cost-effective for osteoporotic women. Clinical criteria always more cost-effective than QUS/BUA for osteoporotic and osteopenic women
Tosteson (1990)^ 423 ^ | Theoretical cohort of 50-year old women in U.S. | CEA and CUA model | Payer | Y | Y | Y/Y/Y/N | Y | Y | Y | 6 of 6 | Thresholds of BMD at which treat (<0.9, <1.0, <1.1 g/cm2) versus treat all | $/LYG and $/QALY | Various U.S. data sources | 5% (benefits and risks) | Targeting HRT will improve cost-effectiveness compared to treating all. | Extensive
Garton (1997)^ 424 ^ | Theoretical cohort of 45-year old women in UK | CEA model | Payer? | N | Y | Y/Y/Y/N | Y | Y | Y | 6 of 6 | All combinations of 3 sites each with 3 thresholds (lowest 25th, 50th, and 75th percentile of population | Pounds/percent of fractures prevented | Various UK | 6% | BMD at one or more sites is a cost-effective way to reduce fractures. Compliance with HRT important. If BMD assessment enhanced HRT compliance, BMD assessment would be more cost-effective than universal HRT. | Compliance only
Torgerson (1996)^ 453 ^ | Unspecified population in UK | CEA calculation only | Payer? | N | Y | Y/N/N/N | N/A | N | N | 2 of 6 | Scan versus treat all | $/case detected | Arbitrary UK values | N/A | Not relevant to choice of test. | None

a Refer to Table 8

Note: "?" denotes cases in which this item was not explicitly stated by authors, but may be inferred.