# Bibliography

Abbasi AA, Rudman D, Wilson CR, et al Observations on nursing home residents with a history of hip fracture Am J Med Sci 1995 310(6):229 34 7503102
Abbott TA, Lawrence BJ, Wallach S Osteoporosis: the need for comprehensive treatment guidelines Clin Ther 1996 18(1):127 49 8851459
Abbott TA 3rd, Mucha L, Manfredonia D, et al Efficient patient identification strategies for women with osteoporosis J Clin Densitomet 1999 2(3):223 30
Abdelhadi M, Nordenström J Bone mineral recovery after parathyroidectomy in patients with primary and renal hyperparathyroidism J Clin Endocrinol Metab 1998 83(11):3845 51 9814456
Abrahamsen B, Bendtzen K, Beck-Nielsen H Cytokines and T-lymphocyte subsets in healthy post-menopausal women: estrogen retards bone loss without affecting the release of IL-1 or IL-1ra Bone 1997 20(3):251 8 9071476
Acar B, Uslu T, Topuz A, et al Relation between bone mineral content and clinical, hormonal and biochemical parameters in postmenopausal women Arch Gynecol Obstet 1998 261(3):121 8 9651656
Adachi JD, Bensen WG, Cividino A Corticosteroid-induced osteoporosis J Am Med Womens Assoc 1998 53(1):25 30, 40 9458622
Adachi Y, Shiota E, Matsumata T, et al Bone mineral density in patients taking H2-receptor antagonist Calcif Tissue Int 1998 62(4):283 5 9504949
Adami S, Passeri M, Ortolani S, et al Effects of oral alendronate and intranasal salmon calcitonin on bone mass and biochemical markers of bone turnover in postmenopausal women with osteoporosis Bone 1995 17(4):383 90 8573412
Adami S, Bufalino L, Cervetti R, et al Ipriflavone prevents radial bone loss in postmenopausal women with low bone mass over 2 years Osteoporos Int 1997 7(2):119 25 9166391
Adami S, Braga V, Squaranti R, et al Bone measurements in asymptomatic primary hyperparathyroidism Bone 1998 22(5):565 70 9600793
Advisory Group on Osteoporosis, Royal College of Physicians. Summary and recommendations of the report "Osteoporosis-Clinical guidelines for the prevention and treatment." 1999. http://www.doh.gov.uk/osteoorep.htm.
Aerssens J, Declerck K, Maeyaert B, et al The effect of modifying dietary calcium intake pattern on the circadian rhythm of bone resorption Calcif Tissue Int 1999 65(1):34 40 10369731
Affinito P, Sorrentino C, Farace MJ, et al Effects of thyroxine therapy on bone metabolism in postmenopausal women with hypothyroidism Acta Obstet Gynecol Scand 1996 75(9):843 8 8931510
Health Technology Assessment Number 6: Bone Densitometry: Patients with Asymptomatic Primary Hyperparathyroidism. Rockville, MD: Agency for Health Care Policy and Reseaerch Publication:1995;96-0004.
Agnusdei D, Gennari C, Bufalino L Prevention of early postmenopausal bone loss using low doses of conjugated estrogens and the non-hormonal, bone-active drug ipriflavone Osteoporos Int 1995 5(6):462 6 8695969
Agnusdei D, Crepaldi G, Isaia G, et al A double blind, placebo-controlled trial of ipriflavone for prevention of postmenopausal spinal bone loss Calcif Tissue Int 1997 61(2):142 7 9236262
Agren M, Karellas A, Leahey D, et al Ultrasound attenuation of the calcaneus: a sensitive and specific discriminator of osteopenia in postmenopausal women Calcif Tissue Int 1991 48(4):240 4 2059875
Ahmed AIH, Blake GM, Rymer JM, et al. Screening for osteopenia and osteoporosis: do the accepted normal ranges lead to overdiagnosis?. Osteoporos Int. 1997;7:432-8. [pmid: 9425500].
Aisenbrey JA Exercise in the prevention and management of osteoporosis Phys Ther 1987 67(7):1100 4 3602105
Akesson K, Vergnaud P, Gineyts E, et al Impairment of bone turnover in elderly women with hip fracture Calcif Tissue Int 1993 53(3):162 9 8242467
Akesson K, Ljunghall S, Gardsell P, et al Serum osteocalcin and fracture susceptibility in elderly women Calcif Tissue Int 1993 53(2):86 90 8402327
Akesson K, Ljunghall S, Jonsson B, et al Assessment of biochemical markers of bone metabolism in relation to the occurrence of fracture: a retrospective and prospective population-based study of women J Bone Miner Res 1995 10(11):1823 9 8592961
Albala C, Yanez M, Devoto E, et al Obesity as a protective factor for postmenopausal osteoporosis Int J Obes Relat Metab Disord 1996 20(11):1027 32 8923160
Alderman B, Weiss N, Daling J, et al Reproductive history and postmenopausal risk of hip and forearm fracture Am J Epidemiol 1986 124(2):262 7 3728442
Alenfeld FE, Wuster C, Funck C, et al Ultrasound measurements at the proximal phalanges in healthy women and patients with hip fractures Osteoporos Int 1998 8(5):393 8 9850344
Alexandersen P, Riis BJ, Christiansen C Monofluorophosphate combined with hormone replacement therapy induces a synergistic effect on bone mass by dissociating bone formation and resorption in postmenopausal women: a randomized study J Clin Endocrinol Metab 1999 84(9):3013 20 10487657
Alhava EM Bone density measurements Calcif Tissue Int 1991 49Suppl:S21 3 1933591
Allander E, Gullberg B, Johnell O, et al. Falls and hip fracture. A reasonable basis for possibilities for prevention? Some preliminary data from the MEDOS study Mediterranean Osteoporosis Study. Scand J Rheumatol Suppl. 1996;103:49-52; discussion 3. [pmid: 8966490].
Allaway SL, Robinson D, Bailey AR, et al Bone density, biochemistry and life-style Methods Inf Med 1993 32(3):233 6 8341157
Allolio B Risk factors for hip fracture not related to bone mass and their therapeutic implications Osteoporos Int 1999 9Suppl 2:S9 S16 10525720
Aloia JF, Vaswani A, Yeh JK, et al Risk for osteoporosis in black women Calcif Tissue Int 1996 59(6):415 23 8939764
Alonso-Bartolome P, Martinez-Taboada VM, Blanco R, et al Insufficiency fractures of the tibia and fibula Semin Arthritis Rheum 1999 28(6):413 20 10406409
American Association of Clinical Endocrinologists, American College of Endocrinology. AACE clinical practice guidelines for the prevention and treatment of postmenopausal osteoporosis. 1996:1-19. http://www.aace.com/clin/guidelines/osteoporosis2001.pdf.
Recommendations for the prevention and treatment of glucocoriticoid-induced osteoporosis. Arthritis Rheum. 1996;39:1791-9. [pmid: 8912500].
Anderson JJ, Metz JA Contributions of dietary calcium and physical activity to primary prevention of osteoporosis in females J Am Coll Nutr 1993 12(4):378 83 8409099
Andreoli TE, Bennett JC, Carpenter CCJ, et al. Cecil essentials of medicine. 4th ed. Philadelphia: WB Saunders Company; 1997.
Andresen R, Werner HJ, Schober HC Contribution of the cortical shell of vertebrae to mechanical behaviour of the lumbar vertebrae with implications for predicting fracture risk Br J Radiol 1998 71(847):759 65 9771387
Andresen R, Radmer S, Banzer D Bone mineral density and spongiosa architecture in correlation to vertebral body insufficiency fractures Acta Radiol 1998 39(5):538 42 9755704
Ankjaer-Jensen A, Johnell O Prevention of osteoporosis: cost-effectiveness of different pharmaceutical treatments Osteoporos Int 1996 6(4):265 75 8883114
Aptel I, Cance-Rouzaud A, Grandjean H Association between calcium ingested from drinking water and femoral bone density in elderly women: evidence from the EPIDOS cohort J Bone Miner Res 1999 14(5):829 33 10320532
Arden NK, Baker J, Hogg C, et al The heritability of bone mineral density, ultrasound of the calcaneus and hip axis length: a study of postmenopausal twins J Bone Miner Res 1996 11(4):530 4 8992884
Arden NK, Griffiths GO, Hart DJ, et al The association between osteoarthritis and osteoporotic fracture: the Chingford Study Br J Rheumatol 1996 35(12):1299 304 9010060
Arden NK, Nevitt MC, Lane NE, et al Osteoarthritis and risk of falls, rates of bone loss, and osteoporotic fractures. Study of Osteoporotic Fractures Research Group Arthritis Rheum 1999 42(7):1378 85 10403265
Arlot ME, Sornay-Rendu E, Garnero P, et al Apparent pre- and postmenopausal bone loss evaluated by DXA at different skeletal sites in women: the OFELY cohort J Bone Miner Res 1997 12(4):683 90 9101381
Armamento-Villareal R, Villareal DT, Avioli LV, et al Estrogen status and heredity are major determinants of premenopausal bone mass J Clin Invest 1992 90(6):2464 71 443403 1469098
Arnala I, Saastamoinen J, Alhava EM Salmon calcitonin in the prevention of bone loss at perimenopause Bone 1996 18(6):629 32 8806006
Arnaud CD Osteoporosis -- new techniques for screening, diagnosis, and clinical monitoring West J Med 1996 164(5):441 2 8686305
Aström J, Ahnqvist S, Beertema J, et al Physical activity in women sustaining fracture of the neck of the femur J Bone Joint Surg Br 1987 69(3):381 3 3584188
Augat P, Iida H, Jiang Y, et al Distal radius fractures: mechanisms of injury and strength prediction by bone mineral assessment J Orthop Res 1998 16(5):629 35 9820289
Augat P, Fuerst T, Genant HK Quantitative bone mineral assessment at the forearm: a review Osteoporos Int 1998 8(4):299 310 10024899
Augat P, Fan B, Lane NE, et al Assessment of bone mineral at appendicular sites in females with fractures of the proximal femur Bone 1998 22(4):395 402 9556141
Augat P, Gordon CL, Lang TF, et al Accuracy of cortical and trabecular bone measurements with peripheral quantitative computed tomography (pQCT) Phys Med Biol 1998 43(10):2873 83 9814524
Australian National Consensus Conference The prevention and management of osteoporosis. Consensus statement 1996 Med J Aust 1997 167(Suppl):S1 S15 http://www.mja.com.au/osteo/diageval.htm 9236768
Bagur AC, Mautalen CA Risk for developing osteoporosis in untreated premature menopause Calcif Tissue Int 1992 51(1):4 7 1393775
Baillie SP, Davison CE, Johnson FJ, et al. Pathogenesis of vertebral crush fractures in men. Age Ageing. 1992;21:139-41. [pmid: 1575093].
Ballard PA, Purdie DW, Langton CM, et al Prevalence of osteoporosis and related risk factors in UK women in the seventh decade: osteoporosis case finding by clinical referral criteria or predictive model? Osteoporos Int 1998 8(6):535 9 10326057
Balogh A, Bettembuk P Hormone replacement therapy and prevention of osteoporosis: risk assessment and practical advice Eur J Obstet Gynecol Reprod Biol 1997 71(2):189 91 9138964
Bando K, Nitta H, Matsubara M, et al Bone mineral density in periodontally healthy and edentulous postmenopausal women Ann Peridon 1998 3(1):322 6
Baran DT, Faulkner KG, Genant HK, et al Diagnosis and management of osteoporosis: guidelines for the utilization of bone densitometry Calcif Tissue Int 1997 61(6):433 40 9383266
Baron JA, La Vecchia C, Levi F The antiestrogenic effect of cigarette smoking in women Am J Obstet Gynecol 1990 162(2):502 14 2178432
Baron JA, Barrett J, Malenka D, et al Racial differences in fracture risk Epidemiology 1994 5(1):42 7 8117781
Baron J, Barrett J, Katz J, et al Total hip arthroplasty: use and select complications in the U.S. Medicare population Am J Public Health 1996 86(1):70 2 8561246 1380364
Barrett JA, Baron JA, Karagas MR, et al Fracture risk in the U.S. Medicare population J Clin Epidemiol 1999 52(3):243 9 10210242
Barrett-Connor E, Chang J, Edelstein S. Coffee-associated osteoporosis offset by daily milk consumption. The Rancho Bernardo Study. JAMA. 1994;271:280-3. [pmid: 8295286].
Barrett-Connor E The economic and human costs of osteoporotic fracture Am J Med 1995 98(2A):3S 8S 7709931
Barrett-Connor E, Gore R, Browner WS, et al Prevention of osteoporotic hip fracture: global versus high-risk strategies Osteoporos Int 1998 8Suppl 1:S2 7 9682789
Barthe N, Braillon P, Ducassou D, et al. Comparison of two Hologic DXA systems (QDR 1000 and QDR 4500/A). Br J Radiol. 1997;70:728-39. [pmid: 9245885].
Barthe N, Basse-Cathalinat B, Meunier PJ, et al Measurement of bone mineral density in mother-daughter pairs for evaluating the family influence on bone mass acquisition: a GRIO survey Osteoporos Int 1998 8(4):379 84 10024909
Bauer DC, Browner WS, Cauley JA, et al Factors associated with appendicular bone mass in older women. The Study of Osteoporotic Fractures Research Group Ann Intern Med 1993 118(9):657 65 8460853
Bauer DC, Gluer CC, Genant H, et al Quantitative ultrasound and vertebral fracture in postmenopausal women J Bone Miner Res 1995 10(3):353 8 7785455
Bauer DC, Orwoll ES, Fox KM, et al Aspirin and NSAID use in older women: effect on bone mineral density and fracture risk. Study of Osteoporotic Fractures Research Group J Bone Miner Res 1996 11(1):29 35 8770694
Bauer DC, Gluer CC, Cauley JA, et al Broadband ultrasound attenuation predicts fractures strongly and independently of densitometry in older women. A prospective study. Study of Osteoporotic Fractures Research Group Arch Intern Med 1997 157(6):629 34 9080917
Bauer DC Biochemical markers of bone turnover and prediction of hip bone loss in older women: The Study of Osteoporotic Fractures J Bone Miner Res 1999 14(8):1404 10 10457273
Bauer DC. Personal communication. March 17, 2000.
Bauer RL, Diehl AK, Barton SA, et al Risk of postmenopausal hip fracture in Mexican American women Am J Public Health 1986 76(8):1020 1 3728760 1646635
Bauer RL, Deyo RA Low risk of vertebral fracture in Mexican American women Arch Intern Med 1987 147(8):1437 9 3498450
Bauer RL Ethnic differences in hip fracture: a reduced incidence in Mexican Americans Am J Epidemiol 1988 127(1):145 9 3337072
Bean N, Bennett KM, Lehmann AB Habitus and hip fracture revisited: skeletal size, strength and cognition rather than thinness? Age Ageing 1995 24(6):481 4 8588536
Beauchesne MF, Miller PF Etidronate and alendronate in the treatment of postmenopausal osteoporosis Ann Pharmacother 1999 33(5):587 99 10369624
Bendich A, Leader S, Muhuri P Supplemental calcium for the prevention of hip fracture: potential health-economic benefits Clin Ther 1999 21(6):1058 72 10440627
Benmalek A, Sabatier J-P. Comparison and cross-calibration of DXA systems: ODX-240 and Sophos L-XRA versus Hologic QDR-4500, for spine bone mineral measurement. Translation of a reference database. Osteoporos Int. 1998;8:570-7. [pmid: 10326063].
Berg JP, Falch JA, Haug E Fracture rate, pre- and postmenopausal bone mass and early and late postmenopausal bone loss are not associated with vitamin D receptor genotype in a high-endemic area of osteoporosis Eur J Endocrinol 1996 135(1):96 100 8765980
Berning B, van Kuijk C, Schutte HE, et al Determinants of lumbar bone mineral density in normal weight, non-smoking women soon after menopause. A study using clinical data and quantitative computed tomography Bone Miner 1993 21(2):129 39 8358250
Berning B, van Kuijk C, Kuiper JW, et al Increased loss of trabecular but not cortical bone density, 1 year after discontinuation of 2 years hormone replacement therapy with Tibolone Maturitas 1999 31(2):151 9 10227009
Bernstein J Test-indication curves Med Decis Making 1997 17(1):103 6 8994157
Bernstein L, Chapman G, Elstein A Framing effects in choices between multioutcome life-expectancy lotteries Med Decis Making 1999 19(3):324 38 10424839
Bernstein J, Grisso JA, Kaplan FS Body mass and fracture risk. A study of 330 patients Clin Orthop 1999(364):227 30
Bettica P, Moro L, Robins SP, et al Bone-resorption markers galactosyl hydroxylysine, pyridinium crosslinks, and hydroxyproline compared Clin Chem 1992 38(11):2313 8 1424129
Bidoli E, Schinella D, Franceschi S Physical activity and bone mineral density in Italian middle-aged women Eur J Epidemiol 1998 14(2):153 7 9556174
Bjarnason K, Nilas L, Hassager C, et al Dual energy X-ray absorptiometry of the spine -- decubitus lateral versus anteroposterior projection in osteoporotic women: comparison to single energy X-ray absorptiometry of the forearm Bone 1995 16(2):255 60 7756055
Bjarnason NH, Bjarnason K, Hassager C, et al The response in spinal bone mass to tibolone treatment is related to bone turnover in elderly women Bone 1997 20(2):151 5 9028540
Bjarnason NH, Christiansen C Early response in biochemical markers predicts long-term response in bone mass during hormone replacement therapy in early postmenopausal women Bone 2000 26(6):561 9 10831926
Blaauw R, Albertse EC, Beneke T, et al Risk factors for the development of osteoporosis in a South African population. A prospective analysis S Afr Med J 1994 84(6):328 32 7740378
Black DM, Cummings SR, Genant HK, et al Axial and appendicular bone density predict fractures in older women J Bone Miner Res 1992 7(6):633 8 1414481
Black DM, Cummings SR, Melton SR Appendicular bone mineral and a woman's lifetime risk of hip fracture J Bone Miner Res 1992 7(6):639 46 1414482
Black DM Why elderly women should be screened and treated to prevent osteoporosis Am J Med 1995 98(Suppl 2A):67S 75S 7709939
Black DM, Bauer DC, Lu Y, et al Should BMD be measured at multiple sites to predict fracture risk in elderly women? J Bone Miner Res 1995 10(Suppl 1):
Black DM Screening and treatment in the elderly to reduce osteoporotic fracture risk Br J Obstet Gynaecol 1996 103(Suppl 13):2 7; discussion -8 8624337
Black DM, Cummings SR, Karpf DB, et al. Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Lancet. 1996;348:1535-41. [pmid: 8950879].
Black DM, Palermo L, Genant HK, et al Four reasons to avoid the use of BMD T-scores in treatment decisions for osteoporosis J Bone Miner Res 1996 11(Suppl 1):
Black DM, Arden NK, Palermo L, et al Prevalent vertebral deformities predict hip fractures and new vertebral deformities but not wrist fractures. Study of Osteoporotic Fractures Research Group J Bone Miner Res 1999 14(5):821 8 10320531
Blake GM, Herd RJ, Fogelman I. A longitudinal study of supine lateral DXA of the lumbar spine: a comparison with posteroanterior spine, hip and total-body DXA. Osteoporos Int. 1996;6:462-70. [pmid: 9116392].
Blake GM, Rea JA, Fogelman I Vertebral morphometry studies using dual-energy x-ray absorptiometry Semin Nucl Med 1997 27(3):276 90 9224667
Blake GM, Gluer CC, Fogelman I. Bone densitometry: current status and future prospects. Br J Radiol. 1997;70. Spec No:S177-86.
Blake GM, Fogelman I Applications of bone densitometry for osteoporosis Endocrinol Metab Clin North Am 1998 27(2):267 88 9669138
Blue Cross and Blue Shield Association. Ultrasonography of the heel for diagnostic osteoporosis and selecting patients for pharmacologic treatment. Chicago: Blue Cross and Blue Shield Association; 1999.
Blue Cross and Blue Shield Association. Monitoring of bone density to assess active treatment of osteoporosis. Chicago: Blue Cross and Blue Shield Association; 2000.
Boden SD, Labropoulos P, Saunders R Hip fractures in young patients: is this early osteoporosis? Calcif Tissue Int 1990 46(2):65 72 2105151
Bohannon AD, Hanlon JT, Landerman R, et al Association of race and other potential risk factors with nonvertebral fractures in community-dwelling elderly women Am J Epidemiol 1999 149(11):1002 9 10355375
Bonde M, Garnero P, Fledelius C, et al Measurement of bone degradation products in serum using antibodies reactive with an isomerized form of an 8 amino acid sequence of the C-telopeptide of type I collagen J Bone Miner Res 1997 12(7):1028 34 9200001
Bone HG, Downs RW Jr., Tucci JR, et al Dose-response relationships for alendronate treatment in osteoporotic elderly women J Clin Endocrinol Metab 1997 82(1):265 74 8989272
Boonen S, Koutri R, Dequeker J, et al Measurement of femoral geometry in type I and type II osteoporosis: differences in hip axis length consistent with heterogeneity in the pathogenesis of osteoporotic fractures J Bone Miner Res 1995 10(12):1908 12 8619371
Boonen S, Lesaffre E, Dequeker J, et al Relationship between baseline insulin-like growth factor-I (IGF-I) and femoral bone density in women aged over 70 years: potential implications for the prevention of age-related bone loss J Am Geriatr Soc 1996 44(11):1301 6 8909344
Borderie D, Cherruau B, Dougados M, et al Biochemical markers as predictors of bone mineral density changes after GnRH agonist treatment Calcif Tissue Int 1998 62(1):21 5 9405728
Borgquist L, Nilsson L, Lindelow G, et al. Perceived health in hip-fracture patients: a prospective follow-up of 100 patients. Age Ageing. 1992;21:109-16. [pmid: 1575088].
Bourguet CC, Hamrick GA, Gilchrist VJ The prevalence of osteoporosis risk factors and physician intervention J Fam Pract 1991 32(3):265 71 2002317
Bouxsein ML, Radloff SE Quantitative ultrasound of the calcaneus reflects the mechanical properties of calcaneal trabecular bone J Bone Miner Res 1997 12(5):839 46 9144351
Bouxsein ML, Coan BS, Lee SC Prediction of the strength of the elderly proximal femur by bone mineral density and quantitative ultrasound measurements of the heel and tibia Bone 1999 25(1):49 54 10423021
Boyce WJ, Vessey MP Habitual physical inertia and other factors in relation to risk of fracture of the proximal femur Age Ageing 1988 17(5):319 27 3232586
Braga de Castro Machado A, Hannon R, Eastell R. Monitoring alendronate therapy for osteoporosis. J Bone Miner Res. 1999;14:602-8. [pmid: 10234582].
Brixen K, Nielsen HK, Charles P, et al Effects of a short course of oral phosphate treatment on serum parathyroid hormone(1-84) and biochemical markers of bone turnover: a dose-response study Calcif Tissue Int 1992 51(4):276 81 1422972
Brixen K, Kassem M, Nielsen HK, et al Short-term treatment with growth hormone stimulates osteoblastic and osteoclastic activity in osteopenic postmenopausal women: a dose response study J Bone Miner Res 1995 10(12):1865 74 8619366
Brocklehurst JC, Exton-Smith AN, Lempert Barber SM, et al. Fracture of the femur in old age: a two-centre study of associated clinical factors and the cause of the fall. Age Ageing. 1978;7:2-15. [pmid: 636928].
Brooke-Wavell K, Jones PRM, Pye DW. Ultrasound and dual X-ray absorptiometry measurement of the calcaneus: Influence of region of interest location. Calcif Tissue Int. 1995;57:20-4. [pmid: 7671160].
Brot C, Jensen LB, Sorensen OH Bone mass and risk factors for bone loss in perimenopausal Danish women J Intern Med 1997 242(6):505 11 9437412
Buchanan JR, Myers C, Greer RB 3rd, et al Assessment of the risk of vertebral fracture in menopausal women J Bone Joint Surg 1987 69(2):212 8 3805081
Burger H, van Daele PL, Algra D, et al Vertebral deformities as predictors of non-vertebral fractures BMJ 1994 309(6960):991 2 7950721
Burger H, van Daele PL, Odding E, et al Association of radiographically evident osteoarthritis with higher bone mineral density and increased bone loss with age. The Rotterdam Study Arthritis Rheum 1996 39(1):81 6 8546742
Burger H, de Laet CE, van Daele PL, et al Risk factors for increased bone loss in an elderly population: the Rotterdam Study Am J Epidemiol 1998 147(9):871 9 9583718
Burger H, de Laet CE, Weel AE, et al Added value of bone mineral density in hip fracture risk scores Bone 1999 25(3):369 74 10495142
Butler M, Norton R, Lee-Joe T, et al The risks of hip fracture in older people from private homes and institutions Age Ageing 1996 25(5):381 5 8921144
Byyny RL, Speroff L, editors. A clinical guide for the care of older women. Baltimore: Williams & Wilkins; 1996.
Caldwell JR Epidemiologic and economic considerations of osteoporosis J Fla Med Assoc 1996 83(8):548 51 9159999
Calvo M, Eyre D, Gundberg C Molecular basis and clinical application of biological markers of bone turnover Endocr Rev 1996 17(4):333 68 8854049
Cameron JR, Sorenson J. Measurement of bone mineral in vivo: an improved method. Science. 1963;142:230-2. [pmid: 14057368].
Caniggia A, Nuti R, Galli M, et al Effect of a long-term treatment with 1,25-dihydroxyvitamin D3 on osteocalcin in postmenopausal osteoporosis Calcif Tissue Int 1986 38(6):328 32 3089554
Cann C Quantitative CT applications: comparison of current scanners Radiology 1987 162(1):257 61 3786773
Cann C Quantitative CT for determination of bone mineral density: a review Radiology 1988 166(2):509 22 3275985
Cappuccio FP, Meilahn E, Zmuda JM, et al High blood pressure and bone-mineral loss in elderly white women: a prospective study. Study of Osteoporotic Fractures Research Group Lancet 1999 354(9183):971 5 10501357
Caraballo PJ, Heit JA, Atkinson EJ, et al Long-term use of oral anticoagulants and the risk of fracture Arch Intern Med 1999 159(15):1750 6 10448778
Carroll J, Testa MA, Erat K, et al Modeling fracture risk using bone density, age, and years since menopause Am J Prev Med 1997 13(6):447 52 9415791
Cauley JA, Cummings SR, Seeley DG, et al Effects of thiazide diuretic therapy on bone mass, fractures, and falls. The Study of Osteoporotic Fractures Research Group Ann Intern Med 1993 118(9):666 73 8489642
Cauley JA, Seeley DG, Ensrud K, et al Estrogen replacement therapy and fractures in older women. Study of Osteoporotic Fractures Research Group Ann Intern Med 1995 122(1):9 16 7985914
Cauley JA, Murphy PA, Riley TJ, et al Effects of fluoridated drinking water on bone mass and fractures: the study of osteoporotic fractures J Bone Miner Res 1995 10(7):1076 86 7484283
Cauley JA, Zmuda JM, Yaffe K, et al Apolipoprotein E polymorphism: a new genetic marker of hip fracture risk -- The Study of Osteoporotic Fractures J Bone Miner Res 1999 14(7):1175 81 10404018
Center J, Beange H, McElduff A People with mental retardation have an increased prevalence of osteoporosis: a population study Am J Ment Retard 1998 103(1):19 28 9678227
Center JR, Nguyen TV, Pocock NA, et al Femoral neck axis length, height loss and risk of hip fracture in males and females Osteoporos Int 1998 8(1):75 81 9692081
Center JR, Nguyen TV, Schneider D, et al Mortality after all major types of osteoporotic fracture in men and women: an observational study Lancet 1999 353(9156):878 82 10093980
Cepollaro C, Gonnelli S, Pondrelli C, et al The combined use of ultrasound and densitometry in the prediction of vertebral fracture Br J Radiol 1997 70(835):691 6 9245880
Chan HH, Lau EM, Woo J, et al Dietary calcium intake, physical activity and the risk of vertebral fracture in Chinese Osteoporos Int 1996 6(3):228 32 8783297
Chander JM, Martin AR, Girman C, et al. Reliability of an osteoporosis-targeted quality of life survey instrument for use in the community: OPT-QoL. Osteoporos Int. 1998;8:127-35. [pmid: 9666935].
Chappard C, Kolta S, Fechtenbaum J, et al Clinical evaluation of spine morphometric X-ray absorptiometry Br J Rheumatol 1998 37(5):496 501 9651075
Chaput de Saintonge DM, Evans SJ, Crane GJ, et al Clinical trials and clinical practice: do doctors use the same criteria to judge outcome? Br J Clin Pharmacol 1997 44(6):583 6 9431836
Chapuy MC, Arlot ME, Duboeuf F, et al Vitamin D3 and calcium to prevent hip fractures in the elderly women N Engl J Med 1992 327(23):1637 42 1331788
Chen JT, Hosoda K, Hasumi K, et al Serum N-terminal osteocalcin is a good indicator for estimating responders to hormone replacement therapy in postmenopausal women J Bone Miner Res 1996 11(11):1784 92 8915787
Chen JT, Shiraki M, Hasumi K, et al 1-alpha-Hydroxyvitamin D3 treatment decreases bone turnover and modulates calcium-regulating hormones in early postmenopausal women Bone 1997 20(6):557 62 9177871
Chen Z, Lohman TG, Stini WA, et al Fat or lean tissue mass: which one is the major determinant of bone mineral mass in healthy postmenopausal women? J Bone Miner Res 1997 12(1):144 51 9240737
Chen Z, Maricic M, Lund P, et al. How the new Hologic hip normal reference values affect the densitometric diagnosis of osteoporosis. Osteoporos Int. 1998;8:423-7. [pmid: 9850349].
Cheng S, Tylavsky F, Carbone L Utility of ultrasound to assess risk of fracture J Am Geriatr Soc 1997 45(11):1382 94 9361666
Chesnut CH, Harris ST Short-term effect of alendronate on bone mass and bone remodeling in postmenopausal women Osteoporos Int 1993 3(Suppl 3):S17 9 8298198
Chesnut CH 3rd, McClung MR, Ensrud KE, et al Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling Am J Med 1995 99(2):144 52 7625419
Chesnut CH 3rd, Bell NH, Clark GS, et al Hormone replacement therapy in postmenopausal women: urinary N-telopeptide of type I collagen monitors therapeutic effect and predicts response of bone mineral density Am J Med 1997 102(1):29 37 9209198
Cheung AP, Wren BG A cost-effectiveness analysis of hormone replacement therapy in the menopause Med J Aust 1992 156(5):312 6 1588862
Chevalier F, Laval-Jeantet AM, Laval-Jeantet M, et al CT image analysis of the vertebral trabecular network in vivo Calcif Tissue Int 1992 51(1):8 13 1393783
Chiodini I, Carnevale V, Torlontano M, et al Alterations of bone turnover and bone mass at different skeletal sites due to pure glucocorticoid excess: study in eumenorrheic patients with Cushing's Syndrome J Clin Endocrinol Metab 1998 83(6):1863 7 9626110
Chrischilles EA, Butler CD, Davis CS, et al A model of lifetime osteoporosis impact Arch Intern Med 1991 151(10):2026 32 1929691
Chrischilles E, Shireman T, Wallace R Costs and health effects of osteoporotic fractures Bone 1994 15(4):377 86 7917575
Chrischilles E Outcomes assessment in osteoporosis: strategies for improvement Med Interface 1996 9(7):127 33 10161369
Christgau S, Rosenquist C, Alexandersen P, et al Clinical evaluation of the Serum CrossLaps One Step ELISA, a new assay measuring the serum concentration of bone-derived degradation products of type I collagen C-telopeptides Clin Chem 1998 44(11):2290 300 9799756
Christiansen C, Riis B, Rodbro P. Prediction of rapid bone loss in postmenopausal women. Lancet. 1987:1105-8.
Christiansen C, Riis BJ, Rodbro P Screening procedure for women at risk of developing postmenopausal osteoporosis Osteoporos Int 1990 1(1):35 40 2133639
Christiansen P, Steiniche T, Brixen K, et al Primary hyperparathyroidism: biochemical markers and bone mineral density at multiple skeletal sites in Danish patients Bone 1997 21(1):93 9 9213014
Christiansen C Practical application of risk assessment Osteoporos Int 1998 8Suppl 1:S43 6 9682797
Christiansen P, Steiniche T, Brixen K, et al Primary hyperparathyroidism: effect of parathyroidectomy on regional bone mineral density in Danish patients: a three-year follow-up study Bone 1999 25(5):589 95 10574580
Christiansen P, Steiniche T, Brixen K, et al Primary hyperparathyroidism: short-term changes in bone remodeling and bone mineral density following parathyroidectomy Bone 1999 25(2):237 44 10456391
Clark A, Schuttinga J Targeted estrogen/progestogen replacement therapy for osteoporosis: calculation of health care cost savings Osteoporos Int 1992 2(4):195 200 1611225
Clark E, Wells G, Boisvert D, et al. Cost-effectiveness of screening for osteoporosis: an overview. Abstracts/Annual Meeting, International Society of Technology Assessment in Health Care. 1993;9.
Clark P, de la Pena F, Gomez Garcia F, et al Risk factors for osteoporotic hip fractures in Mexicans Arch Med Res 1998 29(3):253 7 9775460
Cleghorn D, Polley K, Bellon M, et al. Fracture rates as a function of forearm mineral density in normal postmenopausal women: retrospective and prospective data. Calcif Tissue Int. 1991;49:161-3. [pmid: 1933579].
Clemmesen B, Overgaard K, Riis B, et al Human growth hormone and growth hormone releasing hormone: a double-masked, placebo-controlled study of their effects on bone metabolism in elderly women Osteoporos Int 1993 3(6):330 6 8292844
Clemmesen B, Ravn P, Zegels B, et al A 2-year phase II study with 1-year of follow-up of risedronate (NE-58095) in postmenopausal osteoporosis Osteoporos Int 1997 7(5):488 95 9425508
Clemson L, Cumming RG, Roland M Case-control study of hazards in the home and risk of falls and hip fractures Age Ageing 1996 25(2):97 101 8670535
Cochrane A, Holland W Validation of screening procedures Br Med Bull 1971 27(1):3 8 5100948
Cody DD, McCubbrey DA, Divine GW, et al Predictive value of proximal femoral bone densitometry in determining local orthogonal material properties J Biomech 1996 29(6):753 61 9147972
Cohen FJ, Eckert S, Mitlak BH Geographic differences in bone turnover: data from a multinational study in healthy postmenopausal women Calcif Tissue Int 1998 63(4):277 82 9744983
Cohen O, Rais T, Lepkifker E, et al Lithium carbonate therapy is not a risk factor for osteoporosis Horm Metab Res 1998 30(9):594 7 9808330
Cole RP, Palushock S, Haboubi A Osteoporosis management: physicians' recommendations and womens' compliance following osteoporosis testing Women Health 1999 29(1):101 15 10427644
Collins D, Woods A, Herd R, et al Insulin-like growth factor-I and bone mineral density Bone 1998 23(1):13 6 9662125
Compston JE, Cooper C, Kanis JA. Bone densitometry in clinical practice. BMJ. 1995;310:1507-10. [pmid: 7787600].
Consensus conference: Osteoporosis JAMA 1984 252(6):799 802 6748181
Diagnosis, prophylaxis and treatment of osteoporosis. Am J Med. 1991;90:107-10. [pmid: 1986575].
Diagnosis, prophylaxis and treatment of osteoporosis. Am J Med. 1993;94:646-50. [pmid: 8506892].
Cook DJ, Guyatt GH, Adachi JD, et al Quality of life issues in women with vertebral fractures due to osteoporosis Arthritis Rheum 1993 36(6):750 6 8507215
Cooper C, Barker DJ, Morris J, et al Osteoporosis, falls, and age in fracture of the proximal femur Br Med J (Clin Res Ed) 1987 295(6589):13 5
Cooper C, Barker DJ, Wickham CA. Physical activity, muscle strength, and calcium intake in fracture of the proximal femur in Britain. BMJ. 1988;297:1443-6. [pmid: 3147008]. [pmcid: 1835123].
Cooper C, Wickham CA, Coggon D. Sedentary work in middle life and fracture of the proximal femur. Br J Indust Med. 1990;47:69-70.
Cooper C, Wickham CA, Barker DJ, et al Water fluoridation and hip fracture JAMA 1991 266(4):513 4 2061972
Cooper C, Shah S, Hand DJ, et al. Screening for vertebral osteoporosis using individual risk factors. Osteoporos Int. 1991;2:48-53. [pmid: 1790421].
Cooper C, Atkinson EJ, Wahner HW, et al Is caffeine consumption a risk factor for osteoporosis? J Bone Miner Res 1992 7(4):465 71 1609631
Cooper C, Hannaford P, Croft P, et al Oral contraceptive pill use and fractures in women: a prospective study Bone 1993 14(1):41 5 8443001
Cooper C, Barker DJP Risk factors for hip fracture N Engl J Med 1995 332(12):814 5 7862187
Cooper C The crippling consequences of fractures and their impact on quality of life Am J Med 1997 103(2A):12S 7S; discussion 7S-9S 9302893
Cooper GS, Sandler DP Long-term effects of reproductive-age menstrual cycle patterns on peri- and postmenopausal fracture risk Am J Epidemiol 1997 145(9):804 9 9143210
Cooper C, Stakkestad JA, Radowicki S, et al Matrix delivery transdermal 17beta-estradiol for the prevention of bone loss in postmenopausal women. The International Study Group Osteoporos Int 1999 9(4):358 66 10550454
Cooper C Epidemiology of osteoporosis Osteoporos Int 1999 9Suppl 2:S2 8 10525719
Cornuz J, Feskanich D, Willett WC, et al Smoking, smoking cessation, and risk of hip fracture in women Am J Med 1999 106(3):311 4 10190380
Cosman F, Shen V, Xie F, et al Estrogen protection against bone resorbing effects of parathyroid hormone infusion. Assessment by use of biochemical markers [published erratum appears in Ann Intern Med 1994 Apr 15; 120(8):698] Ann Intern Med 1993 118(5):337 43 8430979
Cosman F, Nieves J, Wilkinson C, et al Bone density change and biochemical indices of skeletal turnover Calcif Tissue Int 1996 58(4):236 43 8661954
Cosman F, Nieves J, Woelfert L, et al Alendronate does not block the anabolic effect of PTH in postmenopausal osteoporotic women J Bone Miner Res 1998 13(6):1051 5 9626638
Coupland C, Wood D, Cooper C Physical inactivity is an independent risk factor for hip fracture in the elderly J Epidemiol Community Health 1993 47(6):441 3 8120496
Coupland CA, Cliffe SJ, Bassey EJ, et al Habitual physical activity and bone mineral density in postmenopausal women in England Int J Epidemiol 1999 28(2):241 6 10342685
Cubrilo-Turek M, Stavljenic-Rukavina A, Turek S, et al The usefulness of biochemical bone markers in predicting the response of hormone replacement therapy in perimenopausal cigarette smoking healthy women Collegium Antropologicum 1999 23(1):195 201 10402723
Cuddihy MT, Gabriel SE, Crowson CS, et al. Forearm fractures as predictors of subsequent osteoporotic fractures. Osteoporos Int. 1999;9:469-75. [pmid: 10624452].
Cumming RG Calcium intake and bone mass: a quantitative review of the evidence Calcif Tissue Int 1990 47(4):194 201 2146986
Cumming RG, Klineberg RJ Epidemiological study of the relation between arthritis of the hip and hip fractures Ann Rheum Dis 1993 52(10):707 10 8257206 1005165
Cumming RG, Klineberg RJ Psychotropics, thiazide diuretics and hip fractures in the elderly Med J Aust 1993 158(6):414 7 8479356
Cumming RG, Klineberg RJ Breastfeeding and other reproductive factors and the risk of hip fractures in elderly women [published erratum appears in Int J Epidemiol 1993 Oct;22(5):962] Int J Epidemiol 1993 22(4):684 91 8225744
Cumming RG, Klineberg RJ Aluminium in antacids and cooking pots and the risk of hip fractures in elderly people Age Ageing 1994 23(6):468 72 9231940
Cumming RG, Klineberg RJ Fall frequency and characteristics and the risk of hip fractures J Am Geriatr Soc 1994 42(7):774 8 8014355
Cumming RG, Klineberg RJ Case-control study of risk factors for hip fractures in the elderly Am J Epidemiol 1994 139(5):493 503 8154473
Cumming RG Nursing home residence and risk of hip fracture Am J Epidemiol 1996 143(12):1191 4 8651217
Cummings SR Are patients with hip fractures more osteoporotic? Review of the evidence Am J Med 1985 78(3):487 94 3976707
Cummings SR, Black DM, Nevitt MC, et al Appendicular bone density and age predict hip fracture in women. The Study of Osteoporotic Fractures Research Group JAMA 1990 263(5):665 8 2404146
Cummings SR, Browner WS, Ettinger B Should prescription of postmenopausal hormone therapy be based on the results of bone densitometry? Ann Intern Med 1990 113(8):565 7 2119160
Cummings SR, Black DM, Nevitt MC, et al. Bone density at various sites for prediction of hip fractures. Lancet. 1993;341:72-5. [pmid: 8093403].
Cummings SR, Marcus R, Palermo L, et al Does estimating volumetric bone density of the femoral neck improve the prediction of hip fracture? A prospective study. Study of Osteoporotic Fractures Research Group J Bone Miner Res 1994 9(9):1429 32 7817827
Cummings SR, Cauley JA, Palermo L, et al Racial differences in hip axis lengths might explain racial differences in rates of hip fracture. Study of Osteoporotic Fractures Research Group Osteoporos Int 1994 4(4):226 9 7949753
Cummings SR, Nevitt MC, Browner WS, et al Risk factors for hip fracture in white women. Study of Osteoporotic Fractures Research Group N Engl J Med 1995 332(12):767 73 7862179
Cummings SR Treatable and untreatable risk factors for hip fracture Bone 1996 18(3 Suppl):165S 7S 8777083
Cummings SR, Browner WS, Bauer DC, et al Endogenous hormones and the risk of hip and vertebral fractures among older women. Study of Osteoporotic Fractures Research Group N Engl J Med 1998 339(11):733 8 9731089
Cummings SR Prevention of hip fractures in older women: a population-based perspective Osteoporos Int 1998 8Suppl 1:S8 12 9682790
Cummings SR, Black DM, Thompson DE Effect of alendronate reduces on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial JAMA 1998 280(24):2077 82 9875874
Cummings SR, Palermo L, Browner W, et al. Monitoring osteoporosis therapy with bone densitometry. JAMA. 2000;283:1318-21. [pmid: 10714731].
Cunningham J, Fordham J, Hewitt T, et al Ultrasound velocity and attenuation at different skeletal sites compared with bone mineral density measured using dual energy X-ray absorptiometry Br J Radiol 1996 69(817):25 32 8785618
D'Erasmo E, Pisani D, Ragno A, et al Relationship between serum albumin and bone mineral density in postmenopausal women and in patients with hypoalbuminemia Horm Metab Res 1999 31(6):385 8 10437629
Dagago-Jack S, Clutter WE. Mineral and metabolic bone disease. In: Ewald GA, McKenzie CR, editors, Manual of Medical Therapeutics. Boston: Little, Brown and Company; 1995.
Dalsky GP, Stocke KS, Ehsani AA, et al. Weight-bearing exercise training and lumbar bone mineral content in postmenopausal women. Ann Intern Med. 1988;108:824-8. [pmid: 3259410].
Daly E, Roche M, Barlow D, et al HRT: an analysis of benefits, risks and costs Br Med Bull 1992 48(2):368 400 1450876
Daniels ED, Pettifor JM, Schnitzler CM, et al Ethnic differences in bone density in female South African nurses J Bone Miner Res 1995 10(3):359 67 7785456
Daniels ED, Pettifor JM, Schnitzler CM, et al Differences in mineral homeostasis, volumetric bone mass and femoral neck axis length in black and white South African women Osteoporos Int 1997 7(2):105 12 9166389
Danielson C, Lyon JL, Egger M, et al Hip fractures and fluoridation in Utah's elderly population JAMA 1992 268(6):746 8 1640574
Danielson ME, Cauley JA, Baker CE, et al Familial resemblance of bone mineral density (BMD) and calcaneal ultrasound attenuation: the BMD in mothers and daughters study J Bone Miner Res 1999 14(1):102 10 9893071
Dargent-Molina P, Favier F, Grandjean H, et al Fall-related factors and risk of hip fracture: the EPIDOS prospective study. [published erratum appears in Lancet 1996 Aug 10;348(9024):416] Lancet 1996 348(9021):145 9 8684153
Dargent-Molina P Risk factors and prevention of fractures in the elderly Curr Opin Rheumatol 1998 10(4):357 61 9725099
Dargent-Molina P, Schott AM, Hans D, et al Separate and combined value of bone mass and gait speed measurements in screening for hip fracture risk: results from the EPIDOS study. Epidemiologie de l'Osteoporose Osteoporos Int 1999 9(2):188 92 10367048
Davis JW, Ross PD, Wasnich RD A longitudinal study of estrogen and calcium supplement use among Japanese women living in Hawaii Prev Med 1995 24(2):159 65 7597018
Davis JW, Grove JS, Wasnich RD, et al Spatial relationships between prevalent and incident spine fractures Bone 1999 24(3):261 4 10071920
Dawson-Hughes B, Shipp C, Sadowski L, et al. Bone density of the radius, spine, and hip in relation to percent of ideal body weight in postmenopausal women. Calcif Tissue Int. 1987;40:310-4. [pmid: 3111668].
Dawson-Hughes B, Dallal GE Effect of radiographic abnormalities on rate of bone loss from the spine Calcif Tissue Int 1990 46(4):280 1 2108799
Dawson-Hughes B, Harris SS, Krall EA, et al Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older N Engl J Med 1997 337(10):670 6 9278463
de Aloysio D, Pansini F, Campobasso C, et al Effects of cyclic therapy with intranasal carbocalcitonin in healthy spontaneous postmenopausal women Clin Exp Obstet Gynecol 1996 23(2):87 93 8737620
de Aloysio D, Gambacciani M, Altieri P, et al Bone density changes in postmenopausal women with the administration of ipriflavone alone or in association with low-dose ERT Gynecol Endocrinol 1997 11(4):289 93 9272427
de la Piedra C, Torres R, Rapado A, et al Serum tartrate-resistant acid phosphatase and bone mineral content in postmenopausal osteoporosis Calcif Tissue Int 1989 45(1):58 60 2504465
de Laet CE, van Hout BA, Burger H, et al Bone density and risk of hip fracture in men and women: cross sectional analysis [published erratum appears in BMJ 1997 Oct 11;315(7113):916] BMJ 1997 315(7102):221 5 9253270
de Laet CE, van Hout BA, Burger H, et al Hip fracture prediction in elderly men and women: validation in the Rotterdam study J Bone Miner Res 1998 13(10):1587 93 9783547
Dean S Hysterectomy and bone mineral density Hospital Medicine 1997 57(5):207 9
Del Campo MT, Gonzalez-Casaus ML, Aguado P, et al Effects of age, menopause and osteoporosis on free, peptide-bound and total pyridinium crosslink excretion Osteoporos Int 1999 9(5):449 54 10550465
Delmas PD, Schlemmer A, Gineyts E, et al Urinary excretion of pyridinoline crosslinks correlates with bone turnover measured on iliac crest biopsy in patients with vertebral osteoporosis J Bone Miner Res 1991 6(6):639 44 1887826
Delmas PD The role of markers of bone turnover in the assessment of fracture risk in postmenopausal women Osteoporos Int 1998 8(Suppl 1):S32 6 9682795
Delmas PD How should the risk of fracture in postmenopausal women be assessed? Osteoporos Int 1999Suppl. 2:S33 S9
Delmas PD, Hardy P, Garnero P, et al Monitoring individual response to hormone replacement therapy with bone markers Bone 2000 26(6):553 60 10831925
Dempster DW, Parisien M, Silverberg SJ, et al On the mechanism of cancellous bone preservation in postmenopausal women with mild primary hyperparathyroidism J Clin Endocrinol Metab 1999 84(5):1562 6 10323380
Dequeker J, Johnell O Osteoarthritis protects against femoral neck fracture: the MEDOS study experience Bone 1993 14Suppl 1:S51 6 8110521
Dere W, Avouac B, Boers M, et al Recommendations for the health economics analysis to be performed with a drug to be registered in prevention or treatment of osteoporosis Calcif Tissue Int 1998 63(2):93 7 9685510
Derisquebourg T, Dubois P, Devogelaer JP, et al Automated computerized radiogrammetry of the second metacarpal and its correlation with absorptiometry of the forearm and spine Calcif Tissue Int 1994 54(6):461 5 8082046
Devogelaer JP, Broll H, Correa-Rotter R, et al Oral alendronate induces progressive increases in bone mass of the spine, hip, and total body over 3 years in postmenopausal women with osteoporosis [published erratum appears in Bone 1996 Jul;19(1):78] Bone 1996 18(2):141 50 8833208
Diaz MN, O'Neill TW, Silman AJ The influence of family history of hip fracture on the risk of vertebral deformity in men and women: the European Vertebral Osteoporosis Study Bone 1997 20(2):145 9 9028539
Dominguez Cabrera C, Sosa Henriquez M, Traba ML, et al Biochemical markers of bone formation in the study of postmenopausal osteoporosis Osteoporos Int 1998 8(2):147 51 9666938
Draper MW, Flowers DE, Huster WJ, et al A controlled trial of raloxifene (LY139481) HCl: impact on bone turnover and serum lipid profile in healthy postmenopausal women J Bone Miner Res 1996 11(6):835 42 8725181
Dresner-Pollak R, Mayer M, Hochner-Celiniker D. The decrease in serum bone-specific alkaline phosphatase predicts bone mineral density response to hormone replacement therapy in early postmenopausal women. Calcif Tissue Int. 2000;66:104-7. [pmid: 10652956].
Dretakis E, Kontakis G, Steriopoulos C, et al Decreased broadband ultrasound attenuation of the calcaneus in women with fragility fracture Acta Orthop Scand 1994 65(3):305 8 8042483
Dretakis E, Damilakis J, Kontakis G, et al. Variation between os calces as measured by broadband ultrasound attenuation. Br J Radiol. 1994;67:636-8. [pmid: 8061997].
Dretakis E, Kontakis G, Steriopoulos K, et al. Broadband ultrasound attenuation of the os calcis in female postmenopausal patients with cervical and trochanteric fracture. Calcif Tissue Int. 1995;57:419-21. [pmid: 8581872].
Drummond MF, O'Brien B, Stoddart GL, et al. Methods of the economic evaluation of health care programmes. 2nd ed. Toronto: Oxford University Press; 1997.
Duboeuf F, Hans D, Schott AM, et al Different morphometric and densitometric parameters predict cervical and trochanteric hip fracture: the EPIDOS Study J Bone Miner Res 1997 12(11):1895 902 9383694
Dunn W, Kan S, Wahner H Errors in longitudinal measurements of bone mineral: effect of source strength in single and dual photon absorptiometry J Nucl Med 1987 28(11):1751 7 3668666
Earnshaw SA, Hosking DJ Clinical usefulness of risk factors for osteoporosis Ann Rheum Dis 1996 55(6):338 9 8694570 1010180
Earnshaw SA, Worley A, Hosking DJ Current diet does not relate to bone mineral density after the menopause. The Nottingham Early Postmenopausal Intervention Cohort (EPIC) Study Group Br J Nutr 1997 78(1):65 72 9292760
Earnshaw SA, Keating N, Hosking DJ, et al Tooth counts do not predict bone mineral density in early postmenopausal Caucasian women. EPIC study group Int J Epidemiol 1998 27(3):479 83 9698139
Eastell R, Robins SP, Colwell T, et al Evaluation of bone turnover in type I osteoporosis using biochemical markers specific for both bone formation and bone resorption Osteoporos Int 1993 3(5):255 60 8400607
Eastell R Forearm fracture Bone 1996 18(3 Suppl):203S 7S 8777089
Eastell R, Colwell A, Hampton L, et al Biochemical markers of bone resorption compared with estimates of bone resorption from radiotracer kinetic studies in osteoporosis J Bone Miner Res 1997 12(1):59 65 9240726
Eckert P, Casez JP, Thiebaud D, et al Bone densitometry of the forearm: comparison of single-photon and dual-energy X-ray absorptiometry Bone 1996 18(6):575 9 8805999
Edelstein SL, Barrett-Connor E Relation between body size and bone mineral density in elderly men and women Am J Epidemiol 1993 138(3):160 9 8356959
Edwards M New drugs for osteoporosis. Comparison of the costs and required returns with those of other drugs intended for long-term use Pharmacoeconomics 1999 15(3):269 78 10537434
Eisman J Relevance of pregnancy and lactation to osteoporosis? Lancet 1998 352(9127):504 5 9716051
Elders PJ, Netelenbos JC, Lips P, et al Perimenopausal bone mass and risk factors Bone Miner 1989 7(3):289 99 2611448
Elffors I, Allander E, Kanis JA, et al The variable incidence of hip fracture in southern Europe: the MEDOS Study Osteoporos Int 1994 4(5):253 63 7812073
Ellerington MC, Hillard TC, Whitcroft SI, et al Intranasal salmon calcitonin for the prevention and treatment of postmenopausal osteoporosis Calcif Tissue Int 1996 59(1):6 11 8661976
Elliot JR, Hanger HC, Gilchrist NL, et al A comparison of elderly patients with proximal femoral fractures and a normal elderly population: a case control study N Z Med J 1992 105(944):420 2 1297935
Elliot JR, Gilchrist NL, Wells JE, et al Historical assessment of risk factors in screening for osteopenia in a normal Caucasian population Aust N Z J Med 1993 23(5):458 62 8297274
Ensrud KE, Cauley J, Lipschutz R, et al Weight change and fractures in older women. Study of Osteoporotic Fractures Research Group Arch Intern Med 1997 157(8):857 63 9129545
Ensrud KE, Stone K, Cauley JA, et al Vitamin D receptor gene polymorphisms and the risk of fractures in older women. For the Study of Osteoporotic Fractures Research Group J Bone Miner Res 1999 14(10):1637 45 10491209
Ensrud KE, Duong T, Cauley JA, et al Low fractional calcium absorption increases the risk for hip fracture in women with low calcium intake Ann Intern Med 2000 132(5):345 53 10691584
Epstein RS, Feng W, Hirsch LJ, et al Intervention thresholds for the treatment of osteoporosis: comparison of different approaches to decision-making Osteoporos Int 1998 8Suppl 1:S22 7 9682793
Erdtsieck RJ, Pols HA, van Kuijk C, et al Course of bone mass during and after hormonal replacement therapy with and without addition of nandrolone decanoate J Bone Miner Res 1994 9(2):277 83 8140941
Erdtsieck RJ, Pols HA, Valk NK, et al Treatment of post-menopausal osteoporosis with a combination of growth hormone and pamidronate: a placebo controlled trial Clin Endocrinol 1995 43(5):557 65
Eriksson SA, Lindgren JU Outcome of falls in women: endogenous factors associated with fracture Age Ageing 1989 18(5):303 8 2603838
Ettinger B, Genant HK, Cann CE Long-term estrogen replacement therapy prevents bone loss and fractures Ann Intern Med 1985 102(3):319 24 2982302
Ettinger B, Grady D Maximizing the benefit of estrogen therapy for prevention of osteoporosis Menopause 1994 1(1):19 24
Ettinger B, Pressman A, Schein J Clinic visits and hospital admissions for care of acid-related upper gastrointestinal disorders in women using alendronate for osteoporosis Am J Manag Care 1998 4(10):1377 82 10338731
Evers SE, Orchard JW, Haddad RG Bone density in postmenopausal North American Indian and Caucasian females Hum Biol 1985 57(4):719 26 4086025
Fairney A, Kyd P, Thomas E, et al The use of cyclical etidronate in osteoporosis: changes after completion of 3 years treatment Br J Rheumatol 1998 37(1):51 6 9487251
Falch JA, Sandvik L, Van Beresteijn EC Development and evaluation of an index to predict early postmenopausal bone loss Bone 1992 13(4):337 41 1389575
Farmer ME, White LR, Brody JA, et al Race and sex differences in hip fracture incidence Am J Public Health 1984 74(12):1374 80 6507690 1652702
Farmer ME, Harris T, Madans JH, et al Anthropometric indicators and hip fracture. The NHANES I epidemiologic follow-up study J Am Geriatr Soc 1989 37(1):9 16 2909610
Faulkner KG, Gluer CC, Palermo L, et al Geometric measurements from dual X-ray absorptiometry scans predict hip fracture J Bone Miner Res 1992 7(1):
Faulkner KG, Cummings SR, Black D, et al Simple measurement of femoral geometry predicts hip fracture: the study of osteoporotic fractures J Bone Miner Res 1993 8(10):1211 7 8256658
Faulkner KG, McClung MR, Coleman LJ, et al. Quantitative ultrasound of the heel: correlation with densitometric measurements at different skeletal sites. Osteoporos Int. 1994;4:42-7. [pmid: 8148571].
Faulkner KG, Roberts LA, McClung MR Discrepancies in normative data between Lunar and Hologic DXA systems Osteoporos Int 1996 6(6):432 6 9116387
Faulkner KG, von Stetten E, Miller P Discordance in patient classification using T-scores J Clin Densitomet 1999 2(3):343 50
Faulkner KG Bone matters: are density increases necessary to reduce fracture risk? J Bone Miner Res 2000 15(2):183 7 10703919
Feldblum PJ, Zhang J, Rich LE, et al Lactation history and bone mineral density among perimenopausal women Epidemiology 1992 3(6):527 31 1420520
Felson DT, Kiel DP, Anderson JJ, et al Alcohol consumption and hip fractures: the Framingham Study Am J Epidemiol 1988 128(5):1102 10 3189283
Felson DT, Anderson JJ, Hannan MT, et al Impaired vision and hip fracture. The Framingham Study J Am Geriatr Soc 1989 37(6):495 500 2715555
Felson DT, Sloutskis D, Anderson JJ, et al Thiazide diuretics and the risk of hip fracture. Results from the Framingham Study JAMA 1991 265(3):370 3 1984536
Felson DT, Zhang Y, Hannan MT, et al The effect of postmenopausal estrogen therapy on bone density in elderly women N Engl J Med 1993 329(16):1141 6 8377776
Felson DT, Zhang Y, Hannan MT, et al Alcohol intake and bone mineral density in elderly men and women. The Framingham Study Am J Epidemiol 1995 142(5):485 92 7677127
Ferrari SL, Rizzoli R, Slosman DO, et al Do dietary calcium and age explain the controversy surrounding the relationship between bone mineral density and vitamin D receptor gene polymorphisms? J Bone Miner Res 1998 13(3):363 70 9525336
Feskanich D, Willett WC, Stampfer MJ, et al Protein consumption and bone fractures in women Am J Epidemiol 1996 143(5):472 9 8610662
Feskanich D, Willett WC, Stampfer MJ, et al A prospective study of thiazide use and fractures in women Osteoporos Int 1997 7(1):79 84 9102069
Feskanich D, Willett WC, Stampfer MJ, et al Milk, dietary calcium, and bone fractures in women: a 12-year prospective study Am J Public Health 1997 87(6):992 7 9224182 1380936
Feskanich D, Hunter DJ, Willett WC, et al Vitamin D receptor genotype and the risk of bone fractures in women Epidemiology 1998 9(5):535 9 9730033
Feskanich D, Owusu W, Hunter DJ, et al Use of toenail fluoride levels as an indicator for the risk of hip and forearm fractures in women Epidemiology 1998 9(4):412 6 9647905
Feskanich D, Weber P, Willett WC, et al Vitamin K intake and hip fractures in women: a prospective study Am J Clin Nutr 1999 69(1):74 9 9925126
Field CS, Ory SJ, Wahner HW, et al Preventive effects of transdermal 17 beta-estradiol on osteoporotic changes after surgical menopause: a two-year placebo-controlled trial Am J Obstet Gynecol 1993 168(1 Pt 1):114 21 8420311
Filipponi P, Pedetti M, Fedeli L, et al Cyclical clodronate is effective in preventing postmenopausal bone loss: a comparative study with transcutaneous hormone replacement therapy J Bone Miner Res 1995 10(5):697 703 7639104
Finsen V, Benum P. Past fractures indicate increased risk of hip fracture. Acta Orthop Scand. 1986;57:337-9. [pmid: 3788499].
Finsen V, Benum P Colles' fracture as an indicator of increased risk of hip fracture. An epidemiological study Ann Chir Gynaecol 1987 76(2):114 8 3497604
Fiore CE, Pennisi P, Gibilaro M, et al Correlation of quantitative ultrasound of bone with biochemical markers of bone resorption in women with osteoporotic fractures J Clin Densitomet 1999 2(3):231 9
Fischer M, Kempers B Phantom studies in osteoporosis Eur J Nucl Med 1993 20(5):434 9 8519262
Fisher ES, Baron JA, Malenka DJ, et al Hip fracture incidence and mortality in New England Epidemiology 1991 2(2):116 22 1932308
Fledelius C, Riis BJ, Overgaard K, et al The diagnostic validity of urinary free pyridinolines to identify women at risk of osteoporosis Calcif Tissue Int 1994 54(5):381 4 8062154
Flicker L, Faulkner KG, Hopper JL, et al Determinants of hip axis length in women aged 10-89 years: a twin study Bone 1996 18(1):41 5 8717535
Foldes J, Tarjan G, Szathmari M, et al Bone mineral density in patients with endogenous subclinical hyperthyroidism: is this thyroid status a risk factor for osteoporosis? Clin Endocrinol 1993 39(5):521 7
Foldes J, Lakatos P, Zsadanyi J, et al Decreased serum IGF-I and dehydroepiandrosterone sulphate may be risk factors for the development of reduced bone mass in postmenopausal women with endogenous subclinical hyperthyroidism Eur J Endocrinol 1997 136(3):277 81 9100552
Foley KT, Owings TM, Pavol MJ, et al Maximum grip strength is not related to bone mineral density of the proximal femur in older adults Calcif Tissue Int 1999 64(4):291 4 10089220
Ford AB Reducing the threat of hip fracture Am J Public Health 1989 79(3):269 70 2916708 1349541
Formica CA, Nieves JW, Cosman F, et al Comparative assessment of bone mineral measurements using dual X-ray absorptiometry and peripheral quantitative computed tomography Osteoporos Int 1998 8(5):460 7 9850355
Forsen L, Bjorndal A, Bjartveit K, et al Interaction between current smoking, leanness, and physical inactivity in the prediction of hip fracture J Bone Miner Res 1994 9(11):1671 8 7863817
Forsen L, Bjartveit K, Bjorndal A, et al Ex-smokers and risk of hip fracture Am J Public Health 1998 88(10):1481 3 9772848 1508466
Forsen L, Meyer HE, Sogaard AJ, et al Mental distress and risk of hip fracture. Do broken hearts lead to broken bones? J Epidemiol Community Health 1999 53(6):343 7 10396480
Foundation for Osteoporosis Research and Education. Section III: Guidelines of care on osteoporosis for primary care physicians. 1997:1-7.
Fountos G, Tzaphlidou M, Kounadi E, et al In vivo measurement of radius calcium/phosphorus ratio by X-ray absorptiometry Appl Radiat Isot 1999 51(3):273 8 10404611
Fournier B, Chappard C, Roux C, et al Quantitative ultrasound imaging at the calcaneus using an automatic region of interest Osteoporos Int 1997 7(4):363 9 9373572
Fowler PB, McIvor J, Sykes L, et al The effect of long-term thyroxine on bone mineral density and serum cholesterol J R Coll Physicians Lond 1996 30(6):527 32 8961207
Fox KM, Magaziner J, Sherwin R, et al Reproductive correlates of bone mass in elderly women J Bone Miner Res 1993 8(8):901 8 8213252
Fox KM, Cummings SR Is tubal ligation a risk factor for low bone density and increased risk of fracture? Am J Obstet Gynecol 1995 172(1 Pt 1):101 5 7847513
Fox KM, Cummings SR, Powell-Threets K, et al Family history and risk of osteoporotic fracture. Study of Osteoporotic Fractures Research Group Osteoporos Int 1998 8(6):557 62 10326061
Franceschi S, Schinella D, Bidoli E, et al The influence of body size, smoking, and diet on bone density in pre- and postmenopausal women Epidemiology 1996 7(4):411 4 8793368
Francis RM, Anderson FH, Torgerson DJ A comparison of the effectiveness and cost of treatment for vertebral fractures in women Br J Rheumatol 1995 34(12):1167 71 8608360
Franklyn JA, Betteridge J, Daykin J, et al Long-term thyroxine treatment and bone mineral density Lancet 1992 340(8810):9 13 1351654
Franklyn J, Betteridge J, Holder R, et al Bone mineral density in thyroxine treated females with or without a previous history of thyrotoxicosis Clin Endocrinol 1994 41(4):425 32
French SA, Folsom AR, Jeffery RW, et al Weight variability and incident disease in older women: the Iowa Women's Health Study Int J Obes Relat Metab Disord 1997 21(3):217 23 9080261
Fujiwara S, Kasagi F, Yamada M, et al Risk factors for hip fracture in a Japanese cohort J Bone Miner Res 1997 12(7):998 1004 9199997
Fuleihan GE, Testa MA, Angell JE, et al Reproducibility of DXA absorptiometry: a model for bone loss estimates J Bone Miner Res 1995 10(7):1004 14 7484275
Gabriel SE, Kneeland TS, Melton LJ 3rd, et al Health-related quality of life in economic evaluations for osteoporosis: whose values should we use? Med Decis Making 1999 19(2):141 8 10231076
Gallagher JC, Kinyamu HK, Fowler SE, et al Calciotropic hormones and bone markers in the elderly J Bone Miner Res 1998 13(3):475 82 9525348
Gambacciani M, Spinetti A, Taponeco F, et al Bone loss in perimenopausal women: a longitudinal study Maturitas 1994 18(3):191 7 8015502
Gambacciani M, Ciaponi M, Cappagli B, et al Effects of combined low dose of the isoflavone derivative ipriflavone and estrogen replacement on bone mineral density and metabolism in postmenopausal women Maturitas 1997 28(1):75 81 9391998
Gardsell P, Johnell J, Nilsson BE. Predicting fractures in women by using forearm bone densitometry. Calcif Tissue Int. 1989;44:235-42. [pmid: 2501005].
Gardsell P, Johnell O, Nilsson BE, et al The predictive value of fracture, disease, and falling tendency for fragility fractures in women Calcif Tissue Int 1989 45(6):327 30 2509022
Gardsell P, Johnell O, Nilsson BE The impact of menopausal age on future fragility fracture risk J Bone Miner Res 1991 6(5):429 33 2068949
Gardsell P, Johnell O, Nilsson B, et al. Predicting various fragility fractures in women by forearm bone densitometry: a follow-up study. Calcif Tissue Int. 1993;52:348-53. [pmid: 8504371].
Garland SW, Lees B, Stevenson JC DXA longitudinal quality control: a comparison of inbuilt quality assurance, visual inspection, multi-rule Shewhart charts and Cusum analysis Osteoporos Int 1997 7(3):231 7 9205636
Garnero P, Shih W, Gineyts E, et al Comparison of new biochemical markers of bone turnover in late postmenopausal osteoporotic women in response to alendronate treatment J Clin Endocrinol Metab 1994 79(6):1693 700 7989477
Garnero P, Gineyts E, Arbault P, et al Different effects of bisphosphonate and estrogen therapy on free and peptide-bound bone cross-links excretion J Bone Miner Res 1995 10(4):641 9 7610936
Garnero P, Hausherr E, Chapuy MC, et al Markers of bone resorption predict hip fracture in elderly women: the EPIDOS Prospective Study J Bone Miner Res 1996 11(10):1531 8 8889854
Garnero P, Sornay-Rendu E, Chapuy MC, et al Increased bone turnover in late postmenopausal women is a major determinant of osteoporosis J Bone Miner Res 1996 11(3):337 49 8852944
Garnero P, Dargent-Molina P, Hans D, et al Do markers of bone resorption add to bone mineral density and ultrasonographic heel measurement for the prediction of hip fracture in elderly women? The EPIDOS prospective study Osteoporos Int 1998 8(6):563 9 10326062
Garnero P, Delmas PD Biochemical markers of bone turnover. Applications for osteoporosis Endocrinol Metab Clin North Am 1998 27(2):303 23 9669140
Garnero P, Darte D, Delmas PD A model to monitor the efficacy of alendronate treatment in women with osteoporosis using a biochemical marker of bone turnover Bone 1999 24(6):603 9 10375203
Garnero P, Sornay-Rendu E, Duboeuf F, et al Markers of bone turnover predict postmenopausal forearm bone loss over 4 years: the OFELY study J Bone Miner Res 1999 14(9):1614 21 10469291
Garton MJ, Cooper C, Reid D Perimenopausal bone density screening -- will it help prevent osteoporosis? Maturitas 1997 26(1):35 43 9032745
Geelhoed E, Harris A, Prince R Cost-effectiveness analysis of hormone replacement therapy and lifestyle intervention for hip fracture Aust J Public Health 1994 18(2):153 60 7948331
Genant HK, Grampp S, Gluer CC, et al Universal standardization for dual x-ray absorptiometry: patient and phantom cross-calibration results J Bone Miner Res 1994 9(10):1503 14 7817795
Genant HK, Engelke K, Fuerst T, et al Noninvasive assessment of bone mineral and structure: state of the art J Bone Miner Res 1996 11(6):707 30 8725168
Gennari L, Becherini L, Masi L, et al Vitamin D receptor genotypes and intestinal calcium absorption in postmenopausal women Calcif Tissue Int 1997 61(6):460 3 9383272
Gennari C, Adami S, Agnusdei D, et al Effect of chronic treatment with ipriflavone in postmenopausal women with low bone mass Calcif Tissue Int 1997 61(Suppl 1):S19 22 9263612
Gennari C, Agnusdei D, Crepaldi G, et al Effect of ipriflavone -- a synthetic derivative of natural isoflavones -- on bone mass loss in the early years after menopause Menopause 1998 5(1):9 15 9689189
Gerrits MI, Vecht-Hart IM, Oldenhave A, et al Comparison of urinary bone resorption markers in women of 40-70 years; day-to-day and long-term variation in individual subjects Maturitas 1998 30(3):247 55 9881324
Gertz BJ, Shao P, Hanson DA, et al Monitoring bone resorption in early postmenopausal women by an immunoassay for cross-linked collagen peptides in urine J Bone Miner Res 1994 9(2):135 42 8140926
Gertz BJ, Clemens JD, Holland SD, et al Application of a new serum assay for type I collagen cross-linked N-telopeptides: assessment of diurnal changes in bone turnover with and without alendronate treatment Calcif Tissue Int 1998 63(2):102 6 9685512
Ghiron LJ, Thompson JL, Holloway L, et al Effects of recombinant insulin-like growth factor-I and growth hormone on bone turnover in elderly women J Bone Miner Res 1995 10(12):1844 52 8619364
Gilfillan C, Silberberg S, Scrivenor P, et al Determinants of forearm mineral density and its correlation with fracture history in women Maturitas 1994 20(2-3):199 208 7715473
Gluer CC, Genant HK Impact of marrow fat on accuracy of quantitative CT J Comput Assist Tomogr 1989 13(6):1023 35 2584480
Gluer C, Cummings S, Pressman A, et al Prediction of hip fractures from pelvic radiographs: the study of osteoporotic fractures J Bone Miner Res 1994 9(5):671 7 8053396
Gluer CC, Cummings SR, Bauer DC, et al Osteoporosis: association of recent fractures with quantitative US findings Radiology 1996 199(3):725 32 8637996
Gnudi S, Malavolta N, Calderoni P, et al Ultrasound in the evaluation of bone fragility caused by osteoporosis: a comparison between different sites of measurement Chir Organi Mov 1996 81(4):383 7 9147929
Gnudi S, Gualtieri G, Malavolta N Simultaneous densitometry and quantitative bone sonography in the estimation of osteoporotic fracture risk Br J Radiol 1998 71(846):625 9 9849385
Godang K, Ueland T, Bollerslev J. Decreased bone area, bone mineral content, formative markers, and increased bone resorptive markers in endogenous Cushing's syndrome. Eur J Endocrinol. 1999;141:126-31. [pmid: 10427155].
Goemaere S, Zegels B, Toye K, et al. Limited clinical utility of a self-evaluating risk assessment scale for postmenopausal osteoporosis: lack of predictive value of lifestyle-related factors. Calcif Tissue Int. 1999;65:354-8. [pmid: 10541759].
Gold MR, Siegel JE, Russell LB, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Gold DT The clinical impact of vertebral fractures: quality of life in women with osteoporosis Bone 1996 18(Suppl 3):S185 S9
Gomez B Jr., Ardakani S, Evans BJ, et al Monoclonal antibody assay for free urinary pyridinium cross-links Clin Chem 1996 42(8 Pt 1):1168 75 8697572
Gonnelli S, Cepollaro C, Agnusdei D, et al. Diagnostic value of ultrasound analysis and bone densitometry as predictors of vertebral deformity in postmenopausal women. Osteoporos Int. 1995;5:413-8. [pmid: 8695961].
Gonnelli S, Cepollaro C, Pondrelli C, et al Ultrasound parameters in osteoporotic patients treated with salmon calcitonin: a longitudinal study Osteoporos Int 1996 6(4):303 7 8883119
Gonnelli S, Cepollaro C, Pondrelli C, et al The usefulness of bone turnover in predicting the response to transdermal estrogen therapy in postmenopausal osteoporosis J Bone Miner Res 1997 12(4):624 31 9101374
Gonnelli S, Cepollaro C, Pondrelli C, et al Bone turnover and the response to alendronate treatment in postmenopausal osteoporosis Calcif Tissue Int 1999 65(5):359 64 10541760
Gorai I, Taguchi Y, Chaki O, et al Specific changes of urinary excretion of cross-linked N-telopeptides of type I collagen in pre- and postmenopausal women: correlation with other markers of bone turnover Calcif Tissue Int 1997 60(4):317 22 9075625
Gordon CL, Lang TF, Augat P, et al Image-based assessment of spinal trabecular bone structure from high-resolution CT images Osteoporos Int 1998 8(4):317 25 10024901
Gotfredsen A, Podenphant J, Norgaard H, et al. Accuracy of lumbar spine bone mineral content by dual photon absorptiometry. J Nucl Med. 1988;29:248-54. [pmid: 3346735].
Goulding A, Gold E, Walker R, et al Women with past history of bone fracture have low spinal bone density before menopause N Z Med J 1997 110(1046):232 3 9236807
Goulding A, Taylor RW Plasma leptin values in relation to bone mass and density and to dynamic biochemical markers of bone resorption and formation in postmenopausal women Calcif Tissue Int 1998 63(6):456 8 9817937
Graafmans WC, Van Lingen A, Ooms ME, et al Ultrasound measurements in the calcaneus: precision and its relation with bone mineral density of the heel, hip, and lumbar spine Bone 1996 19(2):97 100 8853851
Graafmans WC, Ooms ME, Bezemer PD, et al Different risk profiles for hip fractures and distal forearm fractures: a prospective study Osteoporos Int 1996 6(6):427 31 9116386
Graafmans WC, Bouter LM, Lips P The influence of physical activity and fractures on ultrasound parameters in elderly people Osteoporos Int 1998 8(5):449 54 9850353
Grady D, Rubin S, Petitti D, et al Hormone therapy to prevent disease and prolong life in postmenopausal women Ann Intern Med 1992 117(12):1016 37 1443971
Grainge MJ, Coupland CA, Cliffe SJ, et al Cigarette smoking, alcohol and caffeine consumption, and bone mineral density in postmenopausal women. The Nottingham EPIC Study Group Osteoporos Int 1998 8(4):355 63 10024906
Grainge MJ, Coupland CA, Cliffe SJ, et al Association between a family history of fractures and bone mineral density in early postmenopausal women Bone 1999 24(5):507 12 10321911
Grainger DJ, Percival J, Chiano M, et al The role of serum TGF-beta isoforms as potential markers of osteoporosis Osteoporos Int 1999 9(5):398 404 10550458
Grampp S, Jergas M, Lang P, et al Quantitative CT assessment of the lumbar spine and radius in patients with osteoporosis Am J Roentgenol 1996 167(1):133 40 8659357
Grampp S, Majumdar S, Jergas M, et al Distal radius: in vivo assessment with quantitative MR imaging, peripheral quantitative CT, and dual X-ray absorptiometry Radiology 1996 198(1):213 8 8539382
Grampp S, Genant HK, Mathur A, et al Comparisons of noninvasive bone mineral measurements in assessing age-related loss, fracture discrimination, and diagnostic classification J Bone Miner Res 1997 12(5):697 711 9144335
Grampp S, Henk CB, Fuerst TP, et al Diagnostic agreement of quantitative sonography of the calcaneus with dual X-ray absorptiometry of the spine and femur Am J Roentgenol 1999 173(2):329 34 10430129
Grant DJ, McMurdo ME, Mole PA, et al Is previous hyperthyroidism still a risk factor for osteoporosis in post-menopausal women? Clin Endocrinol 1995 43(3):339 45
Green CJ, Bassett K, Foerster V, et al. Bone mineral density testing: does the evidence support its selective use in well women? Vancouver, British Columbia, Canada: British Columbia Office of Health Technology Assessment; 1997. Report No.: 97:2T.
Greendale GA, Barrett-Connor E, Edelstein S, et al Dietary sodium and bone mineral density: results of a 16-year follow-up study J Am Geriatr Soc 1994 42(10):1050 5 7930328
Greendale GA, Barrett-Connor E, Edelstein S, et al Lifetime leisure exercise and osteoporosis. The Rancho Bernardo study Am J Epidemiol 1995 141(10):951 9 7741125
Greendale GA, Unger JB, Rowe JW, et al The relation between cortisol excretion and fractures in healthy older people: results from the MacArthur studies-Mac J Am Geriatr Soc 1999 47(7):799 803 10404922
Greenspan SL, Myers ER, Maitland LA, et al Fall severity and bone mineral density as risk factors for hip fracture in ambulatory elderly JAMA 1994 271(2):128 33 8264067
Greenspan SL, Bouxsein ML, Melton ME, et al Precision and discriminatory ability of calcaneal bone assessment technologies J Bone Miner Res 1997 12(8):1303 13 9258762
Greenspan SL, Dresner-Pollak R, Parker RA, et al Diurnal variation of bone mineral turnover in elderly men and women Calcif Tissue Int 1997 60(5):419 23 9115158
Greenspan SL, Parker RA, Ferguson L, et al Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: a randomized clinical trial J Bone Miner Res 1998 13(9):1431 8 9738515
Greenspan SL, Myers ER, Kiel DP, et al Fall direction, bone mineral density, and function: risk factors for hip fracture in frail nursing home elderly Am J Med 1998 104(6):539 45 9674716
Greenspan SL, Greenspan FS The effect of thyroid hormone on skeletal integrity Ann Intern Med 1999 130(9):750 8 10357695
Gregg EW, Kriska AM, Salamone LM, et al The epidemiology of quantitative ultrasound: a review of the relationships with bone mass, osteoporosis and fracture risk Osteoporos Int 1997 7(2):89 99 9166387
Gregg EW, Cauley JA, Seeley DG, et al Physical activity and osteoporotic fracture risk in older women. Study of Osteoporotic Fractures Research Group Ann Intern Med 1998 129(2):81 8 9669990
Grey AB, Cundy TF, Reid IR. Continuous combined oestrogen/progestin therapy is well tolerated and increases bone density at the hip and spine in post-menopausal osteoporosis. Clin Endocrinol. 1994;40:671-7.
Griffin MR, Ray WA, Fought RL, et al Black-white differences in fracture rates Am J Epidemiol 1992 136(11):1378 85 1488964
Grisso JA, Kelsey JL, Strom BL, et al Risk factors for falls as a cause of hip fracture in women. The Northeast Hip Fracture Study Group N Engl J Med 1991 324(19):1326 31 2017229
Grisso JA, Kelsey JL, Strom BL, et al Risk factors for hip fracture in black women. The Northeast Hip Fracture Study Group N Engl J Med 1994 330(22):1555 9 8177244
Grodstein F, Stampfer MJ, Falkeborn M, et al Postmenopausal hormone therapy and risk of cardiovascular disease and hip fracture in a cohort of Swedish women Epidemiology 1999 10(5):476 80 10468418
Guerrero R, Diaz Martin MA, Diaz Diego EM, et al New biochemical markers of bone resorption derived from collagen breakdown in the study of postmenopausal osteoporosis Osteoporos Int 1996 6(4):297 302 8883118
Guglielmi G, Cammisa M, De Serio A, et al Phalangeal US velocity discriminates between normal and vertebrally fractured subjects Eur Radiol 1999 9(8):1632 7 10525880
Gundberg CM, Nieman SD, Abrams S, et al Vitamin K status and bone health: an analysis of methods for determination of undercarboxylated osteocalcin J Clin Endocrinol Metab 1998 83(9):3258 66 9745439
Gunnes M, Lehmann EH, Mellstrom D, et al The relationship between anthropometric measurements and fractures in women Bone 1996 19(4):407 13 8894148
Gunnes M, Mellstrom D, Johnell O How well can a previous fracture indicate a new fracture? A questionnaire study of 29,802 postmenopausal women Acta Orthop Scand 1998 69(5):508 12 9855234
Guo Z, Wills P, Viitanen M, et al Cognitive impairment, drug use, and the risk of hip fracture in persons over 75 years old: a community-based prospective study Am J Epidemiol 1998 148(9):887 92 9801019
Gurlek A, Bayraktar M, Gedik O Comparison of calcitriol treatment with etidronate-calcitriol and calcitonin-calcitriol combinations in Turkish women with postmenopausal osteoporosis: a prospective study Calcif Tissue Int 1997 61(1):39 43 9192511
Gutin B, Kasper MJ. Can vigorous exercise play a role in osteoporosis prevention? A review. Osteoporos Int. 1992;2:55-69. [pmid: 1536981].
Hadji P, Hars O, Wuster C, et al Stiffness index identifies patients with osteoporotic fractures better than ultrasound velocity or attenuation alone Maturitas 1999 31(3):221 6 10340281
Hadji P, Hars O, Bock K, et al Age changes of calcaneal ultrasonometry in healthy German women Calcif Tissue Int 1999 65(2):117 20 10430642
Hadjidakis D, Kokkinakis E, Sfakianakis M, et al. The type and time of menopause as decisive factors for bone mass changes. Eur J Clin Invest. 1999;29:877-85. [pmid: 10583430].
Hagiwara S, Engelke K, Takada M, et al Accuracy and diagnostic sensitivity of radiographic absorptiometry of the second metacarpal Calcif Tissue Int 1998 62(2):95 8 9437040
Hailey D, Sampietro-Colom L, Marshall D, et al. INAHTA project on the effectiveness of bone density measurement and associated treatments for prevention of fractures. Statement of findings. Edmonton, Alberta, Canada: Alberta Heritage Foundation for Medical Research, on behalf of the International Network of Agencies for Health Technology Assessment; 1996.
Hamed HM, Purdie DW, Steel SA, et al The relation between bone mineral density and early pregnancy loss Br J Obstet Gynaecol 1992 99(12):946 9 1477013
Hamed HM, Purdie DW, Ramsden CS, et al Influence of birth weight on adult bone mineral density Osteoporos Int 1993 3(1):1 2
Han K, Choi J, Moon I, et al Non-association of estrogen receptor genotypes with bone mineral density and bone turnover in Korean pre-, peri-, and postmenopausal women Osteoporos Int 1999 9(4):290 5 10550445
Hanger HC, Sainsbury R Screening the elderly: a Christchurch study N Z Med J 1990 103(899):473 5 2216130
Hanger HC, Smart EJ, Merrilees MJ, et al The prevalence of malnutrition in elderly hip fracture patients N Z Med J 1999 112(1084):88 90 10210293
Hanley JA, McNeil BJ. The meaning and use of the area under a receiver operating characteristic (ROC) curve. Radiology. 1982;143:29-36. [pmid: 7063747].
Hannon R, Blumsohn A, Naylor K, et al Response of biochemical markers of bone turnover to hormone replacement therapy: impact of biological variability J Bone Miner Res 1998 13(7):1124 33 9661076
Hans D, Schott A, Chapuy M, et al. Ultrasound measurements on the os calcis in a prospective multicenter study. Calcif Tissue Int. 1994;55:94-9. [pmid: 7953987].
Hans D, Schott AM, Arlot ME, et al Influence of anthropometric parameters on ultrasound measurements of Os calcis Osteoporos Int 1995 5(5):371 6 8800787
Hans D, Dargent-Molina P, Schott AM, et al Ultrasonographic heel measurements to predict hip fracture in elderly women: the EPIDOS prospective study Lancet 1996 348(9026):511 4 8757153
Hans D, Srivastav SK, Singal C, et al Does combining the results from multiple bone sites measured by a new quantitative ultrasound device improve discrimination of hip fracture? J Bone Miner Res 1999 14(4):644 51 10234587
Hansen M, Overgaard K, Riis B, et al. Role of peak bone mass and bone loss in postmenopausal osteoporosis: 12 year study. BMJ. 1991;303:961-4. [pmid: 1954420]. [pmcid: 1671323].
Hansen M, Overgaard K, Riis B, et al. Potential risk factors for development of postmenopausal osteoporosis -- examined over a 12-year period. Osteoporos Int. 1991;1:95-102. [pmid: 1790399].
Hansen MA, Hassager C, Jensen SB, et al Is heritability a risk factor for postmenopausal osteoporosis? J Bone Miner Res 1992 7(9):1037 43 1414496
Hansen MA Assessment of age and risk factors on bone density and bone turnover in healthy premenopausal women Osteoporos Int 1994 4(3):123 8 8069050
Hansen TS, Abrahamsen B, Henriksen FL, et al Vitamin D receptor alleles do not predict bone mineral density or bone loss in Danish perimenopausal women Bone 1998 22(5):571 5 9600794
Harris S, Dawson-Hughes B. Caffeine and bone loss in healthy postmenopausal women. Am J Clin Nutr. 1994;60:573-8. [pmid: 8092093].
Hasling C, Eriksen EF, Melkko J, et al Effects of a combined estrogen-gestagen regimen on serum levels of the carboxy-terminal propeptide of human type I procollagen in osteoporosis J Bone Miner Res 1991 6(12):1295 300 1724340
Hassager C, Jensen LT, Podenphant J, et al The carboxy-terminal pyridinoline cross-linked telopeptide of type I collagen in serum as a marker of bone resorption: the effect of nandrolone decanoate and hormone replacement therapy Calcif Tissue Int 1994 54(1):30 3 8118750
Health Care Financing Administration. National Physician Fee Schedule Payment Amount File. 2000. http://www.hcfa.gov/stats/carrpuf.htm.
Heaney RP. Nutritional factors in osteoporosis. Annu Rev Nutr. 1993;13:287-316. [pmid: 8369148].
Heaney RP Bone mass, bone loss, and osteoporosis prophylaxis Ann Intern Med 1998 128(4):313 4 9471936
Heidrich FE, Stergachis A, Gross KM Diuretic drug use and the risk for hip fracture Ann Intern Med 1991 115(1):1 6 2048857
Heikkinen JE, Selander KS, Laitinen K, et al Short-term intravenous bisphosphonates in prevention of postmenopausal bone loss J Bone Miner Res 1997 12(1):103 10 9240732
Heikkinen AM, Parviainen M, Niskanen L, et al Biochemical bone markers and bone mineral density during postmenopausal hormone replacement therapy with and without Vitamin D3: a prospective, controlled, randomized study J Clin Endocrinol Metab 1997 82(8):2476 82 9253321
Heilmann P, Wuster C, Prolingheuer C, et al. Measurement of forearm bone mineral density: comparison of precision of five different instruments. Calcif Tissue Int. 1998;62:383-7. [pmid: 9541514].
Heinonen A, Kannus P, Sievanen H, et al Randomised controlled trial of effect of high-impact exercise on selected risk factors for osteoporotic fractures Lancet 1996 348(9038):1343 7 8918277
Hemenway D, Colditz G, Willett W, et al. Fractures and lifestyle: effect of cigarette smoking, alcohol intake, and relative weight on the risk of hip and forearm fractures in middle-aged women. Am J Public Health. 1988;78:1554-8. [pmid: 3189632]. [pmcid: 1349734].
Hemenway D, Colditz GA The effect of climate on fractures and deaths due to falls among white women Accid Anal Prev 1990 22(1):59 65 2322370
Hemenway D, Azrael DR, Rimm EB, et al Risk factors for wrist fracture: effect of age, cigarettes, alcohol, body height, relative weight, and handedness on the risk for distal forearm fractures in men Am J Epidemiol 1994 140(4):361 7 8059771
Hemenway D, Feskanich D, Colditz GA Body height and hip fracture: a cohort study of 90,000 women Int J Epidemiol 1995 24(4):783 6 8550276
Heneghan JP, Kirke PN, Murphy BL, et al Evaluation of quantitative CT vertebral bone mineral density measurement and the Singh index in elderly females with hip fractures -- a case control study Br J Radiol 1997 70(837):923 8 9486068
Hennekens CH, Buring JE. Epidemiology in medicine. Boston: Little, Brown; 1987.
Herd RJ, Ramalingham T, Ryan P, et al. Measurements of broadband ultrasonic attenuation in the calcaneus in premenopausal and postmenopausal women. Osteoporos Int. 1992;2:247-51. [pmid: 1392264].
Herd RJ, Blake GM, Ramalingam T, et al Measurements of postmenopausal bone loss with a new contact ultrasound system Calcif Tissue Int 1993 53(3):153 7 8242465
Herd RJ, Balena R, Blake GM, et al The prevention of early postmenopausal bone loss by cyclical etidronate therapy: a 2-year, double-blind, placebo-controlled study Am J Med 1997 103(2):92 9 9274891
Herings RM, Stricker BH, de Boer A, et al Benzodiazepines and the risk of falling leading to femur fractures. Dosage more important than elimination half-life Arch Intern Med 1995 155(16):1801 7 7654115
Herings RM, Stricker BH, de Boer A, et al Current use of thiazide diuretics and prevention of femur fractures J Clin Epidemiol 1996 49(1):115 9 8598504
Hernandez-Avila M, Colditz GA, Stampfer MJ, et al Caffeine, moderate alcohol intake, and risk of fractures of the hip and forearm in middle-aged women Am J Clin Nutr 1991 54(1):157 63 2058578
Hesley RP, Shepard KA, Jenkins DK, et al Monitoring estrogen replacement therapy and identifying rapid bone losers with an immunoassay for deoxypyridinoline Osteoporos Int 1998 8(2):159 64 9666940
Hillard TC, Whitcroft SJ, Marsh MS, et al Long-term effects of transdermal and oral hormone replacement therapy on postmenopausal bone loss Osteoporos Int 1994 4(6):341 8 7696830
Hillier S, Inskip H, Coggon D, et al Water fluoridation and osteoporotic fracture Community Dent Health 1996 13Suppl 2:63 8
Hinton RY, Smith GS The association of age, race, and sex with the location of proximal femoral fractures in the elderly J Bone Joint Surg Am 1993 75(5):752 9 8501092
Hinton RY, Lennox DW, Ebert FR, et al. Relative rates of fracture of the hip in the United States: geographic, sex, and age variations. J Bone Joint Surg Am. 1995;77:695-702. [pmid: 7744894].
Ho C, Kim R, Schaffler M, et al. Accuracy of dual-energy radiographic absorptiometry of the lumbar spine: cadaver study. Radiology. 1990;176:171-3. [pmid: 2353087].
Ho SC Body measurements, bone mass, and fractures. Does the East differ from the West? Clin Orthop 1996 Feb(323):75 80
Ho SC, Wong E, Chan SG, et al Determinants of peak bone mass in Chinese women aged 21-40 years. III. Physical activity and bone mineral density J Bone Miner Res 1997 12(8):1262 71 9258757
Hochberg M, Ross P, Black D, et al Larger increases in bone mineral density during alendronate therapy are associated with a lower risk of new vertebral fractures in women with postmenopausal osteoporosis Arthritis Rheum 1999 42(6):1246 54 10366118
Hoffman S, Grisso JA, Kelsey JL, et al. Parity, lactation and hip fracture. Osteoporos Int. 1993;3:171-6. [pmid: 8338971].
Hoidrup S, Gronbaek M, Gottschau A, et al Alcohol intake, beverage preference, and risk of hip fracture in men and women. Copenhagen Centre for Prospective Population Studies Am J Epidemiol 1999 149(11):993 1001 10355374
Hoidrup S, Gronbaek M, Pederson AT, et al Hormone replacement therapy and hip fracture risk: effect modification by tobacco smoking, alcohol intake, physical activity, and body mass index Am J Epidemiol 1999 150(10):1085 93 10568624
Holbrook TL, Barrett-Connor E, Wingard DL Dietary calcium and risk of hip fracture: 14-year prospective population study Lancet 1988 2(8619):1046 9 2903278
Holbrook TL, Barrett-Connor E. A prospective study of alcohol consumption and bone mineral density. BMJ. 1993;306:1506-9. [pmid: 8518677]. [pmcid: 1677960].
Holbrook TL, Barrett-Connor E. An 18-year prospective study of dietary calcium and bone mineral density in the hip. Calcif Tissue Int. 1995;56:364-7. [pmid: 7621342].
Homik J, Hailey D. Quantitative ultrasound for bone density measurement. Edmonton, Alberta, Canada: Alberta Heritage Foundation for Medical Research; 1998. Report No.: Health Technology Assessment 11.
Homik J, Hailey D. Selective testing with bone density measurement. Edmonton, Alberta, Canada: Alberta Heritage Foundation for Medical Research; 1999. Report No.: Health Technology Brief 4.
Honkanen R, Alhava EM, Saarikoski S, et al Osteoporosis risk factors in perimenopausal women Calcif Tissue Int 1991 49Suppl:S74 5 1933605
Honkanen R, Kroger H, Tuppurainen M, et al Fractures and low axial bone density in perimenopausal women J Clin Epidemiol 1995 48(7):881 8 7782796
Honkanen R, Tuppurainen M, Kroger H, et al Associations of early premenopausal fractures with subsequent fractures vary by sites and mechanisms of fractures Calcif Tissue Int 1997 60(4):327 31 9075627
Honkanen R, Tuppurainen M, Kroger H, et al Relationships between risk factors and fractures differ by type of fracture: a population-based study of 12,192 perimenopausal women Osteoporos Int 1998 8(1):25 31 9692074
Hopper JL, Seeman E The bone density of female twins discordant for tobacco use N Engl J Med 1994 330(6):387 92 8284003
Hoshino H, Kushida K, Yamazaki K, et al Effect of physical activity as a caddie on ultrasound measurements of the Os calcis: a cross-sectional comparison J Bone Miner Res 1996 11(3):412 8 8852953
Hoshino H, Takahashi M, Kushida K, et al Urinary excretion of type I collagen degradation products in healthy women and osteoporotic patients with vertebral and hip fractures Calcif Tissue Int 1998 62(1):36 9 9405731
Hoshino H, Takahashi M, Kushida K, et al The relationships between the degree of beta-isomerization of type I collagen degradation products in the urine and aging, menopause and osteoporosis with fractures Osteoporos Int 1999 9(5):405 9 10550459
Hosking DJ, Ross PD, Thompson DE, et al Evidence that increased calcium intake does not prevent early postmenopausal bone loss Clin Ther 1998 20(5):933 44 9829445
Hosking D, Chilvers CED, Christiansen C, et al Prevention of bone loss with alendronate in postmenopausal women under 60 years of age N Engl J Med 1998 338(8):485 92 9443925
Houston LA, Grant SF, Reid DM, et al Vitamin D receptor polymorphism, bone mineral density, and osteoporotic vertebral fracture: studies in a UK population Bone 1996 18(3):249 52 8703580
Howard GM, Nguyen TV, Pocock NA, et al Influence of handedness on calcaneal ultrasound: implications for assessment of osteoporosis and study design Osteoporos Int 1997 7(3):190 4 9205629
Huang C, Ross PD, Fujiwara S, et al Determinants of vertebral fracture prevalence among native Japanese women and women of Japanese descent living in Hawaii Bone 1996 18(5):437 42 8739901
Huang Z, Himes JH, McGovern PG Nutrition and subsequent hip fracture risk among a national cohort of white women Am J Epidemiol 1996 144(2):124 34 8678043
Huang C, Ross PD, Yates AJ, et al Prediction of fracture risk by radiographic absorptiometry and quantitative ultrasound: a prospective study Calcif Tissue Int 1998 63(5):380 4 9799821
Hui SL, Slemenda CW, Johnston CC Jr Age and bone mass as predictors of fracture in a prospective study J Clin Invest 1988 81(6):1804 9 442628 3384952
Hui SL, Slemenda CW, Johnston CC Jr Baseline measurement of bone mass predicts fracture in white women Ann Intern Med 1989 111(5):355 61 2764403
Hui SL, Slemenda CW, Carey MA, et al Choosing between predictors of fractures J Bone Miner Res 1995 10(11):1816 22 8592960
Hunt AH The relationship between height change and bone mineral density Orthopaedic Nursing 1996 15(3):57 64; quiz 5-6 8788647
Hustmyer FG, Walker E, Yu XP, et al Cytokine production and surface antigen expression by peripheral blood mononuclear cells in postmenopausal osteoporosis J Bone Miner Res 1993 8(1):51 9 8427049
Hutchinson TA, Polansky SM, Feinstein AR Post-menopausal oestrogens protect against fractures of hip and distal radius. A case-control study Lancet 1979 2(8145):705 9 90802
Iki M, Dohi Y, Nishino H, et al Relative contributions of age and menopause to the vertebral bone density of healthy Japanese women Bone 1996 18(6):617 20 8806004
Ip M, Lam K, Yam L, et al Decreased bone mineral density in premenopausal asthma patients receiving long-term inhaled steroids Chest 1994 105(6):1722 7 8205866
Ismail F, Epstein S, Pacifici R, et al Serum bone gla protein (BGP) and other markers of bone mineral metabolism in postmenopausal osteoporosis [published erratum appears in Calcif Tissue Int 1987 Feb;40(2):117] Calcif Tissue Int 1986 39(4):230 3 3098385
Ito M, Yamada M, Hayashi K, et al Relation of early menarche to high bone mineral density Calcif Tissue Int 1995 57(1):11 4 7671158
Ito M, Hayashi K, Ishida Y, et al Discrimination of spinal fracture with various bone mineral measurements Calcif Tissue Int 1997 60(1):11 5 9030473
Ito M, Lang TF, Jergas M, et al Spinal trabecular bone loss and fracture in American and Japanese women Calcif Tissue Int 1997 61(2):123 8 9236258
Ito M, Ohki M, Hayashi K, et al Relationship of spinal fracture to bone density, textural, and anthropometric parameters Calcif Tissue Int 1997 60(3):240 4 9069159
Jacobsen SJ, Cooper C, Gottlieb MS, et al Hospitalization with vertebral fracture among the aged: a national population-based study,1986-1989 Epidemiology 1992 3(6):515 8 1420517
Jacobsen SJ, Goldberg J, Cooper C, et al The association between water fluoridation and hip fracture among white women and men aged 65 years and older. A national ecologic study Ann Epidemiol 1992 2(5):617 26 1342313
Jacobsen SJ, O'Fallon WM, Melton LJ 3rd Hip fracture incidence before and after the fluoridation of the public water supply, Rochester, Minnesota Am J Public Health 1993 83(5):743 5 8484462 1694705
Jacqmin-Gadda H, Commenges D, Dartigues JF Fluorine concentration in drinking water and fractures in the elderly JAMA 1995 273(10):775 6
Jacqmin-Gadda H, Fourrier A, Commenges D, et al Risk factors for fractures in the elderly Epidemiology 1998 9(4):417 23 9647906
Jaglal SB, Kreiger N, Darlington G Past and recent physical activity and risk of hip fracture Am J Epidemiol 1993 138(2):107 18 8342529
Jaglal SB, Kreiger N, Darlington GA Lifetime occupational physical activity and risk of hip fracture in women Ann Epidemiol 1995 5(4):321 4 8520716
Jamal SA, Browner WS, Bauer DC, et al Intermittent use of nitrates increases bone mineral density: the study of osteoporotic fractures J Bone Miner Res 1998 13(11):1755 9 9797485
Jamal SA, Stone K, Browner WS, et al Serum fructosamine level and the risk of hip fracture in elderly women: a case-cohort study within the study of osteoporotic fractures Am J Med 1998 105(6):488 93 9870834
Jamal SA, Browner WS, Bauer DC, et al Warfarin use and risk for osteoporosis in elderly women. Study of Osteoporotic Fractures Research Group Ann Intern Med 1998 128(10):829 32 9599195
Jarnlo GB, Thorngren KG Background factors to hip fractures Clin Orthop 1993(287):41 9
Jarup L, Alfven T, Persson B, et al Cadmium may be a risk factor for osteoporosis Occup Environ Med 1998 55(7):435 9 9816375
Jee WS, Ma YF, Chow SY Maintenance therapy for added bone mass or how to keep the profit after withdrawal of therapy of osteopenia Bone 1995 17(4 Suppl):309S 19S 8579933
Jensen GF, Christiansen C, Boesen J, et al Relationship between bone mineral content and frequency of postmenopausal fractures Acta Med Scand 1983 213(1):61 3 6829322
Jensen GF Osteoporosis of the slender smoker revisited by epidemiologic approach Eur J Clin Invest 1986 16(3):239 42 3089821
Jensen J, Nielsen LH, Lyhne N, et al Drugs and femoral neck fracture: a case-control study J Intern Med 1991 229(1):29 33 1995760
Jergas M, Breitenseher M, Gluer CC, et al Estimates of volumetric bone density from projectional measurements improve the discriminatory capability of dual X-ray absorptiometry J Bone Miner Res 1995 10(7):1101 10 7484286
Jergas M, Breitenseher M, Gluer CC, et al Which vertebrae should be assessed using lateral dual-energy X-ray absorptiometry of the lumbar spine Osteoporos Int 1995 5(3):196 204 7655181
Jergas M, Genant HK Spinal and femoral DXA for the assessment of spinal osteoporosis Calcif Tissue Int 1997 61(5):351 7 9351874
Jergas M, Gluer CC Assessment of fracture risk by bone density measurements Semin Nucl Med 1997 27(3):261 75 9224666
Jergas M, Genant HK Lateral dual X-ray absorptiometry of the lumbar spine: current status Bone 1997 20(4):311 4 9108350
Jie KG, Bots ML, Vermeer C, et al Vitamin K status and bone mass in women with and without aortic atherosclerosis: a population-based study Calcif Tissue Int 1996 59(5):352 6 8849401
Joakimsen RM, Fonnebo V, Magnus JH, et al The Tromso Study: body height, body mass index and fractures Osteoporos Int 1998 8(5):436 42 9850351
Jodar E, Munoz-Torres M, Escobar-Jimenez F, et al Bone loss in hyperthyroid patients and in former hyperthyroid patients controlled on medical therapy: influence of aetiology and menopause Clin Endocrinol 1997 47(3):279 85
Jodar Gimeno E, Munoz-Torres M, Escobar-Jimenez F, et al. Identification of metabolic bone disease in patients with endogenous hyperthyroidism: role of biological markers in bone turnover. Calcif Tissue Int. 1997;61:370-6. [pmid: 9351877].
Joel ME, Le Gales C Social and economic aspects of osteoporosis Curr Opin Rheumatol 1998 10(4):362 7 9725100
Johannesson M, Jonsson B Economic evaluation of osteoporosis prevention Health Pol 1993 24(2):103 24
Johansen J, Riis B, Delmas P, et al. Plasma BGP: an indicator of spontaneous bone loss and of the effect of oestrogen treatment in postmenopausal women. Eur J Clin Invest. 1988;18:191-5. [pmid: 2968266].
Johansen A, Stone MD The effect of ankle oedema on bone ultrasound assessment at the heel Osteoporos Int 1997 7(1):44 7 9102062
Johansson C, Mellstrom D, Milsom I, et al Prevalence of fractures among 10,000 women from the 1900 to 1940 birth cohorts resident in Gothenburg Maturitas 1991 14(1):65 74 1791774
Johansson C, Mellstrom D, Lerner U, et al Coffee drinking: a minor risk factor for bone loss and fractures Age Ageing 1992 21(1):20 6 1553855
Johansson C, Mellstrom D, Milsom I Reproductive factors as predictors of bone density and fractures in women at the age of 70 Maturitas 1993 17(1):39 50 8412842
Johansson C, Mellstrom D, Rosengren K, et al A community-based population study of vertebral fractures in 85-year-old men and women Age Ageing 1994 23(5):388 92 7825484
Johansson C, Hellstrom L, Ekelund P, et al Urinary incontinence: a minor risk factor for hip fractures in elderly women Maturitas 1996 25(1):21 8 8887305
Johansson C, Skoog I A population-based study on the association between dementia and hip fractures in 85-year olds Aging (Milano) 1996 8(3):189 96 305699 8862194
Johansson C, Molander U, Milsom I, et al Association between urinary incontinence and urinary tract infections, and fractures in postmenopausal women Maturitas 1996 23(3):265 71 8794419
Johnell O, Sernbo I. Health and social status in patients with hip fractures and controls. Age Ageing. 1986;15:285-91. [pmid: 3776751].
Johnell O, Gullberg B, Kanis JA, et al Risk factors for hip fracture in European women: the MEDOS Study. Mediterranean Osteoporosis Study J Bone Miner Res 1995 10(11):1802 15 8592959
Johnell O, O'Neill T, Felsenberg D, et al Anthropometric measurements and vertebral deformities. European Vertebral Osteoporosis Study (EVOS) Group Am J Epidemiol 1997 146(4):287 93 9270407
Johnson RE, Specht EE The risk of hip fracture in postmenopausal females with or without estrogen drug exposure Am J Public Health 1981 71(2):138 44 7457682 1619634
Johnson NE Critique of studies of the relationship between diet and osteoporosis Vital Health Stat 4 1992 Mar(27):51 7
Johnston CC, Slemenda CW, Melton LJ Clinical use of bone densitometry N Engl J Med 1991 324(16):1105 9 2008183
Johnston CC Jr., Slemenda CW Determinants of peak bone mass Osteoporos Int 1993 3Suppl 1:54 5 8461578
Johnston C, Slemenda C Identification of patients with low bone mass by single photon absorptiometry and single-energy X-ray absorptiometry Am J Med 1995 98(suppl 2A):375 405
Joly J, Westhovens R, Borghs H, et al Reference curve and diagnostic sensitivity for a new ultrasound device for the phalanges [correction of phalanages], the DBMsonic 1200, in Belgian women Osteoporos Int 1999 9(4):284 9 10550444
Jones G, Nguyen T, Sambrook P, et al Progressive loss of bone in the femoral neck in elderly people: longitudinal findings from the Dubbo osteoporosis epidemiology study BMJ 1994 309(6956):691 5 7950520
Jones G, Nguyen T, Sambrook PN, et al Thiazide diuretics and fractures: can meta-analysis help? J Bone Miner Res 1995 10(1):106 11 7747616
Jones G, Nguyen T, Sambrook PN, et al. A longitudinal study of the effect of spinal degenerative disease on bone density in the elderly. J Rheumatol. 1995;22:932-6. [pmid: 8587085].
Jones G, Riley M, Couper D, et al Water fluoridation, bone mass and fracture: a quantitative overview of the literature Aust N Z J Public Health 1999 23(1):34 40 10083687
Jonsson B, Gardsell P, Johnell O, et al Remembering fractures: fracture registration and proband recall in southern Sweden J Epidemiol Community Health 1994 48(5):489 90 7964361
Jonsson B, Christiansen C, Johnell O, et al Cost-effectiveness of fracture prevention in established osteoporosis Osteoporos Int 1995 5(2):136 42 7599450
Jonsson B, Christiansen C, Johnell O, et al. Cost-effectiveness of fracture prevention in established osteoporosis. Scand J Rheumatol Suppl. 1996;103:30-8; discussion 39-40. [pmid: 8966488].
Jonsson B Targeting high-risk populations Osteoporos Int 1998 8Suppl 1:S13 6 9682791
Jouanny P, Guillemin F, Kuntz C, et al Environmental and genetic factors affecting bone mass. Similarity of bone density among members of healthy families Arthritis Rheum 1995 38(1):61 7 7818574
Juby A. Managing elderly people's osteoporosis. Why? Who? How?. Can Fam Physician. 1999;45:1526-36. [pmid: 10386218].
Kalender W, Fischer M Quality control and standardisation of absorptiometric and computer tomographic measurements of bone mineral mass and density Radiat Protect Dosimet 1993 49(1/3):229 33
Kalender WA, Felsenberg D, Genant HK, et al The European Spine Phantom -- a tool for standardization and quality control in spinal bone mineral measurements by DXA and QCT Eur J Radiol 1995 20(2):83 92 7588873
Kanis JA, McCloskey EV Epidemiology of vertebral osteoporosis Bone 1992 13Suppl 2:S1 10 1385718
Kanis JA, Melton LJ, Christiansen C, et al The diagnosis of osteoporosis J Bone Miner Res 1994 9(8):1137 41 7976495
Kanis JA Assessment of fracture risk and its application to screening for postmenopausal osteoporosis: synopsis of a WHO report Osteoporos Int 1994 4(6):368 81 7696835
Kanis JA, McCloskey EV Evaluation of the risk of hip fracture Bone 1996 18(3 Suppl):127S 32S 8777077
Kanis JA, Delmas P, Burckhardt P, et al Guidelines for diagnosis and management of osteoporosis. The European Foundation for Osteoporosis and Bone Disease Osteoporos Int 1997 7(4):390 406 9373575
Kanis JA, McCloskey EV, de Takats D, et al Clinical assessment of bone mass, quality and architecture Osteoporos Int 1999 9Suppl 2:524 8
Kanis JA, Torgerson D, Cooper C Comparison of the European and USA practice guidelines for osteoporosis Trends Endocrinol Metab 2000 11(1):28 32 10652503
Kanis JA, Johnell O, Oden A, et al Prediction of fracture from low bone mineral density measurements overestimates risk Bone 2000 26(4):387 91 10719283
Kanis JA, Gluer CC. An update on the diagnosis and assessment of osteoporosis with densitometry. Osteoporos Int. 2000;11:192-202. [pmid: 10824234].
Kannus P, Parkkari J, Sievanen H, et al Epidemiology of hip fractures Bone 1996 18(1 Suppl):57S 63S 8717549
Karagas M, Baron J, Barrett J, et al Patterns of fracture among the United States elderly: geographic and fluoride effects Ann Epidemiol 1996 6(3):209 16 8827156
Karlsson MK, Hasserius R, Obrant KJ Individuals who sustain nonosteoporotic fractures continue to also sustain fragility fractures Calcif Tissue Int 1993 53(4):229 31 8275349
Karlsson KM, Sernbo I, Obrant KJ, et al Femoral neck geometry and radiographic signs of osteoporosis as predictors of hip fracture Bone 1996 18(4):327 30 8726389
Karpf D, Shapiro D, Seeman E, et al Prevention of nonvertebral fractures by alendronate JAMA 1997 277(14):1159 64 9087473
Kassem M, Brixen K, Blum WF, et al Normal osteoclastic and osteoblastic responses to exogenous growth hormone in patients with postmenopausal spinal osteoporosis J Bone Miner Res 1994 9(9):1365 70 7817819
Kawana K, Kushida K, Takahashi M, et al The effect of menopause on biochemical markers and ultrasound densitometry in healthy females Calcif Tissue Int 1994 55(6):420 5 7895180
Kazanjian A, Green CJ, Bassett K, et al Bone mineral density testing in social context Int J Technol Assess Health Care 1999 15(4):679 85 10645109
Keen RW, Nguyen T, Sobnack R, et al Can biochemical markers predict bone loss at the hip and spine?: a 4-year prospective study of 141 early postmenopausal women Osteoporos Int 1996 6(5):399 406 8931035
Keen RW, Woodford-Richens KL, Grant SF, et al Association of polymorphism at the type I collagen (COL1A1) locus with reduced bone mineral density, increased fracture risk, and increased collagen turnover Arthritis Rheum 1999 42(2):285 90 10025922
Keen RW, Hart DJ, Arden NK, et al. Family history of appendicular fracture and risk of osteoporosis: a population-based study. Osteoporos Int. 1999;10:161-6. [pmid: 10501797].
Kelepouris N, Harper KD, Gannon F, et al Severe osteoporosis in men Ann Intern Med 1995 123(6):452 60 7639446
Kelly TL, Crane G, Baran DT. Single x-ray absorptiometry of the forearm: precision, correlation, and reference data. Calcif Tissue Int. 1994;54:212-8. [pmid: 8055369].
Kelly TL SD, Schoenfeld DA, Neer RM Quantitative digital radiography versus dual photon absorptiometry of the lumbar spine J Clin Endocrinol Metab 1988 67(4):839 44 3417851
Kelsey JL Risk factors for osteoporosis and associated fractures Public Health Reports Supplement 1987 104(Suppl):14 20
Kelsey JL, Hoffman S Risk factors for hip fracture N Engl J Med 1987 316(7):404 6 3807977
Kelsey JL, Browner WS, Seeley DG, et al Risk factors for fractures of the distal forearm and proximal humerus. The Study of Osteoporotic Fractures Research Group [published erratum appears in Am J Epidemiol 1992 May 15;135(10):1183] Am J Epidemiol 1992 135(5):477 89 1570814
Khai L, Rencken M, Drinkwater B, et al. Site of bone density measurement may affect therapy decision. Calcif Tissue Int. 1993;53:225-8. [pmid: 8275348].
Khan KM, Green RM, Saul A, et al Retired elite female ballet dancers and nonathletic controls have similar bone mineral density at weightbearing sites J Bone Miner Res 1996 11(10):1566 74 8889858
Khan KM, Henzell SL, Broderick C, et al. Instrument performance in bone density testing at five Australian centres. Aust NZ J Med. 1997;27:526-30.
Khan KM, Bennell KL, Hopper JL, et al Self-reported ballet classes undertaken at age 10-12 years and hip bone mineral density in later life Osteoporos Int 1998 8(2):165 73 9666941
Khosla S, Peterson JM, Egan K, et al Circulating cytokine levels in osteoporotic and normal women J Clin Endocrinol Metab 1994 79(3):707 11 8077350
Khosla S, Atkinson EJ, Riggs BL, et al Relationship between body composition and bone mass in women J Bone Miner Res 1996 11(6):857 63 8725184
Kiel DP, Felson DT, Anderson JJ, et al Hip fracture and the use of estrogens in postmenopausal women.The Framingham Study N Engl J Med 1987 317(19):1169 74 3657888
Kiel DP, Felson DT, Hannan MT, et al Caffeine and the risk of hip fracture: the Framingham Study Am J Epidemiol 1990 132(4):675 84 2403108
Kiel DP, Baron JA, Anderson JJ, et al Smoking eliminates the protective effect of oral estrogens on the risk for hip fracture among women Ann Intern Med 1992 116(9):716 21 1558342
Kiel DP, Zhang Y, Hannan MT, et al The effect of smoking at different life stages on bone mineral density in elderly men and women Osteoporos Int 1996 6(3):240 8 8783299
Kim JG, Lee JY Serum insulin-like growth factor binding protein profiles in postmenopausal women: their correlation with bone mineral density Am J Obstet Gynecol 1996 174(5):1511 7 9065121
Kim SH, Morton DJ, Barrett-Connor EL Carbonated beverage consumption and bone mineral density among older women: the Rancho Bernardo Study Am J Public Health 1997 87(2):276 9 9103110 1380807
Kin K, Lee JHE, Kushida K, et al Bone density and body composition on the Pacific Rim: a comparison between Japan-born and U.S.-born Japanese-American women J Bone Miner Res 1993 8(7):861 9 8352068
Kleerekoper M, Peterson E, Nelson D, et al Identification of women at risk for developing postmenopausal osteoporosis with vertebral fractures: role of history and single photon absorptiometry Bone Miner 1989 7(2):171 86 2804452
Kleerekoper M, Brienza RS, Schultz LR, et al Oral contraceptive use may protect against low bone mass. Henry Ford Hospital Osteoporosis Cooperative Research Group Arch Intern Med 1991 151(10):1971 6 1929685
Kleerekoper M, Nelson D, Peterson E, et al. Outcome variables in osteoporosis trials. Bone. 1992;13:S29-S34. [pmid: 1581116].
Kleerekoper M, Nelson DA, Peterson EL, et al Reference data for bone mass, calciotropic hormones, and biochemical markers of bone remodeling in older (55-75) postmenopausal white and black women J Bone Miner Res 1994 9(8):1267 76 7976509
Klein BE, Klein R, Lee KE, et al Performance-based and self-assessed measures of visual function as related to history of falls, hip fractures, and measured gait time. The Beaver Dam Eye Study Ophthalmology 1998 105(1):160 4 9442793
Knapen MH, Nieuwenhuijzen Kruseman AC, Wouters RS, et al Correlation of serum osteocalcin fractions with bone mineral density in women during the first 10 years after menopause Calcif Tissue Int 1998 63(5):375 9 9799820
Kohrt WM, Snead DB, Slatopolsky E, et al Additive effects of weight-bearing exercise and estrogen on bone mineral density in older women J Bone Miner Res 1995 10(9):1303 11 7502701
Kollerup G, Hermann AP, Brixen K, et al Effects of salmon calcitonin suppositories on bone mass and turnover in established osteoporosis Calcif Tissue Int 1994 54(1):12 5 8118746
Komar L, Nieves J, Cosman F, et al Calcium homeostasis of an elderly population upon admission to a nursing home J Am Geriatr Soc 1993 41(10):1057 64 8409150
Kotowicz MA, Melton LJ 3rd, Cooper C, et al Risk of hip fracture in women with vertebral fracture J Bone Miner Res 1994 9(5):599 605 8053387
Kotzki PO, Buyck D, Hans D, et al Influence of fat on ultrasound measurements of the os calcis Calcif Tissue Int 1994 54(2):91 5 8012877
Kraenzlin ME, Seibel MJ, Trechsel U, et al The effect of intranasal salmon calcitonin on postmenopausal bone turnover as assessed by biochemical markers: evidence of maximal effect after 8 weeks of continuous treatment Calcif Tissue Int 1996 58(4):216 20 8661950
Krall EA, Dawson-Hughes B Smoking and bone loss among postmenopausal women J Bone Miner Res 1991 6(4):331 8 1858519
Krall EA, Dawson-Hughes B Heritable and life-style determinants of bone mineral density J Bone Miner Res 1993 8(1):1 9 8427042
Krall EA, Dawson-Hughes B. Walking is related to bone density and rates of bone loss. Am J Med. 1994;96:20-6. [pmid: 8304358].
Krall EA, Garcia RI, Dawson-Hughes B Increased risk of tooth loss is related to bone loss at the whole body, hip, and spine Calcif Tissue Int 1996 59(6):433 7 8939767
Krall EA, Dawson-Hughes B Smoking increases bone loss and decreases intestinal calcium absorption J Bone Miner Res 1999 14(2):215 20 9933475
Krane SM, Holick MF. Metabolic bone disease. In: Fauci E, Braunwald O., Isselbacher KJ, et al., editors. Harrison's principles of internal medicine. 14th ed. New York: McGraw-Hill Companies, Inc.; 1998.
Kreiger N, Kelsey JL, Holford TR, et al An epidemiologic study of hip fracture in postmenopausal women Am J Epidemiol 1982 116(1):141 8 7102649
Kreiger N, Gross A, Hunter G Dietary factors and fracture in postmenopausal women: a case-control study Int J Epidemiol 1992 21(5):953 8 1468859
Kress BC, Mizrahi IA, Armour KW, et al Use of bone alkaline phosphatase to monitor alendronate therapy in individual postmenopausal osteoporotic women Clin Chem 1999 45(7):1009 17 10388477
Kress BC, Mizrahi IA Monitoring antiosteoporotic treatment of postmenopausal women using biochemical markers of bone turnover Drugs Today 1999 35(3):181 5 12973383
Krieg MA, Thiebaud D, Burckhardt P Quantitative ultrasound of bone in institutionalized elderly women: a cross-sectional and longitudinal study Osteoporos Int 1996 6(3):189 95 8783292
Kriska AM, Sandler RB, Cauley JA, et al The assessment of historical physical activity and its relation to adult bone parameters Am J Epidemiol 1988 127(5):1053 63 3358406
Kritz-Silverstein D, Barrett-Connor E. Early menopause, number of reproductive years, and bone mineral density in postmenopausal women. Am J Public Health. 1993;83:983-8. [pmid: 8328621]. [pmcid: 1694784].
Kritz-Silverstein D, Barrett-Connor E Grip strength and bone mineral density in older women J Bone Miner Res 1994 9(1):45 51 8154308
Kritz-Silverstein D, Barrett-Connor E Oophorectomy status and bone density in older, hysterectomized women Am J Prev Med 1996 12(5):424 9 8909657
Kroger H, Tuppurainen M, Honkanen R, et al Bone mineral density and risk factors for osteoporosis -- a population-based study of 1600 perimenopausal women Calcif Tissue Int 1994 55(1):1 7 7922782
Kroger H, Huopio J, Honkanen R, et al Prediction of fracture risk using axial bone mineral density in a perimenopausal population: a prospective study J Bone Miner Res 1995 10(2):302 6 7754811
Kroger H, Lunt M, Reeve J, et al Bone density reduction in various measurement sites in men and women with osteoporotic fractures of spine and hip: the European quantitation of osteoporosis study Calcif Tissue Int 1999 64(3):191 9 10024374
Kruger MC, Coetzer H, de Winter R, et al Calcium, gamma-linolenic acid and eicosapentaenoic acid supplementation in senile osteoporosis Aging (Milano) 1998 10(5):385 94 305699 9932142
Kung AW, Tang GW, Luk KD, et al Evaluation of a new calcaneal quantitative ultrasound system and determination of normative ultrasound values in southern Chinese women Osteoporos Int 1999 9(4):312 7 10550448
Kurttio P, Gustavsson N, Vartiainen T, et al Exposure to natural fluoride in well water and hip fracture: a cohort analysis in Finland Am J Epidemiol 1999 150(8):817 24 10522652
Kyd PA, Vooght KD, Kerkhoff F, et al Clinical usefulness of bone alkaline phosphatase in osteoporosis Ann Clin Biochem 1998 35(Pt 6):717 25 9838984
Kyd PA, De Vooght K, Kerkhoff F, et al Clinical usefulness of biochemical resorption markers in osteoporosis Ann Clin Biochem 1999 36(Pt 4):483 91 10456211
La Croix AZ, Wienpahl J, White LR, et al Thiazide diuretic agents and the incidence of hip fracture N Engl J Med 1990 322(5):286 90 2296269
La Vecchia C, Negri E, Levi F, et al Cigarette smoking, body mass and other risk factors for fractures of the hip in women Int J Epidemiol 1991 20(3):671 7 1955251
Laatikainen AK, Kroger HP, Tukiainen HO, et al Bone mineral density in perimenopausal women with asthma: a population-based cross-sectional study Am J Respir Crit Care Med 1999 159(4 Pt 1):1179 85 10194163
Lacey JM, Anderson JJ, Fujita T, et al Correlates of cortical bone mass among premenopausal and postmenopausal Japanese women J Bone Miner Res 1991 6(7):651 9 1950670
Lafferty FW, Rowland DY Correlations of dual-energy X-ray absorptiometry, quantitative computed tomography, and single photon absorptiometry with spinal and non-spinal fractures Osteoporos Int 1996 6(5):407 15 8931036
Lafita FR, Garcia B Effect of low-dose continuous estrogen and progesterone therapy with calcium and vitamin D on bone in elderly women Ann Intern Med 2000 132(3):
Lai KC, Goodsitt MM, Murano R, et al A comparison of two dual-energy X-ray absorptiometry systems for spinal bone mineral measurement Calcif Tissue Int 1992 50(3):203 8 1617493
Lai K, Rencken M, Drinkwater B, et al. Site of bone density measurement may affect therapy decision. Calcif Tissue Int. 1993;53:225-8. [pmid: 8275348].
Laitinen K, Valimaki M Alcohol and bone Calcif Tissue Int 1991 49(Suppl):S70 3 1933604
Lang P, Steiger P, Faulkner K, et al Osteoporosis: current techniques and recent developments in quantitative bone densitometry Radiol Clin North Am 1991 29(1):49 76 1985329
Lang T, Takada M, Gee R, et al A preliminary evaluation of the Lunar Expert-XL for bone densitometry and vertebral morphometry J Bone Miner Res 1997 12(1):136 43 9240736
Lang TF, Augat P, Lane NE, et al Trochanteric hip fracture: strong association with spinal trabecular bone mineral density measured with quantitative CT Radiology 1998 209(2):525 30 9807584
Lang TF, Li J, Harris ST, et al Assessment of vertebral bone mineral density using volumetric quantitative CT J Comput Assist Tomogr 1999 23(1):130 7 10050823
Langdahl BL, Ralston SH, Grant SF, et al An Sp1 binding site polymorphism in the COLIA1 gene predicts osteoporotic fractures in both men and women J Bone Miner Res 1998 13(9):1384 9 9738510
Langlois JA, Harris T, Looker AC, et al Weight change between age 50 years and old age is associated with risk of hip fracture in white women aged 67 years and older Arch Intern Med 1996 156(9):989 94 8624179
Langton CM, Palmer SB, Porter RW The measurement of broadband ultrasonic attenuation in cancellous bone Eng Med 1984 13(2):89 91 6540216
Langton CM, Ballard PA, Langton DK, et al. Maximising the cost effectiveness of BMD referral for DXA using ultrasound as a selective population pre-screen. Technol Health Care. 1997;5:235-41. [pmid: 9263372].
Langton CM, Ballard PA, Bennett DK, et al A comparison of the sensitivity and specificity of calcaneal ultrasound measurements with clinical criteria for bone densitometry (DEXA) referral Clin Rheumatol 1997 16(1):117 8 9132320
Langton CM, Langton DK, Beardsworth SA Comparison of accuracy and cost effectiveness of clinical criteria and BUA for referral for BMD assessment by DXA in osteoporotic and osteopenic perimenopausal subjects Technol Health Care 1999 7(5):319 30 10543417
Lantz H, Samuelson G, Bratteby LE, et al. Differences in whole body measurements by DXA-scanning using two Lunar DPX-L machines. Int J Obes. 1999;23:764-70.
Larcos G Predicting clinical discordance of bone mineral density Mayo Clin Proc 1998 73(9):824 8 9737217
Laskey M, Crisp A, Cole T, et al Comparison of the effect of different reference data on Lunar DPX and Hologic QDR-1000 dual-energy X-ray absorptiometers Br J Radiol 1992 65(780):1124 9 1286422
Lau E, Donnan S, Barker DJP, et al. Physical activity and calcium intake in fracture of the proximal femur in Hong Kong. BMJ. 1988;297:1441-3. [pmid: 3147007]. [pmcid: 1835159].
Lau E, Donnan S. Falls and hip fracture in Hong Kong Chinese. Public Health. 1990;104:117-21. [pmid: 2359827].
Lau EM, Cooper C Epidemiology and prevention of osteoporosis in urbanized Asian populations Osteoporos Int 1993 3Suppl 1:23 6 8461569
Lau EM, Woo J, Leung PC, et al Low bone mineral density, grip strength and skinfold thickness are important risk factors for hip fracture in Hong Kong Chinese Osteoporos Int 1993 3(2):66 70 8453192
Lauderdale DS, Jacobsen SJ, Furner SE, et al Hip fracture incidence among elderly Hispanics Am J Public Health 1998 88(8):1245 7 9702161 1508310
Laugier P, Giat P, Berger G Broadband ultrasonic attenuation imaging: a new imaging technique of the os calcis Calcif Tissue Int 1994 54(2):83 6 8012875
Lauritzen JB, Lund B Risk of hip fracture after osteoporosis fractures. 451 women with fracture of lumbar spine, olecranon, knee or ankle Acta Orthop Scand 1993 64(3):297 300 8322584
Lauritzen JB, Schwarz P, McNair P, et al Radial and humeral fractures as predictors of subsequent hip, radial or humeral fractures in women, and their seasonal variation Osteoporos Int 1993 3(3):133 7 8481589
Lauritzen JB Hip fractures: incidence, risk factors, energy absorption, and prevention Bone 1996 18(1 Suppl):65S 75S 8717550
Laval-Jeantet AM, Bergot C, Williams M, et al Dual-energy X-ray absorptiometry of the calcaneus: comparison with vertebral dual-energy X-ray absorptiometry and quantitative computed tomography Calcif Tissue Int 1995 56(1):14 8 7796340
Law M, Wald N, Meade T. Strategies for prevention of osteoporosis and hip fracture. BMJ. 1991;303:453-9. [pmid: 1912840]. [pmcid: 1670562].
Law MR, Hackshaw AK A meta-analysis of cigarette smoking, bone mineral density and risk of hip fracture: recognition of a major effect BMJ 1997 315(7112):841 6 9353503
Le Blanc AD, Evans HJ, Marsh C Precision of dual photon absorptiometry measurements J Nucl Med 1986 27(8):1362 5 3488380
Lee MM, Whittemore AS, Lung DL Reliability of recalled physical activity, cigarette smoking, and alcohol consumption Ann Epidemiol 1992 2(5):705 14 1342322
Lees B, Stevenson J. Preliminary evaluation of a new ultrasound bone densitometer. Calcif Tissue Int. 1993;53:149-52. [pmid: 8242464].
Leino A, Impivaara O, Jarvisalo J, et al Factors related to risk of osteoporosis in 50-year-old women Calcif Tissue Int 1991 49Suppl:S76 7 1933606
Leino A, Jarvisalo J, Impivaara O, et al Ovarian hormone status, life-style factors, and markers of bone metabolism in women aged 50 years Calcif Tissue Int 1994 54(4):262 7 8062141
Lemcke DP. Section IV: Metabolic & endocrine disorders, osteoporosis. In: Lemcke DP, Pattison J, Marshall LA, et al., editors. Primary care of women. Norwalk, CT: Appleton & Lange; 1995.
Lenert L, Treadwell J, Schwartz C Associations between health status and utilities implications for policy Med Care 1999 37(5):479 89 10335750
Leveille SG, LaCroix AZ, Koepsell TD, et al Dietary vitamin C and bone mineral density in postmenopausal women in Washington State, USA J Epidemiol Community Health 1997 51(5):479 85 9425455
Levis S, Altman R Bone densitometry. Clinical considerations Arthritis Rheum 1998 41(4):577 87 9550466
Levy AR, Bensimon DR, Mayo NE, et al Inclement weather and the risk of hip fracture Epidemiology 1998 9(2):172 7 9504286
Lewis LL, Shaver JF, Woods NF, et al Bone resorption levels by age and menopausal status in 5,157 women Menopause 2000 7(1):42 52 10646703
Liberman UA, Weiss SR, Broll J, et al Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis N Engl J Med 1995 333(22):1437 43 7477143
Lijmer JG, Mol BW, Heisterkamp S, et al Empirical evidence of design-related bias in studies of diagnosis JAMA 1999 282(11):1061 6 10493205
Lindquist O. Influence of the menopause on ischaemic heart disease and its risk factors and on bone mineral content. Acta Obstet Gynecol Scand Suppl. 1982;110:1-32. [pmid: 6957134].
Lindsay R Bone mass measurement for premenopausal women Osteoporos Int 1994 4Suppl 1:39 41 8081057
Lindsay R The burden of osteoporosis: cost Am J Med 1995 98(2A):9S 11S 7709941
Lindsay R Risk assessment using bone mineral density determination Osteoporos Int 1998 8Suppl 1:S28 31 9682794
Lindsay R, Cosman F, Lobo RA, et al Addition of alendronate to ongoing hormone replacement therapy in the treatment of osteoporosis: a randomized, controlled clinical trial J Clin Endocrinol Metab 1999 84(9):3076 81 10487668
Link TM, Majumdar S, Augat P, et al Proximal femur: assessment for osteoporosis with T2* decay characteristics at MR imaging Radiology 1998 209(2):531 6 9807585
Link TM, Majumdar S, Augat P, et al In vivo high resolution MRI of the calcaneus: differences in trabecular structure in osteoporosis patients J Bone Miner Res 1998 13(7):1175 82 9661082
Lips P, Taconis WK, van Ginkel FC, et al Radiologic morphometry in patients with femoral neck fractures and elderly control subjects. Comparison with histomorphometric parameters Clin Orthop 1984(183):64 70
Lips P Epidemiology and predictors of fractures associated with osteoporosis Am J Med 1997 103(2A):3S 8S; discussion 8S-11S 9302892
Lissner L, Bengtsson C, Hansson T Bone mineral content in relation to lactation history in pre- and postmenopausal women Calcif Tissue Int 1991 48(5):319 25 2054717
Liu B, Anderson G, Mittmann N, et al Use of selective serotonin-reuptake inhibitors of tricyclic antidepressants and risk of hip fractures in elderly people Lancet 1998 351(9112):1303 7 9643791
Ljunghall S, Gardsell P, Johnell O, et al Synthetic human calcitonin in postmenopausal osteoporosis: a placebo-controlled, double-blind study Calcif Tissue Int 1991 49(1):17 9 1893291
Lloyd T, Rollings N, Eggli DF, et al Dietary caffeine intake and bone status of postmenopausal women Am J Clin Nutr 1997 65(6):1826 30 9174479
Lo Cascio V, Bertoldo F, Gambaro G, et al Urinary galactosyl-hydroxylysine in postmenopausal osteoporotic women: a potential marker of bone fragility J Bone Miner Res 1999 14(8):1420 4 10457275
Lochmuller EM, Eckstein F, Kaiser D, et al Prediction of vertebral failure loads from spinal and femoral dual-energy X-ray absorptiometry, and calcaneal ultrasound: an in situ analysis with intact soft tissues Bone 1998 23(5):417 24 9823447
Lochmuller EM, Zeller JB, Kaiser D, et al Correlation of femoral and lumbar DXA and calcaneal ultrasound, measured in situ with intact soft tissues, with the in vitro failure loads of the proximal femur Osteoporos Int 1998 8(6):591 8 10326066
Looker AC, Harris TB, Madans JH, et al Dietary calcium and hip fracture risk: the NHANES I Epidemiologic Follow-Up Study Osteoporos Int 1993 3(4):177 84 8338972
Looker AC, Orwoll ES, Johnston CC Jr., et al Prevalence of low femoral bone density in older US adults from NHANES III J Bone Miner Res 1997 12(11):1761 8 9383679
Looker AC, Wahner LW, Dunn WL, et al Updated data on proximal femur bone mineral levels of US adults Osteoporos Int 1998 8(5):468 89 9850356
Looney JE, Yoon HK, Fischer M, et al Lack of a high prevalence of the BB vitamin D receptor genotype in severely osteoporotic women J Clin Endocrinol Metab 1995 80(7):2158 62 7608271
Lord SR, Ward JA, Williams P, et al The effects of a community exercise program on fracture risk factors in older women Osteoporos Int 1996 6(5):361 7 8931030
Lotz J, Steeger D, Hafner G, et al Biochemical bone markers compared with bone density measurement by dual energy X-ray absorptiometry Calcif Tissue Int 1995 57(4):253 7 8673861
Luckey MM, Wallenstein S, Lapinski R, et al A prospective study of bone loss in African-American and white women -- a clinical research center study J Clin Endocrinol Metab 1996 81(8):2948 56 8768857
Lufkin EG, Wahner HW, O'Fallon WM, et al Treatment of postmenopausal osteoporosis with transdermal estrogen Ann Intern Med 1992 117(1):1 9 1534476
Lufkin EG, Whitaker MD, Nickelsen T, et al Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial J Bone Miner Res 1998 13(11):1747 54 9797484
Lunde AV, Barrett-Connor E, Morton DJ Serum albumin and bone mineral density in healthy older men and women: the Rancho Bernardo Study Osteoporos Int 1998 8(6):547 51 10326059
Lunt M, Felsenberg D, Adams J, et al Population-based geographic variations in DXA bone density in Europe: the EVOS Study. European Vertebral Osteoporosis Osteoporos Int 1997 7(3):175 89 9205628
Lunt M, Felsenberg D, Reeve J, et al Bone density variation and its effects on risk of vertebral deformity in men and women studied in thirteen European centers: the EVOS Study J Bone Miner Res 1997 12(11):1883 94 9383693
Lutz J Bone mineral, serum calcium, and dietary intakes of mother/daughter pairs Am J Clin Nutr 1986 44(1):99 106 3728353
Lutz J, Tesar R Mother-daughter pairs: spinal and femoral bone densities and dietary intakes Am J Clin Nutr 1990 52(5):872 7 2239764
Luukinen H, Koski K, Laippala P, et al Factors predicting fractures during falling impacts among home-dwelling older adults J Am Geriatr Soc 1997 45(11):1302 9 9361654
Lydick E, Cook K, Turpin J, et al Development and validation of a simple questionnaire to facilitate identification of women likely to have low bone density Am J Manag Care 1998 4(1):37 48 10179905
Lyles KW, Gold DW, Shipp KM, et al. Association of osteoporotic vertebral fractures with impaired functional status. Am J Med. 1993;94:595-601. [pmid: 8506884].
Lyritis GP, Magiasis B, Tsakalakos N Prevention of bone loss in early nonsurgical and nonosteoporotic high turnover patients with salmon calcitonin: the role of biochemical bone markers in monitoring high turnover patients under calcitonin treatment Calcif Tissue Int 1995 56(1):38 41 7796344
Madans J, Kleinman JC, Cornoni-Huntley J The relationship between hip fracture and water fluoridation: an analysis of national data Am J Public Health 1983 73(3):296 8 6824115 1650581
Majumdar S, Genant HK, Grampp S, et al Correlation of trabecular bone structure with age, bone mineral density, and osteoporotic status: in vivo studies in the distal radius using high resolution magnetic resonance imaging J Bone Miner Res 1997 12(1):111 8 9240733
Majumdar S A review of magnetic resonance (MR) imaging of trabecular bone micro-architecture: contribution to the prediction of biomechanical properties and fracture prevalence Technol Health Care 1998 6(5-6):321 7 10100935
Mallmin H, Ljunghall S, Larsson K, et al Short-term effects of pamidronate on biochemical markers of bone metabolism in osteoporosis -- a placebo-controlled dose-finding study Ups J Med Sci 1991 96(3):205 12 1810080
Mallmin H, Ljunghall S, Persson I, et al Fracture of the distal forearm as a forecaster of subsequent hip fracture: a population-based cohort study with 24 years of follow-up Calcif Tissue Int 1993 52(4):269 72 8467406
Mallmin H, Ljunghall S, Persson I, et al Risk factors for fractures of the distal forearm: a population-based case-control study Osteoporos Int 1994 4(6):298 304 7696821
Mango D, Ricci S, Manna P, et al Preventive treatment of cortical bone loss with salmon nasal calcitonin in early postmenopausal women Minerva Endocrinol 1993 18(3):115 21 8183178
Marci CD, Viechnicki MB, Greenspan SL, et al. Bone mineral densitometry substantially influences health-related behaviors of postmenopausal women. Calcif Tissue Int. 2000;66:113-8. [pmid: 10652958].
Marcus R Clinical review 76: the nature of osteoporosis J Clin Endocrinol Metab 1996 81(1):1 5 8550734
Marcus R, Holloway L, Wells B, et al The relationship of biochemical markers of bone turnover to bone density changes in postmenopausal women: results from the Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial J Bone Miner Res 1999 14(9):1583 95 10469288
Margulies JY, Payzer A, Nyska M, et al The relationship between degenerative changes and osteoporosis in the lumbar spine Clin Orthop 1996(324):145 52
Mariconda M, Pavia M, Colonna A, et al Appendicular bone density, biochemical markers of bone turnover and lifestyle factors in female teachers of Southern Italy Eur J Epidemiol 1997 13(8):909 17 9476821
Marone MM, Gouveia CH, Lewin S, et al Influence of body composition on the bone mass of postmenopausal women Rev Paul Med 1997 115(6):1580 8
Marshall D, Johnell O, Wedel H. Meta-analysis of how well measures of bone mineral density predict occurrence of osteoporotic fractures. BMJ. 1996;312:1254-9. [pmid: 8634613].
Martin J, Reid D Appendicular measurements in screening women for low axial bone mineral density Br J Radiol 1996 69(819):234 40 8800867
Marystone J, Barrett-Connor E, Morton D. Inhaled and oral corticosteroids: their effects on bone mineral density in older adults. Am J Public Health. 1995;85:1693-5. [pmid: 7503347]. [pmcid: 1615730].
Masahashi T, Negoro Y, Kuroki T, et al Biochemical markers of bone turnover during hormone replacement therapy Int J Gynaecol Obstet 1999 64(2):163 6 10189026
Massie A, Reid DM, Porter RW Screening for osteoporosis: comparison between dual energy X-ray absorptiometry and broadband ultrasound attenuation in 1000 perimenopausal women Osteoporos Int 1993 3(2):107 10 8453190
Masud T, Langley S, Wiltshire P, et al. Effect of spinal osteophytosis on bone mineral density measurements in vertebral osteoporosis. BMJ. 1993;307:172-3. [pmid: 8343746]. [pmcid: 1678366].
Mautalen C, Vega E, Gonzalez D, et al. Ultrasound and dual X-ray absorptiometry in women with hip fracture. Calcif Tissue Int. 1995;57:165-8. [pmid: 8574930].
Maxim P, Ettinger B, Spitalny GM. Fracture protection by long-term estrogen treatment. Osteoporos Int. 1995;5:23-9. [pmid: 7703620].
May H, Reader R, Murphy S, et al Self-reported tooth loss and bone mineral density in older men and women Age Ageing 1995 24(3):217 21 7645442
Mayo NE, Korner-Bitensky N, Levy AR Risk factors for fractures due to falls Arch Phys Med Rehabil 1993 74(9):917 21 8379836
Mazzuoli GF, Gennari C, Passeri M, et al Hip fracture in Italy: epidemiology and preventive efficacy of bone-active drugs Bone 1993 14Suppl 1:S81 4 8110527
McAuley KA, Jones S, Lewis-Barned NJ, et al Low vitamin D status is common among elderly Dunedin women N Z Med J 1997 110(1048):275 7 9269291
McClung MR. Nonpharmacologic management of osteoporosis. In: Marcus R, editor. Osteoporosis. Boston: Blackwell Scientific Publications; 1994. p. 336-53.
McClung M, Clemmesen B, Daifotis A, et al Alendronate prevents postmenopausal bone loss in women without osteoporosis Ann Intern Med 1998 128(4):253 61 9471927
McDermott MT, Witte MC Bone mineral content in smokers South Med J 1988 81(4):477 80 3358172
McKnight A, Steele K, Mills K, et al Bone mineral density in relation to medical and lifestyle risk factors for osteoporosis in premenopausal, menopausal and postmenopausal women in general practice Br J Gen Pract 1995 45(395):317 20 7619589 1239268
McNeil B, Pauker S, Sox H, et al On the elicitation of preferences for alternative therapies N Engl J Med 1982 306(21):1259 62 7070445
Meema HE, Meindok H Advantages of peripheral radiogrametry over dual-photon absorptiometry of the spine in the assessment of prevalence of osteoporotic vertebral fractures in women J Bone Miner Res 1992 7(8):897 903 1442203
Meier CR, Schlienger RG, Kraenzlin ME, et al. HMG-CoA reductase inhibitors and the risk of fractures. JAMA. 2000;283:3205-10. [pmid: 10866867].
Mele R, Masci G, Ventura V, et al Three-year longitudinal study with quantitative ultrasound at the hand phalanx in a female population Osteoporos Int 1997 7(6):550 7 9604051
Melhus H, Michaelsson K, Kindmark A, et al Excessive dietary intake of vitamin A is associated with reduced bone mineral density and increased risk for hip fracture Ann Intern Med 1998 129(10):770 8 9841582
Melhus H, Michaelsson K, Holmberg L, et al Smoking, antioxidant vitamins, and the risk of hip fracture J Bone Miner Res 1999 14(1):129 35 9893075
Melton LJ 3rd, Kan SH, Wahner HW, et al Lifetime fracture risk: an approach to hip fracture risk assessment based on bone mineral density and age J Clin Epidemiol 1988 41(10):985 94 3193143
Melton LJ 3rd, Kan SH, Frye MA, et al Epidemiology of vertebral fractures in women Am J Epidemiol 1989 129(5):1000 11 2784934
Melton LJ 3rd, Eddy DM, Johnston CC Jr Screening for osteoporosis Ann Intern Med 1990 112(7):516 28 2180356
Melton LJ 3rd, Chrischilles EA, Cooper C, et al Perspective. How many women have osteoporosis? J Bone Miner Res 1992 7(9):1005 10 1414493
Melton LJ 3rd, Atkinson EJ, O'Fallon WM, et al Long-term fracture prediction by bone mineral assessed at different skeletal sites J Bone Miner Res 1993 8(10):1227 33 8256660
Melton LJ 3rd, Bryant SC, Wahner HW, et al Influence of breastfeeding and other reproductive factors on bone mass later in life Osteoporos Int 1993 3(2):76 83 8453194
Melton LJ 3rd, Beard CM, Kokmen E, et al. Fracture risk in patients with Alzheimer's disease. J Am Geriatr Soc. 1994;42:614-9. [pmid: 8201146].
Melton LJ 3rd How many women have osteoporosis now? J Bone Miner Res 1995 10(2):175 7 7754796
Melton LJ 3rd Epidemiology of hip fractures: implications of the exponential increase with age Bone 1996 18(3 Suppl):121S 5S 8777076
Melton LJ 3rd, Khosla S, Atkinson EJ, et al Relationship of bone turnover to bone density and fractures J Bone Miner Res 1997 12(7):1083 91 9200008
Melton LJ 3rd Epidemiology of spinal osteoporosis Spine 1997 22(24 Suppl):2S 11S 9431638
Melton LJ, 3rd, Atkinson EJ, O'Connor MK, et al Bone density and fracture risk in men J Bone Miner Res 1998 13(12):1915 23 9844110
Melton LJ 3rd, Amadio PC, Crowson CS, et al. Long-term trends in the incidence of distal forearm fractures. Osteoporos Int. 1998;8:341-8. [pmid: 10024904].
Melton LJ 3rd Cost-effective treatment strategies for osteoporosis Osteoporos Int 1999 9Suppl 2:S111 6 10525733
Melton LJ 3rd, Atkinson EJ, Cooper C, et al. Vertebral fractures predict subsequent fractures. Osteoporos Int. 1999;10:214-21. [pmid: 10525713].
Metz C Basic principles of ROC analysis Semin Nucl Med 1978 8(4):283 97 112681
Meunier PJ, Confavreux E, Tupinon I, et al Prevention of early postmenopausal bone loss with cyclical etidronate therapy (a double-blind, placebo-controlled study and 1-year follow-up) [published erratum appears in J Clin Endocrinol Metab 1997 Nov;82(11):3740] J Clin Endocrinol Metab 1997 82(9):2784 91 9284696
Meunier P Evidence-based medicine and osteoporosis: a comparison of fracture risk reduction data from osteoporosis randomised clinical trials Int J Clin Pract 1999 53(2):122 9 10344048
Meyer HE, Tverdal A, Falch JA Risk factors for hip fracture in middle-aged Norwegian women and men Am J Epidemiol 1993 137(11):1203 11 8322761
Meyer HE, Henriksen C, Falch JA, et al Risk factors for hip fracture in a high incidence area: a case-control study from Oslo, Norway Osteoporos Int 1995 5(4):239 46 7492862
Meyer HE, Tverdal A, Falch JA Body height, body mass index, and fatal hip fractures: 16 years' follow-up of 674,000 Norwegian women and men Epidemiology 1995 6(3):299 305 7619940
Meyer HE, Tverdal A, Falch JA Changes in body weight and incidence of hip fracture among middle aged Norwegians BMJ 1995 311(6997):91 2 7613409
Meyer HE, Pedersen JI, Loken EB, et al Dietary factors and the incidence of hip fracture in middle-aged Norwegians. A prospective study Am J Epidemiol 1997 145(2):117 23 9006308
Meyer HE, Tverdal A, Selmer R Weight variability, weight change and the incidence of hip fracture: a prospective study of 39,000 middle-aged Norwegians Osteoporos Int 1998 8(4):373 8 10024908
Michaelsson K, Holmberg L, Mallmin H, et al Diet and hip fracture risk: a case-control study. Study Group of the Multiple Risk Survey on Swedish Women for Eating Assessment Int J Epidemiol 1995 24(4):771 82 8550275
Michaelsson K, Bergstrom R, Mallmin H, et al Screening for osteopenia and osteoporosis: selection by body composition Osteoporos Int 1996 6(2):120 6 8704349
Michaelsson K, Holmberg L, Ljunghall S, et al Effect of prefracture versus postfracture dietary assessment on hip fracture risk estimates Int J Epidemiol 1996 25(2):403 10 9119567
Michaelsson K, Bergstrom R, Holmberg L, et al A high dietary calcium intake is needed for a positive effect on bone density in Swedish postmenopausal women Osteoporos Int 1997 7(2):155 61 9166397
Michaelsson K, Baron JA, Johnell O, et al. Variation in the efficacy of hormone replacement therapy in the prevention of hip fracture. Osteoporos Int. 1998;8:540-6. [pmid: 10326058].
Michel BA, Bloch DA, Fries JF. Weight-bearing exercise, overexercise, and lumbar bone density over age 50 years. Arch Intern Med. 1989;149:2325-9. [pmid: 2802897].
Michelotti J, Clark J Femoral neck length and hip fracture risk J Bone Miner Res 1999 14(10):1714 20 10491219
Michelson JD, Myers A, Jinnah R, et al Epidemiology of hip fractures among the elderly. Risk factors for fracture type Clin Orthop 1995(311):129 35
Michelson D, Stratakis C, Hill L, et al Bone mineral density in women with depression N Engl J Med 1996 335(16):1176 81 8815939
Miller CG, Herd JM, Ramlingam T, et al. Ultrasonic velocity measurements through the calcaneus: Which velocity should be measured?. Osteoporos Int. 1993;3:31-5. [pmid: 8422514].
Miller PD, Baran DT, Bilezikian JP, et al Practical clinical application of biochemical markers of bone turnover: consensus of an expert panel J Clin Densitomet 1999 2(3):323 42
Miller PD. Management of osteoporosis. Adv Int Med. 1999;44:175-207.
Miller PD, Zapalowski C, Kulak CA, et al. Bone densitometry: the best way to detect osteoporosis and to monitor therapy. J Clin Endocrinol Metab. 1999;84:1867-71. [pmid: 10372677].
Minisola S, Rosso R, Romagnoli E, et al Serum osteocalcin and bone mineral density at various skeletal sites: a study performed with three different assays J Lab Clin Med 1997 129(4):422 9 9104885
Minisola S, Pacitti MT, Ombricolo E, et al Bone turnover and its relationship with bone mineral density in pre- and postmenopausal women with or without fractures Maturitas 1998 29(3):265 70 9699199
Miura H, Yamamoto I, Yuu I, et al Estimation of bone mineral density and bone loss by means of bone metabolic markers in postmenopausal women Endocr J 1995 42(6):797 802 8822322
Mizuno K, Suzuki A, Ino Y, et al Postmenopausal bone loss in Japanese women Int J Gynaecol Obstet 1995 50(1):33 9 7556857
Mizushima S, Tsuchida K, Yamori Y Preventive nutritional factors in epidemiology: interaction between sodium and calcium Clin Exp Pharmacol Physiol 1999 26(7):573 5 10405793
Mora S, Weber G, Marenzi K, et al Longitudinal changes of bone density and bone resorption in hyperthyroid girls during treatment J Bone Miner Res 1999 14(11):1971 7 10571698
Moritz DJ, Kelsey JL, Grisso JA Hospital controls versus community controls: differences in inferences regarding risk factors for hip fracture Am J Epidemiol 1997 145(7):653 60 9098183
Morris HA, Wishart JM, Horowitz M, et al The reproducibility of bone-related biochemical variables in post-menopausal women Ann Clin Biochem 1990 27(Pt 6):562 8 2080858
Morris HA, Cleghorn DB, Need AG, et al The 5-year reproducibility of calcium-related biochemical variables in postmenopausal women Scand J Clin Lab Invest 1995 55(5):383 9 8545596
Morton DJ, Barrett-Connor EL, Schneider DL Nonsteroidal anti-inflammatory drugs and bone mineral density in older women: the Rancho Bernardo study J Bone Miner Res 1998 13(12):1924 31 9844111
Munger RG, Cerhan JR, Chiu BC Prospective study of dietary protein intake and risk of hip fracture in postmenopausal women Am J Clin Nutr 1999 69(1):147 52 9925137
Murray RE, McGuigan F, Grant SF, et al Polymorphisms of the interleukin-6 gene are associated with bone mineral density Bone 1997 21(1):89 92 9213013
Mussolino ME, Looker AC, Madans JH, et al Phalangeal bone density and hip fracture risk Arch Intern Med 1997 157(4):433 8 9046895
Myers AH, Young Y, Langlois JA Prevention of falls in the elderly Bone 1996 18(1 Suppl):87S 101S 8717552
Naessen T, Persson I, Adami HO, et al Hormone replacement therapy and the risk for first hip fracture. A prospective, population-based cohort study Ann Intern Med 1990 113(2):95 103 2360759
Naessen T, Persson I, Ljunghall S, et al. Women with climacteric symptoms: a target group for prevention of rapid bone loss and osteoporosis. Osteoporos Int. 1992;2:225-31. [pmid: 1392261].
Naganathan V, March L, Hunter D, et al Quantitative heel ultrasound as a predictor for osteoporosis Med J Aust 1999 171(6):297 300 10560444
Nakamura T, Turner CH, Yoshikawa T, et al Do variations in hip geometry explain differences in hip fracture risk between Japanese and white Americans? J Bone Miner Res 1994 9(7):1071 6 7942154
National Osteoporosis Foundation Osteoporosis: review of the evidence for prevention, diagnosis, and treatment and cost-effectiveness analysis Osteoporos Int 1998 8(suppl 4):57 80
National Osteoporosis Foundation. Physician's guide to prevention and treatment of osteoporosis. Washington, DC: Excerpta Medica, Inc.; 1999.
Naves Diaz M, O'Neill TW, Silman AJ The influence of alcohol consumption on the risk of vertebral deformity. European Vertebral Osteoporosis Study Group Osteoporos Int 1997 7(1):65 71 9102066
Need AG, Morris HA, Horowitz M, et al The response to calcitriol therapy in postmenopausal osteoporotic women is a function of initial calcium absorptive status Calcif Tissue Int 1997 61(1):6 9 9192503
Neer RM. Osteoporosis. In: DeGroot LJ, editor. Endocrinology. Philadelphia: WB Saunders Company; 1995.
Nelson DA, Kleerekoper M, Parfitt AM Bone mass, skin color and body size among black and white women Bone Miner 1988 4(3):257 64 3191283
Nelson DA, Kleerekoper M, Peterson E, et al Skin color and body size as risk factors for osteoporosis Osteoporos Int 1993 3(1):18 23 8422511
Nelson ME, Fiatarone MA, Morganti CM, et al Effects of high-intensity strength training on multiple risk factors for osteoporotic fractures. A randomized controlled trial JAMA 1994 272(24):1909 14 7990242
Nevitt MC, Cummings SR, Kidd S, et al Risk factors for recurrent nonsyncopal falls. A prospective study JAMA 1989 261(18):2663 8 2709546
Nevitt MC, Cummings SR, Hudes ES Risk factors for injurious falls: a prospective study J Gerontol 1991 46(5):M164 70 1890282
Nevitt MC, Johnell O, Black DM, et al Bone mineral density predicts non-spine fractures in very elderly women. Study of Osteoporotic Fractures Research Group Osteoporos Int 1994 4(6):325 31 7696827
Nevitt MC, Cummings SR Type of fall and risk of hip and wrist fractures: the study of osteoporotic fractures J Am Geriatr Soc 1994 42(8):
Nevitt MC, Ettinger B, Black DM, et al The association of radiographically detected vertebral fractures with back pain and function: a prospective study Ann Intern Med 1998 128(10):793 800 9599190
Nguyen TV, Sambrook P, Kelly P, et al Prediction of osteoporotic fractures by postural instability and bone density BMJ 1993 307(6912):1111 5 8251809 1679116
Nguyen TV, Kelly PJ, Sambrook PN, et al Lifestyle factors and bone density in the elderly: implications for osteoporosis prevention J Bone Miner Res 1994 9(9):1339 46 7817817
Nguyen TV, Jones G, Sambrook PN, et al Effects of estrogen exposure and reproductive factors on bone mineral density and osteoporotic fractures J Clin Endocrinol Metab 1995 80(9):2709 14 7673413
Nguyen TV, Sambrook PN, Eisman JA Sources of variability in bone mineral density measurements: implications for study design and analysis of bone loss J Bone Miner Res 1997 12(1):124 35 9240735
Nguyen TV, Howard GM, Kelly PJ, et al Bone mass, lean mass, and fat mass: same genes or same environments? Am J Epidemiol 1998 147(1):3 16 9440393
Nguyen TV, Sambrook PN, Eisman JA Bone loss, physical activity, and weight change in elderly women: the Dubbo Osteoporosis Epidemiology Study J Bone Miner Res 1998 13(9):1458 67 9738519
Nicholson PHF, Muller R, Lowet G, et al Do quantitative ultrasound measurements reflect structure independently of density in human vertebral cancellous bone? Bone 1998 23(5):425 31 9823448
Nielsen NM, von der Recke P, Hansen MA, et al Estimation of the effect of salmon calcitonin in established osteoporosis by biochemical bone markers Calcif Tissue Int 1994 55(1):8 11 7922794
Nieves JW, Grisso JA, Kelsey JL A case-control study of hip fracture: evaluation of selected dietary variables and teenage physical activity Osteoporos Int 1992 2(3):122 7 1627898
Njeh CF, Boivin CM, Langton CM The role of ultrasound in the assessment of osteoporosis: a review Osteoporos Int 1997 7(1):7 22 9102067
Njeh CF, Richards A, Boivin CM, et al Factors influencing the speed of sound through the proximal phalanges J Clin Densitomet 1999 2(3):241 9
Nordin B, Need A, Chatterton B, et al. Bone density screening for osteoporosis. Lancet. 1990;336:1327-8.
Nordin BE, Need AG, Chatterton BE, et al The relative contributions of age and years since menopause to postmenopausal bone loss J Clin Endocrinol Metab 1990 70(1):83 8 2294140
Nordin BE, Cleghorn DB, Chatterton BE, et al A 5-year longitudinal study of forearm bone mass in 307 postmenopausal women J Bone Miner Res 1993 8(12):1427 32 8304042
Norimatsu H, Kawanishi J Use of a rapid decrease in trabecular bone density in the early diagnosis of senile osteoporosis Osteoporos Int 1993 3Suppl 1:72 4 8461583
Norman AW, Collins ED Correlation between vitamin D receptor allele and bone mineral density Nutr Rev 1994 52(4):147 9 8028822
Norris RJ Medical costs of osteoporosis Bone 1992 13Suppl 2:S11 6 1627408
Norton R, Campbell AJ, Lee-Joe T, et al Circumstances of falls resulting in hip fractures among older people J Am Geriatr Soc 1997 45(9):1108 12 9288020
Norton R, Campbell AJ, Reid IR, et al Residential status and risk of hip fracture Age Ageing 1999 28(2):135 9 10350409
Nuti R, Martini G, Righi G, et al Comparison of total-body measurements by dual-energy X-ray absorptiometry and dual-photon absorptiometry J Bone Miner Res 1991 6(7):681 7 1950673
Nuti R, Martini G, Gennari C Total body, spine, and femur dual X-ray absorptiometry in spinal osteoporosis Calcif Tissue Int 1993 53(6):388 93 8293352
Nyberg L, Gustafson Y, Berggren D, et al Falls leading to femoral neck fractures in lucid older people J Am Geriatr Soc 1996 44(2):156 60 8576505
O'Connor A, Pennie R, Dales R Framing effects on expectations, decisions, and side effects experienced: the case of influenza immunization J Clin Epidemiol 1997 49(11):1271 6
O'Neill TW, Silman AJ, Naves Diaz M, et al Influence of hormonal and reproductive factors on the risk of vertebral deformity in European women. European Vertebral Osteoporosis Study Group Osteoporos Int 1997 7(1):72 8 9102068
Oden A, Dawson A, Dere W, et al Lifetime risk of hip fractures is underestimated Osteoporos Int 1998 8(6):599 603 10326067
Oelzner P, Franke S, Muller A, et al Relationship between soluble markers of immune activation and bone turnover in post-menopausal women with rheumatoid arthritis Rheumatology (Oxford) 1999 38(9):841 7 128936 10515645
Ohishi T, Takahashi M, Kushida K, et al Urinary collagen crosslinks reflect further bone loss of femoral neck in osteoporotic patients undergoing vitamin D therapy Endocr Res 1998 24(2):259 67 9738702
Ohta H, Sugimoto I, Masuda A, et al Decreased bone mineral density associated with early menopause progresses for at least ten years: cross-sectional comparisons between early and normal menopausal women Bone 1996 18(3):227 31 8703577
Ongphiphadhanakul B, Rajatanavin R, Chailurkit L, et al Prediction of low bone mineral density in postmenopausal women by artificial neural network model compared to logistic regression model J Med Assoc Thai 1997 80(8):508 15 9277083
Ooms ME, Lips P, Van Lingen A, et al Determinants of bone mineral density and risk factors for osteoporosis in healthy elderly women J Bone Miner Res 1993 8(6):669 75 8328308
Ooms ME, Vlasman P, Lips P, et al The incidence of hip fractures in independent and institutionalized elderly people Osteoporos Int 1994 4(1):6 10 8148574
Ooms ME, Roos JC, Bezemer PD, et al Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial J Clin Endocrinol Metab 1995 80(4):1052 8 7714065
Orimo H, Shiraki M, Hayashi Y, et al Effects of 1 alpha-hydroxyvitamin D3 on lumbar bone mineral density and vertebral fractures in patients with postmenopausal osteoporosis Calcif Tissue Int 1994 54(5):370 6 8062152
Orme SM, Belchetz PE Is a low skinfold thickness an indicator of osteoporosis? Clin Endocrinol 1994 41(3):283 7
Orr-Walker BJ, Evans MC, Ames RW, et al Premature hair graying and bone mineral density J Clin Endocrinol Metab 1997 82(11):3580 3 9360510
Orwoll ES The effects of dietary protein insufficiency and excess on skeletal health Bone 1992 13(4):343 50 1389576
Orwoll ES, Oviatt SK, Biddle JA Precision of dual-energy x-ray absorptiometry: development of quality control rules and their application in longitudinal studies J Bone Miner Res 1993 8(6):693 9 8328311
Orwoll ES, Bauer DC, Vogt TM, et al Axial bone mass in older women Ann Intern Med 1996 124(2):187 96 8533993
Osei-Hyiaman D, Satoshi T, Ueji M, et al Timing of menopause, reproductive years, and bone mineral density: a cross-sectional study of postmenopausal Japanese women Am J Epidemiol 1998 148(11):1055 61 9850127
Osteoporosis: review of the evidence for prevention, diagnosis and treatment and cost-effectiveness analysis. Introduction Osteoporos Int 1998 8Suppl 4:S7 S80
Ott S, Kilcoyne R, Chesnut C. Longitudinal changes in bone mass after one year as measured by different techniques in patients with osteoporosis. Calcif Tissue Int. 1986;39:133-8. [pmid: 3093023].
Overgaard K, Hansen MA, Riis BJ, et al Discriminatory ability of bone mass measurements (SPA and DEXA) for fractures in elderly postmenopausal women Calcif Tissue Int 1992 50(1):30 5 1739867
Overgaard K, Christiansen C A new biochemical marker of bone resorption for follow-up on treatment with nasal salmon calcitonin Calcif Tissue Int 1996 59(1):12 6 8661977
Owen RA, Melton LJ, Ilstrup DM, et al Colles' fracture and subsequent hip fracture risk Clin Orthop 1982(171):37 43
Pacifici R, Vannice JL, Rifas L, et al Monocytic secretion of interleukin-1 receptor antagonist in normal and osteoporotic women: effects of menopause and estrogen/progesterone therapy J Clin Endocrinol Metab 1993 77(5):1135 41 8077304
Paganini-Hill A, Ross RK, Gerkins VR, et al. Menopausal estrogen therapy and hip fractures. Ann Intern Med. 1981;95:28-31. [pmid: 7247123].
Paganini-Hill A, Chao A, Ross RK, et al Exercise and other factors in the prevention of hip fracture: the Leisure World study Epidemiology 1991 2(1):16 25 2021661
Pansini F, Bonaccorsi G, Calisesi M, et al Evaluation of bone metabolic markers as indicators of osteopenia in climacteric women Gynecol Obstet Invest 1992 33(4):231 5 1505813
Pantazi H, Papapetrou P Changes in parameters of bone and mineral metabolism during therapy for hyperthyroidism J Clin Endocrinol Metab 2000 85(3):1099 106 10720046
Panteghini M, Pagani F Biological variation in bone-derived biochemical markers in serum Scand J Clin Lab Invest 1995 55(7):609 16 8633185
Papadimitropoulos EA, Coyte PC, Josse RG, et al Current and projected rates of hip fracture in Canada Can Med Assoc J 1997 157(10):1357 63 9371065 1228461
Papaioannou A, Parkinson W, Adachi H, et al Women's decisions about hormone replacement therapy after education and bone densitometry Can Med Assoc J 1998 159(10):1253 7 9861222 1229820
Parazzini F, Bidoli E, Franceschi S, et al Menopause, menstrual and reproductive history, and bone density in northern Italy J Epidemiol Community Health 1996 50(5):519 23 8944857
Parazzini F, Tavani A, Ricci E, et al Menstrual and reproductive factors and hip fractures in post menopausal women Maturitas 1996 24(3):191 6 8844633
Parfitt AM Dietary risk factors for age-related bone loss and fractures Lancet 1983 2(8360):1181 5 6139537
Parfitt AM, Simon LS, Villanueva AR, et al Procollagen type I carboxy-terminal extension peptide in serum as a marker of collagen biosynthesis in bone. Correlation with Iliac bone formation rates and comparison with total alkaline phosphatase J Bone Miner Res 1987 2(5):427 36 3455625
Parra-Cabrera S, Hernandez-Avila M, Tamayo-y-Orozco J, et al Exercise and reproductive factors as predictors of bone density among osteoporotic women in Mexico City Calcif Tissue Int 1996 59(2):89 94 8687975
Parviainen MT, Jaaskelainen K, Kroger H, et al Urinary bone resorption markers in monitoring treatment of symptomatic osteoporosis Clin Chim Acta 1999 279(1-2):145 54 10064126
Patton CL, Millard PS, Kessenich CR, et al Screening calcaneal ultrasound and risk factors for osteoporosis among lesbians and heterosexual women J Womens Health 1998 7(7):909 15 9785317
Pedrazzoni M, Alfano FS, Malvi C, et al Seasonal variation in the incidence of hip fractures in Emilia-Romagna and Parma Bone 1993 14Suppl 1:S57 63 8110522
Pedrazzoni M, Alfano FS, Gatti C, et al Acute effects of bisphosphonates on new and traditional markers of bone resorption Calcif Tissue Int 1995 57(1):25 9 7671161
Peel NF, Johnson A, Barrington NA, et al Impact of anomalous vertebral segmentation on measurements of bone mineral density J Bone Miner Res 1993 8(6):719 23 8328314
Peel NF, Eastell R Diagnostic value of estimated volumetric bone mineral density of the lumbar spine in osteoporosis J Bone Miner Res 1994 9(3):317 20 8191924
Peel NF, Barrington NA, Smith TW, et al Distal forearm fracture as risk factor for vertebral osteoporosis BMJ 1994 308(6943):1543 4 8019311
Peichl P, Rintelen B, Kumpan W, et al Increase of axial and appendicular trabecular and cortical bone density in established osteoporosis with intermittent nasal salmon calcitonin therapy Gynecol Endocrinol 1999 13(1):7 14 10368793
Perez Cano R, Galan Galan F, Dilsen G Risk factors for hip fracture in Spanish and Turkish women Bone 1993 14(Suppl 1):S69 72 8110524
Peris P, Guanabens N, Monegal A, et al. Aetiology and presenting symptoms in male osteoporosis. Br J Rheumatol. 1995;34:936-41. [pmid: 7582699].
Petitti DB, Sidney S Hip fracture in women. Incidence, in-hospital mortality, and five-year survival probabilities in members of a prepaid health plan Clin Orthop 1989(246):150 5
Petley GW, Cotton AM, Murrills AJ, et al Reference ranges of bone mineral density for women in southern England: the impact of local data on the diagnosis of osteoporosis Br J Radiol 1996 69(823):655 60 8696703
Pfeifer M, Pollaehne W, Minne HW Ultrasound analyses of the calcaneus predict relative risk of the presence of at least one vertebral fracture and reflect different physical qualities of bone in different regions of the skeleton Horm Metab Res 1997 29(2):76 9 9105904
Phillips CJ, Moore RA Developing a strategy for the prevention of hip fractures in the elderly due to osteoporosis: the application of economics to the findings from a clinical trial Int J Clin Prac 1998 52(5):335 40
Phipps KR, Orwoll ES, Bevan L The association between water-borne fluoride and bone mineral density in older adults J Dent Res 1998 77(9):1739 48 9759671
Pines A, Katchman H, Villa Y, et al. The effect of various hormonal preparations and calcium supplementation on bone mass in early menopause. Is there a predictive value for the initial bone density and body weight?. J Intern Med. 1999;246:357-61. [pmid: 10583706].
Plotkin H, Gundberg C, Mitnick M, et al Dissociation of bone formation from resorption during 2-week treatment with human parathyroid hormone-related peptide-(1-36) in humans: potential as an anabolic therapy for osteoporosis J Clin Endocrinol Metab 1998 83(8):2786 91 9709948
Pluskiewicz W, Drozdzowska B Ultrasound measurements of proximal phalanges in Polish early postmenopausal women Osteoporos Int 1998 8(6):578 83 10326064
Pluskiewicz W, Drozdzowska B Ultrasonic measurement of the calcaneus in Polish normal and osteoporotic women and men Bone 1999 24(6):611 7 10375204
Pocock N, Eisman J, Hopper J, et al. Genetic determinants of bone mass in adults: a twin study. J Clin Invest. 1987;80:706-10. [pmcid: 442294]. [pmid: 3624485].
Pocock NA, Eisman JA, Kelly PJ, et al Effects of tobacco use on axial and appendicular bone mineral density Bone 1989 10(5):329 31 2605049
Pocock NA, Sambrook PN, Nguyen T, et al Assessment of spinal and femoral bone density by dual X-ray absorptiometry: comparison of lunar and hologic instruments J Bone Miner Res 1992 7(9):1081 4 1414500
Pocock NA, Noakes KA, Howard GM, et al. Screening for osteoporosis: what is the role of heel ultrasound?. Med J Aust. 1996;164:367-70. [pmid: 8606664].
Pocock NA, Noakes KA, Majerovic Y, et al Magnification error of femoral geometry using fan beam densitometers Calcif Tissue Int 1997 60(1):8 10 9030472
Podenphant J, Christiansen C, Catherwood BD, et al Serum bone Gla protein and other biochemical estimates of bone turnover in early postmenopausal women during prophylactic treatment for osteoporosis Acta Med Scand 1985 218(3):329 33 3907290
Podenphant J, Johansen JS, Thomsen K, et al Bone turnover in spinal osteoporosis J Bone Miner Res 1987 2(6):497 503 3502682
Poet J, Serabian I, Camboulives H, et al Broadband ultrasound attenuation of the os calcis: preliminary study Clin Rheumatol 1994 13(2):234 8 8088065
Pols HA, Felsenberg D, Hanley DA, et al Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Foxamax International Trial Study Group Osteoporos Int 1999 9(5):461 8 10550467
Popp-Snijders C, Lips P, Netelenbos JC Intra-individual variation in bone resorption markers in urine Ann Clin Biochem 1996 33(Pt 4):347 8 8836394
Porter RW, Miller CG, Grainger D, et al Prediction of hip fracture in elderly women: a prospective study BMJ 1990 301(6753):638 41 2224217 1663899
Pothuaud L, Lespessailles E, Harba R, et al Fractal analysis of trabecular bone texture on radiographs: discriminant value in postmenopausal osteoporosis Osteoporos Int 1998 8(6):618 25 10326070
Pouilles JM, Tremollieres F, Todorovsky N, et al Precision and sensitivity of dual-energy x-ray absorptiometry in spinal osteoporosis J Bone Miner Res 1991 6(9):997 1002 1789144
Pouilles JM, Tremollieres F, Bonneu M, et al Influence of early age at menopause on vertebral bone mass J Bone Miner Res 1994 9(3):311 5 8191923
Pouilles JM, Tremollieres F, Ribot C. Variability of vertebral and femoral postmenopausal bone loss: a longitudinal study. Osteoporos Int. 1996;6:320-4. [pmid: 8883122].
Pouilles JM, Tremollieres F, Roux C, et al Effects of cyclical etidronate therapy on bone loss in early postmenopausal women who are not undergoing hormonal replacement therapy Osteoporos Int 1997 7(3):213 8 9205633
Prestwood KM, Pilbeam CC, Burleson JA, et al The short-term effects of conjugated estrogen on bone turnover in older women J Clin Endocrinol Metab 1994 79(2):366 71 8045949
Primary osteoporosis. In: Wilson JD, Foster DW, Kronenberg HM, et al. , editors. Williams textbook of endocrinology. Philadelphia: WB Saunders Company; 1998.
Prins SH, Lauritzen J, Jorgensen HL, et al Hip fracture discrimination by imaging ultrasound measurements of the calcaneus Clin Physiol 1999 19(5):419 25 10516893
Prior JC, Vigna YM, Barr SI, et al Ovulatory premenopausal women lose cancellous spinal bone: a five year prospective study Bone 1996 18(3):261 7 8703582
Prior JC, Vigna YM, Wark JD, et al Premenopausal ovariectomy-related bone loss: a randomized, double-blind, one-year trial of conjugated estrogen or medroxyprogesterone acetate J Bone Miner Res 1997 12(11):1851 63 9383690
Prostko M Meta-analysis of prevention of nonvertebral fractures by alendronate JAMA 1997 278(8):631; discussion 631 2
Pruzansky ME, Turano M, Luckey M, et al Low body weight as a risk factor for hip fracture in both black and white women J Orthop Res 1989 7(2):192 7 2918419
Puntila E, Kroger H, Lakka T, et al Physical activity in adolescence and bone density in peri- and postmenopausal women: a population-based study Bone 1997 21(4):363 7 9315340
Rae SA, Wang WJ, Partridge D Artificial neural networks: a potential role in osteoporosis J R Soc Med 1999 92(3):119 22 10396254 1297100
Ralston SH Do genetic markers aid in risk assessment? Osteoporos Int 1998 8Suppl 1:S37 42 9682796
Ranstam J, Kanis JA Influence of age and body mass on the effects of vitamin D on hip fracture risk Osteoporos Int 1995 5(6):450 4 8695967
Ranstam J, Elffors L, Kanis JA A mental-functional risk score for prediction of hip fracture Age Ageing 1996 25(6):439 42 9003879
Rashiq S, Logan R. Role of drugs in fractures of the femoral neck. BMJ. 1986;292:861-3. [pmid: 3083912]. [pmcid: 1339971].
Ravaud P, Reny JL, Giraudeau B, et al Individual smallest detectable difference in bone mineral density measurements J Bone Miner Res 1999 14(8):1449 56 10457279
Ravn P, Overgaard K, Spencer EM, et al Insulin-like growth factors I and II in healthy women with and without established osteoporosis Eur J Endocrinol 1995 132(3):313 9 7889180
Ravn P, Clemmesen B, Riis BJ, et al The effect on bone mass and bone markers of different doses of ibandronate: a new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: a 1-year, randomized, double-blind, placebo-controlled dose-finding study Bone 1996 19(5):527 33 8922653
Ravn P, Fledelius C, Rosenquist C, et al High bone turnover is associated with low bone mass in both pre- and postmenopausal women Bone 1996 19(3):291 8 8873970
Ravn P, Rix M, Andreassen H, et al High bone turnover is associated with low bone mass and spinal fracture in postmenopausal women Calcif Tissue Int 1997 60(3):255 60 9069162
Ravn P, Christensen JO, Baumann M, et al Changes in biochemical markers and bone mass after withdrawal of ibandronate treatment: prediction of bone mass changes during treatment Bone 1998 22(5):559 64 9600792
Ravn P, Hosking D, Thompson D, et al Monitoring of alendronate treatment and prediction of effect on bone mass by biochemical markers in the early postmenopausal intervention cohort study J Clin Endocrinol Metab 1999 84(7):2363 8 10404804
Ravn P, Clemmesen B, Christiansen C Biochemical markers can predict the response in bone mass during alendronate treatment in early postmenopausal women Bone 1999 24(3):237 44 10071916
Ravn P, Alexandersen P, Mollgaard A Bone densitometry: a new, highly responsive region of interest in the distal forearm to monitor the effect of osteoporosis treatment Osteoporos Int 1999 9(4):277 83 10550443
Ravn P, Cizza G, Bjarnason NH, et al Low body mass index is an important risk factor for low bone mass and increased bone loss in early postmenopausal women. Early Postmenopausal Intervention Cohort (EPIC) study group J Bone Miner Res 1999 14(9):1622 7 10469292
Ravn P, Bidstrup M, Wasnich RD, et al. Alendronate and estrogen-progestin in the long-term prevention of bone loss: four-year results from the early postmenopausal intervention cohort study. A randomized, controlled trial. Ann Intern Med. 1999;131:935-42. [pmid: 10610644].
Ray WA, Griffin MR, Schaffner W, et al Psychotropic drug use and the risk of hip fracture N Engl J Med 1987 316(7):363 9 2880292
Ray WA, Griffin MR, Downey W Benzodiazepines of long and short elimination half-life and the risk of hip fracture JAMA 1989 262(23):3303 7 2573741
Ray WA, Griffin MR, Downey W, et al Long-term use of thiazide diuretics and risk of hip fracture Lancet 1989 1(8640):687 90 2564506
Ray WA, Griffin MR, Malcolm E Cyclic antidepressants and the risk of hip fracture Arch Intern Med 1991 151(4):754 6 2012459
Ray NF, Chan JK, Thamer M, et al Medical expenditures for the treatment of osteoporotic fractures in the United States in 1995: report from the National Osteoporosis Foundation J Bone Miner Res 1997 12(1):24 35 9240722
Redelmeier D, Tversky A Discrepancy between medical decisions for individual patients and for groups N Engl J Med 1990 322(16):1162 4 2320089
Reed BY, Zerwekh JE, Sakhaee K, et al Serum IGF 1 is low and correlated with osteoblastic surface in idiopathic osteoporosis J Bone Miner Res 1995 10(8):1218 24 8585426
Reeve J, Pearson J, Mitchell A, et al Evolution of spinal bone loss and biochemical markers of bone remodeling after menopause in normal women Calcif Tissue Int 1995 57(2):105 10 7584869
Reeve J The European Prospective Osteoporosis Study Osteoporos Int 1996 6Suppl 3:16 8 8931040
Reginster JY, Jupsin I, Deroisy R, et al Prevention of postmenopausal bone loss by rectal calcitonin Calcif Tissue Int 1995 56(6):539 42 7648483
Reginster JY Cost effectiveness of treatments in osteoporosis J Rheumatol 1996 23(7):1312 3 8823721
Reginster JY, Deroisy R, Collette J, et al Prediction of bone loss rate in healthy postmenopausal women Calcif Tissue Int 1997 60(3):261 4 9069163
Reid IR, Ames R, Evans MC, et al Determinants of total body and regional bone mineral density in normal postmenopausal women -- a key role for fat mass J Clin Endocrinol Metab 1992 75(1):45 51 1619030
Reisz LG. Osteoporosis. In: Stein JH, editor. Internal medicine. 5th ed. St. Louis: Mosby; 1998.
Relea P, Revilla M, Ripoll E, et al Zinc, biochemical markers of nutrition, and type I osteoporosis Age Ageing 1995 24(4):303 7 7484487
Revilla RM, Hernandez ER, Villa LF, et al Total body bone measurements in spinal osteoporosis by dual-energy X-ray absorptiometry Calcif Tissue Int 1997 61(1):44 7 9192512
Ribot C, Tremollieres F, Pouilles JM Effect of 17 beta-oestradiol and norethisterone acetate on vertebral bone mass and lipid metabolism in early postmenopausal women Maturitas 1992 15(3):217 23 1465035
Ribot C, Pouilles JM, Bonneu M, et al Assessment of the risk of post-menopausal osteoporosis using clinical factors Clin Endocrinol 1992 36(3):225 8
Ribot C, Tremollieres F, Pouilles JM, et al Risk factors for hip fracture. MEDOS study: results of the Toulouse Centre Bone 1993 14Suppl 1:S77 80 8110526
Ribot C, Tremollieres F, Pouilles JM Can we detect women with low bone mass using clinical risk factors? Am J Med 1995 98(2A):52S 5S
Ricci TA, Chowdhury HA, Heymsfield SB, et al Calcium supplementation suppresses bone turnover during weight reduction in postmenopausal women J Bone Miner Res 1998 13(6):1045 50 9626637
Richmond BJ Enthusiasm for ultrasound for osteoporosis screening is premature Cleve Clin J Med 1998 65(8):403 4 9769560
Rico H, Villa LF Serum tartrate-resistant acid phosphatase (TRAP) as a biochemical marker of bone remodeling Calcif Tissue Int 1993 52(2):149 50 8443692
Rico H, Gomez M, Aguado F, et al Impact of weight in obese subjects on bone speed of sound Invest Radiol 1999 34(9):596 9 10485076
Riggs BL, Hodgson SF, O'Fallon WM, et al Effect of fluoride treatment on the fracture rate in postmenopausal women with osteoporosis N Engl J Med 1990 322(12):802 9 2407957
Riggs B, Melton LJ, O'Fallon W Drug therapy for vertebral fractures in osteoporosis: evidence that decreases in bone turnover and increases in bone mass both determine antifracture efficacy Bone 1996 18(3):197S 201S 8777088
Riis BJ, Rodbro P, Christiansen C The role of serum concentrations of sex steroids and bone turnover in the development and occurrence of postmenopausal osteoporosis Calcif Tissue Int 1986 38(6):318 22 3089552
Riis BJ, Overgaard K, Christiansen C Biochemical markers of bone turnover to monitor the bone response to postmenopausal hormone replacement therapy Osteoporos Int 1995 5(4):276 80 7492867
Riis BJ, Hansen MA, Jensen AM, et al Low bone mass and fast rate of bone loss at menopause: equal risk factors for future fracture: a 15-year follow-up study Bone 1996 19(1):9 12 8830981
Rimes KA, Salkovskis PM, Shipman AJ. Psychological and behavioural effects of bone density screening for osteoporosis. Psychol Health. 1999;14:585-608.
Ripoll E, Arribas I, Relea P, et al Beta-2-microglobulin in diseases with high bone remodeling Calcif Tissue Int 1995 57(4):272 6 8673864
Ripoll E, Revilla M, Hernandez ER, et al New evidence that serum beta(2)-microglobulin behaves as a biological marker of bone remodelling in women Eur J Clin Invest 1996 26(8):681 5 8872064
Robins SP, Woitge H, Hesley R, et al Direct, enzyme-linked immunoassay for urinary deoxypyridinoline as a specific marker for measuring bone resorption J Bone Miner Res 1994 9(10):1643 9 7817812
Rosen CJ, Usiskin K, Owens M, et al T lymphocyte surface antigen markers in osteoporosis J Bone Miner Res 1990 5(8):851 5 2239369
Rosen CJ, Holick MF, Millard PS Premature graying of hair is a risk marker for osteopenia J Clin Endocrinol Metab 1994 79(3):854 7 8077373
Rosen CJ, Morrison A, Zhou H, et al Elderly women in northern New England exhibit seasonal changes in bone mineral density and calciotropic hormones Bone Miner 1994 25(2):83 92 8086854
Rosen CJ. The diagnosis and treatment of postmenopausal osteoporosis. In: Rosen CJ, editor. Osteoporosis: diagnostic and therapeutic principles. Totowa, NJ: Humana Press, Inc.; 1996.
Rosen CJ, Chesnut CH 3rd, Mallinak NJ The predictive value of biochemical markers of bone turnover for bone mineral density in early postmenopausal women treated with hormone replacement or calcium supplementation J Clin Endocrinol Metab 1997 82(6):1904 10 9177404
Rosen HN, Moses AC, Garber J, et al Serum CTX: a new marker of bone resorption that shows treatment effect more often than other markers because of low coefficient of variability and large changes with bisphosphonate therapy Calcif Tissue Int 2000 66(2):100 3 10652955
Rosenthall L, Tenenhouse A, Caminis J A correlative study of ultrasound calcaneal and dual-energy X-ray absorptiometry bone measurements of the lumbar spine and femur in 1000 women Eur J Nucl Med 1995 22(5):402 6 7641747
Rosenthall L Selective supplementation of calcaneal ultrasound densitometry with dual-energy x-ray absorptiometry of the spine and femur for population screening Can Assoc Radiol J 1997 48(1):38 41 9030068
Rosenthall L. Influence of bone quality on precision of calcaneal ultrasonometry. Calcif Tissue Int. 1997;61:139-41. [pmid: 9236261].
Rosner AJ, Grima DT, Torrance GW, et al Cost effectiveness of multi-therapy treatment strategies in the prevention of vertebral fractures in postmenopausal women with osteoporosis Pharmacoeconomics 1998 14(5):559 73 10344918
Ross PD, Wasnich RD, Vogel J Detection of prefracture spinal osteoporosis using bone mineral absorptiometry J Bone Miner Res 1988 3(1):1 11 3213600
Ross PD, Wasnich RD, Maclean C, et al. A model for estimating the potential costs and savings of osteoporosis prevention strategies. Bone. 1988;9:337-47. [pmid: 3248197].
Ross PD, Wasnich RD, Davis JW Fracture prediction models for osteoporosis prevention Bone 1990 11(5):327 31 2123644
Ross PD, Davis JW, Epstein RS, et al Pre-existing fractures and bone mass predict vertebral fracture incidence in women Ann Intern Med 1991 114(11):919 23 2024857
Ross PD, Genant HK, Davis JW, et al Predicting vertebral fracture incidence from prevalent fractures and bone density among non-black, osteoporotic women Osteoporos Int 1993 3(3):120 6 8481587
Ross PD, Huang C, Davis JW, et al Predicting vertebral deformity using bone densitometry at various skeletal sites and calcaneus ultrasound Bone 1995 16(3):325 32 7786635
Ross PD, Huang C, Davis JW, et al Vertebral dimension measurements improve prediction of vertebral fracture incidence Bone 1995 16(4 Suppl):257S 62S 7626313
Ross PD, Fujiwara S, Huang C, et al Vertebral fracture prevalence in women in Hiroshima compared to Caucasians or Japanese in the US Int J Epidemiol 1995 24(6):1171 7 8824859
Ross PD Osteoporosis. Frequency, consequences, and risk factors Arch Intern Med 1996 156(13):1399 411 8678708
Ross PD Prediction of fracture risk. II: Other risk factors Am J Med Sci 1996 312(6):260 9 8969615
Ross PD Radiographic absorptiometry for measuring bone mass Osteoporos Int 1997 7Suppl 3:S103 7 9536314
Ross PD, Wasnich RD, Knowlton WK Skeletal alkaline phosphatase (Tandem(c)-R Ostase(c)) measurements predict vertebral fractures: a prospective study. (Abstract) J Bone Miner Res 1997 12(Suppl 1):
Ross PD, Knowlton W Rapid bone loss is associated with increased levels of biochemical markers J Bone Miner Res 1998 13(2):297 302 9495524
Ross PD Predicting bone loss and fracture risk with biochemical markers: a review J Clin Densitomet 1999 2(3):285 94
Ross PD, Kress BC, Parson RE, et al. Serum bone alkaline phosphatase and calcaneus bone density predict fractures: a prospective study. Osteoporos Int. 2000;11:1176-82.
Rosso R, Minisola S, Scarda A, et al Temporal relationship between bone loss and increased bone turnover: a longitudinal study following natural menopause J Endocrinol Invest 1995 18(9):723 8 8719304
Roux C, Lemonnier E, Kolta S, et al Broadband ultrasound attenuation of the calcaneus and bone density measurements Rev Rhum Engl Ed 1993 60(12):771 80
Roux C, Fournier B, Laugier P, et al Broadband ultrasound attenuation imaging: a new imaging method in osteoporosis J Bone Miner Res 1996 11(8):1112 8 8854247
Royal College of Physicians. Osteoporosis: clinical guidelines for prevention and treatment. London: Royal College of Physicians of London; 1999.
Rozenberg S, Kroll M, Vandromme J, et al. Effect of bone density evaluation on hormone replacement therapy prescription. Maturitas. 1996;24:57-61. [pmid: 8794435].
Rubin S, Cummings S Results of bone densitometry affect women's decisions about taking measures to prevent fractures Ann Intern Med 1992 116(12 pt 1):990 5 1586110
Rubin LA, Hawker GA, Peltekova VD, et al Determinants of peak bone mass: clinical and genetic analyses in a young female Canadian cohort J Bone Miner Res 1999 14(4):633 43 10234586
Rupich RC, Griffin MG, Pacifici R, et al Lateral dual-energy radiography: artifact error from rib and pelvic bone J Bone Miner Res 1992 7(1):97 101 1549963
Russell-Aulet M, Wang J, Thornton J, et al Comparison of dual-photon absorptiometry systems for total-body bone and soft tissue measurements: dual-energy X-rays versus gadolinium 153 J Bone Miner Res 1991 6(4):411 5 1858524
Ryan PJ, Blake GM, Herd R, et al Spine and femur BMD by DXA in patients with varying severity spinal osteoporosis Calcif Tissue Int 1993 52(4):263 8 8467405
Ryan AS, Treuth MS, Hunter GR, et al Resistive training maintains bone mineral density in postmenopausal women Calcif Tissue Int 1998 62(4):295 9 9504952
Ryan AS, Elahi D Loss of bone mineral density in women athletes during aging Calcif Tissue Int 1998 63(4):287 92 9744985
Rymer J, Chapman MG, Fogelman I Effect of tibolone on postmenopausal bone loss Osteoporos Int 1994 4(6):314 9 7696824
Saaf M, Hilding A, Thoren M, et al Growth hormone treatment of osteoporotic postmenopausal women - a one-year placebo-controlled study Eur J Endocrinol 1999 140(5):390 9 10229902
Sackett DL, Richardson WS, Rosenberg W, et al. Evidence-based medicine: how to practice and teach EBM. Edinburgh: Churchill Livingstone; 1998.
Sahota O, San P, Cawte SA, et al. A comparison of the longitudinal changes in quantitative ultrasound with dual-energy X-ray absorptiometry: the four-year effects of hormone replacement therapy. Osteoporos Int. 2000;11:52-8. [pmid: 10663359].
Sairanen S, Tahtela R, Laitinen K, et al Nocturnal rise in markers of bone resorption is not abolished by bedtime calcium or calcitonin Calcif Tissue Int 1994 55(5):349 52 7866915
Sakata S, Kushida K, Yamazaki K, et al Ultrasound bone densitometry of os calcis in elderly Japanese women with hip fracture Calcif Tissue Int 1997 60(1):2 7 9030471
Salamone L, Krall E, Dawson-Hughes B. Comparison of broadband ultrasound attenuation to single X-ray absorptiometry measurements at the calcaneus in postmenopausal women. Calcif Tissue Int. 1994;54:87-90. [pmid: 8012876].
Salamone LM, Glynn NW, Black DM, et al Determinants of premenopausal bone mineral density: the interplay of genetic and lifestyle factors J Bone Miner Res 1996 11(10):1557 65 8889857
Salamone LM, Pressman AR, Seeley DG, et al. Estrogen replacement therapy. A survey of older women's attitudes. Arch Intern Med. 1996;156:1293-7. [pmid: 8651837].
Sambrook P, Birmingham J, Kempler S, et al Corticosteroid effects on proximal femur bone loss J Bone Miner Res 1990 5(12):1211 6 2075834
Sandler RB, Slemenda CW, LaPorte RE, et al Postmenopausal bone density and milk consumption in childhood and adolescence Am J Clin Nutr 1985 42(2):270 4 3839625
Sandor T, Felsenberg D, Brown E Comments on the hypotheses underlying fracture risk assessment in osteoporosis as proposed by the World Health Organization Calcif Tissue Int 1999 64(3):267 70 10024389
Sano M, Inoue S, Hosoi T, et al Association of estrogen receptor dinucleotide repeat polymorphism with osteoporosis Biochem Biophys Res Commun 1995 217(1):378 83 8526937
Santavirta S, Konttinen YT, Heliövaara M, et al Determinants of osteoporotic thoracic vertebral fracture. Screening of 57,000 Finnish women and men Acta Orthop Scand 1992 63(2):198 202 1590058
Satoh Y, Soeda Y, Dokou S Analysis of relationships between sex hormone dynamics and bone metabolism and changes in bone mass in surgically induced menopause Calcif Tissue Int 1995 57(4):258 66 8673862
Scariano JK, Glew RH, Bou-Serhal CE, et al Serum levels of cross-linked N-telopeptides and aminoterminal propeptides of type I collagen indicate low bone mineral density in elderly women Bone 1998 23(5):471 7 9823455
Scharla SH, Scheidt-Nave C, Leidig G, et al Lower serum 25-hydroxyvitamin D is associated with increased bone resorption markers and lower bone density at the proximal femur in normal females: a population-based study Exp Clin Endocrinol Diabetes 1996 104(3):289 92 8817249
Schlemmer A, Hassager C, Delmas PD, et al Urinary excretion of pyridinium cross-links in healthy women; the long-term effects of menopause and oestrogen/progesterone therapy Clin Endocrinol 1994 40(6):777 82
Schneider DL, Barrett-Connor EL, Morton DJ Thyroid hormone use and bone mineral density in elderly women. Effects of estrogen JAMA 1994 271(16):1245 9 7848399
Schneider DL, Barrett-Connor EL Urinary N-telopeptide levels discriminate normal, osteopenic, and osteoporotic bone mineral density Arch Intern Med 1997 157(11):1241 5 9183236
Schnitzler CM, Wing JR, Mesquita JM, et al Risk factors for the development of stress fractures during fluoride therapy for osteoporosis J Bone Miner Res 1990 5Suppl 1:S195 200 2339629
Schnitzler CM Bone quality: a determinant for certain risk factors for bone fragility Calcif Tissue Int 1993 53(Suppl 1):S27 S31 8275376
Schott AM, Weill-Engerer S, Hans D, et al Ultrasound discriminates patients with hip fracture equally well as dual energy X-ray absorptiometry and independently of bone mineral density J Bone Miner Res 1995 10(2):243 9 7754803
Schott AM, Cormier C, Hans D, et al How hip and whole-body bone mineral density predict hip fracture in elderly women: the EPIDOS Prospective Study Osteoporos Int 1998 8(3):247 54 9797909
Schwartz KL Risk factors for hip fractures J Fam Pract 1995 41(2):187 8 7636460
Schweiger U, Deuschle M, Korner A, et al Low lumbar bone mineral density in patients with major depression Am J Psychiatry 1994 151(11):1691 3 7943462
Clinical practice guidelines for the diagnosis and management of osteoporosis Can Med Assoc J 1996 155(8):1113 33 8873639 1335371
Scopacasa F, Horowitz M, Need AG, et al The effects of low dose norethisterone on biochemical variables in postmenopausal women Osteoporos Int 1999 9(6):494 8 10624456
Scoutellas V, O'Neill TW, Lunt M, et al Does the presence of postmenopausal symptoms influence susceptibility to vertebral deformity? European Vertebral Osteoporosis Study (EVOS) Group Maturitas 1999 32(3):179 87 10515675
Seeley DG, Browner W, Nevitt M, et al Which fractures are associated with low appendicular bone mass in elderly women? Ann Intern Med 1991 115(11):837 42 1952469
Seeley DG, Cauley JA, Grady D, et al Is postmenopausal estrogen therapy associated with neuromuscular function or falling in elderly women? Study of Osteoporotic Fractures Research Group Arch Intern Med 1995 155(3):293 9 7832601
Seeley DG, Kelsey J, Jergas M, et al Predictors of ankle and foot fractures in older women. The Study of Osteoporotic Fractures Research Group J Bone Miner Res 1996 11(9):1347 55 8864910
Seeman E, Cooper ME, Hopper JL, et al Effect of early menopause on bone mass in normal women and patients with osteoporosis Am J Med 1988 85(2):213 6 3400696
Seeman E, Hopper J, Bach L, et al Reduced bone mass in daughters of women with osteoporosis N Engl J Med 1989 320(9):554 8 2915666
Seeman E, Young N, Szmukler G, et al Risk factors for osteoporosis Osteoporos Int 1993 3Suppl 1:40 3 8461574
Seibel MJ, Cosman F, Shen V, et al Urinary hydroxypyridinium crosslinks of collagen as markers of bone resorption and estrogen efficacy in postmenopausal osteoporosis J Bone Miner Res 1993 8(7):881 9 8352070
Seibel MJ, Woitge HW, Scheidt-Nave C, et al Urinary hydroxypyridinium crosslinks of collagen in population-based screening for overt vertebral osteoporosis: results of a pilot study J Bone Miner Res 1994 9(9):1433 40 7817828
Seibel MJ, Woitge HW, Pecherstorfer M, et al Serum immunoreactive bone sialoprotein as a new marker of bone turnover in metabolic and malignant bone disease J Clin Endocrinol Metab 1996 81(9):3289 94 8784085
Sekioka Y, Kushida K, Yamazaki K, et al Calcaneus bone mineral density using single x-ray absorptiometry in Japanese women Calcif Tissue Int 1999 65(2):106 11 10430640
Semla TP Role of risk assessment and bone density monitoring in osteoporosis Pharmacotherapy 1999 19(1 Pt 2):2S 6S 9915556
Shaw CK An epidemiologic study of osteoporosis in Taiwan Ann Epidemiol 1993 3(3):264 71 8275199
Shaw C, Abrams K, Marteau TM. Psychological impact of predicting individuals' risks of illness: a systematic review. Soc Sci Med. 1999;49:1571-98. [pmid: 10574231].
Sheldon TA, Raffle A, Watt I Department of Health shoots itself in the hip. Why the report of the Advisory Group on Osteoporosis undermines evidence based purchasing BMJ 1996 312(7026):296 7 8611790
Shepherd JA, Prevrhal S. Reporting of bone mineral density values as T-scores or Z-scores: comment on the article by Sowers et al. Arthritis Rheum. 1999;42(11)2497.
Shih WJ, Quan H. Planning and analysis of repeated measures at key time-points in clinical trials sponsored by pharmaceutical companies. Stat Med. 1999;18:961-73. [pmid: 10363334].
Shiraki M, Kushida K, Fukunaga M, et al A placebo-controlled, single-blind study to determine the appropriate alendronate dosage in postmenopausal Japanese patients with osteoporosis. The Alendronate Research Group Endocr J 1998 45(2):191 201 9700472
Consensus statement on prevention and treatment of osteoporosis. 1999.
Silman AJ, O'Neill TW, Cooper C, et al Influence of physical activity on vertebral deformity in men and women: results from the European Vertebral Osteoporosis Study J Bone Miner Res 1997 12(5):813 9 9144348
Silverberg SJ, Shane E, Jacobs TP, et al A 10-year prospective study of primary hyperparathyroidism with or without parathyroid surgery N Engl J Med 1999 341(17):1249 55 10528034
Silverman SL, Greenwald M, Klein RA, et al Effect of bone density information on decisions about hormone replacement therapy: a randomized trial Obstet Gynecol 1997 89(3):321 5 9052578
Simmons A, Barrington S, O'Doherty M, et al Dual energy X-ray absorptiometry normal reference range use within the UK and the effect of different normal ranges on the assessment of bone density Br J Radiol 1995 68(812):903 9 7551789
Sinaki M, Fitzpatrick LA, Ritchie CK, et al Site-specificity of bone mineral density and muscle strength in women: job-related physical activity Am J Phys Med Rehabil 1998 77(6):470 6 9862531
Sinigaglia L, Varenna M, Binelli L, et al Serum levels of pyridinium crosslinks in postmenopausal women and in Paget's disease of bone Calcif Tissue Int 1997 61(4):279 84 9312197
Slemenda CW, Hui SL, Longcope C, et al Cigarette smoking, obesity, and bone mass J Bone Miner Res 1989 4(5):737 41 2816518
Slemenda CW, Hui SL, Longcope C, et al Predictors of bone mass in perimenopausal women. A prospective study of clinical data using photon absorptiometry Ann Intern Med 1990 112(2):96 101 2294827
Slemenda CW Cigarettes and the skeleton N Engl J Med 1994 330(6):430 1 8284011
Slemenda CW, Turner CH, Peacock M, et al The genetics of proximal femur geometry, distribution of bone mass and bone mineral density Osteoporos Int 1996 6(2):178 82 8704359
Slemenda CW Prevention of hip fractures: risk factor modification Am J Med 1997 103(2A):65S 71S; discussion 71S-73S 9302898
Slovik DM. Section III: Endocrinology, osteoporosis. In: Carlson KJ, Eisenstat SA, Frigoletto FD, et al., editors. Primary care of women. St. Louis: Mosby; 1995.
Smeets-Goevaers CG, Lesusink GL, Papapoulos SE, et al The prevalence of low bone mineral density in Dutch perimenopausal women: the Eindhoven perimenopausal osteoporosis study Osteoporos Int 1998 8(5):404 9 9850346
Soballa T, Wuster C, Schlegel J, et al Ultrasound transmission speed and ultrasound bone profile score (UBPS) of the phalanges in normal women and women with osteoporosis Horm Metab Res 1998 30(8):536 41 9761387
Society of Obstetricians and Gynaecologists of Canada. The Canadian Consensus Conference on Menopause and Osteoporosis. J Soc Obstet Gynaecol Can; 1998.
Solomon DH, Mogun H, Avorn J. HMG-CoA reductase inhibitors and the risk of hip fractures in elderly patients. JAMA. 2000;283:3211-6. [pmid: 10866868].
Sone T, Miyake M, Takeda N, et al Urinary excretion of type I collagen crosslinked N-telopeptides in healthy Japanese adults: age- and sex-related changes and reference limits Bone 1995 17(4):335 9 8573404
Sorock GS, Bush TL, Golden AL, et al Physical activity and fracture risk in a free-living elderly cohort J Gerontol 1988 43(5):M134 9 3418034
Soroko SB, Barrett-Connor E, Edelstein SL, et al Family history of osteoporosis and bone mineral density at the axial skeleton: the Rancho Bernardo Study J Bone Miner Res 1994 9(6):761 9 8079652
Sowers MF, Clark MK, Jannausch ML, et al A prospective study of bone mineral content and fracture in communities with differential fluoride exposure Am J Epidemiol 1991 133(7):649 60 2018020
Sowers MR, Clark MK, Hollis B, et al Radial bone mineral density in pre- and perimenopausal women: a prospective study of rates and risk factors for loss J Bone Miner Res 1992 7(6):647 57 1414483
Sowers MF, Kshirsagar A, Crutchfield MM, et al Joint influence of fat and lean body composition compartments on femoral bone mineral density in premenopausal women Am J Epidemiol 1992 136(3):257 65 1415147
Sowers M Pregnancy and lactation as risk factors for subsequent bone loss and osteoporosis J Bone Miner Res 1996 11(8):1052 60 8854240
Sowers M, Crutchfield M, Bandekar R, et al Bone mineral density and its change in pre-and perimenopausal white women: the Michigan Bone Health Study J Bone Miner Res 1998 13(7):1134 40 9661077
Sox HC Jr, Blatt MA, Higgins MC, et al. Medical decision making. Boston: Butterworths; 1988.
Spector TD, Edwards AC, Thompson PW Use of a risk factor and dietary calcium questionnaire in predicting bone density and subsequent bone loss at the menopause Ann Rheum Dis 1992 51(11):1252 3 1466605 1012467
Spector T, McCloskey E, Doyle D, et al Prevalence of vertebral fracture in women and the relationship with bone density and symptoms: the Chingford Study J Bone Miner Res 1993 8(7):817 22 8352064
Staessen JA, Roels HA, Emelianov D, et al Environmental exposure to cadmium, forearm bone density, and risk of fractures: prospective population study. Public Health and Environmental Exposure to Cadmium (PheeCad) Study Group Lancet 1999 353(9159):1140 4 10209978
Stall GM, Harris S, Sokoll LJ, et al Accelerated bone loss in hypothyroid patients overtreated with L-thyroxine Ann Intern Med 1990 113(4):265 9 2375563
Stegman MR, Heaney RP, Travers-Gustafson D, et al Cortical ultrasound velocity as an indicator of bone status Osteoporos Int 1995 5(5):349 53 8800785
Stegman MR, Davies KM, Heaney RP, et al The association of patellar ultrasound transmissions and forearm densitometry with vertebral fracture, number and severity: the Saunders County Bone Quality Study Osteoporos Int 1996 6(2):130 5 8704351
Steiger P, Block JE, Steiger S, et al. Spinal bone mineral density measured with quantitative CT: effect of region of interest, vertebral level, and technique. Radiology. 1990;175:537-43. [pmid: 2326479].
Steiger P, Cummings S, Black D, et al Age-related decrements in bone mineral density in women over 65 J Bone Miner Res 1992 7(6):625 32 1414480
Stevens A, Mulrow C Drugs affecting postural stability and other risk factors in the hip fracture epidemic -- case-control study Community Med 1989 11(1):27 34 2721145
Stevens JA, Powell KE, Smith SM, et al Physical activity, functional limitations, and the risk of fall-related fractures in community-dwelling elderly Ann Epidemiol 1997 7(1):54 61 9034407
Stevenson JC, Lees B, Devenport M, et al Determinants of bone density in normal women: risk factors for future osteoporosis? BMJ 1989 298(6678):924 8 2497859 1836226
Stewart A, Reid DM, Porter RW Broadband ultrasound attenuation and dual energy X-ray absorptiometry in patients with hip fractures: which technique discriminates fracture risk Calcif Tissue Int 1994 54(6):466 9 8082047
Stewart A, Torgerson D, Reid D. Prediction of fractures in perimenopausal women: a comparison of dual energy x ray absorptiometry and broadband ultrasound attenuation. Ann Rheum Dis. 1996;55:140-2. [pmid: 8712866]. [pmcid: 1010110].
Stock JL, Bell NH, Chesnut CH 3rd, et al Increments in bone mineral density of the lumbar spine and hip and suppression of bone turnover are maintained after discontinuation of alendronate in postmenopausal women Am J Med 1997 103(4):291 7 9382121
Stock JL, Waud CE, Coderre JA, et al Clinical reporting to primary care physicians leads to increased use and understanding of bone densitometry and affects the management of osteoporosis: a randomized trial Ann Intern Med 1998 128(12):996 9 9625686
Stolk RP, Van Daele PL, Pols HA, et al Hyperinsulinemia and bone mineral density in an elderly population: the Rotterdam Study [published erratum appears in Bone 1996 Nov;19(5):566] Bone 1996 18(6):545 9 8805995
Stone K, Bauer DC, Black DM, et al Hormonal predictors of bone loss in elderly women: a prospective study. The Study of Osteoporotic Fractures Research Group J Bone Miner Res 1998 13(7):1167 74 9661081
Stracke H, Renner E, Knie G, et al Osteoporosis and bone metabolic parameters in dependence upon calcium intake through milk and milk products Eur J Clin Nutr 1993 47(9):617 22 8243426
Strelitzki R, Clarke AJ, Truscott JG, et al Ultrasonic measurement: an evaluation of three heel bone scanners compared with a bench-top system Osteoporos Int 1996 6(6):471 9 9116393
Strewler GJ. Mineral metabolism and metabolic bone disease, Chapter 17. In: Greenspan FS, Strewler GJ, editors. Basic and clinical endocrinology. 5th ed. Stamford, CT: Appleton and Lange; 1997.
Studenski S, Duncan PW, Chandler J, et al Predicting falls: the role of mobility and nonphysical factors J Am Geriatr Soc 1994 42(3):297 302 8120315
Suarez-Almazor ME, Flowerdew G, Saunders LD, et al The fluoridation of drinking water and hip fracture hospitalization rates in two Canadian communities Am J Public Health 1993 83(5):689 93 8484450 1694711
Suen LK Occupation and risk of hip fracture J Public Health Med 1998 20(4):428 33 9923950
Suman V, Atkinson E, O'Fallon W, et al. A nomogram for predicting lifetime hip fracture risk from radius bone mineral density and age. Bone. 1993;14:843-6. [pmid: 8155407].
Suzuki T, Yoshida H, Hashimoto T, et al Case-control study of risk factors for hip fractures in the Japanese elderly by a Mediterranean Osteoporosis Study (MEDOS) questionnaire Bone 1997 21(5):461 7 9356741
Svendsen OL, Hassager C, Christiansen C Effect of an energy-restrictive diet, with or without exercise, on lean tissue mass, resting metabolic rate, cardiovascular risk factors, and bone in overweight postmenopausal women Am J Med 1993 95(2):131 40 8356979
Bone density measurement-a systematic review J Intern Med 1997 241(Suppl 739):1 60 9042086
Swezey RL, Adams J Fibromyalgia: a risk factor for osteoporosis J Rheumatol 1999 26(12):2642 4 10606376
Szulc P, Chapuy M, Meunier P, et al. Serum undercarboxylated osteocalcin is a marker of the risk of hip fracture in elderly women. J Clin Invest. 1993;91:1769-74. [pmcid: 288157]. [pmid: 8473517].
Szulc P, Arlot M, Chapuy MC, et al Serum undercarboxylated osteocalcin correlates with hip bone mineral density in elderly women J Bone Miner Res 1994 9(10):1591 5 7817805
Tabensky AD, Williams J, DeLuca V, et al Bone mass, areal, and volumetric bone density are equally accurate, sensitive, and specific surrogates of the breaking strength of the vertebral body: an in vitro study J Bone Miner Res 1996 11(12):1981 8 8970902
Taboulet J, Frenkian M, Frendo JL, et al Calcitonin receptor polymorphism is associated with a decreased fracture risk in post-menopausal women Hum Mol Genet 1998 7(13):2129 33 9817931
Taechakraichana N, Limpaphayom K, Ninlagarn T, et al A randomized trial of oral contraceptive and hormone replacement therapy on bone mineral density and coronary heart disease risk factors in postmenopausal women Obstet Gynecol 2000 95(1):87 94 10636509
Taga M, Uemura T, Minaguchi H The effect of hormone replacement therapy in postmenopausal women on urinary C-telopeptide and N-telopeptide of type I collagen, new markers of bone resorption J Endocrinol Invest 1998 21(3):154 9 9591210
Taggart HMA Do drugs affect the risk of hip fracture in elderly women? J Am Geriatr Soc 1988 36(11):1006 10 3171037
Taguchi A, Tanimoto K, Suei Y, et al Oral signs as indicators of possible osteoporosis in elderly women Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1995 80(5):612 6 8556469
Taguchi Y, Gorai I, Zhang MG, et al Differences in bone resorption after menopause in Japanese women with normal or low bone mineral density: quantitation of urinary cross-linked N-telopeptides Calcif Tissue Int 1998 62(5):395 9 9541516
Takada M, Grampp S, Ouyang X, et al A new trabecular region of interest for femoral dual X-ray absorptiometry: short-term precision, age-related bone loss, and fracture discrimination compared with current femoral regions of interest J Bone Miner Res 1997 12(5):832 8 9144350
Takada H, Washino K, Iwata H Risk factors for low bone mineral density among females: the effect of lean body mass Prev Med 1997 26(5 Pt 1):633 8 9327470
Takahashi M, Kushida K, Hoshino H, et al Comparison of bone and total alkaline phosphatase activity on bone turnover during menopause and in patients with established osteoporosis Clin Endocrinol 1997 47(2):177 83
Takahashi M, Kushida K, Kawana K, et al Discrimination ability of pyridinoline crosslinks related markers for bone resorption in postmenopause and osteoporosis Endocr Res 1997 23(1-2):105 17 9187542
Takahashi M, Hoshino H, Kushida K Measurements of urinary nonisomerized form of type I collagen degradation products (alpha-CTx) in aging, menopause, and osteoporosis with fractures Clin Chim Acta 1999 279(1-2):69 76 10064119
Tamai M, Yokouchi M, Komiya S, et al Correlation between vitamin D receptor genotypes and bone mineral density in Japanese patients with osteoporosis Calcif Tissue Int 1997 60(3):229 32 9069156
Tataranni PA, Pettitt DJ, Ravussin E. Dual energy X-ray absorptiometry: inter-machine variability. Int J Obes. 1996;20:1048-50.
Tavani A, Negri E, La Vecchia C Calcium, dairy products, and the risk of hip fracture in women in northern Italy Epidemiology 1995 6(5):554 7 8562636
Tavani A, Negri E, La Vecchia C Coffee intake and risk of hip fracture in women in northern Italy Prev Med 1995 24(4):396 400 7479631
Taylor TN, Chrischilles EA Economic evaluation of interventions in endocrinology Endocrinol Metab Clin North Am 1997 26(1):67 87 9074853
Thamsborg G, Jensen JE, Kollerup G, et al Effect of nasal salmon calcitonin on bone remodeling and bone mass in postmenopausal osteoporosis Bone 1996 18(2):207 12 8833216
Theobald TM, Cauley JA, Gluer CC, et al Black-white differences in hip geometry. Study of Osteoporotic Fractures Research Group Osteoporos Int 1998 8(1):61 7 9692079
Thiebaud D, Burckhardt P, Kriegbaum H, et al Three monthly intravenous injections of ibandronate in the treatment of postmenopausal osteoporosis Am J Med 1997 103(4):298 307 9382122
Thiebaud D, Burckhardt P, Costanza M, et al Importance of albumin, 25(OH)-vitamin D and IGFBP-3 as risk factors in elderly women and men with hip fracture Osteoporos Int 1997 7(5):457 62 9425504
Thompson JM, Modin GW, Arnaud CD, et al Not all postmenopausal women on chronic steroid and estrogen treatment are osteoporotic: predictors of bone mineral density Calcif Tissue Int 1997 61(5):377 81 9351878
Thompson P, Taylor J, Fisher A, et al Quantitative heel ultrasound in 3180 women between 45 and 75 years of age: compliance, normal ranges and relationship to fracture history Osteoporos Int 1998 8(3):211 4 9797904
Thorpe JA, Steel SA, Langton CM A phantom based study on the effect of subject positioning on morphometric X-ray absorptiometry using the Lunar Expert-XL Br J Radiol 1998 71(851):1153 61 10434910
Thorsen K, Kristoffersson A, Lorentzon R The effects of brisk walking on markers of bone and calcium metabolism in postmenopausal women Calcif Tissue Int 1996 58(4):221 5 8661951
Tinetti ME, Speechley M, Ginter SF Risk factors for falls among elderly persons living in the community N Engl J Med 1988 319(26):1701 7 3205267
Tobias JH, Cook DG, Chambers TJ, et al A comparison of bone mineral density between Caucasian, Asian and Afro-Caribbean women Clin Sci 1994 87(5):587 91 7874848
Tohme JF, Cosman F, Lindsay R. Osteoporosis. In: Becker KL, editor. Principles and practice of endocrinology and metabolism. Philadelphia: JB Lippincott Company; 1995.
Toogood JH, Baskerville JC, Markov AE, et al Bone mineral density and the risk of fracture in patients receiving long-term inhaled steroid therapy for asthma J Allergy Clin Immunol 1995 96(2):157 66 7636052
Torgerson DJ, Donaldson C, Russell I, et al. Hormone replacement therapy: compliance and cost after screening for osteoporosis. Eur J Obstet Gynecol Reprod Biol. 1995;59:57-60. [pmid: 7781863].
Torgerson DJ, Donaldson C, Reid DM Bone mineral density measurements: are they worth while? J R Soc Med 1996 89(8):457 61 8795500 1295888
Torgerson DJ Developing a policy on osteoporosis. Bone densitometry is worth while BMJ 1996 312(7040):1225 6 8634577
Torgerson DJ, Campbell MK, Thomas RE, et al Prediction of perimenopausal fractures by bone mineral density and other risk factors J Bone Miner Res 1996 11(2):293 7 8822354
Torgerson DJ, Thomas RE, Campbell MK, et al. Randomized trial of osteoporosis screening. Use of hormone replacement therapy and quality-of-life results. Arch Intern Med. 1997;157:2121-5. [pmid: 9382669].
Torgerson DJ Is there a future for non-menopausal screening strategies for osteoporosis prevention? Osteoporos Int 1998 8Suppl 1:S57 61 9682800
Tosteson AN, Rosenthal D, Melton LJ 3rd, et al Cost effectiveness of screening perimenopausal white women for osteoporosis: bone densitometry and hormone replacement therapy Ann Intern Med 1990 113(8):594 603 2119161
Tosteson AN Hormone replacement therapy: benefit, risk and cost considerations J Clin Pharmacol 1994 34(7):719 22 7929865
Tosteson AN Quality of life in the economic evaluation of osteoporosis prevention and treatment Spine 1997 22(24 Suppl):58S 62S 9431646
Travers-Gustafson D, Stegman MR, Heaney RP, et al Ultrasound, densitometry, and extraskeletal appendicular fracture risk factors: a cross-sectional report on the Saunders County Bone Quality Study Calcif Tissue Int 1995 57(4):267 71 8673863
Treadwell J, Lenert L Health values and prospect theory Med Decis Making 1999 19(3):344 52 10424841
TreeAge Software, Inc. DATA 3. 5 for healthcare. In: . Williamstown, MA: TreeAge Software, Inc.; 1999.
Trichopoulou A, Georgiou E, Bassiakos Y, et al Energy intake and monounsaturated fat in relation to bone mineral density among women and men in Greece Prev Med 1997 26(3):395 400 9144765
Tritos NA, Hartzband P. Rapid improvement of osteoporosis following parathyroidectomy in a premenopausal woman with acute primary hyperparathyroidism. Arch Intern Med. 1999;159:1495-8. [pmid: 10399902].
Tromp AM, Smit JH, Deeg DJ, et al Predictors for falls and fractures in the Longitudinal Aging Study Amsterdam J Bone Miner Res 1998 13(12):1932 9 9844112
Tromp AM, Smit JH, Deeg DJ, et al Quantitative ultrasound measurements of the tibia and calcaneus in comparison with DXA measurements at various skeletal sites Osteoporos Int 1999 9(3):230 5 10450412
Tsai KS, Pan WH, Hsu SH, et al Sexual differences in bone markers and bone mineral density of normal Chinese Calcif Tissue Int 1996 59(6):454 60 8939771
Tsai KS, Hsu SH, Cheng JP, et al Vitamin D stores of urban women in Taipei: effect on bone density and bone turnover, and seasonal variation Bone 1997 20(4):371 4 9108358
Tsai KS, Hsu SH, Yang RS, et al The effectiveness of cyclic and continuous oral clodronate therapy on bone density and markers in osteopenic postmenopausal women Calcif Tissue Int 1999 64(5):384 8 10203414
Tucci JR, Tonino RP, Emkey RD, et al Effect of three years of oral alendronate treatment in postmenopausal women with osteoporosis Am J Med 1996 101(5):488 501 8948272
Tuominen JT, Impivaara O, Puukka P, et al Bone mineral density in patients with type 1 and type 2 diabetes Diabetes Care 1999 22(7):1196 200 10388989
Tuppurainen M, Honkanen R, Kroger H, et al Osteoporosis risk factors, gynaecological history and fractures in perimenopausal women -- the results of the baseline postal enquiry of the Kuopio Osteoporosis Risk Factor and Prevention Study Maturitas 1993 17(2):89 100 8231907
Tuppurainen M, Kröger H, Saarikoski S, et al. The effect of previous oral contraceptive use on bone mineral density in perimenopausal women. Osteoporos Int. 1994;4:93-8. [pmid: 8003847].
Tuppurainen M, Kroger H, Honkanen R, et al Risks of perimenopausal fractures -- a prospective population-based study Acta Obstet Gynecol Scand 1995 74(8):624 8 7660769
Tuppurainen M, Kroger H, Saarikoski S, et al The effect of gynecological risk factors on lumbar and femoral bone mineral density in peri- and postmenopausal women Maturitas 1995 21(2):137 45 7752951
Turner C, Peacock M, Timmerman L, et al. Calcaneal ultrasonic measurements discriminate hip fracture independently of bone mass. Osteoporos Int. 1995;5:130-5. [pmid: 7599449].
Turner LW, Wang MQ, Fu Q Risk factors for hip fracture among southern older women South Med J 1998 91(6):533 40 9634114
Turner LW, Hunt S, Kendrick O, et al. Dairy-product intake and hip fracture among older women: issues for health behavior. Psychol Rep. 1999;85:423-30. [pmid: 10611772].
Hip fracture outcomes in people age 50 and over. Background paper. Washington, DC: U.S. Government Printing Office; 1994. Report No.: OTA-BP-H-120.
Survey of current business. Monthly reports for January 1995-August 1999. Washington, DC: U.S. Government Printing Office; 1995-1999.
Guide to clinical preventive services. 3rd ed. Baltimore: Williams & Wilkins; 1996.
United States Life Tables. 1997. http://www.cdc.gov/nchs/datawh/statab/unpubd/mortabs/lewk3.htm.
Udvarhelyi I, Colditz G, Rai A, et al. Cost-effectiveness and cost-benefit analyses in medical literature. Ann Intern Med. 1992;116:238-44. [pmid: 1530808].
Uebelhart D, Duboeuf F, Meunier PJ, et al Lateral dual-photon absorptiometry: a new technique to measure the bone mineral density at the lumbar spine J Bone Miner Res 1990 5(5):525 31 2368632
Uebelhart D, Schlemmer A, Johansen J, et al Effect of menopause and hormone replacement therapy on the urinary excretion of pyridinium cross-links J Clin Endocrinol Metab 1991 72(2):367 73 1991806
Uitterlinden AG, Pols HA, Burger H, et al A large-scale population-based study of the association of vitamin D receptor gene polymorphisms with bone mineral density J Bone Miner Res 1996 11(9):1241 8 8864898
Uitterlinden AG, Burger H, Huang Q, et al Relation of alleles of the collagen type Ialpha1 gene to bone density and the risk of osteoporotic fractures in postmenopausal women N Engl J Med 1998 338(15):1016 21 9535665
Ulrich CM, Georgiou CC, Snow-Harter CM, et al Bone mineral density in mother-daughter pairs: relations to lifetime exercise, lifetime milk consumption, and calcium supplements Am J Clin Nutr 1996 63(1):72 9 8604673
Ultrasound units make densitometry cheaper and more accessible to PCPs. Diagn Imaging (San Franc) 1998 Nov; Suppl Bone Mass:3-4.
University of California at San Diego Medical Group. Osteoporosis guideline. San Diego; 1998.
Utiger RD Treatment of primary hyperparathyroidism N Engl J Med 1999 341(17):1301 2 10528042
Uusi-Rasi K, Sievanen H, Vuori I, et al Long-term recreational gymnastics, estrogen use, and selected risk factors for osteoporotic fractures J Bone Miner Res 1999 14(7):1231 8 10404026
Valente M, Bufalino L, Castiglione GN, et al Effects of 1-year treatment with ipriflavone on bone in postmenopausal women with low bone mass Calcif Tissue Int 1994 54(5):377 80 8062153
van Berkum FN, Birkenhager JC, van Veen LC, et al Noninvasive axial and peripheral assessment of bone mineral content: a comparison between osteoporotic women and normal subjects J Bone Miner Res 1989 4(5):679 85 2816513
van Daele PLA, Burger H, Algra D, et al Age-associated changes in ultrasound measurements of the calcaneus in men and women: the Rotterdam Study J Bone Miner Res 1994 9(11):1751 7 7863827
van Daele PLA, Seibel MJ, Burger H, et al Evidence for uncoupling of bone formation and bone resorption in women with hip fractures: a prospective study Osteoporos Int 1996 6(Suppl 1):
van Daele PLA, Seibel MJ, Burger H, et al. Case-control analysis of bone resorption markers, disability, and hip fracture risk: the Rotterdam study. BMJ. 1996;312:482-3. [pmid: 8597681].
van Daele PL, Burger H, de Laet CE, et al. Longitudinal changes in ultrasound parameters of the calcaneus. Osteoporos Int. 1997;7:207-12. [pmid: 9205632].
van Hemert AM, Birkenhager JC, De Jong FH, et al Sex hormone binding globulin in postmenopausal women: a predictor of osteoporosis superior to endogenous oestrogens Clin Endocrinol 1989 31(4):499 509
van Hemert AM, Vandenbroucke JP, Birkenhager JC, et al Prediction of osteoporotic fractures in the general population by a fracture risk score. A 9-year follow-up among middle-aged women Am J Epidemiol 1990 132(1):123 35 2192546
Varenna M, Binelli L, Zucchi F, et al Is the metatarsal fracture in postmenopausal women an osteoporotic fracture? A cross-sectional study on 113 cases Osteoporos Int 1997 7(6):558 63 9604052
Varenna M, Binelli L, Zucchi F, et al Prevalence of osteoporosis by educational level in a cohort of postmenopausal women Osteoporos Int 1999 9(3):236 41 10450413
Varney LF, Parker RA, Vincelette A, et al Classification of osteoporosis and osteopenia in postmenopausal women is dependent on site-specific analysis J Clin Densitomet 1999 2(3):275 83
Vasikaran SD, Khan S, McCloskey EV, et al Sustained response to intravenous alendronate in postmenopausal osteoporosis Bone 1995 17(6):517 20 8835304
Vecht-Hart CM, Zwamborn AW, Peeters PH, et al Prediction of peripheral fracture risk by quantitative microdensitometry Prev Med 1997 26(1):86 91 9010902
Vergnaud P, Garnero P, Meunier PJ, et al. Undercarboxylated osteocalcin measured with a specific immunoassay predicts hip fracture in elderly women: the EPIDOS study. J Clin Endocrinol Metab. 1997;82:719-24. [pmid: 9062471].
Verhaar HJ, Koele JJ, Neijzen T, et al Are arm span measurements useful in the prediction of osteoporosis in postmenopausal women? Osteoporos Int 1998 8(2):174 6 9666942
Verhoeven AC, Boers M Limited bone loss due to corticosteroids; a systematic review of prospective studies in rheumatoid arthritis and other diseases J Rheumatol 1997 24(8):1495 503 9263141
Vico L, Prallet B, Chappard D, et al. Contributions of chronological age, age at menarche and menopause and of anthropometric parameters to axial and peripheral bone. Osteoporos Int. 1992;2:153-8. [pmid: 1627903].
Villa ML, Marcus R, Ramirez Delay R, et al Factors contributing to skeletal health of postmenopausal Mexican-American women J Bone Miner Res 1995 10(8):1233 42 8585428
Visentin P, Ciravegna R, Uscello L, et al Site-specific relative risk of fractures in the institutionalized elderly Gerontology 1995 41(5):273 9 8537011
von Mühlen D, Visby Lunde A, Barrett-Connor E, et al. Evaluation of the simple calculated osteoporosis risk estimation (SCORE) in older Caucasian women: the Rancho Bernardo study. Osteoporos Int. 1999;10:79-84. [pmid: 10501784].
Wahner HW, Looker A, Dunn WL, et al Quality control of bone densitometry in a national health survey (NHANES III) using three mobile examination centers J Bone Miner Res 1994 9(6):951 60 8079669
Walker AM Confounding by indication Epidemiology 1996 7(4):335 6 8793355
Walker AM, Stampfer MJ. Observational studies of drug safety. Lancet. 1996;348.
Walsh LJ, Wong CA, Pringle M, et al Use of oral corticosteroids in the community and the prevention of secondary osteoporosis: a cross sectional study BMJ 1996 313(7053):344 6 8760745
Wang PS, Solomon DH, Mogun H, et al. HMG-CoA reductase inhibitors and the risk of hip fractures in elderly patients. JAMA. 2000;283:3211-6. [pmid: 10866868].
Wardlaw GM Putting body weight and osteoporosis into perspective Am J Clin Nutr 1996 63(3 Suppl):433S 6S 8615336
Wasnich RD, Ross PD, Heilbrun L, et al Prediction of postmenopausal fracture risk with use of bone mineral measurements Am J Obstet Gynecol 1985 153(7):745 51 4073139
Wasnich RD, Ross PD, Heilburn LK, et al. Selection of the optimal skeletal site for fracture risk protection. Clin Orthop. 1987;216:262-9. [pmid: 3815956].
Wasnich RD, Ross PD, Davies J, et al A comparison of single and multi-site BMC measurements for assessment of spine fracture probability J Nucl Med 1989 30(7):1166 71 2738698
Wasnich RD Bone mass measurement: prediction of risk Am J Med 1993 95(5A):6S 10S 8256798
Wasnich RD, Davis JW, Ross PD Spine fracture risk is predicted by non-spine fractures Osteoporos Int 1994 4(1):1 5
Wasnich RD A new, standardized approach to fracture risk interpretation Hawaii Med J 1996 55(8):141 3 8823998
Wasnich RD Consensus and the T-score fallacy Clin Rheumatol 1997 16(4):337 9 9259244
Wasnich RD, Ross PD, Thompson DE, et al Skeletal benefits of two years of alendronate treatment are similar for early postmenopausal Asian and Caucasian women Osteoporos Int 1999 9(5):455 60 10550466
Weinstein R, New K, Sappington LJ. Dual-energy X-ray absorptiometry versus single photon absorptiometry of the radius. Calcif Tissue Int. 1991;49:313-6. [pmid: 1782572].
Weiss NS, Ure CL, Ballard JH, et al Decreased risk of fractures of the hip and lower forearm with postmenopausal use of estrogen N Engl J Med 1980 303(21):1195 8 7421945
Weiss SR, Ellman H, Dolker M A randomized controlled trial of four doses of transdermal estradiol for preventing postmenopausal bone loss. Transdermal Estradiol Investigator Group Obstet Gynecol 1999 94(3):330 6 10472854
Wheadon M, Goulding A, Barbezat GO, et al Lactose malabsorption and calcium intake as risk factors for osteoporosis in elderly New Zealand women N Z Med J 1991 104(921):417 9 1923091
Whittington R, Faulds D Hormone replacement therapy: II. A pharmacoeconomic appraisal of its role in the prevention of postmenopausal osteoporosis and ischaemic heart disease Pharmacoeconomics 1994 5(6):513 54 10147266
Who are candidates for prevention and treatment for osteoporosis? Osteoporos Int 1997 7(1):1 6
Whooley MA, Kip KE, Cauley JA, et al Depression, falls, and risk of fracture in older women. Study of Osteoporotic Fractures Research Group Arch Intern Med 1999 159(5):484 90 10074957
Wickham CA, Walsh K, Cooper C, et al Dietary calcium, physical activity, and risk of hip fracture: a prospective study BMJ 1989 299(6704):889 92 2510879 1837771
Williams AR, Weiss NS, Ure CL, et al Effect of weight, smoking, and estrogen use on the risk of hip and forearm fractures in postmenopausal women Obstet Gynecol 1982 60(6):695 9 7145267
Wimalawansa SJ. A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med. 1998;104:219-26. [pmid: 9552083].
Winner S, Morgan C, Evans JG. Perimenopausal risk of falling and incidence of distal forearm fracture. BMJ. 1989;298:1486-8. [pmid: 2503081]. [pmcid: 1836686].
Wolinsky FD, Fitzgerald JF The risk of hip fracture among noninstitutionalized older adults J Gerontol 1994 49(4):S165 75 8014400
Wootton R, Bryson E, Elsasser U, et al Risk factors for fractured neck of femur in the elderly Age Ageing 1982 11(3):160 8 7124555
Assessment of fracture risk and its application to screening for postmenopausal osteoporosis. WHO Technical Report Series 843. Geneva: World Health Organization; 1994.
Worsfold M, Davie MW, Haddaway MJ Age-related changes in body composition, hydroxyproline, and creatinine excretion in normal women Calcif Tissue Int 1999 64(1):40 4 9868282
Wyshak G Hip fracture in elderly women and reproductive history J Gerontol 1981 36(4):424 7 7252073
Wyshak G, Frisch RE, Albright TE, et al Bone fractures among former college athletes compared with nonathletes in the menopausal and postmenopausal years Obstet Gynecol 1987 69(1):121 6 3796912
Wysowski DK, Baum C, Ferguson WJ, et al Sedative-hypnotic drugs and the risk of hip fracture J Clin Epidemiol 1996 49(1):111 3 8598503
Yaffe K, Browner W, Cauley J, et al Association between bone mineral density and cognitive decline in older women J Am Geriatr Soc 1999 47(10):1176 82 10522949
Yamaguchi J, Truman G, Cameron ID. Lifestyle factors affecting bone ultrasonometry of the calcaneus in Japanese women. Calcif Tissue Int. 2000;66:43-6. [pmid: 10602843].
Yamamoto K, Nakamura T, Kishimoto H, et al Risk factors for hip fracture in elderly Japanese women in Tottori Prefecture, Japan Osteoporos Int 1993 3(Suppl 1):48 50 8461576
Yamamoto A, Kishimoto H, Katagiri H. Clinical and experimental studies of quantitative ultrasound measurement in the os calcis: prevalence and incidence of vertebral fracture. J Orthop Sci. 1997;2:64-74.
Yamazaki K, Kushida K, Ohmura A, et al Ultrasound bone densitometry of the os calcis in Japanese women Osteoporos Int 1994 4(4):220 5 7949752
Yang R-S, Wang S-S, Liu T-K. Proximal femoral dimension in elderly Chinese women with hip fractures in Taiwan. Osteoporos Int. 1999;10:109-13. [pmid: 10501789].
Yeap SS, Beaumont M, Bennett A, et al Genetic and environmental factors affecting bone mineral density in large families Postgrad Med J 1998 74(872):349 54 9799889
Yoshimura N, Hashimoto T, Morioka S, et al Determinants of bone loss in a rural Japanese community: the Taiji Study Osteoporos Int 1998 8(6):604 10 10326068
Yoshimura N, Hashimoto T, Sakata K, et al Biochemical markers of bone turnover and bone loss at the lumbar spine and femoral neck: the Taiji study Calcif Tissue Int 1999 65(3):198 202 10441650
Young H, Howey S, Purdie DW Broadband ultrasound attenuation compared with dual-energy X-ray absorptiometry in screening for postmenopausal low bone density Osteoporos Int 1993 3(3):160 4 8481593
Zaninotto M, Bernardi D, Ujka F, et al A proposal for standardizing urine collections for bone resorption markers measurement J Clin Lab Anal 1998 12(3):145 9 9591700
Zerwekh JE, Padalino P, Pak CY The effect of intermittent slow-release sodium fluoride and continuous calcium citrate therapy on calcitropic hormones, biochemical markers of bone metabolism, and blood chemistry in postmenopausal osteoporosis Calcif Tissue Int 1997 61(4):272 8 9312196
Zethraeus N, Stromberg L, Jonsson B, et al The cost of hip fracture Acta Orthop Scand 1997 68(1):13 7 9057561
Zethraeus N, Gerdtham UG Estimating the costs of hip fracture and potential savings Int J Technol Assess Health Care 1998 14(2):255 67 9611901
Zhan Z, Yamamoto I, Morita R, et al Urinary pyridinoline and deoxypyridinoline as bone metabolic markers in predicting therapeutic effects of estrogen and alfacalcidol in women with osteoporosis J Bone Miner Metabol 1999 17(2):113 8
Zhang J, Feldblum PJ, Fortney JA Moderate physical activity and bone density among perimenopausal women Am J Public Health 1992 82(5):736 8 1566956 1694153
Zimmermann CL, Smidt GL, Brooks JS, et al Relationship of extremity muscle torque and bone mineral density in postmenopausal women Phys Ther 1990 70(5):302 9 2333328
Zmuda JM, Cauley JA, Ferrell RE Recent progress in understanding the genetic susceptibility to osteoporosis Genet Epidemiol 1999 16(4):356 67 10207717
Zofkova I, Kancheva RL, Bendlova B Effect of 1,25(OH)2 vitamin D3 on circulating insulin-like growth factor-I and beta 2 microglobulin in patients with osteoporosis Calcif Tissue Int 1997 60(3):236 9 9069158
Zylstra S, Hopkins A, Erk M, et al. Effect of physical activity on lumbar spine and femoral neck bone densities. Int J Sports Med. 1989;10:181-6. [pmid: 2777437].