# References

1 Diagnosis, prophylaxis and treatment of osteoporosis. Am J Med. 1991;90:107-10. [pmid: 1986575].
2 Diagnosis, prophylaxis and treatment of osteoporosis. Am J Med. 1993;94:646-50. [pmid: 8506892].
3 Assessment of fracture risk and its application to screening for postmenopausal osteoporosis. WHO Technical Report Series 843. Geneva: World Health Organization; 1994.
4 Kanis JA Assessment of fracture risk and its application to screening for postmenopausal osteoporosis: synopsis of a WHO report Osteoporos Int 1994 4(6):368 81 7696835
5 Sandor T, Felsenberg D, Brown E Comments on the hypotheses underlying fracture risk assessment in osteoporosis as proposed by the World Health Organization Calcif Tissue Int 1999 64(3):267 70 10024389
6 Marcus R., Holloway L, Wells B, et al The relationship of biochemical markers of bone turnover to bone density changes in postmenopausal women: results from the Postmenopausal Estrogen/Progestin Interventions (PEPI) trial J Bone Miner Res 1999 14(9):1583 95 10469288
7 Wasnich RD Consensus and the T-score fallacy Clin Rheumatol 1997 16(4):337 9 9259244
8 National Osteoporosis Foundation Osteoporosis: review of the evidence for prevention, diagnosis, and treatment and cost-effectiveness analysis Osteoporos Int 1998 8Suppl 4:S7 80
9 Black DM, Palermo L, Genant HK, et al Four reasons to avoid the use of BMD T-scores in treatment decisions for osteoporosis J Bone Miner Res 1996 11(Suppl 1):
10 Faulkner KG, von Stetten E, Miller P Discordance in patient classification using T-scores J Clin Densitomet 1999 2(3):343 50
11 Marcus R Clinical review 76: the nature of osteoporosis J Clin Endocrinol Metab 1996 81(1):1 5 8550734
12 Abbott TA 3rd, Mucha L, Manfredonia D, et al Efficient patient identification strategies for women with osteoporosis J Clin Densitomet 1999 2(3):223 30
13 Kanis JA, Gluer CC An update on the diagnosis and assessment of osteoporosis with densitometry Osteoporos Int 2000 11(3):192 202 10824234
14 Looker AC, Orwoll ES, Johnston CC Jr., et al Prevalence of low femoral bone density in older US adults from NHANES III J Bone Miner Res 1997 12(11):1761 8 9383679
15 Looker AC, Wahner LW, Dunn WL, et al Updated data on proximal femur bone mineral levels of US adults Osteoporos Int 1998 8(5):468 89 9850356
16 Melton LJ 3rd How many women have osteoporosis now? J Bone Miner Res 1995 10(2):175 7 7754796
17 Heaney RP Bone mass, bone loss, and osteoporosis prophylaxis Ann Intern Med 1998 128(4):313 4 9471936
18 Melton LJ 3rd, Atkinson EJ, O'Connor MK, et al Bone density and fracture risk in men J Bone Miner Res 1998 13(12):1915 23 9844110
19 Farmer ME, White LR, Brody JA, et al Race and sex differences in hip fracture incidence Am J Public Health 1984 74(12):1374 80 6507690 1652702
20 Melton LJ 3rd, Amadio PC, Crowson CS, et al. Long-term trends in the incidence of distal forearm fractures. Osteoporos Int. 1998;8:341-8. [pmid: 10024904].
21 Melton LJ 3rd, Kan SH, Frye MA, et al Epidemiology of vertebral fractures in women Am J Epidemiol 1989 129(5):1000 11 2784934
22 Melton LJ 3rd Epidemiology of spinal osteoporosis Spine 1997 22(24 Suppl):2S 11S 9431638
23 Jacobsen SJ, Cooper C, Gottlieb MS, et al Hospitalization with vertebral fracture among the aged: a national population-based study,1986-1989 Epidemiology 1992 3(6):515 8 1420517
24 Gold DT The clinical impact of vertebral fractures: quality of life in women with osteoporosis Bone 1996 18(Suppl 3):S185 S9
25 Nevitt MC, Ettinger B, Black DM, et al The association of radiographically detected vertebral fractures with back pain and function: a prospective study Ann Intern Med 1998 128(10):793 800 9599190
26 Chrischilles EA, Butler CD, Davis CS, et al A model of lifetime osteoporosis impact Arch Intern Med 1991 151(10):2026 32 1929691
27 Cook DJ, Guyatt GH, Adachi JD, et al Quality of life issues in women with vertebral fractures due to osteoporosis Arthritis Rheum 1993 36(6):750 6 8507215
28 Chander JM, Martin AR, Girman C, et al. Reliability of an osteoporosis-targeted quality of life survey instrument for use in the community: OPT-QoL. Osteoporos Int. 1998;8:127-35. [pmid: 9666935].
29 Lyles KW, Gold DW, Shipp KM, et al. Association of osteoporotic vertebral fractures with impaired functional status. Am J Med. 1993;94:595-601. [pmid: 8506884].
30 Ray NF, Chan JK, Thamer M, et al Medical expenditures for the treatment of osteoporotic fractures in the United States in 1995: report from the National Osteoporosis Foundation J Bone Miner Res 1997 12(1):24 35 9240722
31 Rosner AJ, Grima DT, Torrance GW, et al Cost effectiveness of multi-therapy treatment strategies in the prevention of vertebral fractures in postmenopausal women with osteoporosis Pharmacoeconomics 1998 14(5):559 73 10344918
32 Abbott TA, Lawrence BJ, Wallach S Osteoporosis: the need for comprehensive treatment guidelines Clin Ther 1996 18(1):127 49 8851459
33 Blake GM, Gluer CC, Fogelman I. Bone densitometry: current status and future prospects. Br J Radiol. 1997;70. Spec No:S177-86.
34 Blake GM, Fogelman I Applications of bone densitometry for osteoporosis Endocrinol Metab Clin North Am 1998 27(2):267 88 9669138
35 Genant HK, Engelke K, Fuerst T, et al Noninvasive assessment of bone mineral and structure: state of the art J Bone Miner Res 1996 11(6):707 30 8725168
36 Jergas M, Genant HK Spinal and femoral DXA for the assessment of spinal osteoporosis Calcif Tissue Int 1997 61(5):351 7 9351874
37 Cameron JR, Sorenson J. Measurement of bone mineral in vivo: an improved method. Science. 1963;142:230-2. [pmid: 14057368].
38 Langton CM, Palmer SB, Porter RW The measurement of broadband ultrasonic attenuation in cancellous bone Eng Med 1984 13(2):89 91 6540216
39 Lochmuller EM, Eckstein F, Kaiser D, et al Prediction of vertebral failure loads from spinal and femoral dual-energy X-ray absorptiometry, and calcaneal ultrasound: an in situ analysis with intact soft tissues Bone 1998 23(5):417 24 9823447
40 Bouxsein ML, Radloff SE Quantitative ultrasound of the calcaneus reflects the mechanical properties of calcaneal trabecular bone J Bone Miner Res 1997 12(5):839 46 9144351
41 Bouxsein ML, Coan BS, Lee SC Prediction of the strength of the elderly proximal femur by bone mineral density and quantitative ultrasound measurements of the heel and tibia Bone 1999 25(1):49 54 10423021
42 Lochmuller EM, Zeller JB, Kaiser D, et al Correlation of femoral and lumbar DXA and calcaneal ultrasound, measured in situ with intact soft tissues, with the in vitro failure loads of the proximal femur Osteoporos Int 1998 8(6):591 8 10326066
43 Nicholson PHF, Muller R, Lowet G, et al Do quantitative ultrasound measurements reflect structure independently of density in human vertebral cancellous bone? Bone 1998 23(5):425 31 9823448
44 Cummings SR, Black DM, Nevitt MC, et al. Bone density at various sites for prediction of hip fractures. Lancet. 1993;341:72-5. [pmid: 8093403].
45 Huang C, Ross PD, Yates AJ, et al Prediction of fracture risk by radiographic absorptiometry and quantitative ultrasound: a prospective study Calcif Tissue Int 1998 63(5):380 4 9799821
46 Langton CM, Ballard PA, Bennett DK, et al A comparison of the sensitivity and specificity of calcaneal ultrasound measurements with clinical criteria for bone densitometry (DEXA) referral Clin Rheumatol 1997 16(1):117 8 9132320
47 Richmond BJ Enthusiasm for ultrasound for osteoporosis screening is premature Cleve Clin J Med 1998 65(8):403 4 9769560
48 Cummings SR Prevention of hip fractures in older women: a population-based perspective Osteoporos Int 1998 8Suppl 1:S8 12 9682790
49 Marshall D, Johnell O, Wedel H. Meta-analysis of how well measures of bone mineral density predict occurrence of osteoporotic fractures. BMJ. 1996;312:1254-9. [pmid: 8634613].
50 Hui SL, Slemenda CW, Carey MA, et al Choosing between predictors of fractures J Bone Miner Res 1995 10(11):1816 22 8592960
51 Sackett DL, Richardson WS, Rosenberg W, et al. Evidence-based medicine; how to practice and teach EBM. Edinburgh: Churchill Livingstone; 1998.
52 Udvarhelyi I, Colditz G, Rai A, et al. Cost-effectiveness and cost-benefit analyses in medical literature. Ann Intern Med. 1992;116:238-44. [pmid: 1530808].
53 Gold MR, Siegel JE, Russell LB, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
54 Cummings SR, Nevitt MC, Browner WS, et al Risk factors for hip fracture in white women. Study of Osteoporotic Fractures Research Group N Engl J Med 1995 332(12):767 73 7862179
55 Dargent-Molina P, Favier F, Grandjean H, et al Fall-related factors and risk of hip fracture: the EPIDOS prospective study Lancet 1996 348(9021):145 9 8684153
56 Dargent-Molina P, Schott AM, Hans D, et al Separate and combined value of bone mass and gait speed measurements in screening for hip fracture risk: results from the EPIDOS study. Epidemiologie de l'Osteoporose Osteoporos Int 1999 9(2):188 92 10367048
57 Porter RW, Miller CG, Grainger D, et al Prediction of hip fracture in elderly women: a prospective study BMJ 1990 301(6753):638 41 2224217 1663899
58 Graafmans WC, Ooms ME, Bezemer PD, et al Different risk profiles for hip fractures and distal forearm fractures: a prospective study Osteoporos Int 1996 6(6):427 31 9116386
59 Seeley DG, Kelsey J, Jergas M, et al Predictors of ankle and foot fractures in older women. The Study of Osteoporotic Fractures Research Group J Bone Miner Res 1996 11(9):1347 55 8864910
60 Honkanen R, Tuppurainen M, Kroger H, et al Relationships between risk factors and fractures differ by type of fracture: a population-based study of 12,192 perimenopausal women Osteoporos Int 1998 8(1):25 31 9692074
61 Mallmin H, Ljunghall S, Persson I, et al Risk factors for fractures of the distal forearm: a population-based case-control study Osteoporos Int 1994 4(6):298 304 7696821
62 Tuppurainen M, Kroger H, Honkanen R, et al Risks of perimenopausal fractures--a prospective population-based study Acta Obstet Gynecol Scand 1995 74(8):624 8 7660769
63 Cooper C, Shah S, Hand DJ, et al. Screening for vertebral osteoporosis using individual risk factors. Osteoporos Int. 1991;2:48-53. [pmid: 1790421].
64 Orwoll ES, Bauer DC, Vogt TM, et al Axial bone mass in older women Ann Intern Med 1996 124(2):187 96 8533993
65 Bauer DC, Browner WS, Cauley JA, et al Factors associated with appendicular bone mass in older women. The Study of Osteoporotic Fractures Research Group Ann Intern Med 1993 118(9):657 65 8460853
66 Aloia JF, Vaswani A, Yeh JK, et al Risk for osteoporosis in black women Calcif Tissue Int 1996 59(6):415 23 8939764
67 Tobias JH, Cook DG, Chambers TJ, et al A comparison of bone mineral density between Caucasian, Asian and Afro-Caribbean women Clin Sci 1994 87(5):587 91 7874848
68 Evers SE, Orchard JW, Haddad RG Bone density in postmenopausal North American Indian and Caucasian females Hum Biol 1985 57(4):719 26 4086025
69 Bauer RL Ethnic differences in hip fracture: a reduced incidence in Mexican Americans Am J Epidemiol 1988 127(1):145 9 3337072
70 Nakamura T, Turner CH, Yoshikawa T, et al Do variations in hip geometry explain differences in hip fracture risk between Japanese and white Americans? J Bone Miner Res 1994 9(7):1071 6 7942154
71 Grisso JA, Kelsey JL, Strom BL, et al Risk factors for hip fracture in black women. The Northeast Hip Fracture Study Group N Engl J Med 1994 330(22):1555 9 8177244
72 Fujiwara S, Kasagi F, Yamada M, et al Risk factors for hip fracture in a Japanese cohort J Bone Miner Res 1997 12(7):998 1004 9199997
73 Suzuki T, Yoshida H, Hashimoto T, et al Case-control study of risk factors for hip fractures in the Japanese elderly by a Mediterranean Osteoporosis Study (MEDOS) questionnaire Bone 1997 21(5):461 7 9356741
74 Gunnes M, Lehmann EH, Mellstrom D, et al The relationship between anthropometric measurements and fractures in women Bone 1996 19(4):407 13 8894148
75 Hemenway D, Feskanich D, Colditz GA Body height and hip fracture: a cohort study of 90,000 women Int J Epidemiol 1995 24(4):783 6 8550276
76 Joakimsen RM, Fonnebo V, Magnus JH, et al The Tromso Study: body height, body mass index and fractures Osteoporos Int 1998 8(5):436 42 9850351
77 Meyer HE, Tverdal A, Falch JA Risk factors for hip fracture in middle-aged Norwegian women and men Am J Epidemiol 1993 137(11):1203 11 8322761
78 Hunt AH The relationship between height change and bone mineral density Orthopaedic Nursing 1996 15(3):57 64; quiz 5-6 8788647
79 Ravn P, Cizza G, Bjarnason NH, et al Low body mass index is an important risk factor for low bone mass and increased bone loss in early postmenopausal women. Early Postmenopausal Intervention Cohort (EPIC) study group J Bone Miner Res 1999 14(9):1622 7 10469292
80 Albala C, Yanez M, Devoto E, et al Obesity as a protective factor for postmenopausal osteoporosis Int J Obes Relat Metab Disord 1996 20(11):1027 32 8923160
81 Chen Z, Lohman TG, Stini WA, et al Fat or lean tissue mass: which one is the major determinant of bone mineral mass in healthy postmenopausal women? J Bone Miner Res 1997 12(1):144 51 9240737
82 Khosla S, Atkinson EJ, Riggs BL, et al Relationship between body composition and bone mass in women J Bone Miner Res 1996 11(6):857 63 8725184
83 Michaelsson K, Bergstrom R, Mallmin H, et al Screening for osteopenia and osteoporosis: selection by body composition Osteoporos Int 1996 6(2):120 6 8704349
84 Marone MM, Gouveia CH, Lewin S, et al Influence of body composition on the bone mass of postmenopausal women Rev Paul Med 1997 115(6):1580 8
85 Takada H, Washino K, Iwata H Risk factors for low bone mineral density among females: the effect of lean body mass Prev Med 1997 26(5 Pt 1):633 8 9327470
86 Meyer HE, Tverdal A, Falch JA Body height, body mass index, and fatal hip fractures: 16 years' follow-up of 674,000 Norwegian women and men Epidemiology 1995 6(3):299 305 7619940
87 Johnell O, O'Neill T, Felsenberg D, et al Anthropometric measurements and vertebral deformities. European Vertebral Osteoporosis Study (EVOS) Group Am J Epidemiol 1997 146(4):287 93 9270407
88 Wolinsky FD, Fitzgerald JF The risk of hip fracture among noninstitutionalized older adults J Gerontol 1994 49(4):S165 75 8014400
89 Grisso JA, Kelsey JL, Strom BL, et al Risk factors for falls as a cause of hip fracture in women. The Northeast Hip Fracture Study Group N Engl J Med 1991 324(19):1326 31 2017229
90 Bernstein J, Grisso JA, Kaplan FS Body mass and fracture risk. A study of 330 patients Clin Orthop 1999(364):227 30
91 Ensrud KE, Cauley J, Lipschutz R, et al Weight change and fractures in older women. Study of Osteoporotic Fractures Research Group Arch Intern Med 1997 157(8):857 63 9129545
92 Meyer HE, Tverdal A, Falch JA Changes in body weight and incidence of hip fracture among middle aged Norwegians BMJ 1995 311(6997):91 2 7613409
93 French SA, Folsom AR, Jeffery RW, et al Weight variability and incident disease in older women: the Iowa Women's Health Study Int J Obes Relat Metab Disord 1997 21(3):217 23 9080261
94 Meyer HE, Tverdal A, Selmer R Weight variability, weight change and the incidence of hip fracture: a prospective study of 39,000 middle-aged Norwegians Osteoporos Int 1998 8(4):373 8 10024908
95 Langlois JA, Harris T, Looker AC, et al Weight change between age 50 years and old age is associated with risk of hip fracture in white women aged 67 years and older Arch Intern Med 1996 156(9):989 94 8624179
96 Pruzansky ME, Turano M, Luckey M, et al Low body weight as a risk factor for hip fracture in both black and white women J Orthop Res 1989 7(2):192 7 2918419
97 Soroko SB, Barrett-Connor E, Edelstein SL, et al Family history of osteoporosis and bone mineral density at the axial skeleton: the Rancho Bernardo Study J Bone Miner Res 1994 9(6):761 9 8079652
98 Grainge MJ, Coupland CA, Cliffe SJ, et al Association between a family history of fractures and bone mineral density in early postmenopausal women Bone 1999 24(5):507 12 10321911
99 Fox KM, Cummings SR, Powell-Threets K, et al Family history and risk of osteoporotic fracture. Study of Osteoporotic Fractures Research Group Osteoporos Int 1998 8(6):557 62 10326061
100 Seeman E, Hopper J, Bach L, et al Reduced bone mass in daughters of women with osteoporosis N Engl J Med 1989 320(9):554 8 2915666
101 Barthe N, Basse-Cathalinat B, Meunier PJ, et al Measurement of bone mineral density in mother-daughter pairs for evaluating the family influence on bone mass acquisition: a GRIO survey Osteoporos Int 1998 8(4):379 84 10024909
102 Danielson ME, Cauley JA, Baker CE, et al Familial resemblance of bone mineral density (BMD) and calcaneal ultrasound attenuation: the BMD in mothers and daughters study J Bone Miner Res 1999 14(1):102 10 9893071
103 Hansen MA, Hassager C, Jensen SB, et al Is heritability a risk factor for postmenopausal osteoporosis? J Bone Miner Res 1992 7(9):1037 43 1414496
104 Pocock NA, Eisman JA, Hopper JL, et al. Genetic determinants of bone mass in adults: a twin study. J Clin Invest. 1987;80:706-10. [pmcid: 442294]. [pmid: 3624485].
105 Arden NK, Baker J, Hogg C, et al The heritability of bone mineral density, ultrasound of the calcaneus and hip axis length: a study of postmenopausal twins J Bone Miner Res 1996 11(4):530 4 8992884
106 Slemenda CW, Turner CH, Peacock M, et al The genetics of proximal femur geometry, distribution of bone mass and bone mineral density Osteoporos Int 1996 6(2):178 82 8704359
107 Black DM, Arden NK, Palermo L, et al Prevalent vertebral deformities predict hip fractures and new vertebral deformities but not wrist fractures. Study of Osteoporotic Fractures Research Group J Bone Miner Res 1999 14(5):821 8 10320531
108 Davis JW, Grove JS, Wasnich RD, et al Spatial relationships between prevalent and incident spine fractures Bone 1999 24(3):261 4 10071920
109 Ross PD, Davis JW, Epstein RS, et al Pre-existing fractures and bone mass predict vertebral fracture incidence in women Ann Intern Med 1991 114(11):919 23 2024857
110 Ross PD, Genant HK, Davis JW, et al Predicting vertebral fracture incidence from prevalent fractures and bone density among non-black, osteoporotic women Osteoporos Int 1993 3(3):120 6 8481587
111 Wasnich RD, Davis JW, Ross PD Spine fracture risk is predicted by non-spine fractures Osteoporos Int 1994 4(1):1 5
112 Lauritzen JB, Schwarz P, McNair P, et al Radial and humeral fractures as predictors of subsequent hip, radial or humeral fractures in women, and their seasonal variation Osteoporos Int 1993 3(3):133 7 8481589
113 Mallmin H, Ljunghall S, Persson I, et al Fracture of the distal forearm as a forecaster of subsequent hip fracture: a population-based cohort study with 24 years of follow-up Calcif Tissue Int 1993 52(4):269 72 8467406
114 Finsen V, Benum P Colles' fracture as an indicator of increased risk of hip fracture. An epidemiological study Ann Chir Gynaecol 1987 76(2):114 8 3497604
115 Cuddihy MT, Gabriel SE, Crowson CS, et al. Forearm fractures as predictors of subsequent osteoporotic fractures. Osteoporos Int. 1999;9:469-75. [pmid: 10624452].
116 Honkanen R, Tuppurainen M, Kroger H, et al Associations of early premenopausal fractures with subsequent fractures vary by sites and mechanisms of fractures Calcif Tissue Int 1997 60(4):327 31 9075627
117 Gunnes M, Mellstrom D, Johnell O How well can a previous fracture indicate a new fracture? A questionnaire study of 29,802 postmenopausal women Acta Orthop Scand 1998 69(5):508 12 9855234
118 Burger H, van Daele PL, Algra D, et al Vertebral deformities as predictors of non-vertebral fractures BMJ 1994 309(6960):991 2 7950721
119 Karlsson MK, Hasserius R, Obrant KJ Individuals who sustain nonosteoporotic fractures continue to also sustain fragility fractures Calcif Tissue Int 1993 53(4):229 31 8275349
120 Lauritzen JB, Lund B Risk of hip fracture after osteoporosis fractures. 451 women with fracture of lumbar spine, olecranon, knee or ankle Acta Orthop Scand 1993 64(3):297 300 8322584
121 Ribot C, Tremollieres F, Pouilles JM, et al Risk factors for hip fracture. MEDOS study: results of the Toulouse Centre Bone 1993 14Suppl 1:S77 80 8110526
122 Law MR, Hackshaw AK A meta-analysis of cigarette smoking, bone mineral density and risk of hip fracture: recognition of a major effect BMJ 1997 315(7112):841 6 9353503
123 Hopper JL, Seeman E The bone density of female twins discordant for tobacco use N Engl J Med 1994 330(6):387 92 8284003
124 Cornuz J, Feskanich D, Willett WC, et al Smoking, smoking cessation, and risk of hip fracture in women Am J Med 1999 106(3):311 4 10190380
125 Forsen L, Bjorndal A, Bjartveit K, et al Interaction between current smoking, leanness, and physical inactivity in the prediction of hip fracture J Bone Miner Res 1994 9(11):1671 8 7863817
126 Kiel DP, Baron JA, Anderson JJ, et al Smoking eliminates the protective effect of oral estrogens on the risk for hip fracture among women Ann Intern Med 1992 116(9):716 21 1558342
127 Melhus H, Michaelsson K, Holmberg L, et al Smoking, antioxidant vitamins, and the risk of hip fracture J Bone Miner Res 1999 14(1):129 35 9893075
128 Diaz MN, O'Neill TW, Silman AJ The influence of family history of hip fracture on the risk of vertebral deformity in men and women: the European Vertebral Osteoporosis Study Bone 1997 20(2):145 9 9028539
129 Grainge MJ, Coupland CA, Cliffe SJ, et al Cigarette smoking, alcohol and caffeine consumption, and bone mineral density in postmenopausal women. The Nottingham EPIC Study Group Osteoporos Int 1998 8(4):355 63 10024906
130 Hoidrup S, Gronbaek M, Gottschau A, et al Alcohol intake, beverage preference, and risk of hip fracture in men and women. Copenhagen Centre for Prospective Population Studies Am J Epidemiol 1999 149(11):993 1001 10355374
131 Hemenway D, Colditz G, Willett W, et al. Fractures and lifestyle: effect of cigarette smoking, alcohol intake, and relative weight on the risk of hip and forearm fractures in middle-aged women. Am J Public Health. 1988;78:1554-8. [pmid: 3189632]. [pmcid: 1349734].
132 Felson DT, Zhang Y, Hannan MT, et al Alcohol intake and bone mineral density in elderly men and women. The Framingham Study Am J Epidemiol 1995 142(5):485 92 7677127
133 Felson DT, Kiel DP, Anderson JJ, et al Alcohol consumption and hip fractures: the Framingham Study Am J Epidemiol 1988 128(5):1102 10 3189283
134 Barrett-Connor E, Chang J, Edelstein S. Coffee-associated osteoporosis offset by daily milk consumption. The Rancho Bernardo Study. JAMA. 1994;271:280-3. [pmid: 8295286].
135 Harris S, Dawson-Hughes B. Caffeine and bone loss in healthy postmenopausal women. Am J Clin Nutr. 1994;60:573-8. [pmid: 8092093].
136 Lloyd T, Rollings N, Eggli DF, et al Dietary caffeine intake and bone status of postmenopausal women Am J Clin Nutr 1997 65(6):1826 30 9174479
137 Johansson C, Mellstrom D, Lerner U, et al Coffee drinking: a minor risk factor for bone loss and fractures Age Ageing 1992 21(1):20 6 1553855
138 Tavani A, Negri E, La Vecchia C Coffee intake and risk of hip fracture in women in northern Italy Prev Med 1995 24(4):396 400 7479631
139 Kiel DP, Felson DT, Hannan MT, et al Caffeine and the risk of hip fracture: the Framingham Study Am J Epidemiol 1990 132(4):675 84 2403108
140 Hernandez-Avila M, Colditz GA, Stampfer MJ, et al Caffeine, moderate alcohol intake, and risk of fractures of the hip and forearm in middle-aged women Am J Clin Nutr 1991 54(1):157 63 2058578
141 Chapuy MC, Arlot ME, Duboeuf F, et al Vitamin D3 and calcium to prevent hip fractures in the elderly women N Engl J Med 1992 327(23):1637 42 1331788
142 Dawson-Hughes B, Harris SS, Krall EA, et al Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older N Engl J Med 1997 337(10):670 6 9278463
143 Earnshaw SA, Worley A, Hosking DJ Current diet does not relate to bone mineral density after the menopause. The Nottingham Early Postmenopausal Intervention Cohort (EPIC) Study Group Br J Nutr 1997 78(1):65 72 9292760
144 Cooper C, Barker DJP, Wickham C. Physical activity, muscle strength, and calcium intake in fracture of the proximal femur in Britain. BMJ. 1988;297:1443-6. [pmid: 3147008]. [pmcid: 1835123].
145 Tavani A, Negri E, La Vecchia C Calcium, dairy products, and the risk of hip fracture in women in northern Italy Epidemiology 1995 6(5):554 7 8562636
146 Feskanich D, Willett WC, Stampfer MJ, et al Milk, dietary calcium, and bone fractures in women: a 12-year prospective study Am J Public Health 1997 87(6):992 7 9224182 1380936
147 Wickham CA, Walsh K, Cooper C, et al Dietary calcium, physical activity, and risk of hip fracture: a prospective study BMJ 1989 299(6704):889 92 2510879 1837771
148 Looker AC, Harris TB, Madans JH, et al Dietary calcium and hip fracture risk: the NHANES I Epidemiologic Follow-Up Study Osteoporos Int 1993 3(4):177 84 8338972
149 Stracke H, Renner E, Knie G, et al Osteoporosis and bone metabolic parameters in dependence upon calcium intake through milk and milk products Eur J Clin Nutr 1993 47(9):617 22 8243426
150 Sandler RB, Slemenda CW, LaPorte RE, et al Postmenopausal bone density and milk consumption in childhood and adolescence Am J Clin Nutr 1985 42(2):270 4 3839625
151 Michaelsson K, Bergstrom R, Holmberg L, et al A high dietary calcium intake is needed for a positive effect on bone density in Swedish postmenopausal women Osteoporos Int 1997 7(2):155 61 9166397
152 Aptel I, Cance-Rouzaud A, Grandjean H Association between calcium ingested from drinking water and femoral bone density in elderly women: evidence from the EPIDOS cohort J Bone Miner Res 1999 14(5):829 33 10320532
153 Holbrook T, Barrett-Connor E. An 18-year prospective study of dietary calcium and bone mineral density in the hip. Calcif Tissue Int. 1995;56:364-7. [pmid: 7621342].
154 Lau EM, Cooper C. Epidemiology and prevention of osteoporosis in urbanized Asian populations. Osteoporos Int. 1993;3 Suppl 1:23-6. [pmid: 8461569].
155 Holbrook TL, Barrett-Connor E, Wingard DL Dietary calcium and risk of hip fracture: 14-year prospective population study Lancet 1988 2(8619):1046 9 2903278
156 Johnell O, Gullberg B, Kanis JA, et al Risk factors for hip fracture in European women: the MEDOS Study. Mediterranean Osteoporosis Study J Bone Miner Res 1995 10(11):1802 15 8592959
157 Komar L, Nieves J, Cosman F, et al Calcium homeostasis of an elderly population upon admission to a nursing home J Am Geriatr Soc 1993 41(10):1057 64 8409150
158 Ranstam J, Kanis JA Influence of age and body mass on the effects of vitamin D on hip fracture risk Osteoporos Int 1995 5(6):450 4 8695967
159 Jones G, Riley M, Couper D, et al Water fluoridation, bone mass and fracture: a quantitative overview of the literature Aust N Z J Public Health 1999 23(1):34 40 10083687
160 Sowers MF, Clark MK, Jannausch ML, et al A prospective study of bone mineral content and fracture in communities with differential fluoride exposure Am J Epidemiol 1991 133(7):649 60 2018020
161 Karagas MR, Baron JA, Barrett JA, et al Patterns of fracture among the United States elderly: geographic and fluoride effects Ann Epidemiol 1996 6(3):209 16 8827156
162 Feskanich D, Owusu W, Hunter DJ, et al Use of toenail fluoride levels as an indicator for the risk of hip and forearm fractures in women Epidemiology 1998 9(4):412 6 9647905
163 Cauley JA, Murphy PA, Riley TJ, et al Effects of fluoridated drinking water on bone mass and fractures: the study of osteoporotic fractures J Bone Miner Res 1995 10(7):1076 86 7484283
164 Foley KT, Owings TM, Pavol MJ, et al Maximum grip strength is not related to bone mineral density of the proximal femur in older adults Calcif Tissue Int 1999 64(4):291 4 10089220
165 Kritz-Silverstein D, Barrett-Connor E Grip strength and bone mineral density in older women J Bone Miner Res 1994 9(1):45 51 8154308
166 Lau EM, Woo J, Leung PC, et al Low bone mineral density, grip strength and skinfold thickness are important risk factors for hip fracture in Hong Kong Chinese Osteoporos Int 1993 3(2):66 70 8453192
167 Meyer HE, Henriksen C, Falch JA, et al Risk factors for hip fracture in a high incidence area: a case-control study from Oslo, Norway Osteoporos Int 1995 5(4):239 46 7492862
168 Elliot JR, Hanger HC, Gilchrist NL, et al A comparison of elderly patients with proximal femoral fractures and a normal elderly population: a case control study N Z Med J 1992 105(944):420 2 1297935
169 Nguyen T, Sambrook P, Kelly P, et al Prediction of osteoporotic fractures by postural instability and bone density BMJ 1993 307(6912):1111 5 8251809 1679116
170 Felson DT, Anderson JJ, Hannan MT, et al Impaired vision and hip fracture. The Framingham Study J Am Geriatr Soc 1989 37(6):495 500 2715555
171 Klein BE, Klein R, Lee KE, et al Performance-based and self-assessed measures of visual function as related to history of falls, hip fractures, and measured gait time. The Beaver Dam Eye Study Ophthalmology 1998 105(1):160 4 9442793
172 Coupland CA, Cliffe SJ, Bassey EJ, et al Habitual physical activity and bone mineral density in postmenopausal women in England Int J Epidemiol 1999 28(2):241 6 10342685
173 Uusi-Rasi K, Sievanen H, Vuori I, et al Long-term recreational gymnastics, estrogen use, and selected risk factors for osteoporotic fractures J Bone Miner Res 1999 14(7):1231 8 10404026
174 Hoshino H, Kushida K, Yamazaki K, et al Effect of physical activity as a caddie on ultrasound measurements of the Os calcis: a cross-sectional comparison J Bone Miner Res 1996 11(3):412 8 8852953
175 Bidoli E, Schinella D, Franceschi S Physical activity and bone mineral density in Italian middle-aged women Eur J Epidemiol 1998 14(2):153 7 9556174
176 Jaglal SB, Kreiger N, Darlington GA Lifetime occupational physical activity and risk of hip fracture in women Ann Epidemiol 1995 5(4):321 4 8520716
177 Gregg EW, Cauley JA, Seeley DG, et al Physical activity and osteoporotic fracture risk in older women. Study of Osteoporotic Fractures Research Group Ann Intern Med 1998 129(2):81 8 9669990
178 Paganini-Hill A, Chao A, Ross RK, et al Exercise and other factors in the prevention of hip fracture: the Leisure World study Epidemiology 1991 2(1):16 25 2021661
179 Coupland C, Wood D, Cooper C Physical inactivity is an independent risk factor for hip fracture in the elderly J Epidemiol Community Health 1993 47(6):441 3 8120496
180 Lau E, Donnan S, Barker DJP, et al. Physical activity and calcium intake in fracture of the proximal femur in Hong Kong. BMJ. 1988;297:1441-3. [pmid: 3147007]. [pmcid: 1835159].
181 Stevens JA, Powell KE, Smith SM, et al Physical activity, functional limitations, and the risk of fall-related fractures in community-dwelling elderly Ann Epidemiol 1997 7(1):54 61 9034407
182 Jaglal SB, Kreiger N, Darlington G Past and recent physical activity and risk of hip fracture Am J Epidemiol 1993 138(2):107 18 8342529
183 Boyce WJ, Vessey MP Habitual physical inertia and other factors in relation to risk of fracture of the proximal femur Age Ageing 1988 17(5):319 27 3232586
184 Khan KM, Green RM, Saul A, et al Retired elite female ballet dancers and nonathletic controls have similar bone mineral density at weightbearing sites J Bone Miner Res 1996 11(10):1566 74 8889858
185 Khan KM, Bennell KL, Hopper JL, et al Self-reported ballet classes undertaken at age 10-12 years and hip bone mineral density in later life Osteoporos Int 1998 8(2):165 73 9666941
186 Puntila E, Kroger H, Lakka T, et al Physical activity in adolescence and bone density in peri- and postmenopausal women: a population-based study Bone 1997 21(4):363 7 9315340
187 Nieves JW, Grisso JA, Kelsey JL A case-control study of hip fracture: evaluation of selected dietary variables and teenage physical activity Osteoporos Int 1992 2(3):122 7 1627898
188 Suen LK Occupation and risk of hip fracture J Public Health Med 1998 20(4):428 33 9923950
189 Gardsell P, Johnell O, Nilsson BE, et al The predictive value of fracture, disease, and falling tendency for fragility fractures in women Calcif Tissue Int 1989 45(6):327 30 2509022
190 Cooper C, Barker DJ, Morris J, et al Osteoporosis, falls, and age in fracture of the proximal femur Br Med J (Clin Res Ed) 1987 295(6589):13 5
191 Lau E, Donnan S. Falls and hip fracture in Hong Kong Chinese. Pub Health. 1990;104:117-21. [pmid: 2359827].
192 Cumming RG, Klineberg RJ Fall frequency and characteristics and the risk of hip fractures J Am Geriatr Soc 1994 42(7):774 8 8014355
193 Greenspan SL, Myers ER, Kiel DP, et al Fall direction, bone mineral density, and function: risk factors for hip fracture in frail nursing home elderly Am J Med 1998 104(6):539 45 9674716
194 Jarnlo GB, Thorngren KG Background factors to hip fractures Clin Orthop 1993(287):41 9
195 Norton R, Campbell AJ, Lee-Joe T, et al Circumstances of falls resulting in hip fractures among older people J Am Geriatr Soc 1997 45(9):1108 12 9288020
196 Clemson L, Cumming RG, Roland M Case-control study of hazards in the home and risk of falls and hip fractures Age Ageing 1996 25(2):97 101 8670535
197 Luukinen H, Koski K, Laippala P, et al Factors predicting fractures during falling impacts among home-dwelling older adults J Am Geriatr Soc 1997 45(11):1302 9 9361654
198 Yaffe K, Browner W, Cauley J, et al Association between bone mineral density and cognitive decline in older women J Am Geriatr Soc 1999 47(10):1176 82 10522949
199 Johansson C, Skoog I A population-based study on the association between dementia and hip fractures in 85-year olds Aging (Milano) 1996 8(3):189 96 305699 8862194
200 Melton LJ 3rd, Beard CM, Kokmen E, et al. Fracture risk in patients with Alzheimer's disease. J Am Geriatr Soc. 1994;42:614-9. [pmid: 8201146].
201 Guo Z, Wills P, Viitanen M, et al Cognitive impairment, drug use, and the risk of hip fracture in persons over 75 years old: a community-based prospective study Am J Epidemiol 1998 148(9):887 92 9801019
202 Schweiger U, Deuschle M, Korner A, et al Low lumbar bone mineral density in patients with major depression Am J Psychiatry 1994 151(11):1691 3 7943462
203 Michelson D, Stratakis C, Hill L, et al Bone mineral density in women with depression N Engl J Med 1996 335(16):1176 81 8815939
204 Whooley MA, Kip KE, Cauley JA, et al Depression, falls, and risk of fracture in older women. Study of Osteoporotic Fractures Research Group Arch Intern Med 1999 159(5):484 90 10074957
205 Ito M, Yamada M, Hayashi K, et al Relation of early menarche to high bone mineral density Calcif Tissue Int 1995 57(1):11 4 7671158
206 Osei-Hyiaman D, Satoshi T, Ueji M, et al Timing of menopause, reproductive years, and bone mineral density: a cross-sectional study of postmenopausal Japanese women Am J Epidemiol 1998 148(11):1055 61 9850127
207 Parazzini F, Bidoli E, Franceschi S, et al Menopause, menstrual and reproductive history, and bone density in northern Italy J Epidemiol Community Health 1996 50(5):519 23 8944857
208 Ohta H, Sugimoto I, Masuda A, et al Decreased bone mineral density associated with early menopause progresses for at least ten years: cross-sectional comparisons between early and normal menopausal women Bone 1996 18(3):227 31 8703577
209 Bagur AC, Mautalen CA Risk for developing osteoporosis in untreated premature menopause Calcif Tissue Int 1992 51(1):4 7 1393775
210 Pouilles JM, Tremollieres F, Bonneu M, et al Influence of early age at menopause on vertebral bone mass J Bone Miner Res 1994 9(3):311 5 8191923
211 Tuppurainen M, Honkanen R, Kroger H, et al Osteoporosis risk factors, gynaecological history and fractures in perimenopausal women -- the results of the baseline postal enquiry of the Kuopio Osteoporosis Risk Factor and Prevention Study Maturitas 1993 17(2):89 100 8231907
212 O'Neill TW, Silman AJ, Naves Diaz M, et al Influence of hormonal and reproductive factors on the risk of vertebral deformity in European women. European Vertebral Osteoporosis Study Group Osteoporos Int 1997 7(1):72 8 9102068
213 Cumming RG, Klineberg RJ Breastfeeding and other reproductive factors and the risk of hip fractures in elderly women Int J Epidemiol 1993 22(4):684 91 8225744
214 Melton LJ 3rd, Bryant SC, Wahner HW, et al Influence of breastfeeding and other reproductive factors on bone mass later in life Osteoporos Int 1993 3(2):76 83 8453194
215 Felson DT, Zhang Y, Hannan MT, et al The effect of postmenopausal estrogen therapy on bone density in elderly women N Engl J Med 1993 329(16):1141 6 8377776
216 Cauley JA, Seeley DG, Ensrud K, et al Estrogen replacement therapy and fractures in older women. Study of Osteoporotic Fractures Research Group Ann Intern Med 1995 122(1):9 16 7985914
217 Naessen T, Persson I, Adami HO, et al Hormone replacement therapy and the risk for first hip fracture. A prospective, population-based cohort study Ann Intern Med 1990 113(2):95 103 2360759
218 Kiel DP, Felson DT, Anderson JJ, et al Hip fracture and the use of estrogens in postmenopausal women. The Framingham Study N Engl J Med 1987 317(19):1169 74 3657888
219 Johnson RE, Specht EE The risk of hip fracture in postmenopausal females with or without estrogen drug exposure Am J Public Health 1981 71(2):138 44 7457682 1619634
220 Grodstein F, Stampfer MJ, Falkeborn M, et al Postmenopausal hormone therapy and risk of cardiovascular disease and hip fracture in a cohort of Swedish women Epidemiology 1999 10(5):476 80 10468418
221 Michaelsson K, Baron JA, Johnell O, et al. Variation in the efficacy of hormone replacement therapy in the prevention of hip fracture. Osteoporos Int. 1998;8:540-6. [pmid: 10326058].
222 Maxim P, Ettinger B, Spitalny GM. Fracture protection by long-term estrogen treatment. Osteoporos Int. 1995;5:23-9. [pmid: 7703620].
223 Kleerekoper M, Brienza RS, Schultz LR, et al Oral contraceptive use may protect against low bone mass. Henry Ford Hospital Osteoporosis Cooperative Research Group Arch Intern Med 1991 151(10):1971 6 1929685
224 Tuppurainen M, Kröger H, Saarikoski S, et al. The effect of previous oral contraceptive use on bone mineral density in perimenopausal women. Osteoporos Int. 1994;4:93-8. [pmid: 8003847].
225 Cooper C, Hannaford P, Croft P, et al Oral contraceptive pill use and fractures in women: a prospective study Bone 1993 14(1):41 5 8443001
226 Fox KM, Cummings SR Is tubal ligation a risk factor for low bone density and increased risk of fracture? Am J Obstet Gynecol 1995 172(1 Pt 1):101 5 7847513
227 Alderman B, Weiss N, Daling J, et al Reproductive history and postmenopausal risk of hip and forearm fracture Am J Epidemiol 1986 124(2):262 7 3728442
228 Hamed HM, Purdie DW, Steel SA, et al The relation between bone mineral density and early pregnancy loss Br J Obstet Gynaecol 1992 99(12):946 9 1477013
229 Feldblum PJ, Zhang J, Rich LE, et al Lactation history and bone mineral density among perimenopausal women Epidemiology 1992 3(6):527 31 1420520
230 Jones G, Nguyen T, Sambrook PN, et al Thiazide diuretics and fractures: can meta-analysis help? J Bone Miner Res 1995 10(1):106 11 7747616
231 Cauley JA, Cummings SR, Seeley DG, et al Effects of thiazide diuretic therapy on bone mass, fractures, and falls. The Study of Osteoporotic Fractures Research Group Ann Intern Med 1993 118(9):666 73 8489642
232 Feskanich D, Willett WC, Stampfer MJ, et al A prospective study of thiazide use and fractures in women Osteoporos Int 1997 7(1):79 84 9102069
233 Heidrich FE, Stergachis A, Gross KM Diuretic drug use and the risk for hip fracture Ann Intern Med 1991 115(1):1 6 2048857
234 Stall GM, Harris S, Sokoll LJ, et al Accelerated bone loss in hypothyroid patients overtreated with L-thyroxine Ann Intern Med 1990 113(4):265 9 2375563
235 Schneider DL, Barrett-Connor EL, Morton DJ Thyroid hormone use and bone mineral density in elderly women. Effects of estrogen JAMA 1994 271(16):1245 9 7848399
236 Fowler PB, McIvor J, Sykes L, et al The effect of long-term thyroxine on bone mineral density and serum cholesterol J R Coll Physicians Lond 1996 30(6):527 32 8961207
237 Franklyn J, Betteridge J, Holder R, et al Bone mineral density in thyroxine treated females with or without a previous history of thyrotoxicosis Clin Endocrinol 1994 41(4):425 32
238 Franklyn JA, Betteridge J, Daykin J, et al Long-term thyroxine treatment and bone mineral density Lancet 1992 340(8810):9 13 1351654
239 Greenspan SL, Greenspan FS The effect of thyroid hormone on skeletal integrity Ann Intern Med 1999 130(9):750 8 10357695
240 Meier CR, Schlienger RG, Kraenzlin ME, et al. HMG-CoA reductase inhibitors and the risk of fractures. JAMA. 2000;283:3205-10. [pmid: 10866867].
241 Wang PS, Solomon DH, Mogun H, et al. HMG-CoA reductase inhibitors and the risk of hip fractures in elderly patients. JAMA. 2000;283:3211-6. [pmid: 10866868].
242 Liu B, Anderson G, Mittmann N, et al Use of selective serotonin-reuptake inhibitors of tricyclic antidepressants and risk of hip fractures in elderly people Lancet 1998 351(9112):1303 7 9643791
243 Ray WA, Griffin MR, Malcolm E Cyclic antidepressants and the risk of hip fracture Arch Intern Med 1991 151(4):754 6 2012459
244 Ray W, Griffin M, Schaffner W, et al Psychotropic drug use and the risk of hip fracture N Engl J Med 1987 316(7):363 9 2880292
245 Jacqmin-Gadda H, Fourrier A, Commenges D, et al Risk factors for fractures in the elderly Epidemiology 1998 9(4):417 23 9647906
246 Cohen O, Rais T, Lepkifker E, et al Lithium carbonate therapy is not a risk factor for osteoporosis Horm Metab Res 1998 30(9):594 7 9808330
247 Morton DJ, Barrett-Connor EL, Schneider DL Nonsteroidal anti-inflammatory drugs and bone mineral density in older women: the Rancho Bernardo study J Bone Miner Res 1998 13(12):1924 31 9844111
248 Bauer DC, Orwoll ES, Fox KM, et al Aspirin and NSAID use in older women: effect on bone mineral density and fracture risk. Study of Osteoporotic Fractures Research Group J Bone Miner Res 1996 11(1):29 35 8770694
249 Cumming RG, Klineberg RJ Psychotropics, thiazide diuretics and hip fractures in the elderly Med J Aust 1993 158(6):414 7 8479356
250 Herings RM, Stricker BH, de Boer A, et al Benzodiazepines and the risk of falling leading to femur fractures. Dosage more important than elimination half-life Arch Intern Med 1995 155(16):1801 7 7654115
251 Ray WA, Griffin MR, Downey W Benzodiazepines of long and short elimination half-life and the risk of hip fracture JAMA 1989 262(23):3303 7 2573741
252 Cummings SR Are patients with hip fractures more osteoporotic? Review of the evidence Am J Med 1985 78(3):487 94 3976707
253 Wysowski DK, Baum C, Ferguson WJ, et al Sedative-hypnotic drugs and the risk of hip fracture J Clin Epidemiol 1996 49(1):111 3 8598503
254 Stevens A, Mulrow C Drugs affecting postural stability and other risk factors in the hip fracture epidemic -- case-control study Community Med 1989 11(1):27 34 2721145
255 Caraballo PJ, Heit JA, Atkinson EJ, et al Long-term use of oral anticoagulants and the risk of fracture Arch Intern Med 1999 159(15):1750 6 10448778
256 Jamal SA, Browner WS, Bauer DC, et al Warfarin use and risk for osteoporosis in elderly women. Study of Osteoporotic Fractures Research Group Ann Intern Med 1998 128(10):829 32 9599195
257 Adachi Y, Shiota E, Matsumata T, et al Bone mineral density in patients taking H2-receptor antagonist Calcif Tissue Int 1998 62(4):283 5 9504949
258 Jamal SA, Browner WS, Bauer DC, et al Intermittent use of nitrates increases bone mineral density: the study of osteoporotic fractures J Bone Miner Res 1998 13(11):1755 9 9797485
259 Ross PD, Wasnich RD, Davis JW Fracture prediction models for osteoporosis prevention Bone 1990 11(5):327 31 2123644
260 van Hemert AM, Vandenbroucke JP, Birkenhager JC, et al Prediction of osteoporotic fractures in the general population by a fracture risk score. A 9-year follow-up among middle-aged women Am J Epidemiol 1990 132(1):123 35 2192546
261 Ranstam J, Elffors L, Kanis JA A mental-functional risk score for prediction of hip fracture Age Ageing 1996 25(6):439 42 9003879
262 Burger H, de Laet CE, Weel AE, et al Added value of bone mineral density in hip fracture risk scores Bone 1999 25(3):369 74 10495142
263 Tromp AM, Smit JH, Deeg DJ, et al Predictors for falls and fractures in the Longitudinal Aging Study Amsterdam J Bone Miner Res 1998 13(12):1932 9 9844112
264 Kleerekoper M, Peterson E, Nelson D, et al Identification of women at risk for developing postmenopausal osteoporosis with vertebral fractures: role of history and single photon absorptiometry Bone Miner 1989 7(2):171 86 2804452
265 Falch JA, Sandvik L, Van Beresteijn EC Development and evaluation of an index to predict early postmenopausal bone loss Bone 1992 13(4):337 41 1389575
266 Verhaar HJ, Koele JJ, Neijzen T, et al Are arm span measurements useful in the prediction of osteoporosis in postmenopausal women? Osteoporos Int 1998 8(2):174 6 9666942
267 Elliot JR, Gilchrist NL, Wells JE, et al Historical assessment of risk factors in screening for osteopenia in a normal Caucasian population Aust N Z J Med 1993 23(5):458 62 8297274
268 Ballard PA, Purdie DW, Langton CM, et al Prevalence of osteoporosis and related risk factors in UK women in the seventh decade: osteoporosis case finding by clinical referral criteria or predictive model? Osteoporos Int 1998 8(6):535 9 10326057
269 Ribot C, Pouilles JM, Bonneu M, et al Assessment of the risk of post-menopausal osteoporosis using clinical factors Clin Endocrinol 1992 36(3):225 8
270 Slemenda CW, Hui SL, Longcope C, et al Predictors of bone mass in perimenopausal women. A prospective study of clinical data using photon absorptiometry Ann Intern Med 1990 112(2):96 101 2294827
271 Lydick E, Cook K, Turpin J, et al Development and validation of a simple questionnaire to facilitate identification of women likely to have low bone density Am J Manag Care 1998 4(1):37 48 10179905
272 Goemaere S, Zegels B, Toye K, et al. Limited clinical utility of a self-evaluating risk assessment scale for postmenopausal osteoporosis: lack of predictive value of lifestyle-related factors. Calcif Tissue Int. 1999;65:354-8. [pmid: 10541759].
273 Hanley JA, McNeil BJ. The meaning and use of the area under a receiver operating characteristic (ROC) curve. Radiology. 1982;143:29-36. [pmid: 7063747].
274 Von Mühlen D, Visby Lunde A, Barrett-Connor E, et al. Evaluation of the simple calculated osteoporosis risk estimation (SCORE) in older Caucasian women: the Rancho Bernardo study. Osteoporos Int. 1999;10:79-84. [pmid: 10501784].
275 Epstein RS, Feng W, Hirsch LJ, et al Intervention thresholds for the treatment of osteoporosis: comparison of different approaches to decision-making Osteoporos Int 1998 8Suppl 1:S22 7 9682793
276 Black DM, Cummings SR, Karpf DB, et al. Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Lancet. 1996;348:1535-41. [pmid: 8950879].
277 Liberman UA, Weiss SR, Broll J, et al Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis N Engl J Med 1995 333(22):1437 43 7477143
278 Adami S, Passeri M, Ortolani S, et al Effects of oral alendronate and intranasal salmon calcitonin on bone mass and biochemical markers of bone turnover in postmenopausal women with osteoporosis Bone 1995 17(4):383 90 8573412
279 Pols HA, Felsenberg D, Hanley DA, et al Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Foxamax International Trial Study Group Osteoporos Int 1999 9(5):461 8 10550467
280 Bone HG, Downs RW Jr., Tucci JR, et al Dose-response relationships for alendronate treatment in osteoporotic elderly women J Clin Endocrinol Metab 1997 82(1):265 74 8989272
281 Chesnut CH 3rd, McClung MR, Ensrud KE, et al Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling Am J Med 1995 99(2):144 52 7625419
282 Greenspan SL, Parker RA, Ferguson L, et al Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: a randomized clinical trial J Bone Miner Res 1998 13(9):1431 8 9738515
283 Cummings SR, Black DM, Thompson DE Effect of alendronate reduces on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial JAMA 1998 280(24):2077 82 9875874
284 Melton LJ 3rd, Atkinson EJ, O'Fallon WM, et al Long-term fracture prediction by bone mineral assessed at different skeletal sites J Bone Miner Res 1993 8(10):1227 33 8256660
285 Black DM, Cummings SR, Genant HK, et al Axial and appendicular bone density predict fractures in older women J Bone Miner Res 1992 7(6):633 8 1414481
286 Cummings SR, Black DM, Nevitt MC, et al Appendicular bone density and age predict hip fracture in women. The Study of Osteoporotic Fractures Research Group JAMA 1990 263(5):665 8 2404146
287 Hui SL, Slemenda CW, Johnston CC Jr Baseline measurement of bone mass predicts fracture in white women Ann Intern Med 1989 111(5):355 61 2764403
288 Hui SL, Slemenda CW, Johnston CC Jr Age and bone mass as predictors of fracture in a prospective study J Clin Invest 1988 81(6):1804 9 442628 3384952
289 Cleghorn D, Polley K, Bellon M, et al. Fracture rates as a function of forearm mineral density in normal postmenopausal women: retrospective and prospective data. Calcif Tissue Int. 1991;49:161-3. [pmid: 1933579].
290 Bauer DC, Gluer CC, Cauley JA, et al Broadband ultrasound attenuation predicts fractures strongly and independently of densitometry in older women. A prospective study. Study of Osteoporotic Fractures Research Group Arch Intern Med 1997 157(6):629 34 9080917
291 de Laet CE, Van Hout BA, Burger H, et al Hip fracture prediction in elderly men and women: validation in the Rotterdam study J Bone Miner Res 1998 13(10):1587 93 9783547
292 Duboeuf F, Hans D, Schott AM, et al Different morphometric and densitometric parameters predict cervical and trochanteric hip fracture: the EPIDOS Study J Bone Miner Res 1997 12(11):1895 902 9383694
293 Garnero P, Dargent-Molina P, Hans D, et al Do markers of bone resorption add to bone mineral density and ultrasonographic heel measurement for the prediction of hip fracture in elderly women? The EPIDOS prospective study Osteoporos Int 1998 8(6):563 9 10326062
294 Hans D, Dargent-Molina P, Schott AM, et al Ultrasonographic heel measurements to predict hip fracture in elderly women: the EPIDOS prospective study Lancet 1996 348(9026):511 4 8757153
295 Kroger H, Huopio J, Honkanen R, et al Prediction of fracture risk using axial bone mineral density in a perimenopausal population: a prospective study J Bone Miner Res 1995 10(2):302 6 7754811
296 Mele R, Masci G, Ventura V, et al Three-year longitudinal study with quantitative ultrasound at the hand phalanx in a female population Osteoporos Int 1997 7(6):550 7 9604051
297 Nevitt MC, Johnell O, Black DM, et al Bone mineral density predicts non-spine fractures in very elderly women. Study of Osteoporotic Fractures Research Group Osteoporos Int 1994 4(6):325 31 7696827
298 Schott AM, Cormier C, Hans D, et al How hip and whole-body bone mineral density predict hip fracture in elderly women: the EPIDOS Prospective Study Osteoporos Int 1998 8(3):247 54 9797909
299 Stewart A, Torgerson DJ, Reid DM. Prediction of fractures in perimenopausal women: a comparison of dual energy x ray absorptiometry and broadband ultrasound attenuation. Ann Rheum Dis. 1996;55:140-2. [pmid: 8712866]. [pmcid: 1010110].
300 Vecht-Hart CM, Zwamborn AW, Peeters PH, et al Prediction of peripheral fracture risk by quantitative microdensitometry Prev Med 1997 26(1):86 91 9010902
301 de Laet CE, van Hout BA, Burger H, et al Bone density and risk of hip fracture in men and women: cross sectional analysis BMJ 1997 315(7102):221 5 9253270
302 Jones G, Nguyen T, Sambrook P, et al Progressive loss of bone in the femoral neck in elderly people: longitudinal findings from the Dubbo osteoporosis epidemiology study BMJ 1994 309(6956):691 5 7950520
303 Masud T, Langley S, Wiltshire P, et al. Effect of spinal osteophytosis on bone mineral density measurements in vertebral osteoporosis. BMJ. 1993;307:172-3. [pmid: 8343746]. [pmcid: 1678366].
304 Arlot ME, Sornay-Rendu E, Garnero P, et al Apparent pre- and postmenopausal bone loss evaluated by DXA at different skeletal sites in women: the OFELY cohort J Bone Miner Res 1997 12(4):683 90 9101381
305 Grampp S, Henk CB, Fuerst TP, et al Diagnostic agreement of quantitative sonography of the calcaneus with dual X-ray absorptiometry of the spine and femur Am J Roentgenol 1999 173(2):329 34 10430129
306 Kroger H, Lunt M, Reeve J, et al Bone density reduction in various measurement sites in men and women with osteoporotic fractures of spine and hip: the European quantitation of osteoporosis study Calcif Tissue Int 1999 64(3):191 9 10024374
307 Varney LF, Parker RA, Vincelette A, et al Classification of osteoporosis and osteopenia in postmenopausal women is dependent on site-specific analysis J Clin Densitomet 1999 2(3):275 83
308 Ahmed AIH, Blake GM, Rymer JM, et al. Screening for osteopenia and osteoporosis: do the accepted normal ranges lead to overdiagnosis?. Osteoporos Int. 1997;7:432-8. [pmid: 9425500].
309 Petley GW, Cotton AM, Murrills AJ, et al Reference ranges of bone mineral density for women in southern England: the impact of local data on the diagnosis of osteoporosis Br J Radiol 1996 69(823):655 60 8696703
310 Chen Z, Maricic M, Lund P, et al. How the new Hologic hip normal reference values affect the densitometric diagnosis of osteoporosis. Osteoporos Int. 1998;8:423-7. [pmid: 9850349].
311 Simmons A, Barrington S, O'Doherty M, et al Dual energy X-ray absorptiometry normal reference range use within the UK and the effect of different normal ranges on the assessment of bone density Br J Radiol 1995 68(812):903 9 7551789
312 Lunt M, Felsenberg D, Reeve J, et al Bone density variation and its effects on risk of vertebral deformity in men and women studied in thirteen European centers: the EVOS Study J Bone Miner Res 1997 12(11):1883 94 9383693
313 Laskey M, Crisp A, Cole T, et al Comparison of the effect of different reference data on Lunar DPX and Hologic QDR-1000 dual-energy X-ray absorptiometers Br J Radiol 1992 65(780):1124 9 1286422
314 Kalender WA, Felsenberg D, Genant HK, et al The European Spine Phantom -- a tool for standardization and quality control in spinal bone mineral measurements by DXA and QCT Eur J Radiol 1995 20(2):83 92 7588873
315 Fischer M, Kempers B Phantom studies in osteoporosis Eur J Nucl Med 1993 20(5):434 9 8519262
316 Blake GM, Herd RJ, Fogelman I. A longitudinal study of supine lateral DXA of the lumbar spine: a comparison with posteroanterior spine, hip and total-body DXA. Osteoporos Int. 1996;6:462-70. [pmid: 9116392].
317 Garland SW, Lees B, Stevenson JC DXA longitudinal quality control: a comparison of inbuilt quality assurance, visual inspection, multi-rule Shewhart charts and Cusum analysis Osteoporos Int 1997 7(3):231 7 9205636
318 Khan KM, Henzell SL, Broderick C, et al. Instrument performance in bone density testing at five Australian centres. Aust NZ J Med. 1997;27:526-30.
319 Orwoll ES, Oviatt SK, Biddle JA Precision of dual-energy x-ray absorptiometry: development of quality control rules and their application in longitudinal studies J Bone Miner Res 1993 8(6):693 9 8328311
320 Pocock NA, Noakes KA, Majerovic Y, et al Magnification error of femoral geometry using fan beam densitometers Calcif Tissue Int 1997 60(1):8 10 9030472
321 Wahner HW, Looker A, Dunn WL, et al Quality control of bone densitometry in a national health survey (NHANES III) using three mobile examination centers J Bone Miner Res 1994 9(6):951 60 8079669
322 Kung AW, Tang GW, Luk KD, et al Evaluation of a new calcaneal quantitative ultrasound system and determination of normative ultrasound values in southern Chinese women Osteoporos Int 1999 9(4):312 7 10550448
323 Fuleihan GE, Testa MA, Angell JE, et al Reproducibility of DXA absorptiometry: a model for bone loss estimates J Bone Miner Res 1995 10(7):1004 14 7484275
324 Ravaud P, Reny JL, Giraudeau B, et al Individual smallest detectable difference in bone mineral density measurements J Bone Miner Res 1999 14(8):1449 56 10457279
325 Greenspan SL, Bouxsein ML, Melton ME, et al Precision and discriminatory ability of calcaneal bone assessment technologies J Bone Miner Res 1997 12(8):1303 13 9258762
326 Kotzki PO, Buyck D, Hans D, et al Influence of fat on ultrasound measurements of the os calcis Calcif Tissue Int 1994 54(2):91 5 8012877
327 Njeh CF, Boivin CM, Langton CM The role of ultrasound in the assessment of osteoporosis: a review Osteoporos Int 1997 7(1):7 22 9102067
328 Rico H, Gomez M, Aguado F, et al Impact of weight in obese subjects on bone speed of sound Invest Radiol 1999 34(9):596 9 10485076
329 Gluer CC, Genant HK Impact of marrow fat on accuracy of quantitative CT J Comput Assist Tomogr 1989 13(6):1023 35 2584480
330 Howard GM, Nguyen TV, Pocock NA, et al Influence of handedness on calcaneal ultrasound: implications for assessment of osteoporosis and study design Osteoporos Int 1997 7(3):190 4 9205629
331 Johansen A, Stone MD The effect of ankle oedema on bone ultrasound assessment at the heel Osteoporos Int 1997 7(1):44 7 9102062
332 Jones G, Nguyen T, Sambrook PN, et al. A longitudinal study of the effect of spinal degenerative disease on bone density in the elderly. J Rheumatol. 1995;22:932-6. [pmid: 8587085].
333 Agren M, Karellas A, Leahey D, et al Ultrasound attenuation of the calcaneus: a sensitive and specific discriminator of osteopenia in postmenopausal women Calcif Tissue Int 1991 48(4):240 4 2059875
334 Alenfeld FE, Wuster C, Funck C, et al Ultrasound measurements at the proximal phalanges in healthy women and patients with hip fractures Osteoporos Int 1998 8(5):393 8 9850344
335 Cunningham J, Fordham J, Hewitt T, et al Ultrasound velocity and attenuation at different skeletal sites compared with bone mineral density measured using dual energy X-ray absorptiometry Br J Radiol 1996 69(817):25 32 8785618
336 Faulkner KG, McClung MR, Coleman LJ, et al. Quantitative ultrasound of the heel: correlation with densitometric measurements at different skeletal sites. Osteoporos Int. 1994;4:42-7. [pmid: 8148571].
337 Formica CA, Nieves JW, Cosman F, et al Comparative assessment of bone mineral measurements using dual X-ray absorptiometry and peripheral quantitative computed tomography Osteoporos Int 1998 8(5):460 7 9850355
338 Graafmans WC, Van Lingen A, Ooms ME, et al Ultrasound measurements in the calcaneus: precision and its relation with bone mineral density of the heel, hip, and lumbar spine Bone 1996 19(2):97 100 8853851
339 Grampp S, Jergas M, Lang P, et al Quantitative CT assessment of the lumbar spine and radius in patients with osteoporosis Am J Roentgenol 1996 167(1):133 40 8659357
340 Laval-Jeantet AM, Bergot C, Williams M, et al Dual-energy X-ray absorptiometry of the calcaneus: comparison with vertebral dual-energy X-ray absorptiometry and quantitative computed tomography Calcif Tissue Int 1995 56(1):14 8 7796340
341 Martin J, Reid D Appendicular measurements in screening women for low axial bone mineral density Br J Radiol 1996 69(819):234 40 8800867
342 Massie A, Reid DM, Porter RW Screening for osteoporosis: comparison between dual energy X-ray absorptiometry and broadband ultrasound attenuation in 1000 perimenopausal women Osteoporos Int 1993 3(2):107 10 8453190
343 Naganathan V, March L, Hunter D, et al Quantitative heel ultrasound as a predictor for osteoporosis Med J Aust 1999 171(6):297 300 10560444
344 Pocock NA, Noakes KA, Howard GM, et al. Screening for osteoporosis: what is the role of heel ultrasound?. Med J Aust. 1996;164:367-70. [pmid: 8606664].
345 Rosenthall L, Tenenhouse A, Caminis J A correlative study of ultrasound calcaneal and dual-energy X-ray absorptiometry bone measurements of the lumbar spine and femur in 1000 women Eur J Nucl Med 1995 22(5):402 6 7641747
346 Roux C, Lemonnier E, Lolta S, et al Broadband ultrasound attenuation of the calcaneus and bone density measurements Rev Rhum Engl Ed 1993 60(12):771 80
347 Salamone L, Krall E, Dawson-Hughes B. Comparison of broadband ultrasound attenuation to single X-ray absorptiometry measurements at the calcaneus in postmenopausal women. Calcif Tissue Int. 1994;54:87-90. [pmid: 8012876].
348 Schott AM, Weill-Engerer S, Hans D, et al Ultrasound discriminates patients with hip fracture equally well as dual energy X-ray absorptiometry and independently of bone mineral density J Bone Miner Res 1995 10(2):243 9 7754803
349 Tromp AM, Smit JH, Deeg DJ, et al Quantitative ultrasound measurements of the tibia and calcaneus in comparison with DXA measurements at various skeletal sites Osteoporos Int 1999 9(3):230 5 10450412
350 Turner C, Peacock M, Timmerman L, et al. Calcaneal ultrasonic measurements discriminate hip fracture independently of bone mass. Osteoporos Int. 1995;5:130-5. [pmid: 7599449].
351 Young H, Howey S, Purdie DW Broadband ultrasound attenuation compared with dual-energy X-ray absorptiometry in screening for postmenopausal low bone density Osteoporos Int 1993 3(3):160 4 8481593
352 Salamone LM, Pressman AR, Seeley DG, et al. Estrogen replacement therapy. A survey of older women's attitudes. Arch Intern Med. 1996;156:1293-7. [pmid: 8651837].
353 Rozenberg S, Kroll M, Vandromme J, et al. Effect of bone density evaluation on hormone replacement therapy prescription. Maturitas. 1996;24:57-61. [pmid: 8794435].
354 Rimes KA, Salkovskis PM, Shipman AJ. Psychological and behavioural effects of bone density screening for osteoporosis. Psychol Health. 1999;14:585-608.
355 Marci CD, Viechnicki MB, Greenspan SL, et al. Bone mineral densitometry substantially influences health-related behaviors of postmenopausal women. Calcif Tissue Int. 2000;66:113-8. [pmid: 10652958].
356 Papaioannou A, Parkinson W, Adachi H, et al Women's decisions about hormone replacement therapy after education and bone densitometry Can Med Assoc J 1998 159(10):1253 7 9861222 1229820
357 Silverman SL, Greenwald M, Klein RA, et al Effect of bone density information on decisions about hormone replacement therapy: a randomized trial Obstet Gynecol 1997 89(3):321 5 9052578
358 Rubin SM, Cummings SR Results of bone densitometry affect women's decisions about taking measures to prevent fractures Ann Intern Med 1992 116(12 pt 1):990 5 1586110
359 Stock JL, Waud CE, Coderre JA, et al Clinical reporting to primary care physicians leads to increased use and understanding of bone densitometry and affects the management of osteoporosis: a randomized trial Ann Intern Med 1998 128(12):996 9 9625686
360 Nguyen TV, Sambrook PN, Eisman JA Bone loss, physical activity, and weight change in elderly women: the Dubbo Osteoporosis Epidemiology Study J Bone Miner Res 1998 13(9):1458 67 9738519
361 Cappuccio FP, Meilahn E, Zmuda JM, et al High blood pressure and bone-mineral loss in elderly white women: a prospective study. Study of Osteoporotic Fractures Research Group Lancet 1999 354(9183):971 5 10501357
362 Burger H, de Laet CE, van Daele PL, et al Risk factors for increased bone loss in an elderly population: the Rotterdam Study Am J Epidemiol 1998 147(9):871 9 9583718
363 Wimalawansa SJ. A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med. 1998;104:219-26. [pmid: 9552083].
364 Braga de Castro Machado A, Hannon R, Eastell R. Monitoring alendronate therapy for osteoporosis. J Bone Miner Res. 1999;14:602-8. [pmid: 10234582].
365 Faulkner K Bone matters: are density increases necessary to reduce fracture risk? J Bone Miner Res 2000 15(2):183 7 10703919
366 Hochberg M, Ross P, Black D, et al Larger increases in bone mineral density during alendronate therapy are associated with a lower risk of new vertebral fractures in women with postmenopausal osteoporosis Arthritis Rheum 1999 42(6):1246 54 10366118
367 Cummings SR, Palermo L, Browner W, et al. Monitoring osteoporosis therapy with bone densitometry. JAMA. 2000;283:1318-21. [pmid: 10714731].
368 Calvo M, Eyre D, Gundberg C Molecular basis and clinical application of biological markers of bone turnover Endocr Rev 1996 17(4):333 68 8854049
369 Garnero P, Delmas PD Biochemical markers of bone turnover. Applications for osteoporosis Endocrinol Metab Clin North Am 1998 27(2):303 23 9669140
370 Miller PD, Baran DT, Bilezikian JP, et al Practical clinical application of biochemical markers of bone turnover: consensus of an expert panel J Clin Densitomet 1999 2(3):323 42
371 Greenspan SL, Dresner-Pollak R, Parker RA, et al Diurnal variation of bone mineral turnover in elderly men and women Calcif Tissue Int 1997 60(5):419 23 9115158
372 Gertz BJ, Clemens JD, Holland SD, et al Application of a new serum assay for type I collagen cross-linked N-telopeptides: assessment of diurnal changes in bone turnover with and without alendronate treatment Calcif Tissue Int 1998 63(2):102 6 9685512
373 Uebelhart D, Schlemmer A, Johansen J, et al Effect of menopause and hormone replacement therapy on the urinary excretion of pyridinium cross-links J Clin Endocrinol Metab 1991 72(2):367 73 1991806
374 Ravn P, Hosking D, Thompson D, et al Monitoring of alendronate treatment and prediction of effect on bone mass by biochemical markers in the early postmenopausal intervention cohort study J Clin Endocrinol Metab 1999 84(7):2363 8 10404804
375 Chen JT, Hosoda K, Hasumi K, et al Serum N-terminal osteocalcin is a good indicator for estimating responders to hormone replacement therapy in postmenopausal women J Bone Miner Res 1996 11(11):1784 92 8915787
376 Vergnaud P, Garnero P, Meunier PJ, et al. Undercarboxylated osteocalcin measured with a specific immunoassay predicts hip fracture in elderly women: the EPIDOS study. J Clin Endocrinol Metab. 1997;82:719-24. [pmid: 9062471].
377 Gundberg CM, Nieman S D, Abrams S, et al Vitamin K status and bone health: an analysis of methods for determination of undercarboxylated osteocalcin J Clin Endocrinol Metab 1998 83(9):3258 66 9745439
378 Pansini F, Bonaccorsi G, Calisesi M, et al Evaluation of bone metabolic markers as indicators of osteopenia in climacteric women Gynecol Obstet Invest 1992 33(4):231 5 1505813
379 Guerrero R, Diaz Martin MA, Diaz Diego EM, et al New biochemical markers of bone resorption derived from collagen breakdown in the study of postmenopausal osteoporosis Osteoporos Int 1996 6(4):297 302 8883118
380 Melton LJ 3rd, Khosla S, Atkinson EJ, et al Relationship of bone turnover to bone density and fractures J Bone Miner Res 1997 12(7):1083 91 9200008
381 Minisola S, Pacitti MT, Ombricolo E, et al Bone turnover and its relationship with bone mineral density in pre- and postmenopausal women with or without fractures Maturitas 1998 29(3):265 70 9699199
382 Taguchi Y, Gorai I, Zhang MG, et al Differences in bone resorption after menopause in Japanese women with normal or low bone mineral density: quantitation of urinary cross-linked N-telopeptides Calcif Tissue Int 1998 62(5):395 9 9541516
383 Szulc P, Chapuy M, Meunier P, et al. Serum undercarboxylated osteocalcin is a marker of the risk of hip fracture in elderly women. J Clin Invest. 1993;91:1769-74. [pmcid: 288157]. [pmid: 8473517].
384 Akesson K, Ljunghall S, Jonsson B, et al Assessment of biochemical markers of bone metabolism in relation to the occurrence of fracture: a retrospective and prospective population-based study of women J Bone Miner Res 1995 10(11):1823 9 8592961
385 Ross PD, Kress BC, Parson RE, et al. Serum bone alkaline phosphatase and calcaneus bone density predict fractures: a prospective study. Osteoporos Int. 2000;11:1176-82.
386 Garnero P, Hausherr E, Chapuy MC, et al Markers of bone resorption predict hip fracture in elderly women: the EPIDOS Prospective Study J Bone Miner Res 1996 11(10):1531 8 8889854
387 van Daele PLA, Seibel MJ, Burger H, et al. Case-control analysis of bone resorption markers, disability, and hip fracture risk: the Rotterdam study. BMJ. 1996;312:482-3. [pmid: 8597681].
388 Christiansen C, Riis BJ, Rodbro P Screening procedure for women at risk of developing postmenopausal osteoporosis Osteoporos Int 1990 1(1):35 40 2133639
389 Nordin BE, Cleghorn DB, Chatterton BE, et al A 5-year longitudinal study of forearm bone mass in 307 postmenopausal women J Bone Miner Res 1993 8(12):1427 32 8304042
390 Miura H, Yamamoto I, Yuu I, et al Estimation of bone mineral density and bone loss by means of bone metabolic markers in postmenopausal women Endocr J 1995 42(6):797 802 8822322
391 Reeve J, Pearson J, Mitchell A, et al Evolution of spinal bone loss and biochemical markers of bone remodeling after menopause in normal women Calcif Tissue Int 1995 57(2):105 10 7584869
392 Rosso R, Minisola S, Scarda A, et al Temporal relationship between bone loss and increased bone turnover: a longitudinal study following natural menopause J Endocrinol Invest 1995 18(9):723 8 8719304
393 Cosman F, Nieves J, Wilkinson C, et al Bone density change and biochemical indices of skeletal turnover Calcif Tissue Int 1996 58(4):236 43 8661954
394 Keen RW, Nguyen T, Sobnack R, et al Can biochemical markers predict bone loss at the hip and spine?: a 4-year prospective study of 141 early postmenopausal women Osteoporos Int 1996 6(5):399 406 8931035
395 Reginster JY, Deroisy R, Collette J, et al Prediction of bone loss rate in healthy postmenopausal women Calcif Tissue Int 1997 60(3):261 4 9069163
396 Sinigaglia L, Varenna M, Binelli L, et al Serum levels of pyridinium crosslinks in postmenopausal women and in Paget's disease of bone Calcif Tissue Int 1997 61(4):279 84 9312197
397 Bauer DC Biochemical markers of bone turnover and prediction of hip bone loss in older women: the Study of Osteoporotic Fractures J Bone Miner Res 1999 14(8):1404 10 10457273
398 Yoshimura N, Hashimoto T, Sakata K, et al Biochemical markers of bone turnover and bone loss at the lumbar spine and femoral neck: the Taiji study Calcif Tissue Int 1999 65(3):198 202 10441650
399 Garnero P, Sornay-Rendu E, Duboeuf F, et al Markers of bone turnover predict postmenopausal forearm bone loss over 4 years: the OFELY study J Bone Miner Res 1999 14(9):1614 21 10469291
400 Mariconda M, Pavia M, Colonna A, et al Appendicular bone density, biochemical markers of bone turnover and lifestyle factors in female teachers of Southern Italy Eur J Epidemiol 1997 13(8):909 17 9476821
401 Hansen MA Assessment of age and risk factors on bone density and bone turnover in healthy premenopausal women Osteoporos Int 1994 4(3):123 8 8069050
402 Garnero P, Shih WJ, Gineyts E, et al Comparison of new biochemical markers of bone turnover in late postmenopausal osteoporotic women in response to alendronate treatment J Clin Endocrinol Metab 1994 79(6):1693 700 7989477
403 Kyd PA, Vooght KD, Kerkhoff F, et al Clinical usefulness of bone alkaline phosphatase in osteoporosis Ann Clin Biochem 1998 35(Pt 6):717 25 9838984
404 Garnero P, Darte D, Delmas PD A model to monitor the efficacy of alendronate treatment in women with osteoporosis using a biochemical marker of bone turnover Bone 1999 24(6):603 9 10375203
405 Ravn P, Clemmesen B, Christiansen C Biochemical markers can predict the response in bone mass during alendronate treatment in early postmenopausal women Bone 1999 24(3):237 44 10071916
406 Overgaard K, Christiansen C A new biochemical marker of bone resorption for follow-up on treatment with nasal salmon calcitonin Calcif Tissue Int 1996 59(1):12 6 8661977
407 Riis BJ, Overgaard K, Christiansen C Biochemical markers of bone turnover to monitor the bone response to postmenopausal hormone replacement therapy Osteoporos Int 1995 5(4):276 80 7492867
408 Chesnut CH 3rd, Bell NH, Clark GS, et al Hormone replacement therapy in postmenopausal women: urinary N-telopeptide of type I collagen monitors therapeutic effect and predicts response of bone mineral density Am J Med 1997 102(1):29 37 9209198
409 Gonnelli S, Cepollaro C, Pondrelli C, et al The usefulness of bone turnover in predicting the response to transdermal estrogen therapy in postmenopausal osteoporosis J Bone Miner Res 1997 12(4):624 31 9101374
410 Heikkinen AM, Parviainen M, Niskanen L, et al Biochemical bone markers and bone mineral density during postmenopausal hormone replacement therapy with and without Vitamin D3: a prospective, controlled, randomized study J Clin Endocrinol Metab 1997 82(8):2476 82 9253321
411 Rosen CJ, Chesnut CH 3rd, Mallinak NJ The predictive value of biochemical markers of bone turnover for bone mineral density in early postmenopausal women treated with hormone replacement or calcium supplementation J Clin Endocrinol Metab 1997 82(6):1904 10 9177404
412 Hesley RP, Shepard KA, Jenkins DK, et al Monitoring estrogen replacement therapy and identifying rapid bone losers with an immunoassay for deoxypyridinoline Osteoporos Int 1998 8(2):159 64 9666940
413 Masahashi T, Negoro Y, Kuroki T, et al Biochemical markers of bone turnover during hormone replacement therapy Int J Gynaecol Obstet 1999 64(2):163 6 10189026
414 Zhan Z, Yamamoto I, Morita R, et al Urinary pyridinoline and deoxypyridinoline as bone metabolic markers in predicting therapeutic effects of estrogen and alfacalcidol in women with osteoporosis J Bone Miner Metabol 1999 17(2):113 8
415 Delmas PD, Hardy P, Garnero P, et al Monitoring individual response to hormone replacement therapy with bone markers Bone 2000 26(6):553 60 10831925
416 Dresner-Pollak R, Mayer M, Hochner-Celiniker D. The decrease in serum bone-specific alkaline phosphatase predicts bone mineral density response to hormone replacement therapy in early postmenopausal women. Calcif Tissue Int. 2000;66:104-7. [pmid: 10652956].
417 Bjarnason NH, Christiansen C Early response in biochemical markers predicts long-term response in bone mass during hormone replacement therapy in early postmenopausal women Bone 2000 26(6):561 9 10831926
418 Kelepouris N, Harper KD, Gannon F, et al Severe osteoporosis in men Ann Intern Med 1995 123(6):452 60 7639446
419 Baillie SP, Davison CE, Johnson FJ, et al. Pathogenesis of vertebral crush fractures in men. Age Ageing. 1992;21:139-41. [pmid: 1575093].
420 Peris P, Guanabens N, Monegal A, et al. Aetiology and presenting symptoms in male osteoporosis. Br J Rheumatol. 1995;34:936-41. [pmid: 7582699].
421 Langton CM, Ballard PA, Langton DK, et al Maximizing the cost-effectiveness of BMD referral for DXA using ultrasound as a selective population prescreen Technol Health Care 1997 5(3):235 41 9263372
422 Langton CM, Langton DK, Beardsworth SA Comparison of accuracy and cost effectiveness of clinical criteria and BUA for referral for BMD assessment by DXA in osteoporotic and osteopenic perimenopausal subjects Technol Health Care 1999 7(5):319 30 10543417
423 Tosteson A, Rosenthal DI, Melton LJ 3rd., et al Cost effectiveness of screening perimenopausal white women for osteoporosis: bone densitometry and hormone replacement therapy Ann Intern Med 1990 113(8):594 603 2119161
424 Garton MJ, Cooper C, Reid D Perimenopausal bone density screening -- will it help prevent osteoporosis? Maturitas 1997 26(1):35 43 9032745
425 Kanis JA, McCloskey EV Evaluation of the risk of hip fracture Bone 1996 18(3 Suppl):127S 32S 8777077
426 Swedish Council on Technology Assessment in Health Care Bone density measurement-a systematic review J Intern Med 1997 241(Suppl 739):1 60 9042086
427 Hailey D, Sampietro-Colom L, Marshall D, et al. INAHTA project on the effectiveness of bone density measurement and associated treatments for prevention of fractures. Statement of findings. Edmonton, Alberta, Canada: Alberta Heritage Foundation for Medical Research, on behalf of the International Network of Agencies for Health Technology Assessment; 1996.
428 Green CJ, Bassett K, Foerster V, et al. Bone mineral density testing: does the evidence support its selective use in well women? Vancouver, British Columbia, Canada: British Columbia Office of Health Technology Assessment; 1997. Report No. 97:2T.
429 Homik J, Hailey D. Quantitative ultrasound for bone density measurement. Edmonton, Alberta, Canada: Alberta Heritage Foundation for Medical Research; 1998. Report No. Health Technology Assessment 11.
430 Homik J, Hailey D. Selective testing with bone density measurement. Edmonton, Alberta, Canada: Alberta Heritage Foundation for Medical Research; 1999. Report No. Health Technology Brief 4.
431 Ultrasonography of the heel for diagnostic osteoporosis and selecting patients for pharmacologic treatment. Chicago: Blue Cross and Blue Shield Association; 1999.
432 Osteoporosis: clinical guidelines for prevention and treatment. London: Royal College of Physicians of London; 1999.
433 Consensus statement on prevention and treatment of osteoporosis. 1999.
434 Monitoring of bone density to assess active treatment of osteoporosis. Chicago: Blue Cross and Blue Shield Association; 2000.
435 Bauer DC. Personal communication. March 17, 2000.
436 Health Technology Assessment Number 6: Bone Densitometry: Patients with Asymptomatic Primary Hyperparathyroidism. AHCPR Pub. 1995; 96-0004.
437 Guide to clinical preventive services. 3rd ed. Baltimore: Williams & Wilkins; 1996.
438 Kreiger N, Kelsey JL, Holford TR, et al An epidemiologic study of hip fracture in postmenopausal women Am J Epidemiol 1982 116(1):141 8 7102649
439 Bean N, Bennett KM, Lehmann AB Habitus and hip fracture revisited: skeletal size, strength and cognition rather than thinness? Age Ageing 1995 24(6):481 4 8588536
440 Turner LW, Wang MQ, Fu Q Risk factors for hip fracture among southern older women South Med J 1998 91(6):533 40 9634114
441 Smeets-Goevaers CG, Lesusink GL, Papapoulos SE, et al The prevalence of low bone mineral density in Dutch perimenopausal women: the Eindhoven perimenopausal osteoporosis study Osteoporos Int 1998 8(5):404 9 9850346
442 Kroger H, Tuppurainen M, Honkanen R, et al Bone mineral density and risk factors for osteoporosis -- a population-based study of 1600 perimenopausal women Calcif Tissue Int 1994 55(1):1 7 7922782
443 Blaauw R, Albertse EC, Beneke T, et al Risk factors for the development of osteoporosis in a South African population. A prospective analysis S Afr Med J 1994 84(6):328 32 7740378
444 Parra-Cabrera S, Hernandez-Avila M, Tamayo-y-Orozco J, et al Exercise and reproductive factors as predictors of bone density among osteoporotic women in Mexico City Calcif Tissue Int 1996 59(2):89 94 8687975
445 Shaw CK An epidemiologic study of osteoporosis in Taiwan Ann Epidemiol 1993 3(3):264 71 8275199
446 Sowers MR, Clark MK, Hollis B, et al Radial bone mineral density in pre- and perimenopausal women: a prospective study of rates and risk factors for loss J Bone Miner Res 1992 7(6):647 57 1414483
447 Brot C, Jensen LB, Sorensen OH Bone mass and risk factors for bone loss in perimenopausal Danish women J Int Med 1997 242(6):505 11
448 Grampp S, Genant HK, Mathur A, et al Comparisons of noninvasive bone mineral measurements in assessing age-related loss, fracture discrimination, and diagnostic classification J Bone Miner Res 1997 12(5):697 711 9144335
449 Shiraki M, Kushida K, Fukunaga M, et al A placebo-controlled, single-blind study to determine the appropriate alendronate dosage in postmenopausal Japanese patients with osteoporosis. The Alendronate Research Group Endocr J 1998 45(2):191 201 9700472
450 Parviainen MT, Jaaskelainen K, Kroger H, et al Urinary bone resorption markers in monitoring treatment of symptomatic osteoporosis Clin Chim Acta 1999 279(1-2):145 54 10064126
451 Ravn P, Bidstrup M, Wasnich RD, et al. Alendronate and estrogen-progestin in the long-term prevention of bone loss: four-year results from the early postmenopausal intervention cohort study. A randomized, controlled trial. Ann Int Med. 1999;131:935-42. [pmid: 10610644].
452 Hosking D, Chilvers CED, Christiansen C, et al Prevention of bone loss with alendronate in postmenopausal women under 60 years of age N Engl J Med 1998 338(8):485 92 9443925
453 Torgerson DJ, Donaldson C, Reid DM Bone mineral density measurements: are they worth while? J R Soc Med 1996 89(8):457 61 8795500 1295888
454 Physician's guide to prevention and treatment of osteoporosis. Washington, DC: Excerpta Medica, Inc.; 1999.
455 Section III: Guidelines of care on osteoporosis for primary care physicians. 1997:1-7.
456 AACE clinical practice guidelines for the prevention and treatment of postmenopausal osteoporosis. 1996:1-19.
457 Recommendations for the prevention and treatment of glucocoriticoid-induced osteoporosis. Arthritis Rheum. 1996;39:1791-9. [pmid: 8912500].
458 Clinical practice guidelines for the diagnosis and management of osteoporosis. Can Med Assoc J. 1996;155:1113-33. [pmid: 8873639]. [pmcid: 1335371].
459 Kanis JA, Delmas P, Burckhardt P, et al Guidelines for diagnosis and management of osteoporosis. The European Foundation for Osteoporosis and Bone Disease Osteoporos Int 1997 7(4):390 406 9373575
460 Summary and recommendations of the report "Osteoporosis -- Clinical guidelines for the prevention and treatment." 1999.
461 Canadian Consensus Conference on Menopause: Osteoporosis. J Soc Obstet Gynaecol Can; 1998.
462 The prevention and management of osteoporosis Med J Aust 1997 167(Suppl):51 515
463 Osteoporosis guidelines. San Diego; 1998.
464 McClung MR. Nonpharmacologic management of osteoporosis. In: Marcus R, editor. Osteoporosis. Boston: Blackwell Scientific Publications; 1994. p. 336-53.
465 Miller PD. Management of osteoporosis. Adv Intern Med. 1999;44:175-207. [pmid: 9929709].
466 Juby A. Managing elderly people's osteoporosis. Why? Who? How?. Can Fam Physician. 1999;45:1526-36. [pmid: 10386218].
467 Rosen CJ. The diagnosis and treatment of postmenopausal osteoporosis. In: Rosen CJ, editor. Osteoporosis: diagnostic and therapeutic principles. Totowa, NJ: Humana Press, Inc.; 1996.
468 Lemcke DP. Section IV: Metabolic & Endocrine Disorders, Osteoporosis. In: Lemcke DP, Pattison J, Marshall LA, et al., editors. Primary care of women. Norwalk: Appleton & Lange; 1995.
469 Slovik DM. Section III: Endocrinology, Osteoporosis. In: Carlson KJ, Eisenstat SA, Frigoletto FD, et al., editors. Primary care of women. St. Louis: Mosby; 1995.
470 Byyny RL, Speroff L, editors. A clinical guide for the care of older women. Baltimore: Williams & Wilkins; 1996.
471 Krane SM, Holick MF. Metabolic bone disease. In: Fauci AS, Braunwald E, Isselbacher KJ, et al., editors. Harrison's principles of internal medicine. 14th ed. New York: McGraw-Hill Companies, Inc.; 1998.
472 Dagago-Jack S, Clutter WE. Mineral and metabolic bone disease. In: Ewald GA, McKenzie CR, editors. manual of medical therapeutics. Boston: Little, Brown and Company; 1995.
473 Reisz LG. Osteoporosis. In: Stein JH, editor. Internal medicine. 5th ed. St. Louis: Mosby; 1998.
474 Andreoli TE, Bennett JC, Carpenter CCJ, et al. Cecil essentials of medicine. 4th ed. Philadelphia: WB Saunders Company; 1997.
475 Neer RM. Osteoporosis. In: DeGroot LJ, editor. Endocrinology. Philadelphia: WB Saunders Company; 1995.
476 Primary osteoporosis. In: Wilson JD, Foster DW, Kronenberg HM, et al. Williams textbook of endocrinology. Philadelphia: WB Saunders Company; 1998.
477 Tohme JF, Cosman F, Lindsay R. Osteoporosis. In: Becker KL, editor. Principles and practice of endocrinology and metabolism. Philadelphia: JB Lippincott Company; 1995.
478 Strewler GJ. Mineral metabolism and metabolic bone disease, Chapter 17. In: Greenspan FS, Strewler GJ, editors. Basic and clinical endocrinology. 5th ed. Stamford, CT: Appleton and Lange; 1997.