# Acknowledgments

We thank the following members of the Oregon Health & Science University (OHSU) Evidence-based Practice Center staff for their contributions to this project: Piper Hackett, B.S. Kathryn Pyle Krages, A.M.L.S., M.A. Alix E. Seif, M.A. Patty Davies, M.S. Patty Davies, M.S.Gary Miranda, M.A. Connie Levesque, B.S. Cynthia Davis-O'Reilly Benjamin Chan, M.S. Jeani Crichlow, B.S. Lynne Schwabe I'eisha Parker Linda Slattery Katy Lesowski