# Future Research

Much of the evidence for diagnosis and monitoring strategies for osteoporosis comes from epidemiologic studies. To be more useful for clinicians and patients, and include a wider diversity of patient populations, future research should focus on the application of these data to the clinical setting.

Tools for assessing risk factors should be tested in prospective studies to determine if their use can correctly stratify women by risk factors, influence treatment decisions, and ultimately reduce fracture outcomes.

Clinical trials should be done to determine if identifying and reducing modifiable risk factors influences fracture outcomes. Some of these modifiable risk factors already have demonstrated effects on fracture risk after intervention, such as supplementation with calcium and vitamin D, and estrogen replacement after menopause. Examples of additional interventions to test include smoking cessation, correcting visual loss, and improving physical function.

Randomized controlled trials of treatments for osteoporosis should be done to test the hypothesis that overall fracture risk, rather than bone measurement results alone, determines the likelihood that a patient will benefit from therapy. Selection of patients for trials should focus on groups of patients who are at high risk of fracture based on clinical risk factors and who have relatively normal bone measurement results. Trials also should address whether patients identified to have bone loss demonstrated by different techniques at different sites have a similar benefit to those identified solely by hip DXA measurements.

Additional research is needed to examine the quality of information provided to patients who undergo various bone measurement tests, as well as to identify other patient education and information needs.

Future research should examine the clinical utility of the WHO working group's criterion for diagnosing osteoporosis, specifically:

- To determine whether the diagnosis of osteoporosis provides benefits to patients above that which is provided by predicting their risk of fractures.
- To assess the added value of obtaining bone measurement tests at more than one site, and the usefulness of using T-scores for different sites.
- To define the prognosis and treated course in patients who would be diagnosed to have osteoporosis by a wrist or spine measure but would not be diagnosed to have osteoporosis by a hip measure.
- To determine if the use of bone measurement results and risk factors together to estimate absolute fracture risk is a valuable method to define treatment thresholds.

Studies of using bone measurement tests for monitoring response to therapy could compare fracture outcomes in a group of patients who had tailored therapy based on test results versus a group in whom changes in therapy, if any, were guided by the history alone. A study also could record how often test results in patients on therapy led to a change in therapy or improved compliance, to establish the mechanism by which monitoring led to improved outcomes. By comparing patients, such a study could establish that monitoring changes in test results can reliably predict fracture risk in individual patients by distinguishing an inadequate response to therapy from an adequate response or poor adherence, and that monitoring changes in therapy made because of an inadequate test response can reduce the rate of fractures.

Prospective studies of biochemical markers should define, apply, and evaluate criteria for using marker results in clinical decisionmaking.

Determining the utility of screening for secondary disorders using common laboratory tests requires studies of the frequency of abnormal baseline laboratory tests in large cohorts, such as the SOF, or in large treatment trials of osteoporosis. Clinical followup of these subjects would provide data on bone measurement test results or fracture outcomes.

Studies to formally account for the adverse quality-of-life impact of treatment and treatment side effects are needed to more accurately determine the balance of risks and benefits of therapy options for patients.

Three areas for additional cost-effectiveness research include:

- Identifying a scientifically appropriate cut point for QUS/BUA that can be used in either a sequential diagnostic approach or for diagnosis with QUS alone.
- Performing a cost-effectiveness analysis using data from EPIDOS (or other large cohort) with various cut points similar to that performed with the SOF data in our analysis to support these results.
- Conducting a more detailed, societal perspective cost-effectiveness analysis perhaps incorporated into the trial described above that would address some of the deficiencies of our analysis.

If these findings can be demonstrated in one or two other populations and in a more complete economic evaluation, a randomized controlled trial of diagnostic approaches would be a useful next step. Alternatively, an observational study with randomization of groups of patients to diagnostic or monitoring procedures could be conducted.