# Conclusions

Table 14 summarizes the type of study design and the quality of the evidence from studies examined for each key question in the analytic framework (Figure 1). It is important to note the difference between key questions that lack evidence because studies show no effect as opposed to those that lack evidence due to poorly done or absence of studies.

Table 14. Summary of evidence for key questions in analytic framework^a^

Linkage: Step in analytic framework | Study type ^b^ | Quality of evidence (defined in Appendix C)
Arrow 1
What risk factors predict bone density, bone loss, and fractures? | II-2 | Good: Several large prospective studies; many consistent findings.
Are tools for assessing risk factors accurate in identifying women at risk for fractures? | II-2 | Fair-Good: Few studies; tools usually are not validated or tested prospectively.
Arrow 2
How well do the different bone measurement tests at different sites predict fractures? | II-2 | Fair-Good: Several large fair and good-quality cohort studies.
What factors related to bone testing influence diagnosis? | II-2 | Fair-Good: Studies vary because of multiple techniques, sites, and reference standards; difficult to apply to individual patients.
Can markers be used instead of bone measurement tests in identifying women at risk for osteoporosis? | II-2 | Poor-good: Small samples; narrow spectrum of patients; inconsistent results.
What are the adverse effects of using markers to identify women at risk for osteoporosis? | | No studies available.
How well do markers predict fractures? | II-2 | Fair-good: Small samples; results not generalizable; inconsistent results.
Arrow 3
Are risk factors useful in treatment decisions? | III | There are no studies of patients who are at high risk of fracture based on clinical risk factors but who have normal bone measurement results.
How do the results of bone measurement tests affect patients' and physicians' decisions and actions? | I, II-3, III | Poor-Fair: Small descriptive studies; study population may not be generalizable.
Are bone measurement tests effective for monitoring response to therapy and for guiding decisions about changes in management? | III, II-2 | Poor-Fair: No studies of the use of monitoring in clinical decisions.
Can markers help select patients for treatment? | II-2 | Poor-Good: Two large population-based studies; others small and from single institutions; results inconsistent.
What are the adverse effects of using markers to identify women at risk for osteoporosis? | | No studies available.
Can markers predict response to therapy? | II-2 | Poor-Good: Several population-based or multicenter studies; results inconsistent; gold standard (2-yr change in DXA) may not be reliable.
What diagnostic or laboratory tests are appropriate for evaluating patients with osteoporosis for secondary causes? | III | No studies available.
Arrow 4
What are the costs and cost-effectiveness of diagnostic strategies for identifying women with osteoporosis? | III | Poor: Only cost-effectiveness models are available; none are based on comparative studies of diagnostic approaches.

a U.S. Preventive Services Task Force^437^

b Study design categories: I = randomized, controlled trials; II-1 = controlled trials without randomization; II-2 = cohort or case-control; II-3 = multiple time series; III - opinions, descriptive epidemiology.

DXA = dual-energy X-ray absorptiometry

## Risk Factors

### What Risk Factors Predict Bone Density, Bone Loss, and Fractures?

Several factors are consistently associated with increased risks of low bone density and fractures in postmenopausal women, including increasing age, white race, low weight or weight loss, nonuse of estrogen replacement, history of previous fracture, family history of fracture, history of falls, and low scores on one or more measures of physical activity or function. Other factors are less consistent predictors across studies, but also have significant associations with bone density and fractures. These include smoking, alcohol use, caffeine use, low calcium and vitamin D intake, and use of certain drugs. Additional risk factors are important in specific studies. The relative risks of several risk factors are comparable to that of a 1 standard deviation difference in bone density. Predictors for low bone density are similar to those for fracture except for those specifically related to falls. Most of the strongest risk factors are consistently related to outcomes in different racial and ethnic populations. Risk factors are generally similar for the various fracture sites except that fractures related to falls have additional functional risk factors.

### Are Tools for Assessing Risk Factors Accurate in Identifying Women at Risk for Fractures?

Few studies report results of the performance of tools for assessing clinical risk factors for osteoporosis. Our evidence review suggests that specific tools to assess risk have inadequate sensitivity and specificity and have not yet been widely tested. Generalizability of these tools to the clinical setting is therefore currently limited. However, some tools -- especially those developed in large community populations and containing variables known to be strong predictors -- may ultimately be applicable to the clinical setting once they are tested there.

Although this approach may be useful in the general population, translating the results of population studies to the care and management of individuals requires additional considerations. Risk factors that are not common may be dominant in individual patients. Also, some risk factors may be important for different types of fractures and for different age groups, for example. It is not yet known how tools for risk assessment would perform under these varying circumstances. In addition, clinicians may find it difficult to selectively exclude low-risk women from diagnostic protocols because a substantial number of women without specific risk factors also experience fractures. Patients may have similar concerns.

### Are Risk Factors Useful in Treatment Decisions?

Identification of important risk factors could be useful in making treatment decisions. Although models have been proposed, they have not been prospectively tested in large trials and are not used by clinicians. Clinical trials have not focused on what should be done for patients who have several risk factors and a high overall risk of fracture but who do not meet the WHO definition for osteoporosis. A few risk factors -- sex, race, age, menopause, a history of previous fracture, and low bone density -- have been primary selection criteria for randomized trials of bisphosphonates and provide clues to the validity of the risk-based approach.

## Bone Measurement Testing

### How Well do the Different Bone Measurement Tests at Different Sites Predict Fractures?

Among different bone density tests measured at various sites, bone density measured at the femoral neck by DXA is the best predictor of hip fracture and is comparable to forearm measurements for predicting fracture at other sites.

In recent prospective studies, QUS measured at the heel predicted hip fracture and all nonspine fractures as well or nearly as well as DXA measured at the femoral neck. For both tests, a result in the osteoporotic range is associated with an increased short-term probability of hip fracture. However, clinical trials of recent pharmacologic therapies have used a low hip DXA, rather than QUS, as a criterion for entry. Physicians who use QUS must consider whether the results of these trials are generalizable to patients identified by QUS to have a high risk of fracture.

QUS of the heel and DXA of the hip provide independent information about fracture risk. Individuals who have low scores by one of these tests, but not the other, have a greater risk of fracture than those who have higher scores by both tests, and a lower risk of fracture than those whose results on both tests are low.

Both of these tests predict hip fracture better than DXA of the lumbar spine. RA or QMD of the hand can predict the risk of nonspine fractures in general, many of which are in the forearm, but there are no recent data about the ability of hand measurement to predict hip fracture. Correlations between different bone measurement tests are generally too low to be accepted as evidence that one test will identify patients at similar risk to those identified by another test. While peripheral measures may approach hip DXA in predicting hip fracture, there are no recent prospective studies that directly compare prediction of hip fracture by these tests with DXA of the hip.

### What Factors Related to Bone Testing Influence Diagnosis?

The likelihood of being diagnosed with osteoporosis varies greatly, depending on the site and type of bone measurement test, on the brand of densitometer, and on the relevance of the reference range in the local population. The variation between techniques, along with the lack of methods to integrate bone density results with clinical predictors, makes it difficult for clinicians to provide accurate information to patients about their test results.

The likelihood of being diagnosed with osteoporosis also depends on the number of sites tested. Testing in the forearm, hip, spine, or heel will generally identify different groups of patients. A physician cannot say, based only on a forearm test, that the patient "does not have osteoporosis." Conversely, although the results of a test at any site are associated to some degree with fractures at other sites, the physician may not be able to assess whether the patient who has a low T-score on a hand or forearm test has significant bone loss at other sites.

Because of these limitations, some experts question whether there is added benefit to the patient from using T-scores to diagnose osteoporosis, as opposed to reporting test results as continuous values and assessing overall risk. Others propose that results using various techniques and sites be "calibrated" to the results of DXA of the hip and reported as a "T-score equivalent." The success of this approach may be limited by differences in precision and low correlation among different techniques.

### How do Bone Measurement Test Results Affect Patients' and Physicians' Decisions and Actions?

One randomized trial suggests that women who undergo densitometry are more likely to start HRT than women who do not. In a randomized trial and a large uncontrolled case series, women who had densitometry and were told they had osteoporosis were more likely to start or continue HRT than women who were told they had normal bone density. In one randomized trial, physicians found densitometry reports confusing and were not confident that their interpretations of T-scores were correct. While overall the reporting format did not influence treatment decisions, gynecologists who better understood the report were more likely to prescribe changes in HRT than those who considered the report confusing. These results suggest that the behaviors of both patients and physicians are influenced by the results of bone measurement tests.

## Monitoring

### Are Bone Measurement Tests Effective for Monitoring Response to Therapy and for Guiding Decisions about Changes in Management?

Currently, the weight of evidence is against repeating bone density tests within the first year of treatment. There is insufficient evidence to determine whether repeating bone density tests 2 years after starting therapy is useful. There also are no studies about the effect of monitoring responses to therapy using densitometry, or of the choice of test, on the outcome of therapy.

## Biochemical Markers

### Can Markers be Used Instead of Bone Measurement Tests in Identifying Women at Risk for Osteoporosis?

No single marker or cluster of markers accurately predicted the results of densitometry in individuals. Densitometry measures current bone status, whereas markers measure the process of bone turnover.

### How Well do Markers Predict Fractures?

No marker was associated with increased fracture risk consistently across all studies. The EPIDOS study provides evidence that using markers in conjunction with densitometry may increase predictability, but this result has not been confirmed in other studies.

### Can Markers Help Select Patients for Treatment?

Studies correlating marker results and bone loss indicated no clear trend. Sensitivity and specificity were too low to be useful for the purpose of selecting patients for treatment. Some studies found better test accuracy when a combination of two or more markers and/or other risk factors was used to predict bone loss.

### What are the Adverse Effects of Using Markers to Identify Women at Risk for Osteoporosis?

The primary adverse effect of biochemical markers is the potential for false-positive and false-negative results. Rates of false-positive and false-negative test results vary widely. If markers were used to select women for treatment, a false-positive test could lead to the initiation of unnecessary treatment. A false-negative result could lead to more serious consequences if markers were to be used as an initial test to select women for further testing.

### Can Markers Predict Response to Therapy?

There is a small correlation between response to therapy as measured by densitometry and marker results, but no marker is accurate enough to reliably identify nonresponders to treatment. The best results, from the EPIDOS study, have not been replicated in other studies. The use of bone density at 2 years as the gold standard for measuring response to therapy has been called into question by a recent study that found that bone density at 2 years is not a reliable predictor of subsequent response to therapy.

## Evaluation for Secondary Causes

### What Diagnostic or Laboratory Tests are Appropriate for Evaluating Patients with Osteoporosis for Secondary Causes?

There is no evidence on which to base recommendations for a strategy of testing to determine secondary causes of osteoporosis. The accumulated literature suggests only the presence of low bone density in certain disorders such as hyperparathyroidism, multiple myeloma, and hyperthyroidism, but not the prevalence of these disorders given a diagnosis of osteoporosis.

Despite this lack of evidence, expert opinion and practice guidelines provide many suggestions for diagnostic workups. Some support extensive testing to rule out major concomitant disease, while others suggest a limited testing strategy based on findings in the history and physical examination. Because the diagnosis of primary osteoporosis is often seen as a diagnosis of exclusion, the pattern of diagnostic testing may continue to be costly until the diagnostic yield is fully demonstrated.

Within the community, the pattern of testing varies widely, particularly by specialty type. Our supplemental analysis suggested that assumptions about the probability of a secondary disease or disorder to explain the occurrence of osteoporosis vary by practice type and specialty. TSH, chemistry battery, and complete blood count were the most frequently ordered tests cited by respondents. These also were the most frequently recommended tests in our review of expert guidelines.

## Cost

### What are the Costs and Cost-Effectiveness of Diagnostic Strategies for Identifying Women with Osteoporosis?

In the literature we reviewed, economic assessments suggested that diagnosis and treatment of women at risk for osteoporosis would be more cost-effective by targeting treatment to those with the lowest bone measurement results. Inclusion of another assessment prior to the bone measurement test may improve the cost-effectiveness of diagnosis. The other assessment could be a risk profile (such as SCORE) or a less expensive, and perhaps more widely available, diagnostic test such as QUS of the heel.

We conducted cost-effectiveness analyses to estimate cost per hip fracture prevented using data from EPIDOS and SOF (see Supplemental Analysis 2). These analyses suggested that a sequential diagnostic approach was more cost-effective than using DXA of the femoral neck alone. The sequential approach we considered was QUS of the heel followed by DXA of the femoral neck only for those with low values of QUS/BUA. Diagnosis with DXA of the femoral neck alone prevented more fractures in most cases, but at an increased cost per fracture prevented compared with the sequential approach. Using SOF data, if the overall incidence of fractures were increased, that is, if the population were at a five- to tenfold higher risk of fracture than the SOF reported, the incremental cost per hip fracture prevented using diagnosis with QUS alone (compared with DXA alone) dropped. QUS alone may be a cost-effective option in high-risk populations. In senstitivity analyses, if treatment efficacy following diagnosis with QUS were 5 percent or 15 percent less than that following diagnosis with DXA, diagnosis with QUS alone would have higher costs to prevent fewer hip fractures than other diagnostic options. If reduction in fracture risk reduction is as little as 5 percent less than diagnosis with DXA, QUS alone may be dominated by other alternatives.