# Results

## Risk Factors

Although the role of clinical risk factors in diagnosing and monitoring osteoporosis is currently unresolved, much research indicates that clinical risk factors serve as important predictors of bone density and fractures. Prospective studies have demonstrated that while bone density is a major predictor of future fractures, it is only one factor in a complex interaction of many (Figure 3). Other factors that are not related to bone density, such as those related to falls, significantly contribute to hip fracture occurrence.

Figure 3. Risk factors for fracture ^a^ a Risk of fracture depends on many factors relating to reisk of fall, force of impact, and strength of bone. Some risk factors, such as age, have multiple effects while others are specific to one of these components. Adapted from Kanis JA, McCloskey EV.^ 424 ^

Some risk factors are potentially modifiable. Identification of these factors could allow a clinical intervention, such as changing medication or improving visual acuity, to prevent falls leading to fractures. Women at risk may benefit by knowing what their risk factors are and how to modify them. Preventive measures such as exercise, increased calcium intake, cessation of smoking or excess alcohol use, and improved safety measures at home are steps women could make to potentially reduce their fracture risks.

In this section, we address three questions about risk factors, focusing on those that are most useful in the clinical setting:

- What risk factors predict bone density, bone loss, and fractures?
- Are tools for assessing risk factors accurate in identifying women at risk for fractures?
- Are risk factors useful in treatment decisions?

### What Risk Factors Predict Bone Density, Bone Loss, and Fractures?

Many studies have been published about risk factors for low bone density, bone loss, and fractures in postmenopausal women. These studies vary by design, population, measurement of risk factors and outcomes, and methods of analysis. No single study includes all risk factors and outcomes of interest, although longitudinal studies and well-done case-control studies that use multiple regression methods provide some of the best evidence about the independent contribution of risk factors.

The Study of Osteoporotic Fractures (SOF), a good-quality prospective study of nearly 10,000 U.S. women age 65 and older, tested the relationship of potential clinical risk factors in multivariate models.^ 54 ^ Fourteen risk factors remained significant predictors in the model after adding a history of fracture since age 50 and calcaneal bone density, including 5 measures of function (not walking for exercise, on feet 4 or fewer hours per day, inability to rise from a chair, low distant depth perception, low low-frequency contrast sensitivity), and 2 modifiable risk factors (current caffeine intake and current use of long-acting benzodiazepines). The other significant risk factors included age, history of maternal hip fracture, no increase in weight since age 25, height at age 25, self-rated health, previous hyperthyroidism, and resting pulse over 80 beats per minute. The relative risk of hip fracture per one standard deviation decrease in calcaneal bone density was 1.6 (1.3-1.9). This was comparable to the magnitude of the relative risks of most of the other significant predictors in the model that ranged from 1.2 to 2.0 (Evidence Table 1).

These results were used to illustrate the combined influence of declining calcaneal bone density and increasing number of clinical risk factors on hip fracture risk (Figure 4). Those with 5 or more of the 14 risk factors found to be significant in the model had increased rates of hip fractures compared with those with zero to two risk factors at all levels of calcaneal bone density. Specifically, women in the middle tertile of bone density with five or more risk factors had 14.7 hip fractures per 1,000 women-years compared with those with zero to two risk factors who had a rate of 1.1 per 1,000 women-years.

Figure 4. The combined influence of bone density and clinical risk factors on the annual risk of hip fracture ^a^ a The risk of hip fracture increased with increasing numbers of risk factors at all levels of calcaneal bone density in the Study of Osteoporotic Fractures cohort. Multiple regression models identified 14 significant risk factors used to stratify subjects. Adapted from Cummings SR, Nevitt MC, Browner WS, et al.^ 54 ^

These data demonstrate that factors other than bone density significantly affect the risk of fracture. Other investigations support this observation. A good-quality, large prospective study of fall-related factors and hip fracture from the Epidemiologie de l'Osteoporose (EPIDOS) cohort of European women age 75 years and older found that independent fall-related predictors of hip fracture included slower gait speed, difficulty in performing a tandem walk, reduced visual acuity, and small calf circumference.^ 55 ^ After adjustment for femoral bone density, all functional measures remained significant. Another study from the same cohort reported that femoral bone density (adjusted RR [ARR] for hip fracture 1.6; CI 1.38-1.95), calcaneal BUA (ARR 1.4; CI 1.2-1.7), gait speed (ARR 1.5; CI 1.3-1.7), and age (ARR 1.5; CI 1.2-1.8) have approximately the same discriminant value to identify women at high risk of hip fractures.^ 56 ^

Similarly, in a prospective study of 1,177 elderly women in residential care, cognition assessed with the Clifton Assessment Procedure for the Elderly (CAPE) was a strong predictor of hip fracture compared with calcaneal QUS (Figure 5).^ 57 ^ CAPE measures three components: orientation, mental ability, and psychomotor coordination. In women who had calcaneal QUS measurements in the lowest third of participants, the incidence of hip fracture over 2 years was 12.8 percent in those with poor cognition scores, 6.5 percent with medium cognition, and 3.4 percent with high cognition. In women in the highest third, those with poor cognition scores had over four times the incidence of hip fracture as those with high cognition (6.2 percent versus 3.1 percent for medium cognition, and 1.5 percent for high cognition). Notably, the risk of fracture was higher for women with relatively high bone density and poor cognition (6.2 percent) than for those with relatively low bone density and high cognition (3.4 percent).

Figure 5. 2-year incidence of hip fractures based on calcaneal ultrasound and cognition scores ^a^ a Cognitive function was measured in elderly, institutionalized women and found to be an important risk factor for hip fractures at all levels of ultrasound measures of the calcaneus. Adapted from Porter RW, Miller CG, Grainger D, et al.^ 57 ^

Although most studies about risk factors and fractures have focused on hip fracture outcomes, risk factors for other types of fractures also have been reported.^58-61^ Other fractures, such as wrist and vertebral fractures, are more common in postmenopausal women than hip fractures and may be especially dominant in younger peri- and postmenopausal women. In a population-based prospective cohort of 3,140 Finnish women age 47-56 years (mean age 53), DXA of the lumbar spine and femoral neck and other clinical risk factors were assessed at baseline, and incident fractures were recorded over 2.7 years of followup.^ 62 ^ Fractures of the wrist were the most common type of fracture in this cohort (n=46), followed by fractures of the ankle (n=30) and rib (n=26); vertebral (n=7) and hip (n=1) fractures were less common. In this study, women with fractures had significantly lower bone density at lumbar and femoral sites compared with those without fractures. History of a previous fracture was a strong predictor of further fractures (OR 2.83 [CI 1.95-4.10]). Women with fractures also had higher weekly alcohol intake (100 g/week or more; OR 1.70 [CI 1.08-2.67]), and were more likely to be younger than 45 years when they had undergone bilateral oophorectomy (OR 3.64; CI 1.01-13.04). Women on hormone replacement therapy (HRT) were less likely to have a fracture (OR 0.94;0. CI 88-0.99). Smoking, type of menopause, age at menarche, parity, and lactation history did not differ between the groups.

A prospective study of incident vertebral fractures in 5,807 postmenopausal women 65 years or older from the SOF found several differences between women with fractures and those without.^ 25 ^ Women experiencing their first vertebral fracture were significantly older and thinner, had a decline in grip strength compared with previous values, were less likely to take estrogen, and reported more mean height loss since age 25 years than women without fractures. A case-control study of vertebral fracture risk factors in 1,012 women in the United Kingdom found that those with fractures were significantly older, shorter, had an earlier menopause, lower parity, and a greater frequency of hyperthyroidism than those without vertebral fractures.^ 63 ^

Risk factors for low bone density and bone loss also could be important to consider when making decisions about bone specific treatment such as bisphosphonates. If a woman's risk factors are primarily functional, such as an unsteady gait or poor cognitive function that increase her risk for falls leading to fractures, improving her bone density by prescribing medications may not be in her best interest. Several studies evaluated risk factors for low bone density and bone loss and are described in Evidence Tables 2 and 3. Risk factors associated with spine and proximal femur bone density have been reported by the SOF based on analysis of cross-sectional data.^ 64 ^ Weight was the most strongly associated factor. Estrogen exposure, physical activity, and calcium intake were positively associated with bone density, whereas a family history of osteoporosis was associated with reduced bone density. A similar analysis of risk factors associated with bone density at radial sites was conducted in the SOF cohort.^ 65 ^ This study found that a large number of factors influenced the bone density of these women, and that age, weight, muscle strength, and estrogen use were the most important. These findings are summarized in Figure 6.

Figure 6. Correlates of lumbar, femoral neck, and distal radius bone density ^a^ a Correlations were derived from multivariable analyses of the Study of Osteoporotic Fractures cohort and indicate positive (+) and negative (-) effects on bone density. Three symbols indicate 3% or greater change in bone density per unit change in variable; 2 symbols, a 1% to 3% change; and one symbol, a change of less than 1%. Adapted from Orwoll ES, Bauer DC, Vogt TM, et al.^ 64 ^

Numerous studies about single or related risk factors for osteoporosis and fractures also have been published. These studies were conducted in a variety of populations and present additional insights about individual factors that were not considered in studies investigating multiple predictors.

#### Race and Ethnicity

Throughout the adult lifespan, black women have higher bone density than white women at every site tested.^ 66 ^ They have a higher peak bone density and a slightly slower rate of adult bone loss from the femur and spine. These measures have been found to be higher in whites than in Asians^ 67 ^ and North American Indians.^ 68 ^ Hip fractures are more common in white women (139/100,000) than in Mexican-American (67/100,000) or black (55/100,000) women.^ 69 ^ Japanese women also have a lower fracture rate than white women.^ 70 ^

In a good-quality case-control study, risk factors for hip fracture in U.S. urban black women were similar to those found in studies of nonblack women.^ 71 ^ These include thinness, previous stroke, use of aids in walking, and alcohol consumption (odds ratios listed in Evidence Table 1). Postmenopausal estrogen therapy for 1 year or more was protective.

A good-quality prospective cohort study of elderly Japanese women found that age, low body mass index (BMI = [weight in kg]/[height in m]^2^), regular alcohol use, previous vertebral fractures, and having five or more children were risk factors for hip fracture.^ 72 ^ A case-control study in Japan also found low BMI and alcohol use related to hip fracture.^ 73 ^ In addition, it noted that previous residence in a rural area, sleep disturbance, stroke with hemiplegia, coffee use, and use of a Western bed were risk factors; eating fish was found to be protective.

#### Height, Weight, and Body Mass Index

Several studies reported a positive relationship between fracture and height.^74-77^ Some of these associations included current height, height at age 25, and height loss.^54,74^ Height loss also was associated with low bone density.^ 78 ^ These relationships may be explained by the differences in bone geometry that promote fracture occurrence in taller women.

Weight and BMI are consistent predictors of bone density and fractures in many studies. Increasing weight and BMI are associated with higher bone density,^79-85^ and both lean body mass and fat body mass appear to affect bone density in most of these studies.

Women with higher weight and BMI have lower risks for fractures,^54,74,77,86-89^ although this effect was more consistent for hip fractures than wrist fractures in some studies.^ 90 ^ Involuntary weight loss and weight variability significantly increased risks for fracture in several studies, including the SOF.^91-95^ Low body weight was as significant a risk factor for hip fracture for black women^ 96 ^ and Japanese women^ 72 ^ as for white women. Mechanisms for this relationship include decreased sex hormone-binding globulin levels that increase free sex steroid levels in obese women,^ 80 ^ weight-bearing mechanical forces on bone, cushioning of the hip against the impact of a fall, and weight loss acting as a marker of illness and fragility.

#### Family History

Consistently, women with a family history of osteoporosis have lower bone density than those without.^97,98^ In the SOF cohort, the risk of hip or wrist fracture was increased in those with a family member with a hip or wrist fracture. The relative risk of hip fracture for those with a mother's (RR 1.48; CI 1.03-2.11), sister's (RR 1.83; CI 1.20-2.80), or brother's (RR 2.26; CI 1.16-4.42) history of hip fracture was not affected by adjustment for bone density.^54,99^

Studies of postmenopausal women and their premenopausal daughters report that daughters of women with low bone density also had low bone density when compared with daughters of women with normal bone density,^100-102^ although this was not found in every study.^ 103 ^ Studies of twins indicate that bone density^104-106^ is more highly correlated in monozygotic than in dizygotic twins.

#### Previous Fractures

Fracture history is associated with an increased risk for future osteoporotic fractures, independent of bone density. Data from the SOF cohort showed that women with a vertebral deformity found on conventional spine X-ray were almost three times as likely as others to suffer a hip fracture over 8 years of followup.^ 107 ^ Women with previous vertebral fractures are at increased risk for subsequent vertebral fractures.^108-111^ Those with previous wrist fractures have increased risks for subsequent hip fractures,^112-115^ and those women with previous fractures of various types are at risk for subsequent fractures at several sites,^116-119^ specifically at the hip.^54,120,121^ Having had a previous fracture identifies women who may have any number of predisposing risk factors that could result in another fracture.

#### Smoking, Alcohol, and Caffeine

A meta-analysis of 29 published cross-sectional studies of smoking and bone density indicated that postmenopausal bone loss was greater in current smokers than in nonsmokers.^ 122 ^ Bone density diminished by an additional 2 percent for every 10-year increase in age for smokers, with a difference of 6 percent at age 80. A study of twins found that for every 10 pack-years of smoking, the bone density of the twin who smoked more heavily was significantly lower at the lumbar spine and femoral shaft than that of the other twin.^ 123 ^

A meta-analysis of 19 cohort and case-control studies of smoking and hip fracture found that in current smokers relative to nonsmokers, the risk of hip fracture was similar at age 50 but greater thereafter by an estimated 17 percent at age 60, 41 percent at 70, 71 percent at 80, and 108 percent at 90.^ 122 ^ Individual studies reported that the risk of hip fracture increased with the amount smoked and did not reach nonsmoker levels until 10 years after cessation.^ 124 ^ Other studies found that the risk for hip fracture was higher for thinner smokers than for normal or overweight smokers,^ 125 ^ use of estrogen did not protect against fracture in smokers as it did in nonsmokers,^ 126 ^ and the risk for hip fracture was highest in smokers with low intake of vitamins E and C.^ 127 ^

Alcohol use is an inconsistent predictor of bone mass and fractures, probably because participants of studies typically represent low to moderate users and nonusers.^128-131^ Excessive alcohol use is a known secondary cause of osteoporosis. Data from the Framingham Study found that alcohol intake of at least 7 ounces per week was associated with high bone density,^ 132 ^ and current alcohol consumption was associated with a significant increase in risk of hip fracture, particularly in women under 65 years old (relative risk [RR] 2.96; CI 1.24-7.10).^ 133 ^ The effects of moderate alcohol on bone may be related to the augmentation of endogenous estrogen levels by alcohol.

Caffeine intake is inconsistently associated with bone density and fractures. Some studies have found that caffeine use is associated with low bone density at several sites^ 134 ^ and with annual percent loss of bone density,^ 135 ^ while others have found no association.^129,136,137^ The SOF reported current caffeine intake as a risk factor for hip fracture (RR 1.2; CI 1.0-1.5).^ 54 ^ In other studies, the risk for hip fractures was found to be mildly increased in women who drank more than two cups of coffee per day^73,138,139^ and more than four cups of coffee per day.^ 140 ^

#### Calcium, Vitamin D, and Fluoride

Randomized controlled trials indicate that supplemental calcium and vitamin D reduce the risk of hip fractures and other nonvertebral fractures in elderly women.^141,142^ The influence of calcium intake from dietary sources is less clear. Some studies report little or no association between dietary intake of calcium rich foods and bone density^ 143 ^ or fractures,^144-147^ including a study of NHANES I data.^ 148 ^ Other studies report that calcium intake through milk and milk products in childhood and adolescence was significantly lower in women with osteoporosis than in controls, although there was little difference between groups for intake later in life.^149,150^ In other studies, dietary calcium intake was associated with higher bone density^151-153^ and reduced risk of fracture.^121,154-156^ Vitamin D had its strongest positive effect in particularly frail, elderly women.^157,158^

Exposure to high levels of fluoride in drinking water has been found to cause changes in bone mineralization. Fluoride ions are incorporated into bone as fluoroapatite, influencing mineral structure and affecting bone strength. As a result, bone density may be higher than normal, but fractures are more common. A meta-analysis of studies of fluoride and bone density indicated that those with higher fluoride exposure had a reduced risk for diagnosis of osteoporosis (RR 0.39; CI 0.2-0.75).^ 159 ^ A similar meta-analysis of 18 studies of fluoride and fractures indicated that those with higher fluoride exposure had increased risks for any type of fracture (RR 1.12; CI 1.04-1.21).^ 159 ^ Several individual studies, however, did not find these relationships.^160-163^

#### Physical Function, Exercise, and Falls

Several measures of physical function have been found to be associated with bone density. Greater grip strength, usually measured by a hand-held dynamometer, had a significant positive association with bone density of the proximal femur,^164,165^ spine, and wrist sites,^ 165 ^ as well as a protective effect for hip fracture.^166-168^ Lower quadriceps strength,^ 169 ^ slower gait speed,^ 56 ^ and other functional measures^54,58^ were predictive of hip fracture. The risk of hip fracture also was increased in women with impaired vision.^54,89,170,171^

Several studies support the association between current exercise and higher bone density.^172-175^ Women with higher current activity levels have lower risk for fractures than those with less activity.^144,176-183^ Previous levels of exercise, such as during adolescence and young adulthood, have inconsistent associations with bone density later in life,^184-186^ but previous recreational activities were associated with a reduced risk of hip fracture in one study.^ 187 ^ Having had a previously active job in midlife also was associated with a reduced risk of hip fractures.^176,188^

More than 90 percent of hip fractures occur following a fall.^ 89 ^ For women over 70, the tendency to fall is a more important predictor than other factors in some studies.^189,190^ A history of falls is a significant risk factor for fractures in many studies.^88,168,191,192^ Risk factors for falls with resulting fractures include impaired mobility,^55,193,194^ environmental hazards,^195,196^ fear of falling, reduced knee extension strength, and poor visual acuity.^ 197 ^

#### Cognition and Depression

In the SOF, women with low baseline bone density had worse baseline cognitive scores, and women with vertebral fractures had lower cognitive test scores and a greater odds of cognitive deterioration than those without fractures.^ 198 ^ Hip fracture was found to be associated with both Alzheimer's disease and vascular dementia in a study that found the rate of hip fracture in these women to be more than twice that of the general population.^ 199 ^ Another study found that hip fractures are associated with Alzheimer's disease.^ 200 ^ Even women with mild impairment on the Mini-Mental Status Exam had a higher risk for hip fracture than those with normal results.^ 201 ^

Women with depression have been found to have lower spine^ 202 ^ and hip bone density^ 203 ^ than other women. Depressed women in the SOF also were more likely to fall, and to have increased rates of vertebral and nonvertebral fractures, than nondepressed women.^ 204 ^

#### Reproductive Factors

Several studies support associations between high bone density and a long reproductive period characterized by early menarche and late menopause,^ 205 ^ although late age at menopause and short time since menopause seem to be the most consistent factors across studies.^62,206-210^ One study found that the effect of menopause on fracture incidence was stronger than the effect of a 5-year increase in age.^ 211 ^ Late menopause also was associated with reduced risk for vertebral deformity.^ 212 ^ Other studies found no relationship among these factors.^207,213,214^ Experts believe there is an age-dependent risk associated with reproductive factors that assumes higher importance in younger cohorts.

Use of estrogen replacement has been consistently associated with higher bone density^ 215 ^ and decreased risks of fractures of many types, including wrist, vertebral, hip, and other nonvertebral fractures.^216-222^ Estrogen had a protective effect on fracture risk if used ever^ 218 ^ or used within 2 years of the study,^ 218 ^ for younger as well as for older postmenopausal women.^216,221^ The use of progestins has not been well evaluated in these studies.

A history of oral contraceptive use was protective against low bone density in some women,^223,224^ although the risk of subsequent fractures in women who had ever used oral contraceptives was greater than that of nonusers in another study.^ 225 ^ The effects of current doses of oral contraceptives on postmenopausal osteoporosis has yet to be determined.

Tubal ligation^ 226 ^ and parity^213,227^ were not found to be associated with fractures. Parity^72,214,228^ and number of previous miscarriages^ 228 ^ were not associated with bone density. Breastfeeding was protective for hip fracture in one study,^ 213 ^ but not in another,^ 227 ^ and was associated with higher bone density in others.^214,229^

#### Drugs

Many studies have reported the effects of commonly used drugs on bone. We considered glucocorticoid use as a secondary cause for low bone density and fractures and did not evaluate it in this review.

A meta-analysis of 18 observational studies found that current thiazide users were protected against hip fracture, with an overall odds ratio of 0.82 (CI 0.73-0.91).^ 230 ^ In the SOF, women on thiazides for more than 10 years had significantly higher bone density than nonusers.^ 231 ^ Thiazides also have been associated with reduced risk of wrist fractures.^ 232 ^ However, no randomized controlled trials of thiazides for fracture prevention have yet been conducted. A protective effect for furosemide also has been reported.^ 233 ^

Thyroxine-treated women with low thyroid-stimulating hormone (TSH) levels were found to lose bone density from the spine more rapidly than women without known thyroid disease.^ 234 ^ Low bone density measured at several anatomical sites also was found for long-term users of thyroid hormones at thyroxine- equivalent doses of 1.6 microgram/kg or greater.^ 235 ^ Other studies found no relationship between thyroxine use and bone density.^236-239^

A recent large, population-based, nested case-control analysis of individuals over 50 years old in the United Kingdom found that the use of statin drugs (HMG-CoA reductase inhibitors) for treatment of hypercholesterolemia was associated with a decreased risk of fractures (OR for women 0.56; CI 0.43-0.74).^ 240 ^ A case-control study including 6,110 New Jersey residents age 65 and older (83 percent women) found similar associations between statin use and reduction in hip fractures (adjusted OR 0.05; CI 0.37-0.76).^ 241 ^ Randomized controlled trials have not yet been done to confirm these relationships.

Use of antidepressants -- including selective seratonin uptake inhibitors, secondary-amine tricyclics, and tertiary-amine tricyclics -- has been associated with increased risks for hip fracture.^242-245^ Use of lithium was not associated with decreased bone density.^ 246 ^

Women who used propionic acid, but not acetic acid, nonsteroidal anti-inflammatory drugs (NSAIDs) had higher bone density at the radius and lumbar spine than nonusers.^ 247 ^ Data from the SOF indicated that daily use of aspirin or NSAIDs was associated with increased bone density of the hip and spine, but there was not a significant change in risk for hip fracture.^ 248 ^

Studies of other commonly used drugs have had conflicting or inconclusive results. Use of benzodiazepines increased the risk of hip fracture in some,^244,245,249-252^ but not all studies.^253,254^ Long-term exposure to oral anticoagulation was associated with an increased risk of vertebral and rib fractures in one study,^ 255 ^ but not in another.^ 256 ^ Chronic use of H2 receptor antagonists had little effect on bone density.^ 257 ^ Intermittent users of nitrates had greater hip and heel bone density than nonusers; daily users had only slightly greater hip bone density than nonusers.^ 258 ^

#### Summary

Several factors are consistently associated with increased risks of low bone density and fractures in postmenopausal women, including increasing age, white race, low weight or weight loss, nonuse of estrogen replacement, history of previous fracture, family history of fracture, history of falls, and low scores on one or more measures of physical activity or function. Other factors are less consistent predictors across studies, but also have significant associations with bone density and fractures. These include smoking, alcohol use, caffeine use, low calcium and vitamin D intake, and use of certain drugs. The relative risks of several risk factors are comparable to that of a one standard deviation difference in bone density. Predictors for low bone density are similar to those for fracture except for those specifically related to falls. Most of the strongest risk factors are consistently related to outcomes in different racial and ethnic populations. Risk factors are generally similar for the various fracture sites except that fractures related to falls have additional functional risk factors.

### Are Tools for Assessing Risk Factors Accurate in Identifying Women at Risk for Fractures?

In contrast to the extensive body of literature about determining clinical risk factors for osteoporosis and fractures, few studies evaluate how to use these risk factors to identify individual women at risk for fracture.^ 259 ^ Ideally, tools for assessing risk factors would aid clinicians in determining who should and should not undergo bone density testing, reduce modifiable risk factors, and consider treatment.

Evidence Table 4 summarizes 17 studies that describe methods of determining risk for individual women based on selected clinical risk factors for the purpose of identifying those at risk for low bone density, bone loss, or fractures.^63,83,88,156,260-272^ These models do not depend on bone measurement test results to predict outcomes, although some studies included models with and without bone density, or compared the performance of risk factor assessment with bone density in predicting fracture. All models included in this review reported sensitivity and specificity or area under the receiver-operator characteristic (ROC) curve (a graph of sensitivity plotted against 1 minus specificity for all possible cutoff points). The area under the curve can be interpreted as a measure of the logistic model's predictive power. A model that completely lacks predictive power has an area under the curve of 0.50; values of at least 0.80 are usually required to consider a test to be effective.^ 273 ^

Variables in the models differed among studies. Most studies determined which variables to include by finding the most significant predictors within their study population and combining them to create a score. These scores were developed by assigning a certain number of points to risk factors based on the magnitude of their odds ratios, standardizing the beta coefficients of the regression results, or stratifying the results and designating a threshold for a positive score. Some models focused on certain types of variables, such as a model that included weight over 70 kilograms as the only variable,^ 83 ^ and another that included four cognitive and functional variables.^ 261 ^ Others included a broader range of variables such as age, weight, activity level, family history, and smoking status.^ 267 ^

Four studies evaluated hip fracture outcomes, two studies evaluated vertebral fractures, and two studies evaluated all types of fractures. These studies determined how well risk factors were associated with fractures known to have occurred already (four case-control studies), or how well they would predict fractures in the future (four prospective studies). The other nine studies evaluated bone density outcomes. These studies determined how well risk factors identified women with low bone density obtained by densitometry at the time of the study (all cross-sectional studies). Only 3 of the 17 studies validated the model in a population different from that in which it was developed.

One risk assessment tool from a good-quality study assigned points to selected risk factors for low femoral neck bone density (age, weight, race, estrogen use, presence of rheumatoid arthritis, history of fractures) to create a summary measure referred to as the Simple Calculated Osteoporosis Risk Estimation (SCORE).^ 271 ^ These risk factors were obtained from over 1,200 women from the community and were subsequently tested in a validation group (n=259). SCORE had an area under the ROC curve of 0.81 in the development group, and a sensitivity of 91 percent and a specificity of 40 percent in the validation group.

The performance of SCORE also was evaluated in a separate cohort from the Rancho Bernardo Study.^ 274 ^ These women had a mean age approximately 10 years older than women in the SCORE cohorts. A total of 1,013 postmenopausal white women age 44 to 98 years underwent assessment with SCORE protocol and DXA of the femoral neck. Using the recommended cut point of 6, the sensitivity of SCORE was 98 percent, specificity 12.5 percent, positive predictive value 69 percent, and negative predictive value 75 percent. SCORE also has been used in two studies of cost-effectiveness.^12,275^ These applications of SCORE are discussed in the Cost section of this report.

The best performing model for fracture outcomes reported an area under the ROC curve of 0.83.^ 262 ^ This model was based on a prospective study of 5,208 subjects in the Rotterdam Study whose risk factors were determined at baseline. Hip fracture outcomes were determined 3.8 years later and risk points were assigned from beta coefficients of regression models. Variables in the model included age, gender, height, use of a walking aid, current smoking, and weight. These are all easily obtainable variables that represent several of the most consistent predictors reported from other studies. Adding femoral neck bone density to the model and remodeling all of the parameters improved its performance slightly (ROC area 0.88) (Figure 7). This model has not been tested prospectively in a separate population.

Figure 7. Predictive value of risk scores for hip fracture ^a^ a Risk scores are based on clinical risk factors (age, gender, height, use of a walking aid, current smoking, and weight) and are dichotomized at different cutoff values. The lines indicate positive predictive value for the score with and without femoral neck bone density in the model. Adapted from Burger H, de Laet CE, Weel AE, et al.^ 262 ^

#### Summary

Few studies report results of the performance of tools for assessing clinical risk factors for osteoporosis. Our evidence review suggests that specific tools to assess risk have inadequate sensitivity and specificity and have not yet been widely tested. Generalizability of these tools to the clinical setting is therefore currently limited. However, some tools, especially those developed in large community populations and containing variables known to be strong predictors, may ultimately be applicable to the clinical setting once they are tested there.

Although this approach may be useful in the general population, translating the results of population studies to the care and management of individuals requires additional considerations. Risk factors that are not common may be dominant in individual patients. Also, some risk factors may be important for different types of fractures and for different age groups, for example. It is not yet known how tools for risk assessment would perform under these varying circumstances. In addition, clinicians may find it difficult to selectively exclude low-risk women from diagnostic protocols because a substantial number of women without specific risk factors also experience fractures. Patients may have similar concerns.

### Are Risk Factors Useful in Treatment Decisions?

The use of risk factors other than low bone density in treatment decisions is advocated by experts^7,9^ and included in guidelines by the National Osteoporosis Foundation.^ 8 ^ In one approach, treatment decisions are based on the overall risk of fracture, rather than on the bone measurement test alone. The assumption underlying this approach is that the number needed to treat is lower, and the cost-effectiveness of treatment is higher, for higher risk patients.

As a first step in using this risk-based approach, the National Osteoporosis Foundation presented a model that integrates additive risk factors into testing and treatment nomograms.^ 8 ^ This model predicts the risk of fracture based on age, history of a previous fracture, and risk factors (family history of fracture, thinness, and smoking), with and without the addition of bone density results. Separate nomograms were developed for different types of therapy (HRT, calcitonin, and alendronate). According to these models, if the combination of a woman's age and cumulative risk factors exceeds certain thresholds on the appropriate nomogram, she would be either treated, tested by densitometry, or followed without testing or treatment (Figures 8-9). These nomograms have not been tested in patient populations or prospective studies.

Figure 8. Testing nomogram for 5 years of alendronate therapy ^a^ a Lines indicate testing and treatment thresholds for women who have had prior vertebral fractures and whose T-score is not known and risk factors (family history, weight, smoking status) are known. No testing or treatment is indicated if below the diagnostic zone; testing should be offered if within the diagnostic zone; treatment may be indicated if above the diagnostic zone. Adapted from National Osteoporosis Foundation.^ 8 ^

Figure 9. Treatment nomogram for 5 years of alendronate therapy ^a^ a Lines indicate treatment thresholds for women who have had prior vertebral fractures and whose T-score and risk factors (family history, weight, smoking status) are known. Adapted from National Osteoporosis Foundation.^ 8 ^

We found no studies in our literature search testing a risk-based treatment approach. Such studies would directly compare the benefits of treatment for women who have clinical risk factors but normal or mildly low bone density with those for women with few risk factors but lower bone density. Alternatively, we examined the entry criteria of eight trials of alendronate therapy to assess how applicable recent treatment trials are to a risk-based approach. In these trials, treatment was intended to halt or reverse the loss of bone and prevent fractures in women who had osteoporosis (secondary prevention).^276-283^ We focused on alendronate trials because many clinicians consider calcium and vitamin D supplementation a standard of care for older women, and because the decision to begin HRT is a complex process involving consideration of risks and benefits unrelated to osteoporosis treatment. Subjects in these trials were predominantly white postmenopausal women, generally in their mid-60s to 70s, and were often selected because of their low bone density and, in some trials, previous vertebral fractures.

One study from the Fracture Intervention Trial (FIT) included 2,027 women who had T-scores of -1.6 or less and preexisting vertebral fractures.^ 276 ^ The 3-year risk of hip fracture in the placebo group was 2.2 percent (1.1 percent in the alendronate group, relative hazard [RH] 0.49 [CI 0.23-0.99]), and the 3-year risk of any clinical fracture was 18.2 percent (13.6 percent in the alendronate group, RH 0.72 [CI 0.58-0.90]).

A second study from FIT included 4,432 women who also had T-scores of −1.6 or less, but did not have preexisting vertebral fractures.^ 283 ^ The 4-year incidences of hip fracture (1.1 percent) and any clinical fractures (14.1 percent) in the placebo group were less than those of the women in the placebo group of the FIT study that included women with preexisting vertebral fractures. In this second study, only the subgroup of treated patients (n=1,627) who had a T-score under −2.5 had a significant reduction in all clinical fractures, from 19.6 to 13.1 percent (RR 0.64; CI 0.50-0.82). There was no reduction in fractures for patients who had a T-score between −2.0 and −2.5 or for those between −1.6 and −2.5.

These results suggest that women with preexisting vertebral fractures and low bone density have a higher incidence of fractures than women with low bone density alone. Women with more risk factors for fracture, such as those with preexisting vertebral fractures or the lowest bone density, had the greatest benefit with treatment. These results do not indicate that patients with a high overall fracture risk who have a T-score above −2.5 will not benefit from therapy. In the highest risk group of the second study (those who had a T-score under −2.5), the incidence of fractures was still much lower than the estimated risk for an 80-year-old woman with a T-score of −1.5 and two or more risk factors.^ 8 ^ The FIT investigators did not attempt to stratify patients by overall risk, and they have not published any subgroup analyses that compare the benefit of treatment in patients who had very high overall fracture risk but relatively high bone density for their age. None of the other studies reviewed has done this, either.

#### Summary

Identification of important risk factors could be useful in making treatment decisions. Although models have been proposed, they have not been prospectively tested in large trials and are not used by clinicians. Clinical trials have not focused on patients who have several risk factors and a high overall risk of fracture but who do not meet the WHO definition for osteoporosis. A few risk factors -- sex, race, age, menopause, a history of previous fracture, and low bone density -- have been primary selection criteria for randomized trials of bisphosphonates and provide clues to the validity of the risk-based approach.

## Bone Measurement Tests

In this section we examine how well different tests predict fracture and how well they agree about which patients have osteoporosis. We focused on recent prospective studies of bone density measures in use today, particularly DXA of the hip and spine, QUS of the heel, and RA or DXA of the hand or forearm. We also examine how bone testing in general affects patients' and physicians' behaviors and treatment decisions.

### How Well do the Different Bone Measurement Tests at Different Sites Predict Fractures?

The literature describing the performance of bone measurement tests to predict fractures is extensive. We focused our review on a meta-analysis published in 1996 that provided a summary of older studies, and on prospective cohort studies that were not included in the meta-analysis or that were published since 1996. We did not review case-control studies because previous systematic reviews found that the results of case-control studies of fracture risk vary widely^ 49 ^, and that at least some of the variation is related to the method used to select cases and controls.^ 252 ^ Case-control studies do indicate whether, on average, mean values of bone density measured by a particular technique differ for patients who have and have not had a fracture, but they do not measure how well the test discriminates between high-risk and low-risk individuals.

The meta-analysis^ 49 ^ that assessed 23 publications from 11 separate prospective cohort studies published before 1996 pooled studies to estimate the age-adjusted relative risk of various types of fractures for a one standard deviation decrease in bone density. Nearly all available data included in these studies were from women in their late 60s or older and all tests used densitometry techniques. Data from these studies were insufficient to estimate age-specific relative risks or to assess the relationship between length of followup and relative risk.

Results of the meta-analysis indicated that measurements made at the hip predicted hip fracture better than measurements made at other sites.^44,284,285^ For bone density measurements made at the femoral neck, the pooled relative risk per one standard deviation decrease in bone density was 2.6 (CI 2.0-3.5).

This estimate was based almost entirely on one high-quality report from the SOF cohort using data from 8,134 women over 65 years of age after 1.8 years of followup.^ 44 ^ In that study, the relative risk of hip fracture per one standard deviation decrease was 2.7 (CI 2.0-3.6) for measurements made at the proximal femur, versus 2.0 (CI 1.5-2.7) for measurements made at the heel, 1.6 (CI 1.2-2.1) for the distal radius, and 1.6 (CI 1.2-2.2) for the lumbar spine. Because of the clinical importance of hip fracture, these findings established DXA of the hip and, in particular, the femoral neck as the standard test for measuring bone density in epidemiologic studies.

For measures made in the forearm (proximal radius), the pooled relative risk for one standard deviation decrease in bone density was 2.1 (CI 1.6-2.7) for hip fractures.^189,286-289^ The individual studies contributing to the estimate of the relative risk of forearm bone density for hip fracture included a series of 135 nursing home residents (RR 1.9; CI 1.4-2.7), a population-based study of 1,076 postmenopausal women (RR 2.5; CI 1.3-4.8), and a report of 9,704 subjects in the SOF cohort (RR 1.4; CI 1.1-1.8).

For studies using densitometry methods, calcaneal bone density was associated with forearm (RR 1.6; CI 1.4-1.8), hip (RR 2.0; CI 1.7-2.4), and vertebral fractures^ 49 ^ (RR 2.4; CI 1.8-3.2). In two reports from the SOF cohort, the relative risk of heel bone density for hip fracture was 2.0 (CI 1.5-2.7) and 2.7 (CI 1.8-4.0). No other cohort study reported about prediction of hip fracture from calcaneal densitometry measurement.

For measurement of bone density at the forearm, the relative risk was 2.2 (CI 1.7-2.6) for vertebral fractures, and 1.5 (CI 1.3-1.6) for fractures at all sites. For forearm fractures, measurement at the proximal radius (RR 1.8; CI 1.5-2.1) and distal radius (RR 1.7; CI 1.4-2.0) were slightly better than measurement at the heel (RR 1.6; CI 1.4-1.8), lumbar spine (RR 1.5; CI 1.3-1.8), and hip (RR 1.4; CI 1.4-1.6). For vertebral fractures, measurement at the lumbar spine (RR 2.3; CI 1.9-2.8), heel (RR 2.4; CI 1.8-3.2), and proximal radius (RR 2.2; CI 1.7-2.6) had similar results.

We identified 15 cohort studies -- either not included in the Marshall meta-analysis, or published since 1996 -- of peri- or postmenopausal women who had DXA, QUS, RA (including QMD), or other bone measurement tests that reported fracture outcomes.^44,45,57,285,290-300^ The cohorts include the SOF, EPIDOS, Hawaii Osteoporosis Study (HOS), Diagnostisch Onderzoek Mammacarcinoom (DOM), two projects from Aberdeen, and one each from Rotterdam, Kuopio, Finland, and Modena, Italy (Table 9). Table 10 shows the quality grading of these 15 studies, based on the system described in Appendix C. We found no data from recent prospective studies about peripheral DXA, QCT, pQCT, SXA, and several other commonly used tests and sites.

Table 9. Prospective studies of densitometry

Study | Population/setting | Exclusions from population | N | Age | Proportion of original cohort in sample | Site, machine, and measure
Study of Osteoporotic Fractures (SOF)^44,285,290,297^ | Community-dwelling white women from four U.S. areas recruited from lists (e.g., jury selection, drivers' licenses, HMO memberships) | Black women | 8,134 | >65 years | 97% returned at 5 years | Heel QUS: UBA 575; BUA
Study of Osteoporotic Fractures (SOF)^44,285,290,297^ | Community-dwelling white women from four U.S. areas recruited from lists (e.g., jury selection, drivers' licenses, HMO memberships) | Women unable to walk without assistance, or with bilateral hip replacements | | | 72% of original cohort known to be alive | Spine, Hip DXA: Hologic QDR 1000; BMD, BMC
Study of Osteoporotic Fractures (SOF)^44,285,290,297^ | Community-dwelling white women from four U.S. areas recruited from lists (e.g., jury selection, drivers' licenses, HMO memberships) | | | | Fracture followup 99% complete
Epidemiologie de l'Osteoporose (EPIDOS)^292-294,298^ | Women from five cities in France recruited from voting lists and health insurance companies | Black women | 7,575 | >75 years | 2% lost to followup | Heel QUS: Lunar Achilles; BUA, SOS
Epidemiologie de l'Osteoporose (EPIDOS)^292-294,298^ | Women from five cities in France recruited from voting lists and health insurance companies | Women with bilateral hip replacement, previous hip fracture, Paget's disease of bone, malignant bone disease, renal failure, hyperthyroidism, or treated hypothyroidism | | | | Hip DXA: Lunar DPX Plus; BMD
Epidemiologie de l'Osteoporose (EPIDOS)^292-294,298^ | Women from five cities in France recruited from voting lists and health insurance companies | Women with bilateral hip replacement, previous hip fracture, Paget's disease of bone, malignant bone disease, renal failure, hyperthyroidism, or treated hypothyroidism | | | | Whole body DXA: Lunar DPX Plus; BMD, BMC
Hawaii Osteoporosis Study (HOS)^ 45 ^ | Women of Japanese ancestry, recruited from a 30% random sample of wives of participants in the Honolulu Heart Program | N/A | 560 | Mean 73.7 years | Not reported | Heel QUS: Walker-Sonix; BUA
Hawaii Osteoporosis Study (HOS)^ 45 ^ | Women of Japanese ancestry, recruited from a 30% random sample of wives of participants in the Honolulu Heart Program | | | | | Hand absorptiometry: OsteoGram Phalangeal; BMD Bonalyzer Metacarpal; BMD
Diagnostisch Onderzoek Mammacarcinoom (DOM)^ 300 ^ | Ongoing screening program for breast cancer (every woman born between 1911 and 1941 living in the vicinity of Utrecht, the Netherlands) | None | 440 | Mean 57 years | 82% participation | Hand quantitative microdensitometry: machine not specified
| 10 women for each age year from DOM were asked to participate in the osteoporosis study
Osteoporosis Risk Factor and Prevention Study (OSTPRE)^ 295 ^ | Random stratified sample of 14,220 women in Kuopio Province, Finland | Women with spinal osteophytes or deformations, hip deformations, or incorrect measures were excluded after densitometry | 3,222 | Mean 53.4 years | Of 3,222 undergoing densitometry, 97.5% followup | Hip, spine DXA: Lunar DPX, BMD
Aberdeen - Porter^ 57 ^ | Women aged >70 years in residential care within the catchment areas of Doncaster and Hull Royal Infirmaries, Aberdeen | Women not able to walk with assistance and those with bilateral hip surgery | 1,414 | >70 years | 100% | Heel QUS: Osteosonics Ultrasonic bone analyzer 1001; BUA
Aberdeen - Porter^ 57 ^ | Women aged >70 years in residential care within the catchment areas of Doncaster and Hull Royal Infirmaries, Aberdeen | Women not able to walk with assistance and those with bilateral hip surgery | 1,414 | Mean 84 years
Aberdeen - Stewart^ 299 ^ | Women from 45 to 49 years old recruited from population-based register within 20 mile radius of Aberdeen | Not specified | 790 | 45-49 years | 79% of 1,000 consenting included | Heel QUS: Walker-Sonix UBA 575; BUA
Aberdeen - Stewart^ 299 ^ | Women from 45 to 49 years old recruited from population-based register within 20 mile radius of Aberdeen | Not specified | 790 | 45-49 years | 79% of 1,000 consenting included | Hip, spine DXA: Norland XR-26; BMD, BMC, or both (not reported)
Rotterdam^ 291 ^ | People >55 years living in Ommoord (Rotterdam) | None | 3,078 women | >55 years | Complete followup on 7,046 (88%); 4,268 women | Hip DXA: Lunar DPX-L; BMD
Rotterdam^ 291 ^ | People >55 years living in Ommoord (Rotterdam) | None | 3,078 women | >55 years | Complete data on 5,304 (66%); 3,078 women
Modena^ 296 ^ | Consecutive admissions over 8 months to Department of Orthopedic Surgery, Modena, Italy | Patients with diseases of bone metabolism, rheumatoid arthritis, under treatment with specified drugs, or HRT were excluded | 211 | Mean 52 years | 84% (211/250) | Hand QUS: Sonic 1200; SOS of phalanx

BMC = bone mineral content; BMD = bone mineral density; BUA = broadband ultrasound attenuation; DPX = dual-photon X-ray; DXA = dual-energy X-ray absorptiometry; HMO = health maintenance organization; HRT = hormone replacement therapy; QDR = quantitative digital radiography; QUS = quantitative ultrasound; UBA = ultrasound bone analyzer

Table 10. Quality grading -- prospective studies of bone measurement techniques and fracture risk

Cohort | Publication | | Grade
EPIDOS
EPIDOS | | Good | Fair | Poor
EPIDOS | Duboeuf (1997)^ 292 ^ | X
EPIDOS | Schott (1998)^ 298 ^ | X
EPIDOS | Garnero (1998)^ 293 ^ | | X^a^
EPIDOS | Hans (1996)^ 294 ^ | | X^a^
SOF
SOF | Black (1992)^ 285 ^ | X
SOF | Cummings (1993)^ 44 ^ | X
SOF | Nevitt (1994)^ 297 ^ | X
SOF | Bauer (1997)^ 290 ^ | | X^b^
| Porter (1990)^ 57 ^ | X
| de Laet (1998)^ 291 ^ | | X^c^
| Huang (1998)^ 45 ^ | | X^d^
| Kroger (1995)^ 295 ^ | | X^d^
| Mele (1997)^ 296 ^ | | X^d^
| Stewart (1996)^ 299 ^ | | | X^e^
| Vecht-Hart (1997)^ 300 ^ | | | X^e^

a 75% of initial cohort received all tests used in the analyses, and differences between those included and not included were not reported.

b 64% of initial cohort received all tests used in the analyses.

c 48% of initial cohort had followup measures used in the analyses.

d Self-reported fractures confirmed from medical records and radiographs.

e Some or all of self-reported fracture outcomes were not verified.

EPIDOS = Epidemiologie de L'Osteoporose; SOF = Study of Osteoporotic Fractures

#### Dual-Energy X-ray Absorptiometry of the Hip

Publications from five cohorts presented data about the ability of hip DXA measures to predict subsequent fractures in different age groups.^44,285,290-295,297-299^

We summarized studies that reported DXA of the hip or QUS of the heel for the prediction of hip fractures or all nonspine fractures (Evidence Table 5). Rather than reporting details of individual studies, we reported results from the cohorts according to the subgroups addressed (e.g., subgroups by age). We described the probability of a fracture in subjects classified as "high risk" or "low risk" according to their hip DXA result. Classification of "high" and "low" risk varied across studies and was based on the cutoff value for the test. In one analysis of the SOF cohort, for example, the overall risk of hip fracture during approximately 2 years of followup was about 1 percent (9 per 1,000). If the hip DXA indicated osteoporosis, the probability of a hip fracture was 2.3 percent; if not, the probability was 0.46 percent (about 5 per 1,000). For the average patient in this cohort, then, low bone density increased the chance of fracture within 2 years from 9 to 23 per 1,000, while an osteopenic or normal result decreased the probability of fracture from 9 to 5 per 1,000. ^1^

1 The limitations of measuring these differences in probabilities are that they depend on the length of followup and the pretest probability of fracture.

DXA of the hip predicted hip fracture best in the SOF and Rotterdam studies (RR per one standard deviation decrease 2.6 [CI 1.9-3.8] and 2.5 [CI 1.8-3.6]). Prediction was not as good in women over 75 years of age. In the EPIDOS cohort, the overall relative risk was 1.9 (CI 1.6-2.4), and in the subgroup of women over 85 years of age, the relative risk was 1.6 (CI 1.3-2.2). In the SOF cohort, the relative risk was higher for women age 65 to 79 (RR 2.9; CI 2.2-3.9) than for those over 80 years of age (RR 2.1; CI 1.4-3.2).

Two recent studies included younger, perimenopausal women between the ages of 45 and 56, but these subjects had too few hip fractures to estimate the relative risk. The adjusted relative risk for all nonspine fractures was 1.39 (CI 1.2-1.6) in one study^ 295 ^ and 1.4 (CI 1.3-2.4) in the other,^ 299 ^ which is comparable to the relative risks for all nonspine fractures in older women.

The method used in the Rotterdam study to identify categories of risk resulted in the strongest association between the category and actual incidence of fracture.^ 291 ^ These investigators used a regression equation, derived from a previous study, to classify women as "high risk," "moderate risk," or "low risk" for fracture, based on age and the result of the DXA of the femoral neck.^ 301 ^ Over 3.8 years of followup, the probability of hip fracture was 0.7 percent in the low risk group versus 6.9 percent in the high risk group. Other cohort studies stratified by age to achieve a similar level of discrimination. The absolute differences in risk increase with the baseline probability, so these differences are larger in older subjects, even though the relative risk in these cohorts may be lower.

The least discrimination occurred in the study of the youngest cohort of women (age 45 to 49 years), which reported results for all nonspine fractures.^ 299 ^ The 2-year probability of fracture in the group with high bone density was 2.4 percent versus 1.7 percent in the group with low bone density. The low difference (7 per 1,000) reflects the fact that bone density testing provides less information about the short-term risk of fracture in younger, lower risk individuals. ^2^

2 We confined all analyses of prospective studies to the time horizon actually observed, rather than extrapolating to 5-year or lifetime risk.

#### Quantitative Ultrasound of the Heel

Six publications evaluated the association of QUS measures of the heel with subsequent fractures: one from SOF,^ 290 ^ two from EPIDOS,^293,294^ one from HOS,^ 45 ^ and two from Aberdeen.^57,299^ All six studies evaluated hip fractures, but one^ 45 ^ included vertebral fractures and another^ 299 ^ reported fractures of the wrist, toes, ribs, foot, and nose, as well as of the hip. The baseline probability of hip fracture over 2 to 3 years ranged from 1 to 5.2 percent (Evidence Table 5).

Three reports directly compared the performance of QUS of the heel with that of DXA of the hip. In a study of a subset of the SOF cohort, the overall probability of a hip fracture was 0.9 percent.^ 290 ^ The relative risk of DXA of the hip for hip fracture was 2.6 (CI 1.9-3.8) versus 2.0 (CI 1.5-2.7) for QUS. QUS was still associated with an increased risk for hip fracture after adjustment for the hip DXA result. As shown in Evidence Table 5, a "high risk" ultrasound result increased the probability of a hip fracture from 0.9 to 1.8 percent, while a "low risk" ultrasound result decreased the probability of a fracture from 0.9 to 0.6 percent. As mentioned earlier, for DXA of the hip the comparable probabilities are 2.3 percent for a "high risk" test result and 0.5 percent for a "low risk" result.

Table 11 shows the probability of fracture for subgroups of women in the SOF defined by having "low risk" or "high risk" QUS and hip DXA results. Using a cutoff value of 85 (dB/MHz), 786 women had a "low risk" result, and none of them had a fracture. Using a cutoff value of 80 (dB/MHz), 4,182 women had a "high risk" QUS, and 1,081 had a "low risk" QUS. Those who had a "low risk" QUS result had a low risk of fracture, regardless of their hip DXA result (.001 if the hip DXA was "high risk" and 0 if it was "low risk").

Table 11. Probability of fracture in subgroups of women defined by QUS and DXA of the hip results^a^

QUS cut point | Ultrasound result ^b^ | DXA of the hip result ^c^ | Probability of fracture
85 | high | high | .0220 (35/1594)
| high | low | .0053 (19/3613)
| low | low | 0 (0/694)
| low | high | 0 (0/92)
80 | high | high | .0227 (35/1541)
| high | low | .0055 (18/3271)
| low | low | .0010 (1/1036)
| low | high | 0 (0/145)
75 | high | high | .0233 (34/1458)
| high | low | .0050 (14/2814)
| low | low | .0013 (5/1493)
| low | high | .0044 (1/228)

a Bauer DC^435^

b A QUS result lower than the cut point in the first column is classified as "high risk," and a QUS result higher than the cut point is classified as "low risk."

c Dual-energy X-ray absorptiometry of the femoral neck using a T-score = -2.5 as the cutoff value for "high" versus "low" risk.

DXA = Dual-energy X-ray absorptiometry; QUS = Quantitative ultrasound

These subsets of the SOF excluded women who had a fracture before QUS measurements were done. This bias is potentially important because women who had fractures early in the study may have differed in risk factors and in the predictability of their fractures from women who fractured later.

In the second study, from the EPIDOS cohort,^ 294 ^ the relative risk for hip fracture per standard deviation unit was 2.0 (CI 1.6-2.4) for QUS versus 1.9 (CI 1.6-2.4) for DXA of the hip. In the third study,^ 299 ^ the relative risks for DXA of the femoral neck and QUS for all nonspine fractures were nearly equal (1.4; CI 1.3-2.4 versus 1.43; CI 1.2-2.4). Absolute risk differences for QUS ranged from 0.007 to 0.017, compared with 0.007 to 0.025 for DXA of the hip. The number of women with low bone density who subsequently had any nonspine fracture was similar for QUS (between 2 and 8 in 100) and hip DXA (between 2 and 7 in 100), as was the number of women with normal bone density who had a fracture. Three studies^45,296,299^ included vertebral fractures in their evaluation of the association of QUS and fracture risk. The odds ratio for a vertebral fracture, adjusted for age and calculated for one standard deviation decrease in calcaneal BUA, was 1.50 (CI 1.05-2.16) in one study^ 45 ^ in which 39 patients of a sample of 560 sustained a vertebral fracture. For the other two studies, no vertebral fractures occurred in the samples.

#### Dual-Energy X-Ray Absorptiometry of the Spine

Five publications from three population-based studies evaluated the association of DXA measures of the spine with subsequent hip fractures.^44,285,295,297,299^ Only one report evaluated hip fractures alone.^ 44 ^ The results of this latter study were identical to those of earlier studies, in which measurement of bone density in the spine had a relative risk for hip fracture of 1.6 per 1 standard deviation decrease.^ 49 ^ The poorer discrimination of spine measurements for hip fracture can be seen by comparing the age-specific probabilities for hip DXA (Evidence Table 5) and spine DXA (Evidence Table 6). With hip DXA, for 80- to 84-year-old women, the probability of hip fracture was 0.7 percent for a "low risk" result and 5 percent for a "high risk" result. For spine DXA, the comparable probabilities were 1 percent and 3.3 percent.

In elderly women, lumbar spine densitometry can have false-negative results because of arthritis of the spine.^302,303^ In the two studies for which there were available data to perform the calculations,^44,299^ between 3 and 8 women in every 100 who had low test results for DXA of the spine subsequently suffered a fracture. In 100 women who had a test result above the cutoff values used in these studies, up to 5 patients suffered a fracture.

#### Bone Measures of the Hand

Two population-based studies, the HOS and the DOM (Netherlands) study (Evidence Table 6), evaluated the ability of RA or QMD of the hand to predict fractures.^45,300^ Neither study reported hip fractures. In the Hawaii study, RA of the hand predicted vertebral fractures very well (RR 3.41; CI 1.7-7.7), and was comparable to QUS, DXA of the spine, and DXA of the hip for predicting all nonspine fractures (RR 1.5; CI 0.9-2.6). In the Netherlands study, which used QMD of the index finger, women in the lowest three bone density quartiles were 6.7 times as likely as women in the highest quartile to have a nonspine fracture. Women in the highest quartile had a risk for any nonspine fracture of 2.9 percent versus 9.6 percent in the lowest three quartiles.

#### Other Tests and Sites

One report from the EPIDOS study evaluated the association of DXA measures of the whole body with subsequent hip fractures.^ 298 ^ The relative risk for hip fracture was 1.6 (CI 1.2-2.0), versus 1.9 (CI 1.5-2.3) for hip DXA. Patients who had a T-score under −2.5 had a hip fracture risk of 2.3 percent, while those below this threshold had a risk of 1.4 percent. One case series of 211 patients in an orthopedic clinic examined the ability of QUS of the hand to predict nonspine fractures.^ 296 ^

#### Summary

Among different bone measurement tests at various sites, bone density measured at the femoral neck by DXA is the best predictor of hip fracture and is comparable to forearm measurements for predicting fracture at other sites.

In recent prospective studies, QUS measured at the heel predicted hip fracture and all nonspine fractures as well or nearly as well as DXA measured at the femoral neck. For both tests, a result in the osteoporotic range is associated with an increased short-term probability of hip fracture. However, clinical trials of recent pharmacologic therapies have used a low hip DXA, rather than QUS, as a criterion for entry. Physicians who use QUS must consider whether the results of these trials are generalizable to patients identified by QUS to have a high risk of fracture.

QUS of the heel and DXA of the hip provide independent information about fracture risk. Individuals who have low scores by one of these tests, but not the other, have a greater risk of fracture than those who have higher scores by both tests, and a lower risk of fracture than those whose results on both tests are low.

Both of these tests predict hip fracture better than DXA of the lumbar spine. RA or QMD of the hand can predict the risk of nonspine fractures in general, many of which are in the forearm, but there are no recent data about the ability of hand measurement to predict hip fracture. Correlations between different bone measurement tests are generally too low to be accepted as evidence that one test will identify patients at similar risk to those identified by another test. While peripheral measures may approach hip DXA in predicting hip fracture, there are no recent prospective studies that directly compare prediction of hip fracture of these tests with DXA of the hip.

### What Factors Related to Bone Testing Influence Diagnosis?

In addition to predicting fractures, bone measurement tests are used to diagnose osteoporosis, frequently by the WHO study group definition of a T-score less than −2.5. Published studies consistently show that the probability of being diagnosed with osteoporosis depends on the choice of test and site (Evidence Table 7).^10,304-307^ One analytical study, for example, found that in the NHANES III sample, 6 percent of women over 60 years old would be diagnosed to have osteoporosis if DXA of the total hip were used as the only test, versus 14 percent for DXA of the lumbar spine, 3 percent for QUS, and 50 percent for QCT.^ 10 ^

#### Varying Reference Ranges and Types of Machines

A few studies have examined how the use of different reference ranges, the use of reference ranges based on different young adult female samples, and the use of different brands or types of DXA machines affect the frequency of diagnosis of osteoporosis. When used in the same patients, DXA machines from different makers differ in the proportion of patients diagnosed to have osteoporosis by 6 percent to 15 percent.^308-313^

#### Precision and Reliability

The precision of a test can affect its clinical utility for diagnosing a disease. For densitometry, results need to be precise enough to distinguish patients who have osteoporosis from those who do not. This means that variation between repeated measures should be low relative to the difference between values in osteoporotic and osteopenic or nonosteoporotic individuals.

The simplest evaluation of precision assesses agreement of repeated readings on a "phantom," which is a block of material with a known, stable amount of mineral.^314,315^ These repeated measures may be performed over hours, days, or years. In these in vitro studies of DXA at the hip and spine, the short-term and long-term coefficient of variation (CV) is less than 1.1 percent, meaning that the standard deviation of repeated DXA readings is 1.1 percent or less of the mean.^316-320^ In the NHANES III survey, three DXA machines from the same manufacturer were deployed in mobile units and used to make several thousand measurements over 3 years.^ 321 ^ The short-term precision for the three machines ranged from 1.4 to 2.1 percent at the femoral neck to 0.40 to 0.80 percent at the intertrochanter region, while the long-term precision was close to 0.50 percent for all sites. In similar studies, the in vitro precision of BUA of the heel was 0.8 to 1.2 percent.^ 322 ^

While the in vitro precision is frequently highlighted in review articles and information from manufacturers, operator skill and variability among subjects are more important than in vitro machine performance in obtaining reliable densitometry results.^ 323 ^ Measurement error is higher in elderly patients than in young women, and at the spine and greater trochanter than at the femoral neck.^ 324 ^

The expertise required to obtain reliable scans differs among bone density tests and is better characterized for older technologies and for axial and hip DXA than for peripheral sites and newer technologies. In the NHANES III study, for example, 3.5 percent of DXA scans were unreadable, mostly because patients moved during the examination. Another 33 percent of scans required reanalysis to apply quality standards concerning the location of the regions of interest.^ 321 ^

Several dozen articles have examined in vivo precision of various bone density tests. Most of these studies concern the reproducibility of results when a single research densitometry technician conducts repeat examinations on a small number of patients. In these studies, precision varies by technique and site (Table 6). Only a few studies, however, have examined interobserver reliability among technicians in academic settings.^321,325^ In one of the best studies, the precision of QUS, DXA, and SXA of the heel was compared in 53 young normal females and 108 osteoporotic women over 55 years of age.^ 325 ^ The study examined four aspects of precision. The precision of repeated measurements by a single examiner without repositioning the patient ranged from 2.01 to 7.76 percent for three QUS instruments, versus 1.34 percent for SXA and 1.23 percent for DXA. Repeated measurements made 2 weeks apart had results similar to these. For repeat measurements by different examiners on the same day, however, precision was 2.48 to 9.44 percent for QUS, 1.84 percent for SXA, and 1.91 percent for DXA.

These reports reflect the results of using densitometry in highly controlled academic research centers, many of which have implemented quality control techniques that are more sensitive, but also more expensive and time-consuming, than those recommended by manufacturers.^317,319,321^ In contrast to most common laboratory and radiologic tests, the precision of densitometry tests in everyday practice (outside research protocols and major referral centers) has not been studied. Patient factors such as obesity, handedness, edema (for ultrasound),^326-331^ and osteoarthritis (for DXA of the spine)^ 332 ^ affect estimates of bone density.

#### Diagnostic Agreement

Evidence Table 8 summarizes several studies of the correlation or diagnostic agreement (sensitivity and specificity) of DXA of the hip or spine with QUS, QCT, pQCT, SXA, and pDXA.^46,325,333-351^ In studies of QUS, the correlation coefficients of ultrasound parameters (BUA, SOS, or stiffness) with DXA of the hip or spine were most often in the range of 0.4 to 0.6. In the smaller number of studies that examined pQCT of the forearm, the correlation coefficients were in the range of 0.35 to 0.45.

#### Summary

The likelihood of being diagnosed with osteoporosis varies greatly, depending on the site and type of bone measurement test, the brand of densitometer, and the relevance of the reference range in the local population. The variation between techniques, along with the lack of methods to integrate bone density results with clinical predictors, makes it difficult for clinicians to provide accurate information to patients about their test results.

The likelihood of being diagnosed with osteoporosis also depends on the number of sites tested. Testing in the forearm, hip, spine, or heel will generally identify different groups of patients. A physician cannot say, based only on a forearm test, that the patient "does not have osteoporosis." Conversely, although the results of a test at any site are associated to some degree with fractures at other sites, the physician may not be able to assess whether the patient who has a low T-score on a hand or forearm test has significant bone loss at other sites.

Because of these limitations, some experts question whether there is added benefit to the patient from using T-scores to diagnose osteoporosis, as opposed to reporting test results as continuous values and assessing overall risk. Others propose that results using various techniques and sites be "calibrated" to the results of DXA of the hip and reported as a "T-score equivalent." The success of this approach may be limited by differences in precision and low correlation among different techniques.

### How do Bone Measurement Test Results Affect Patients' and Physicians' Decisions and Actions?

Many clinicians believe that the results of bone measurement tests motivate patients to exercise, adhere to medication regimens, and change other behaviors to reduce their risk of fracture. Of 1,335 women from the SOF cohort who completed a questionnaire about estrogen therapy and were taking estrogen, 33.6 percent reported their primary reason was prevention or treatment of osteoporosis.^ 352 ^ Furthermore, test results appear to influence physicians' decisions to prescribe HRT.^ 353 ^ On the other hand, the psychological effect of receiving a result indicating osteoporosis could produce anxiety and perceived vulnerability^ 354 ^ that may be unwarranted. We reviewed four publications that address the influence of test results on women's decisions about treatment and health-related behaviors.^355-358^ One publication evaluated the effect of bone measurements on practice patterns of physicians and also evaluated their level of understanding the reports they receive.^ 359 ^

#### Patients' Decisions and Health Behaviors

In a randomized trial of 141 women within 3 years of menopause who were referred from three private practices, those who underwent bone density testing were more likely to fill a prescription for HRT than women who received an educational message about osteoporosis (63.4 percent versus 20.0 percent, p <0.05).^ 357 ^

The results of the largest study, an uncontrolled case series, suggest that women make changes based upon testing, and that there is a relationship between test results and the degree and direction of changes.^ 355 ^ These investigators collected baseline data and presented a 12-minute educational video about bone density to 1,203 postmenopausal women over 50 years of age (mean 62 years) who were referred to an osteoporosis program at a women's health center and who received DXA measures of the hip and spine. Over 15 months of followup, HRT use decreased from 42 percent prior to the test to 13 percent in the group classified as normal (T-score above -2), from 46 to 33 percent in the group whose bone density was moderately decreased (T-score between -2 and -3), and there was no change for the severely low group (T-score less than -3; 46 percent before the test and 47 percent afterwards). For the subset of women who had never taken HRT (n=394), 5 percent, 32 percent, and 35 percent initiated this treatment for the normal, moderately low, and severely low groups, respectively. Calcium supplement use increased after densitometry in all three groups. Twenty percent of women with normal test results reported being afraid of falling, compared with 39 percent for the moderately low group and 58 percent for the severely low group.

In a similar but smaller study,^ 356 ^ 37 postmenopausal women (average age 58.5 years) who were referred to an orthopedic clinic received an education kit and session, were tested for bone density with hip and spine DXA, and filled out a questionnaire asking under what circumstances they would initiate HRT. Women were categorized as "normal" (0.99 standard deviations below the mean average), "moderate" risk (1 to 1.99 standard deviations below average), "high" risk (2 to 2.99 standard deviations below average), and "very high" risk (3 or more standard deviations below average). Before receiving the results, 10 women said they wanted HRT, regardless of the outcome of the densitometry test. After the test results, four additional women requested HRT. A followup telephone survey conducted after 1 year (n=35) showed no difference between normal and low bone density groups in the proportion of women on HRT. However, seven women whose BMD test results were low were taking bisphosphonates at followup.

A survey of 261 women who received densitometry studied their perception of risk of fracture and degree of worry, and whether they made changes based on their test results.^ 358 ^ Of the 53 percent who reported that their test was below normal, virtually all of them (94 percent) reported initiating preventive measures. Remarkably, 56 percent of those who reported their test was normal also initiated prevention measures. Women who reported below normal test results were more likely to start HRT than those with normal or above results. Of the entire group, 24 percent who reported below normal results said they began limiting activities to avoid falling; for women 65 years and older, this proportion rose to 31 percent. About one-third of the sample (86 women) had a second bone measurement test. About 26 women reported losing bone at an accelerated rate; of these, 22 initiated additional prevention.

#### Physicians' Decisions and Practice Patterns

One randomized trial examined the effect of densitometry on the practice patterns of 57 primary care physicians who ordered DXA tests for their patients, and also their understanding of the reports they received.^ 359 ^ Physicians were randomly assigned either to a group that would receive their patients' results in the form of a short technical report, or to a group that would receive a long report written by an endocrinologist with access to clinical information. The outcome measures, obtained by telephone interview after each physician received at least two reports, were level of understanding of the reports and differences between groups in treatment decisions. Differences in understanding between the short- and long-form groups were statistically significant. For the group that received the short technical report, 3 percent understood the T- and Z-scores, 30 percent understood the role of bone density in identifying osteoporosis, 12 percent understood the relationship between bone density and risk of fracture, and 36 percent thought the report was confusing. This compares with 32 percent (p=0.005), 86 percent (p=0.001), 45 percent (p=0.014), and 1 percent (p=0.003), respectively, for the group that received the long report. Overall, the groups did not differ significantly in referrals to a specialist, additional testing, or changes in pharmacological treatments for osteoporosis. However, in a subgroup analysis, gynecologists who received the long report were more likely to prescribe changes in pharmacological treatments for osteoporosis (61 percent versus 19 percent).

#### Summary

One randomized trial suggests that women who undergo densitometry are more likely to start HRT than women who do not. In a randomized trial and a large uncontrolled case series, women who had densitometry and were told they had osteoporosis were more likely to start or continue HRT than women who were told they had normal bone density.

In another randomized trial, physicians found densitometry reports confusing and were not confident that their interpretations of T-scores were correct. While overall the reporting format did not influence treatment decisions, gynecologists who better understood the report were more likely to prescribe changes in HRT than those who considered the report confusing. These results suggest that the behaviors of both patients and physicians are influenced by the results of bone measurement tests.

## Monitoring Therapy with Repeat Bone Measurement Tests

### Are Bone Measurement Tests Effective for Monitoring Response to Therapy and for Guiding Decisions about Changes in Management?

To be effective in monitoring, a test needs to be sufficiently accurate to detect differences in bone density over time. These differences must predict fracture risk, and changes in therapy made because of these differences must reduce the risk of fracture. To determine if bone measurement tests are effective for monitoring, we reviewed studies related to:

- The reliability of densitometry in detecting changes in bone density in patients on therapy for osteoporosis.
- How well changes in densitometry predict fracture outcomes in patients on therapy.
- How well an "adequate" response to therapy can be distinguished from an "inadequate" response.
- If adjustment of therapy based on changes in bone density leads to reduction in fracture risk.

The potential value of serial densitometry is limited by the rate of change in bone density and by the precision of the tests themselves. Table 12 shows that for a test with a coefficient of variation (CV) of only 1 percent, 10 months is the earliest that a 3 percent annual change in bone density could be reliably detected, and it would take almost 3 years to reliably detect a 1 percent annual change in bone density.

Table 12. Interval between measurements required to reliably detect bone loss^a^

Precision error | Estimated bone loss | Difference in measurements ^b^ | Time frame for a reliable bone mass measurement followup
CV% | % | % | Years
1 | 1 | 2.77 | 2.77
1 | 3 | 2.77 | 0.92
2 | 1 | 5.54 | 5.54
2 | 3 | 5.54 | 1.85
3 | 1 | 8.32 | 8.32
3 | 3 | 8.32 | 2.77
4 | 1 | 11.08 | 11.08
4 | 3 | 11.08 | 3.70
5 | 1 | 13.30 | 13.30
5 | 3 | 13.30 | 4.43
6 | 1 | 16.63 | 16.63
6 | 3 | 16.63 | 5.54

a Agency for Health Care Policy and Research^436^

b Two scans (measurements) would have to differ by more than this amount to be confident that a real change had occurred with 95% confidence that the detected losses are real.

CV = Coefficient of variation

Bone density tests are not precise enough to reliably measure short-term bone loss in postmenopausal women who are not on treatment for osteoporosis. In population-based studies, postmenopausal women lose bone (femoral neck) at a rate of 0.45 to 0.6 percent per year.^302,360-362^ In one of these studies, which stratified by age, the rate was 0.6 percent per year in women age 60 to 69, 1.1 percent per year in women age 70 to 79, and 2.1 percent per year in women over 80 years of age.^ 360 ^ Higher rates of bone loss have been reported in case series and in the control groups of therapeutic trials performed in patients recruited from specialty referral clinics.^363,364^

In recent trials of therapy for osteoporosis, gains in bone density of the hip ranged from 1.2 to 8.3 percent per year for various osteoporosis treatments (Evidence Table 9). In these trials, average bone density at the hip increased during the first 2 years of treatment, and the difference in bone gain or loss between treatment and placebo groups was statistically significant. However, none of these differences was statistically significant after 6 months or 1 year of treatment.

In randomized trials of treatment for osteoporosis, the relationship between changes in bone density and fracture rates is inconsistent.^ 365 ^ For some therapies, however, such as fluoride, increases in bone density have been associated with unchanged or even increased fragility. Other treatments, such as osteocalcin, reduced fracture rates without an appreciable effect on bone density. Because of these results, there is a consensus that while reduction or reversal of bone loss is an important intermediate outcome, it is not an adequate substitute for direct evidence that a treatment prevents fractures.^ 8 ^

One report from the FIT showed that, on average, women who had larger increases (3 percent or more) in total hip bone density after taking alendronate for 2 years had a lower risk of vertebral fracture than women who had unchanged or lost bone density.^ 366 ^ The differences between patients who had a small (3 percent or less) increase and those who lost bone were not statistically significant, and the results did not change when the analysis was limited to patients with high adherence, which was measured by pill counts. These findings do not support the view that monitoring bone density changes can help detect poor compliance.

As the authors pointed out, the findings "do not necessarily suggest that measurement of change in bone density in individual patients can predict their specific risk for vertebral fractures."^ 366 ^ Most importantly, the analysis did not address whether the women who lost bone or had small increases in bone density benefited less from therapy than women who had a greater response. These women may have been at higher risk of fracture in the first place, and might have had even worse results had they been taking placebo. At present there is no way to know whether increasing the dosage of the medication might improve outcomes.

While the studies in Evidence Table 9 demonstrated high average rates of increase in bone density in treated patients, none tried to correlate individuals' results with other measures of adherence, and none used the results of repeat densitometry to make changes or adjustments in therapy. Also, no observational studies tracked how clinicians use bone density results in patients who are already on treatment.

High-quality, indirect evidence about the potential impact of adjusting therapy based on the results of bone density tests comes from a very recent report of the FIT and Multiple Outcomes of Raloxifene Evaluation Trial.^ 367 ^ Patients in the treatment arms of the two trials (n=6,588) had DXA of the hip and spine at baseline and at 12 and 24 months. During the first year of alendronate therapy, a small group of patients (1.4 percent) appeared to have a decline of 4 percent or more in bone density (these were the worst responders). These patients had a 92 percent chance of gaining bone density in the second year of treatment, and their average gain (4.8 percent) was higher than that of patients who had seemed to respond to alendronate in the first year. Conversely, patients who gained the most bone density in the first year (8 percent or more) lost bone density on average in the second year of treatment. A similar pattern was observed for raloxifene. The investigators attributed this pattern to the statistical phenomena known as "regression to the mean."^ 367 ^

#### Summary

Currently, the weight of evidence is against repeating bone density tests within the first year of treatment. There is insufficient evidence to determine whether repeating bone mineral density tests 2 years after starting therapy is useful. There are no studies about the effect of monitoring responses to therapy using densitometry, or of the choice of test, on the outcome of therapy.

## Biochemical Markers

It is widely believed that both bone density and the rate of continuing bone loss are independent risk factors for fractures. Bone loss occurs when bone resorption outpaces bone formation during bone remodeling. Markers of bone turnover are biochemical substances found in the blood or urine that reflect this process. Although resorption and formation are coupled, in postmenopausal women, high rates of bone turnover due to estrogen depletion result in net bone loss. Broader use of markers has been advocated to identify women at high risk for osteoporosis or women who are not improving on treatment. Such identification could lead to earlier initiation or adjustment of therapy and improved outcomes. The rationale for these uses of markers is that changes in levels of biochemical markers in response to changes in hormonal milieu or antiresorptive therapy are generally seen before changes in bone density can be detected.^ 368 ^

Table 13 shows the markers addressed in this report.^368,369^ Markers of bone formation include serum total alkaline phosphatase (ALP) and bone-specific alkaline phosphatase (BALP), serum osteocalcin or bone gla-protein, carboxyterminal propeptide of type I procollagen (PICP), and amino propeptide of type I collagen (PINP).

Table 13. Description of biochemical markers

Marker | Abbreviation | Collection | Assay
Formation markers
Total alkaline phosphatase | ALP | Serum | IRMA
Bone-specific alkaline phosphatase | BALP | Serum | IRMA, ELISA
Osteocalcin, bone gla-protein | OC | Serum | RIA, ELISA
Carboxyterminal propeptide of type I procollagen | PICP | Serum | RIA
Carboxy propeptide of type I collagen | ICTP | Serum | RIA
Resorption markers
Hydroxyproline | HPR | Urine
Calcium | CA | Urine
Pyridinoline | PYR | Urine | EIA
Deoxypyridinoline | D-PYR | Urine | EIA, RIA
Type I collagen cross-linked C-telopeptide | CTX | Urine/Serum | ELISA
Type I collagen cross-linked N-telopeptide | NTX | Urine | ELISA
Tartrate-resistant acid phosphatase | TRAP | Serum

Markers of bone resorption include urinary hydroxyproline, urinary calcium, tartrate-resistant acid phosphatase (TRAP), the collagen cross-links urinary pyridinoline (PYR) and urinary deoxypyridinoline (D-PYR), carboxy propeptide of type I collagen (ICTP), type I collagen cross-linked C-telopeptides (CTX), and type I collagen cross-linked N-telopeptides (NTX). CTX and NTX can be measured in serum or urine, but the urine test is more widely used.^ 370 ^ According to Quest Diagnostics, Incorporated, the cost of marker tests ranges from about $75.00 for BALP, to $150.00 for serum NTX.

Most of these markers have come into use recently and are not yet widely used in clinical practice. In the MEDLINE search we conducted for this review, only 43 of 1,038 citations were published before 1990. Urinary D-PYR measured by immunoassay (Pyrilinks-D®), and urinary NTX immunoassay (Osteomark®) are the most widely available markers in U.S. clinical laboratories.^ 370 ^ Urinary CTX immunoassay (CrossLaps®), serum NTX immunoassay (Osteomark®), and urinary PYR immunoassay have the most limited availability.

Several factors should be taken into account when interpreting results of marker tests. Marker levels vary substantially over the course of a day and from day to day.^371-373^ For example, in one study of 14 women, the daily peak value for urinary NTX was 20% higher than the mean value over 24 hours.^ 371 ^ Collecting several specimens, and collecting them at specific times of the day, may give a more accurate picture of the level of bone turnover than single measurements. In addition, marker levels may take several months to stabilize after initiating treatment, and the rate of change may be an important indicator of the rate of turnover or rate of bone loss. In a study of women on alendronate treatment, osteocalcin had a smaller, gradual decrease over 12 months than NTX, which decreased about 60 percent at 6 months after start of treatment.^ 374 ^ Another study measured markers at 3 months, 6 months, and 12 months.^ 375 ^ Decreased D-PYR levels remained steady at 6 months, whereas bone density continued to increase.

The method by which markers are measured and defined also may affect results. Kits using different methods, and kits from different manufacturers, may have different analytic performance characteristics.^376,377^

We considered two populations of women for this review: those who have not been treated for osteoporosis, and those who are currently on treatment. Women not on treatment are those who may have bone loss but have never had their bone density measured, or who have a bone density that is known to be in the normal or osteopenic range. In theory, the use of markers in these women could lead to reduction in fractures by identifying women who are at high risk because of rapid bone loss. Treatment could be initiated to prevent osteoporosis by reversing or slowing bone loss. The second population of interest in this review is women undergoing treatment for osteoporosis. In theory, clinicians could use markers to identify women who were not responding to treatment. After identifying these "nonresponders," clinicians could decide to increase or change current treatment, potentially leading to decreased risk of fracture.

Longitudinal studies usually report the relationship of average levels of markers in a group to fracture rates as an odds ratio, or to bone density as the correlation coefficient. The accuracy of a test in an individual patient is more useful to a clinician making a decision about management. When available, we report these individual-level results (Evidence Tables 10, 12, 14, 16). If necessary, we calculated test results from data reported, for example by counting data points above and below a threshold on a scatter plot. When a threshold was not defined in a study, we chose 2 or more thresholds to compare results at different levels of sensitivity and specificity. In all cases, we defined a "positive" marker result as one suggesting high bone turnover, and defined a "negative" marker test result as one suggesting normal (or low) bone turnover. Table 13a shows the definitions of sensitivity and specificity pertaining to each condition.

Table 13a. Definition of sensitivity and specificity for marker studies

Evidence Table | Description of patients | Condition | Definition of + Test | Definition of - Test | Definition of Sensitivity | Definition of Specificity
10 | Not on treatment, with or without osteoporosis | Current osteo-porosis | Marker suggests osteoporosis (high turnover) | Marker suggests normal BMD (low or "normal" turnover) | Proportion of patients with osteoporosis who had a marker test indicating high turnover (+ test) | Proportion of patients with normal BMD who had a marker test indicating low/normal turnover (- test)
12 | Not on treatment, with or without osteoporosis | Future fracture | High turnover | Low/normal turnover | Proportion of patients who fractured who had a marker test indicating high turnover (+ test) | Proportion of patients who did not fracture who had a marker test indicating low/normal turnover (- test)
14 | Not on treatment, without osteoporosis | High rate of bone loss over time | High turnover | Low/normal turnover | Proportion of patients with a high rate of bone loss who had a marker test indicating high turnover (+ test) | Proportion of patients with a low rate of bone loss who had a marker test indicating low/normal turnover (- test)
16 | On treatment, with osteoporosis | Poor response to treatment (high rate of bone loss over time) | High turnover | Low/normal turnover | Proportion of patients with a high rate of bone loss who had a marker test indicating high turnover (+ test) | Proportion of patients with a low rate of bone loss who had a marker test indicating low/normal turnover (- test)

In the absence of clinical trials that compare a "marker-based" strategy to a conventional approach for selecting patients for treatment, we examined whether markers are correlated with bone loss and fractures. We also sought any evidence that marker results had been used in a systematic way to make decisions about treatment, or that these decisions lead to reduction in fracture risk. We examined the adverse effects of measuring markers and of using markers to guide treatment decisions.

### Can Markers Be Used Instead of Bone Measurement Tests to Identify Women Who Have Low Bone Density?

Five cross-sectional studies evaluated whether levels of markers can be used to distinguish women who currently have low bone density from those who have normal bone density.^378-382^ (Evidence Table 10). In these studies, markers and densitometry were done at the same time. The clinical question these studies address is whether markers could identify women who had osteoporosis or osteopenia, which was diagnosed by densitometry, the "gold standard" determination of disease.

Two good-quality studies^380,382^ measured urinary NTX and found that between 51 and 61 percent of women with osteoporosis had higher levels, and that 50 to 82 percent of those without osteoporosis had lower levels. Overall, only 22% of women with high levels of NTX had osteoporosis. High levels of BALP correctly identified 70% of patients with osteoporosis, but 42% of women without osteoporosis also had high levels, and overall only 21% of women with high levels had osteoporosis. The predictive values of osteocalcin and PICP levels (15%-23%) were similar to those for NTX and BALP, while those for PYR and D-PYR levels were worse (12%-13%).^ 380 ^

The other three studies were small (n= 34 to 78) and did not reflect the mix of patients seen in general clinical practice.^378,379,381^ Across all studies, for all markers measured, to correctly identify 80 percent of women with low bone density, fewer than 30 percent of those withnormal bone density would be classified correctly. In one small study in which women with osteoporosis were identified before enrollment, CTX was more accurate. Seventy-five percent of women with osteoporosis had an elevated CTX level, and 85 percent of normal controls had lower CTX levels.^ 379 ^ At this cutoff, 25 percent of women with osteoporosis would be incorrectly classified as having normal bone density. Lowering the cutoff for a positive test to result in no false-negative results would lead to 73 percent of women with normal bone density to be classified as osteoporotic.

#### Summary

No single marker or cluster of markers accurately identified individuals who had osteoporosis, as determined by the results of densitometry. It is not surprising that agreement between the two tests was poor. Densitometry measures current bone status, whereas markers measure the process of bone turnover and may indicate the beginning of bone deterioration that would not be detected by densitometry for several more years.

### How Well do Markers Predict Fractures?

Three prospective studies^383-385^ and three nested case-control studies^376,386,387^ examined how well marker results predicted fracture rates over time in women not undergoing treatment for osteoporosis (Evidence Table 11). Three of the six studies were population-based,^376,384,386^ and four calculated age-adjusted or age-stratified odds ratios or relative risks.^383, 385-387^

In a large, good-quality, population-based study of 305 Swedish women aged 40 to 80, those with decreased levels (1 standard deviation decrease) of ICTP were 1.9 times more likely to have a fracture of any type 5 years later, and those with decreased levels (1 standard deviation decrease) of PICP were 1.8 times more likely to fracture.^ 384 ^ This study sample was randomly selected from population files of one city, making it similar to a general clinical population. However, there was a 63 percent participation rate, suggesting that the sample may not be representative.

In the EPIDOS cohort,^ 386 ^ women with levels of CTX 2 standard deviations above the premenopausal mean were 2.2 times more likely to have a hip fracture within 22 months, and those with free D-PYR above this range were 1.9 times more likely to fracture. Other markers measured (BALP, osteocalcin, NTX) were not significant predictors of fracture.

In the Rotterdam study, increased levels of free, but not total, PYR and D-PYR were associated with increased risk of hip fracture.^ 387 ^ Women with higher levels of free D-PYR were 1.4 times more likely to fracture at a mean follow-up of 22 months. BALP and NTX were not predictive of fracture in this and another study.^ 386 ^ An increased level of ALP was associated with risk of fracture in one of two studies.^ 385 ^

In the Rotterdam study, women with osteocalcin levels above the median were 3.1 times more likely to have a hip fracture at a median follow-up of 2.4 years, but this difference was not statistically significant (95 percent CI 1.0-9.2). In both reports from EPIDOS, there was no association between elevated total osteocalcin levels and the subsequent risk of fracture.^384,386^ However, increased levels of undercarboxylated osteocalcin, were associated with an increased risk of hip fracture (OR = 2.0, 95 percent CI = 1.2-3.2).^ 376 ^ There was also a strong association between increased levels of undercarboxylated osteocalcin and fracture in a group of elderly women living in a nursing facility who had vitamin D deficiency.^ 383 ^ Those with increased levels of undercarboxylated osteocalcin at baseline were 5.9 times more likely to sustain a hip or other non-vertebral fracture within 18 months. While the results of these two analyses need to be confirmed in other prospective studies, they have generated intense interest. Investigators are examining whether these results reflect decreased intake or deficiency of vitamin K, which mediates carboxylation of osteocalcin.

Results of well-done studies in which markers were combined with other risk factors to enhance prediction of fracture are inconsistent. One good-quality study found a greater risk of fracture in women with both a low bone density and either high CTX or high free D-PYR levels than in women with either risk factor alone.^ 386 ^ Other studies did not find the same increased predictive value when bone density and markers were combined. In the Rotterdam study, adjustment for bone density did not affect risk estimates for the markers, but adjustment for disability (ability to rise, walk, bend) did.^ 387 ^ According to a Hawaiian study, adjustment for baseline calcaneous bone density did not affect the relationship between marker levels and risk of vertebral fracture at three year follow-up.^ 385 ^ In the Swedish study, combining markers with bone density did not increase ability to predict fracture.^ 384 ^

The ability of a test to predict fracture in an individual patient is more useful to clinicians than the association of these outcomes in a group. Two studies provided sufficient data to calculate the accuracy of three markers (CTX, undercarboxylated osteocalcin, D-PYR) to predict hip fracture in individuals^383,386^ (Evidence Table 12).

In a nested case-control analysis of 109 elderly women (more than 74 years old) with hip fractures and 292 without fractures in the EPIDOS study, CTX and D-PYR had similar accuracy to predict hip fracture at a mean follow up period of 22 months.^ 386 ^ Garnero defined a "positive" test for CTX or D-PYR as one that was two standard deviations or more above the mean for premenopausal women. Of the women who had a fracture within 22 months of follow up, 36% had a CTX above this value, as did 19% of those who did not have a fracture. For D-PYR, 36% of the women who had a fracture had a "positive" test result, as did 19% of those who did not have a fracture. In the study of institutionalized women with vitamin D deficiency,^ 383 ^ 53 percent of those who fractured had an elevated undercarboxylated osteocalcin level at baseline, and 79 percent of those without an elevated level did not fracture. Almost half of the women who fractured were not identified as at-risk by their marker result. Follow-up time was short in both of these studies (22 months in EPIDOS and 18 months in the institutionalized women with vitamin D deficiency); accuracy of the tests might have been different with a longer period of observation.

#### Summary

No marker was associated with increased fracture risk consistently across all studies. The EPIDOS study^ 386 ^ provides evidence that using markers in conjunction with densitometry may increase predictability, but this result has not been confirmed in other studies.

### Can Markers Help Select Patients for Treatment?

If markers can accurately predict which patients are at risk for rapid bone loss, they could help clinicians select patients who would benefit most from treatment, potentially leading to initiation of treatment in time to prevent further bone loss and eventual fracture. However, we identified no studies in which treatment decisions were made on the basis of marker test results.

Evidence Table 13 describes 11 longitudinal studies that provide information on the association between mean group marker levels and rates of bone loss as measured by densitometry at follow-up. Follow-up periods ranged from 1 to 5 years.^388-398^ Most of these are small studies of volunteers at single institutions. One, a subset of women from the Study of Osteoporotic Fractures, is population-based.^ 397 ^

In this multicenter study of 295 women aged 67 to 89 participating in the Study of Osteoporotic Fractures,^ 397 ^ osteocalcin, PYR, NTX, and CTX levels measured at baseline correlated significantly with annual percent change in bone density by hip DXA measured an average of 3.8 years later. BALP, however, was not significantly correlated with DXA.

In the OFELY study, a large, population-based study of determinants of bone loss in postmenopausal women in France,^ 399 ^ osteocalcin, NTX, and CTX were significantly associated with forearm bone loss. This study had the longest follow-up period, 4 years.

There was no clear trend across all the studies regarding the correlation between marker results and bone loss. It is difficult to compare these studies because of differences in populations, markers measured, and site of bone density measures. For example, one of six studies of ALP,^ 392 ^ one of three studies of BALP,^ 393 ^ and one of five studies of urinary calcium found a significant correlation with bone loss.^ 395 ^ Two of six studies found a significant correlation^393,397^ between hip DXA and OC. Six studies measured HPR, and two found a significant correlation.^389,393^

When a regression equation with osteocalcin, ALP, CA, and HPR was used to predict bone loss at different sites, these markers were correlated with bone density at the proximal forearm and ultradistal forearm, but not at the spine or total body.^ 398 ^

Evidence Table 14 describes 10 studies that provided data on the accuracy of markers to predict bone loss in individuals not on treatment for osteoporosis.^388-395,397,399^ The best study^ 397 ^ reported the rate of bone loss over three to five years of follow-up in 295 white women over 65 years old from four centers in the SOF cohort. The investigators examined how well six different markers identified women who subsequently lost bone at a rapid rate of 1.1% per year of follow up. The ability of six different markers to predict this rate of bone loss was poor. As shown in Evidence Table 14, the investigators evaluated the performance of each marker at two different cutoffs. The first cutoff defined a "positive" test result as one that was above the median. Using this cutoff, marker test results were positive in 56 to 72 percent of women with rapid bone loss (more than 1.1 percent per year), but were also positive in approximately 50 percent of women with slower rates of bone loss. The second, stricter cutoff defined a "positive" test result as one that was in the highest quartile. Using this cutoff, marker test results were positive in 29 to 33 percent of women with rapid bone loss and in approximately 25 percent of women with slower rates of bone loss Another good-quality study has similar results,^ 399 ^ The best results for any marker were from a third good-quality study,^ 389 ^ conducted in 307 healthy female volunteers from 39 to 72 years old. One-third (33 percent) of women who had rapid bone loss had a "positive" hydroxyproline test result. Among women who had a "negative" test result, 50 percent were rapid bone losers.

In the remaining studies, markers had high sensitivity and low specificity for predicting which women would lose bone rapidly,^ 395 ^ or had poor sensitivity.^ 392 ^ These studies were small and were conducted at single institutions. One study^ 394 ^ measured the accuracy of six markers to predict bone loss by spine and hip densitometry 4 years later in 141 volunteers participating in an ovarian screening program in the United Kingdom. Sensitivity of osteocalcin, ALP, CA, HPR, PYR, and D-PYR ranged from 33 to 58 percent, and specificity ranged from 50 to 72 percent.

Three longitudinal studies provided information that made it possible to calculate test characteristics when a combination of two or more markers and/or other risk factors was used to predict bone loss.^388,390,393^ Predictive value was improved when results of several markers were combined, or when markers were combined with risk factors such as initial bone density,^ 390 ^ body mass index,^ 393 ^ fat mass,^ 388 ^ or calcium intake.^ 393 ^

A cross-sectional study of 320 teachers in one Italian town^ 400 ^ examined the relationship of markers to other risk factors for osteoporosis. Only age and time since menopause were significantly associated with PYR; age, number of cigarettes smoked per day, and body mass index were associated with serum osteocalcin. There was no relationship between these markers and bone density measured at the distal forearm. In another study of 249 premenopausal volunteers,^ 401 ^ osteocalcin and PYR were not associated with height, weight, calcium intake, vitamin D supplementation, caffeine intake, or bone density measured at the lumbar spine, distal forearm, and proximal femur.

#### Summary

Studies correlating marker results and bone loss indicated no clear trend. Sensitivity and specificity were too low to be useful for the purpose of selecting patients for treatment. Some studies found better test accuracy when a combination of two or more markers and/or other risk factors was used to predict bone loss.

### Can Markers Predict Response to Therapy?

There is no direct evidence about whether the use of markers to monitor treatment in women with osteoporosis leads to a reduction in fracture risk. The best evidence for this would be a trial in which women on treatment are randomized to monitoring with markers or usual care, and then prospectively followed for incidence of fracture. We found no studies that used this design. Also, no studies measured outcomes, either fracture or bone density, after changes were made in treatment based on the results of marker tests.

Some researchers have advocated using markers as a way of monitoring compliance with treatment. We identified no studies of the use of markers to increase compliance. It is not clear whether this is a more effective method than directly asking the patient about compliance, side effects, or difficulty with following the regimen.

Evidence Tables 15 and 16 describe studies in which markers were used to monitor or predict response to therapy in women already on treatment for osteoporosis.

#### Bisphosphonates, calcitonin, or raloxifene

We identified six longitudinal studies of the use of markers to monitor or predict response to alendronate treatment^282,374,402-405^ (Evidence Table 15). Data from these studies were mainly from randomized controlled trials of alendronate therapy, and several were population-based or multi-center. One study^ 404 ^ measured changes in markers from baseline to 3 months, and the others measured changes in markers from baseline to 6 months. Changes in marker levels were compared to changes in bone density measures at 12 months, 24 months, or 30 months. The dose of alendronate varied across the studies. All used DXA as the measure of bone loss, either of the spine, hip, wrist, total body, or some combination.

In four studies comparing levels of BALP to spine bone density performed 12 to 30 months later, correlation coefficients ranged from -0.06 to -0.67.^282,402,405,374^ The relationship was statistically significant in three studies. Hip DXA, measured in two studies, was not significantly associated with BALP, and total body and wrist bone density were not significantly associated with BALP.

Osteocalcin was associated with spine DXA in all four studies that measured this marker (range -0.25 to -0.63), at the hip in the two studies measuring this (range -0.18 to -0.39), and in 2 of 3 studies for total body DXA (see Evidence Table 15). Osteocalcin correlated significantly at the forearm in one of two studies measuring this. NTX correlated significantly at the spine in three of four studies (range -0.26 to -0.53), at the hip in all three studies using this measure (range -0.27 to -0.30), for total body in two of three studies (-0.20 to -0.34), and at the wrist in one of two studies (-0.02 to -0.12). ICTP (-0.20) and PICP (-0.67) correlated significantly in the one study that compared these markers to spine DXA. D-PYR was measured in two studies. The relationship was nonsignificant for all bone density measures at the spine, hip, total body and wrist. No study measured ALP, urinary Ca, HPR, CTX, or TRAP.

One longitudinal study examined the ability of levels of markers to predict fractures in women taking nasal calcitonin. In this study, 208 women aged 68 to 72 were followed over 2 years.^ 406 ^ CTX and other markers were measured at baseline and 9 months. In 14 women who sustained a fracture at any site, CTX levels remained unchanged from baseline, while in 150 women who did not fracture, CTX decreased an average of 30 percent (range -75.1 to 44.7 percent, p = .002).

Although some marker results correlate significantly with densitometry, the size of this association in many cases is small, suggesting that markers have limited ability alone to identify nonresponders to treatment. The largest study (n= 794), a multicenter study covering four clinical centers, had correlation coefficients that were statistically significant, although small.^ 374 ^ In studies of mean group values, markers, especially osteocalcin, are more closely correlated with spine DXA than with DXA at other sites.

One potential use of markers is to rapidly identify women who are not responding to treatment, and who therefore would benefit by adjustment of therapy. A positive marker test in this case would identify a woman whose bone density is not expected to improve, that is, a "nonresponder."

How accurately do markers identify women who fail to respond to therapy, as judged by bone densitometry? Four studies by two authors provided information on the ability of markers to predict nonresponse to alendronate therapy after 2 years.^374,402,404,405^ (Evidence Table 16). When possible, we calculated test characteristics using different cutoff values for a positive marker test.

In one study,^ 374 ^ 103 (13 percent) of 794 alendronate users had no increase in spine bone density after 2 years of treatment (i.e., were nonresponders). Of these, NTX after 6 months of treatment was negative (at least 40 percent lower) in 55 patients; we defined these results as "false negatives". Among 151 patients in whom the change in NTX was "positive", 47 (32 percent) proved to be nonresponders (positive predictive value = 0.32). In other words, if the change in NTX suggested nonresponse, the probability of nonresponse increased from 13 percent to 32 percent. Positive predictive values in the other studies ranged from 0.27 to 0.92.

Three studies measured osteocalcin levels.^374,402,405^ In a study in which 13 of 51 women did not respond to treatment, intact osteocalcin identified 92 percent of the nonresponders and 76 percent of responders at a less than 20 percent decrease cutoff level.^ 402 ^ At a less than 10 percent cutoff, 77 percent of nonresponders and 84 percent of responders were identified. The other two studies, measuring total osteocalcin, identified 54 percent of nonresponders when 78 percent of responders were correctly identified,^ 374 ^ and 57 percent of nonresponders when 98 percent of the responders were correctly identified^ 405 ^ (the proportion of women who were nonresponders is not given in these studies). The false negative rates were 43 to 46 percent; about half of all women who were in fact responding to treatment would be classified as nonresponders, potentially leading to unnecessary adjustment in treatment.

#### Hormone Replacement Therapy

Eleven studies prospectively compared markers with bone density measurements in women on hormone replacement therapy^6,375,407-415^ (Evidence Table 15). Most of these studies were small, with the majority having fewer than 100 subjects and the largest containing 388 subjects. Osteocalcin significantly correlated with spine DXA in five of eight studies.^407-409,411,413^

Two studies provided data on the accuracy of markers to predict response to hormone replacement therapy in individuals^375,408^ (Evidence Table 16). In one study,^ 408 ^ 20 of 109 women did not respond to treatment. NTX identified 55 to 85 percent of these nonresponders and 56 to 80 percent of responders, depending on the NTX cutoff level. At these levels, between 20 and 44 percent of women could potentially be subject to adjustment of therapy that was in fact effective. A study measuring osteocalcin^ 375 ^ was less accurate in predicting response. Seven of 36 women in this study did not respond to treatment according to densitometry measures, and between 14 and 71 percent of these women were identified, depending on the cutoff used for a positive marker test result.

A study of 63 women at one university hospital in Israel^ 416 ^ found a 40 percent decrease in BALP at 6 months had 56 percent sensitivity, 83 percent specificity, 95 percent positive predictive value, and 25 percent negative predictive value to predict spine bone density gain after 2 years of hormone replacement therapy. There was no association between change in hip bone density and percent of decrease in BALP.

Two recent studies also examined the ability of formation and resorption markers to predict response to hormone replacement therapy.^415,417^ In one,^ 415 ^ 388 postmenopausal women participating in 2 clinical trials of transdermal estradiol were followed for changes in spine bone density at 2 years' follow-up. BALP, osteocalcin, and serum and urinary CTX measured at 3 and 6 months were correlated with bone density at 2 years. To determine the accuracy of these markers to predict therapeutic response in individuals, sensitivity was calculated using a cutoff at which no more than 10% of the nonresponders (women with a bone density increase of less than 2.26 percent) would be incorrectly classified. Eighty-nine women who had a change in bone density within the precision error of the technique were excluded from the analysis. At 3 months, osteocalcin and BALP were inaccurate, but improved at 6 months to about 30 to 40 percent sensitivity to identify responders. Performance of CTX was better at both 3 and 6 months (52 to 56 percent sensitivity). Repeated measures at 6 months did not improve accuracy of CTX substantially over levels measured at 3 months.

In another recent study,^ 417 ^ serum and urinary CTX also performed better than the formation markers BALP and osteocalcin in predicting 3-year response to estradiol as measured by hip bone density. When cutoff values for markers were used that kept the false-positive rates low (i.e., only one woman whose marker result decreased but did lose bone density), sensitivity was low for osteocalcin and BALP (36 to 50 percent), but better for serum and urinary CTX (56 to 67 percent).

False-positive and false-negative tests occurred at a high rate in these studies. At cutoff levels for markers giving acceptable false-positive rates, false-negatives are very high, and vice versa. A false-positive test could lead to an unnecessary increase in dosage or change in drug choice when the treatment was in fact effective. A false-negative test could delay adjustment to more effective treatment until more accurate measures indicated nonresponse to treatment. This could in turn lead to increased risk of fracture.

#### Summary

There is a small correlation between response to therapy as measured by densitometry and marker results, but in individuals, no marker is accurate enough to reliably identify nonresponders to treatment as defined by subsequent BMD tests. The best results, from the EPIDOS study, have not been replicated in other studies. The use of BMD at 2 years as the gold standard for measuring response to therapy has been called into question by a recent study,^ 367 ^ which found that BMD at 2 years is not a reliable predictor of subsequent response to therapy.

## Evaluation for Secondary Causes of Osteoporosis

### What Diagnostic or Laboratory Tests are Appropriate for Evaluating Patients with Osteoporosis for Secondary Causes?

Osteoporosis can be a sign of systemic disease such as hyperparathyroidism, multiple myeloma, vitamin D deficiency, hyperthyroidism, liver disease, renal failure, and rare disorders such as Menkes syndrome, Marfan syndrome, Ehlers-Danlos syndrome, and homocystinuria due to cystathione deficiency, among others. While some factors, such as corticosteroid and excessive alcohol use, can be ascertained in a routine history and physical examination, diagnosis of many of the other secondary causes of osteoporosis requires laboratory testing.

We addressed the question of what is the appropriate evaluation for secondary causes for women with osteoporosis by conducting a search of the medical literature and a review of expert guidelines and recommendations. Because of the lack of evidence for this question, we also performed a supplemental analysis of physician practice patterns.

Our literature search found no data about the prevalence of secondary causes of osteoporosis in women found to have low bone density or an atraumatic fracture in population-based studies or in the primary care setting. There also is no evidence available to judge when a search for secondary causes is needed, which secondary causes should be sought, or the probability of a secondary cause in women diagnosed with osteoporosis.

Some literature, however, does report either bone density, measures of bone turnover, or the occurrence of osteoporosis in individuals with diseases or disorders known to be secondary causes of osteoporosis, such as hyperthyroidism, hyperparathyroidism, or Cushing's syndrome. These reports were not reviewed because they did not add information about the occurrence of the disease or disorder in women with osteoporosis, and because of methodologic limitations of these studies such as referral bias and small sample sizes. Several small case series report the occurrence of secondary osteoporosis in men referred with severe osteoporosis or vertebral fracture.^418-420^ The majority of men in these series (54 to 78 percent) were found to have secondary causes of osteoporosis, although it is unclear whether these diagnoses were preestablished or whether osteoporosis was diagnosed first and the secondary causes detected by a subsequent laboratory evaluation. The distribution of secondary causes attributable in women may be markedly different, however. Regardless, because these series include men from tertiary referral centers, they are unlikely to represent the larger community population with osteoporosis. Only a prospective, systematically evaluated cohort of women with newly diagnosed osteoporosis would provide data to appropriately answer this question.

Guidelines and recommendations about laboratory testing to identify secondary causes of osteoporosis were obtained from expert sources published within the last 10 years (Appendix D). We considered three sources: published practice guidelines, review articles on diagnosis and management of osteoporosis, and chapters published in textbooks likely to be consulted by primary care practitioners or endocrinologists. We attempted to delineate the practice base and audience for which the recommendations were written, the level of evidence review undertaken in preparation of the review, the secondary disorders that should be considered, and the specific laboratory tests to be used routinely or as indicated by history or examination.

Of the 10 practice guidelines we reviewed, only 3 appeared to be based on a formal evidence review; the rest were based on expert opinion. Only one of the four review articles and none of the textbook chapters were based on an evidence review. Despite this, even within an evidence-based review, many of the recommendations for laboratory testing were stated as being empirically-based rather than evidence based. This is consistent with the lack of direct data on the prevalence of secondary causes of osteoporosis or on the outcomes of diagnostic algorithms. Slightly greater weight could be given to practice guidelines, however, because these frequently represent the considered opinion of a group of experts and undergo peer review. Expert opinion is usually written by a single subspecialist whose opinion may be based on the management of complicated osteoporosis, and may not be representative of the larger population.

Without exception, all practice guidelines suggest a laboratory evaluation, at least in some patients with established osteoporosis, to exclude secondary causes. The scope of this workup, however, varies among guidelines. Because osteoporosis is often a "diagnosis of exclusion," most guidelines and opinions affirm that the diagnosis of primary osteoporosis cannot be made until coexistent disease or disorders are ruled out. In the first two practice guidelines in Appendix D from osteoporosis foundations, the statements of philosophy strongly contrast. The National Osteoporosis Foundation cautions practitioners that "limited biochemical testing may be required in some cases," whereas the Foundation for Osteoporosis Research and Education states that "the workup of secondary causes can be extensive."

The majority of the 10 practice guidelines suggest that the routine evaluation of a woman with osteoporosis would include measurement of serum calcium, phosphorus, ALP, liver enzymes, and creatinine, all part of a metabolic panel, as well as a complete blood count. Most guidelines suggest additional tests, depending on indications of individual patients. These might include serum protein electrophoresis, thyroid function tests, 24-hour urinary calcium, parathyroid hormone, and 25-OH vitamin D levels.

The majority of expert opinions cited in textbooks describe a more extensive routine evaluation: serum calcium, phosphorus, ALP, and creatinine, or, alternatively, a metabolic panel plus thyroid function tests, complete blood count, and serum or urine protein electrophoresis. If indicated by history and physical examination, additional testing would include measurement of parathyroid hormone and 25-OH vitamin D levels. At least half of the review articles would include a metabolic panel and complete blood count, as well as thyroid function tests. Additional testing, if indicated, would include protein electrophoresis, follicle-stimulating hormone, and a bone biopsy.

Review of these guidelines indicates a lack of agreement in the medical community about the appropriate evaluation for secondary causes. Without evidence of the prevalence of secondary disorders in a population tested by bone density measurement, subsequently diagnosed with osteoporosis, and then evaluated for secondary disorders, it is unlikely that this can be resolved. As a first step, identification of the prevalences of specific secondary causes of osteoporosis in a population of women identified with low bone density would be invaluable. An evaluation could then be constructed based on the probability of disease.

To obtain more information about how physicians evaluate women with osteoporosis for secondary causes, we performed a supplemental analysis about physician practice patterns based on responses to a questionnaire. Details of this analysis are presented in a subsequent section (see Supplemental Analysis 1: Practice Variation in the Evaluation of Secondary Causes). The results of this pilot study indicated that physician practice patterns vary in the community. Physician test-ordering behavior differed among primary care practitioners and specialists. Family practitioners less frequently recommended bone density tests for postmenopausal women, obtained bone density tests, and undertook evaluations for secondary causes compared with internists, endocrinologists, and obstetricians/gynecologists. Endocrinologists more frequently evaluated patients for secondary causes than primary care practitioners. TSH, chemistry battery, and complete blood count were the most frequently ordered tests cited by respondents. These were also the most frequently recommended tests in our review of expert guidelines discussed above.

## Cost

### What are the Costs and Cost-Effectiveness of Diagnostic Strategies for Identifying Women with Osteoporosis?

We took two approaches to address the question about the cost-effectiveness of diagnostic strategies. First, we conducted a literature review and critically appraised relevant articles. Finding this literature limited, we performed a supplemental analysis by constructing our own models of cost-effectiveness. We compared various combinations of QUS measurements of the heel and DXA measurements of the hip for hip fracture outcomes using data from two large prospective cohort studies of osteoporosis. For a full description of this analysis, see Supplemental Analysis 2: Model-Based Economic Comparison of Diagnostic Alternatives.

For our literature review, we identified eight economic evaluations of different strategies for diagnosing osteoporosis. All of these studies used cost-effectiveness models and none were based on comparative trials. Two studies complied fully with all six components of the quality criteria we used (described in Table 8), and two others complied with five of six components (Evidence Table 17).

Three studies examined the premise that selection of patients for testing should be based on the patient's overall risk of fracture, as determined by age and other risk factors. One of these studies evaluated the impact of four diagnostic strategies on the risk of hip fracture.^ 275 ^ The four strategies were defined by combining bone density using DXA with one of two cutoffs (T-score of -2 or -2.5), alone or in conjunction with the SCORE instrument^ 271 ^ (described in Evidence Table 4). If a hypothetical cohort of 1,000 women were tested first with SCORE, 544 would not go on to a DXA scan, 38 women who had a T-score under -2.5 would not be identified and treated, and five more fractures would occur. Use of SCORE, however, would reduce costs of diagnosis.

Another study compared the costs of diagnosing osteoporosis using SCORE with different combinations of DXA of the hip, spine, and forearm radius in 392 women who were retirees or employees of a corporation in northern California.^ 12 ^ One hundred of these women (26 percent) had a T-score under -2.5 with DXA at one or more of the three sites (used as the gold standard in this study). The cost of performing all three tests on every patient was $235. The authors suggested a sequential strategy in which all women first underwent an evaluation using SCORE. Women determined to be at higher risk then received densitometry (e.g., DXA at the radius followed by DXA at the hip and spine for those not assessed as osteoporotic at the radius). Assuming SCORE costs $5 per patient to administer, the example sequential strategy would identify 98 of the 100 osteoporotic women, at a cost of $170 per case. With this strategy, all but 84 of the 392 women would require densitometry, and the majority of women with osteoporosis would undergo DXA at three sites (hip, spine, and radius).

Two other studies reviewed data on women age 60 to 69 years^ 421 ^ and women age 50 to 54 years^ 422 ^ to compare using QUS and/or a series of clinical questions to determine who to refer for assessment with DXA. These authors used DXA of the femoral neck and/or the lumbar spine as the gold standard for comparison. Their referral criteria (relevant to these analyses) included (1) women suspected to be osteoporotic from radiological and clinical findings, (2) women with a medical condition predisposing them to osteoporosis, (3) women on corticosteroids, (4) women who underwent menopause before age 45, and (5) women with a family history of osteoporosis.

In the older cohort (age 60 to 69 years), the sensitivity and specificity (73 percent and 81 percent, respectively) were better and the cost per osteoporotic case identified was lower for QUS compared with the referral criteria and with DXA for all women. For women age 50 to 54, when disease prevalence is considered, QUS also had the lowest cost per osteoporotic case identified. The authors used sensitivity analyses to determine that if DXA costs were less than 3.5 times those of QUS, then DXA for all women was more cost-effective. However, when both osteoporotic and osteopenic cases were targeted, the authors found the referral criteria to have lower cost per case identified than QUS, and sensitivity analyses found this pattern to be consistent across ratios of DXA to QUS costs. An additional clinical criterion -- estrogen-deficient women who would undergo or continue with treatment if found to be osteoporotic or osteopenic -- also was included with the other clinical criteria in the younger cohort. However, the cost per case detected was higher for this group than for the five-question clinical criteria group.

The other studies compared universal HRT with selective therapy based on the results of bone density tests.^423,424^ These analyses did not provide information about the choice of diagnostic test.