# Methods

## Literature Search and Selection of Articles

Relevant studies were identified from multiple searches of MEDLINE (1966 to 2000) and HealthSTAR (1975 to 2000), from the reference lists of systematic reviews (Table 7), and from local and national experts (Appendix A). Letters were sent to manufacturers of bone measurement tests requesting additional information about the performance of their instruments, but we received no new data.

Search strings for each of the six topic areas are listed in Appendix B. Databases were searched three times during the course of the project, with the final search in April 2000. Retrieved abstracts were entered into an electronic database (EndNote™). Figure 2 indicates the numbers of abstracts and full-text articles reviewed for all topics in each stage of the review. For all topics combined, 10,174 citations were retrieved, including 6,194 citations about risk factors, 2,125 about bone measurement tests, 110 about bone measurement tests for monitoring, 1,427 about markers, and 318 about costs or cost-effectiveness. The search yielded no papers with data for the secondary causes topic.

Figure 2. Search and selection of citations

A lead investigator was assigned for each topic. Two investigators reviewed each set of titles and abstracts to select articles for full-text review. A research assistant tracked the inclusion status and names of reviewers for each abstract reviewed. We included abstracts that had original data about postmenopausal women and were relevant to a key question in one or more topic areas. For studies of prediction using risk factors, bone measurement tests, or biochemical markers, we selected articles if they reported the relation between a specific risk factor, or a risk assessment tool (a set of risk factors), and bone measurement test results, bone loss, or fracture at any site. We excluded studies of predictors of osteoporosis and fracture in patients with steroid use because we considered this a well-known secondary cause of osteoporosis. We also excluded case reports, animal studies, cadaver studies, studies in patients with serious conditions (organ transplant recipients, inpatients, and those with other known secondary causes of osteoporosis), and studies that did not have an English language abstract.

When a disagreement between two reviewers arose, the lead investigator for the topic reexamined the abstract and determined whether the full text of the article should be retrieved. Investigators also were encouraged to flag abstracts that they felt could be relevant for other topics. Support staff maintained a database to refer these citations to the appropriate investigator if they were not already present in their topic-specific abstract database.

After this review, 530 articles about risk factors, 123 about bone measurement tests, 23 about bone measurement tests for monitoring, 277 about biochemical markers, and 53 about costs were selected as possibly relevant. An additional 242 studies were retrieved after reviewing reference lists of studies and by suggestion of the expert panel or leading researchers in the field. The full text of these 1,248 studies were retrieved from the library or ordered through interlibrary loan. Investigators read the full-text version of the retrieved papers and reapplied the initial eligibility criteria. For all topics, we excluded articles if they did not provide sufficient information to determine the methods for selecting subjects and for analyzing data. For some topics, additional criteria were applied to select studies that were systematically reviewed and included in evidence tables as follows:

Risk Factors. Articles were included if they specified methods for measuring risk factors and if they reported bone density, bone loss, or radiographically verified fractures. Secondary causes of osteoporosis, although important to consider for individual patients, were not included here as clinical risk factors. Randomized controlled trials of interventions were not included in the review of risk factors, although it was acknowledged that trials of calcium and vitamin D supplementation, for example, provide additional support for the importance of calcium and vitamin D deficiencies as risk factors.

Bone Density and Quantitative Ultrasound Tests. Prospective studies of predicting fracture risks from bone density and QUS tests were included. We excluded studies of single- and dual-photon absorptiometry, which have been widely replaced by more recent technologies. Case-control studies were examined if they provided sufficient data to construct a cross-tabulation of fracture status by densitometry or QUS results. Studies of the agreement between different densitometry tests were systematically reviewed if they provided data on how the use of different tests affected classification of patients using T-scores or Z-scores.

Markers. We included prospective studies of the diagnostic accuracy of selected markers using bone densitometry as the reference standard and studies of the use of markers to predict fracture, bone loss, or response to therapy.

Cost. We examined reports that compared two or more diagnostic approaches, specified the tests and sites considered, and reported costs associated with diagnosis and subsequent events.

## Data Extraction and Synthesis

The following information about the patient population, interventions, clinical endpoints, study design, and study quality was extracted from full-text, published studies of fracture or bone density prediction and used to construct evidence tables: identifying information (study name, years of observation); setting (population-based, referral clinic-based, other); study design (randomized trial, prospective, longitudinal cohort study, nested case-control study, other case-control study, cross-sectional study); predictors studied (specific risk factors, bone density and QUS tests, other imaging tests, biological marker assays); length of followup; statistical methods for handling confounders (statistical adjustment, stratification, none) and attrition; numbers of subjects recruited, included, and completing study; and characteristics of the sample (demographic variables, time since menopause, other risk factors). For studies of diagnostic agreement, we also abstracted information about the reference range or decision limits used to classify test results and about the criteria for the determination of disease. For economic evaluations, we also extracted the type of economic evaluation, the primary outcomes reported, data sources, cost unit, discount rate, and what parameters were varied in the sensitivity analyses and results.

All data were abstracted by the lead investigator for the topic. If the lead investigator encountered difficulty in finding or interpreting information in the published report, a second investigator reviewed the article and a consensus was reached. In several cases, we contacted authors to request data that were not included in published reports.

## Assessment of Study Quality

To assess the internal validity of individual studies, we applied a set of criteria developed by the Third U.S. Preventive Services Task Force (Appendix C). This includes a description of a set of minimal criteria for each study design and general definitions of three categories of quality (good, fair, and poor) based on those criteria. These ratings were used to assess cohort studies, randomized controlled trials, and case-control studies within the risk factor, bone measurement test, and marker sections of this paper. The diagnostic test category was used in the diagnostic performance of bone measurement tests and biochemical marker literature as well. We also noted test-review bias and concealment of the test result when assessing disease status (e.g., fracture). A brief description of ratings with criteria by study design follows.

### Cohort studies (prospective studies) or randomized controlled trials

A "good" rating was achieved if the study met all the following criteria: comparable groups were assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments were used and applied equally to the groups; interventions were spelled out clearly; important outcomes were considered; appropriate attention was given to confounders in the analysis; and intention-to-treat analysis was used in randomized controlled trials.

A study received a "fair" rating if any of the following problems were seen: generally comparable groups were assembled initially, but some question remains whether some (although not major) differences occurred in followup; measurement instruments were acceptable (although not the best) and generally applied equally; some, but not all, important outcomes were considered; some, but not all, potential confounders were accounted for; and intention-to-treat analysis was used in randomized controlled trials.

Studies were given a "poor" rating if any of the following flaws existed: groups assembled initially were not close to being comparable or were not maintained throughout the study; unreliable or invalid measurement instruments were used or instruments were not applied equally among groups (including not masking outcome assessment); key confounders were given little or no attention; and intention-to-treat analysis was lacking in randomized controlled trials.

### Diagnostic Accuracy Studies

A study received a "good" rating if the following criteria were met: one or more relevant available diagnostic tests were evaluated; a credible reference standard was used; the reference standard was interpreted independently of the diagnostic test; the reliability of the test was assessed; indeterminate results were few or handled in a reasonable manner; and a large number (more than 100) of broad-spectrum patients with and without disease was included.

A study received a "fair" rating if it evaluated one or more relevant available diagnostic tests; used a reasonable, although not the best, reference standard; interpreted the reference standard independently of the diagnostic test; and consisted of a moderate sample size (50 to 100 subjects) and a "medium" spectrum of patients.

A diagnostic accuracy study with a "poor" rating was characterized by having one or more of the following flaws: an inappropriate reference standard was used; the diagnostic test was administered improperly; a biased ascertainment of the reference standard was shown; or a very small sample size of a very narrowly selected spectrum of patients was included.

### Case-Control Studies

A "good" rating included the following: an appropriate ascertainment of cases and a nonbiased selection of case and control participants were obtained; exclusion criteria were applied equally to cases and controls; the response rate was equal to or greater than 80 percent; diagnostic procedures and measurements were accurate and applied equally to cases and controls; and appropriate attention was given to confounding variables.

A "fair" rating included those studies that were recent, relevant, and without major apparent selection or diagnostic workup bias; had response rates of less than 80 percent; or provided attention to some but not all important confounding variables.

A "poor" rating was given to a study in this category if it had major selection or diagnostic workup biases, response rates were less than 50 percent, or little or no attention was provided to confounding variables.

### Other considerations in study quality

For studies of the relation between risk factors and fracture or other outcomes, we also assessed completeness and length of followup; the use of co-interventions in compared groups; the training level of the personnel conducting the intervention; the inclusion and exclusion criteria used in individual studies; and the methods used to establish the outcome measure.^ 51 ^

Economic evaluations for the cost topic were assessed using six principles for evaluating the quality of cost-effectiveness and cost-benefit studies.^ 52 ^ These six principles, defined in Table 8, provide a method of assessing the quality of economic evaluations and are consistent with more extensive guides such as the work of the Panel on Cost-Effectiveness.^ 53 ^ We used the number of "yes" responses to construct a simple scoring system for quality, with a maximum of 5 or 6, depending on whether discounting was appropriate. The quality score includes a "<" symbol if one or more of the six principles were addressed, but not completely.

Table 8. Summary of six principles for economic evaluations^a^

Principle | Description
Perspective stated | Whose costs and consequences are considered?
Benefit described | What are noneconomic consequences of program?
Costs included | What are the intervention costs, morbidity or side-effect costs, averted costs, and induced costs?
Discounting included | Are future costs and consequences adjusted for timing?
Sensitivity analyzed | For values that are uncertain (e.g., assumed), are analyses performed using alternative values?
Incremental cost-effectiveness comparisons presented | Are alternatives compared in a way that allows decisions on prioritization to be made?

a Adapted from Udvarhelyi^52^

### Quantitative Information

For each study of risk factors, we recorded the relative risk (RR) or odds ratio (OR) for fracture and, when available, the correlation coefficient for fracture or bone density. For prospective studies of fracture prediction using bone density and QUS test results, we calculated the prevalence of fractures in the sample and the probability of a fracture, given various bone density and QUS test results. We then calculated the "risk difference," which we defined as the difference between the probability of a fracture if a test revealed osteoporosis and the probability of a fracture otherwise. If a study reported results for different decision limits (cutoffs), we calculated a risk difference for each threshold.

For studies of the agreement between tests, we recorded or calculated the correlation coefficient, sensitivity, specificity, likelihood ratio (LR), and slope of the regression line for bone density and QUS tests to predict other tests, or of markers to predict the results of bone density or QUS testing. The LR for a positive test was calculated using the formula LR={[PV/(1-PV)]/[p*(d)/1-p*(d)]}, where PV is the probability of the disease, given a positive test result, and p*(d) is the apparent prevalence of disease, estimated as p(d)=(number of true positives+number of false negatives)/(number of patients screened).^ 51 ^