# Introduction

This evidence report describes the effectiveness of various strategies for diagnosing and monitoring postmenopausal women with osteoporosis, as specified in the following six topic areas provided to the investigators by the Agency for Healthcare Research and Quality (AHRQ):

Risk Factors. What is the role of clinical risk factors, in conjunction with bone measurement tests, in identifying high-risk women and guiding initial treatment decisions?

Bone Measurement Tests. What are the advantages and disadvantages of various bone measurement tests at different anatomic sites for identifying women at high risk of fracture?

Monitoring. Are bone measurement tests effective for monitoring response to treatment and for guiding decisions about changes in management?

Biochemical Markers. What is the role of markers of bone turnover for identifying women at risk of bone loss, guiding initial treatment decisions, or monitoring response to therapy?

Evaluation for Secondary Causes of Osteoporosis. What diagnostic or laboratory tests are appropriate for evaluating patients with osteoporosis for secondary causes?

Cost. Assuming consistent treatment approaches, what are the costs and cost-effectiveness of various diagnostic strategies for identifying women with osteoporosis?

These topic areas do not include the effectiveness of dietary, lifestyle, hormonal, and medical interventions for primary prevention or treatment of osteoporosis. This report is confined to diagnostic and monitoring strategies as they apply to individual women and does not include issues regarding mass screening in the general population. Also, while most of the literature addressing these topic areas is aimed at an audience of clinical researchers who specialize in osteoporosis, we have attempted to assess the research findings from the perspectives of clinicians and patients. However, it is not the purpose of this report to propose practice recommendations.

## Definition of Osteoporosis

The term "osteoporosis" describes both a process of decreasing bone density as well as the clinical outcome of fracture. As a result, several definitions of osteoporosis have been offered. In 1991, for example, an international consensus development conference sponsored by three organizations (the National Institute of Arthritis and Musculoskeletal Disease, the National Osteoporosis Foundation, and the European Foundation for Osteoporosis and Bone Disease) defined osteoporosis as "a systemic skeletal disease characterized by low bone mass and microarchitectural deterioration of bone tissue, leading to enhanced bone fragility and a consequent increase in fracture risk."^ 1 ^ This definition emphasizes that, in addition to bone mass, the structure of bone also is an important factor in the mechanism of fractures. In 1993, another international consensus development conference, sponsored by the same organizations, endorsed this definition.^ 2 ^ That conference concluded that bone measurements should be used to diagnose osteoporosis, but it did not specify what available tests or sites should be used or how specific results could be used to make decisions for individual patients.

In 1994, a World Health Organization (WHO) working group made a distinction between the definition and the diagnosis of osteoporosis.^ 3 ^ The WHO working group noted that there was a wide range in estimates of the prevalence of osteoporosis (2.5 to 95 percent), depending on what value of bone density was classified as abnormal. While it endorsed the earlier definition of osteoporosis, the working group proposed that, in epidemiologic studies, osteoporosis should be diagnosed when bone mineral density (BMD) is 2.5 standard deviations below the mean for healthy young adult women at the spine, hip, or wrist, or when a history of an atraumatic fracture is present.^ 4 ^

The number of standard deviation units above or below the young healthy mean is called the "T-score." A "Z-score" is the number of standard deviation units above or below the mean for one's own age group. The WHO working group chose a T-score of −2.5 or less as the criterion, noting that it would classify 30 percent of postmenopausal women as having osteoporosis -- twice as many than if the diagnosis were based on low femoral bone density alone. The working group also proposed that low bone mass or "osteopenia" be diagnosed when bone density was 1.0 to 2.5 standard deviations below the young healthy mean (−2.5 standard deviations <T-score <−1.0 standard deviation). These diagnostic criteria have been incorporated into bone density reports and in the inclusion criteria for recent randomized controlled trials of therapies for osteoporosis. Although they were not intended for use as a clinical treatment threshold, they are being used as such -- much as blood pressure, glucose, and cholesterol measurements are used in diagnosing hypertension, diabetes, and hypercholesterolemia.

Some experts criticize the working group's approach to diagnosis because it ignores the quality of bone and the rate of bone loss.^5, 6^ Many experts suggest that the overall risk of fracture -- not the T-score -- should be used to make decisions in the individual patient,^7-9^ and that T-scores are confusing and may be misinterpreted by physicians and patients.^10,11^

To exclude osteoporosis by the WHO criterion, the T-scores for tests at the wrist, hip, and spine must be above -2.5. In practice, however, a patient may be told that she does not have osteoporosis based on a result at just one site, even though this may miss osteoporosis at other anatomic sites. For example, in a prospective study, 392 women who volunteered for a worksite osteoporosis awareness program had dual-energy X-ray absorptiometry (DXA) of the hip and spine and peripheral DXA of the wrist.^ 12 ^ A total of 100 women (26 percent) had osteoporosis by the WHO criterion. Nine of these 100 women had a T-score below -2.5 at all three sites, and 65 had a T-score below -2.5 at two of the three sites.

Because of the problems with the WHO definition, several participants in the WHO working group now recommend that the diagnosis of osteoporosis should be based only on the T-score obtained at the hip and measured by DXA.^ 13 ^ They propose that measurements at other sites and with other technologies may be useful for assessing risk for fracture, but they should not be used for diagnosis of osteoporosis.

## Prevalence/Burden of Illness

Osteoporosis affects a large proportion of American women over the age of 50. Estimates of rates of prevalence depend on the instrument used to measure bone density and on the characteristics, including ethnicity, of the population studied.

The third National Health and Nutrition Examination Survey (NHANES III) reports prevalence rates for osteoporosis by race; these rates are adjusted for age and for census undercount estimates from 1990 and 1993. NHANES III is a 6-year cross-sectional study of noninstitutionalized civilians in the United States. All subjects over age 20 were eligible unless they had experienced fractures in both hips, and each eligible subject's left hip was scanned unless it had been fractured previously. The sample size was sufficiently large (n =3,311 women over age 50) and ethnically representative to justify extrapolation to the entire U.S. population. The young healthy mean was established by scanning 415 women age 20 to 29. All measurements were made using DXA of the proximal femur.^ 14 ^

From these data, an estimated 12 million (41 percent) white women over age 50 met WHO criterion for osteopenia and 5 million (15 percent) for osteoporosis (Table 1). The prevalence of osteoporosis in Mexican-American women is similar to white women, while rates in black women are approximately half that of the other groups (8 percent). Including all races, an estimated 14 million women over age 50 have osteopenia and over 5 million have osteoporosis.^ 15 ^

Table 1. Prevalence of low femoral neck bone density in U.S. women over age 50 (DXA)^a^

Race | Osteopenia (-2.5 <T-score <-1.0) | | Osteoporosis (T-score <-2.5)
| Prevalence (%)^b^ | Millions^c^ | Prevalence (%)^b^ | Millions^c^
All | 40 | 14 | 15 | 5
NHW | 41 | 12 | 15 | 5
NHB | 28 | 0.9 | 8 | 0.3
MA | 38 | 0.3 | 16 | 0.1

a Data taken from NHANESIII: Looker AC, Wahner LW, Dunn WL, et al.1^15^

b Age adjusted to 1980 U.S. Census

c Undercount adjusted estimates from March 1990 and 1993.

DXA = dual-energy X-ray absorptiometry; NHW = non-Hispanic white; NHB = non-Hispanic black; MA = Mexican American; NHANESIII = National Health and Nutrition Examination Study III

The prevalence of osteoporosis increases with age for all sites measured. By the WHO definition, up to 70 percent of women over age 80 have osteoporosis based on low measurements at the spine, hip, or wrist (Table 2). Percentages almost double across all sites during the eighth decade and again during the ninth.^ 16 ^ Age is an important factor in the relationship between bone density and the absolute risk of fracture. An increase in age of 13 years increases the risk of hip fracture by the same amount as a one standard deviation decrease in bone density. As illustrated in Table 3, the 5-year risk of hip fracture of a 90-year-old woman with a T-score of -1.0 is 2 percent, which is equivalent to that of a 70-year-old woman with a T-score of −2.0. Older women have a much higher fracture rate than younger women with the same bone density because of increasing risks from other factors such as bone quality and tendency to fall.^ 17 ^

Table 2. Osteoporosis prevalence (%) in white women in the U.S. over age 50 by decade (DPA and SPA)^a^

Age | Spine | Hip | Wrist | At spine, hip, or wrist
50-59 | 7.6 | 3.9 | 3.7 | 14.8
60-69 | 11.8 | 8.0 | 11.8 | 21.6
70-79 | 25.0 | 24.5 | 23.1 | 38.5
>80 | 32.0 | 47.5 | 50.0 | 70.0
All | 16.5 | 16.2 | 17.4 | 30.3

a Data taken from Melton LJ 3rd^16^

DPA = dual photon absorptiometry; SPA = single photon absorptiometry

Table 3. 5-year hip fracture rates for women without previous hip fracture by age^a^

T-score
Age | -5 | -4 | -3 | -2 | -1 | 0 | 1 | 2
50 yrs | | | 0.024 | 0.0095 | 0.0038 | 0.0015 | 0.0006 | 0.00023
60 yrs | | 0.069 | 0.029 | 0.011 | 0.0047 | 0.0018 | 0.0007 | 0.00025
70 yrs | | 0.127 | 0.055 | 0.023 | 0.0096 | 0.0039 | 0.001
80 yrs | 0.35 | 0.2 | 0.09 | 0.042 | 0.018 | 0.007 | 0.0028
90 yrs | 0.29 | 0.19 | 0.097 | 0.046 | 0.02 | 0.006

a Data derived from decision model presented in the National Osteoporosis Foundation Report^8^

Women with osteoporosis are more likely to have fractures. In a population-based study conducted in Minnesota, for every one standard deviation reduction in bone density, the age-adjusted odds ratio for hip fracture was 2.40 (95 percent confidence interval [CI] 1.27-3.68). Spine and wrist sites had lower, yet significantly elevated, risks of fracture (spine 1.66 [1.18-2.33]; wrist 1.56 [1.20-2.03]).^ 18 ^

Demographic trends for hip fracture parallel those for osteoporosis. Hip fracture incidence in white women rises from 50 per 100,000 at age 50 to 237 per 100,000 at age 65 (Table 4). White women are generally two to three times more likely than nonwhite women to suffer a hip fracture.^ 19 ^ Hip fractures are associated with high rates of mortality and loss of independence. Wrist fracture incidence tends to increase at earlier ages than hip fractures, with 268 per 100,000 women at age 45-54 (Table 5).^ 20 ^

Table 4. Hip fracture incidence per 100,000 per year for U.S. women^a^

Age | White | Nonwhite | RR ^b^
30-34 | 3.7 | 12.3 | 0.3 (0.08-0.99)
35-39 | 3.2 | 9.6 | 0.3 (0.09-1.54)
40-44 | 21.9 | 14.2 | 1.5 (0.54-4.70)
45-49 | 33.9 | 10.6 | 3.2 (1.03-10.6)
50-54 | 50.1 | 18.4 | 2.7 (1.05-6.70)
55-59 | 88.9 | 31.4 | 2.8 (1.33-6.20)
60-64 | 152.8 | 38.2 | 4.0 (1.27-12.4)
65-69 | 237.2 | 101.5 | 2.3 (1.35-3.97)
70-74 | 530.5 | 167.4 | 3.2 (1.92-4.99)
75-79 | 1,018.4 | 409.0 | 2.5 (1.64-3.80)
80-84 | 1,731.5 | 880.6 | 2.0 (1.35-2.81)

a Data taken from Farmer ME, White LR, Brody JA, et al.^19^

b Relative risk comparing white women vs. nonwhite women (95% confidence interval)

Table 5. Incidence of distal forearm fractures among Rochester, Minnesota women^a^

Age group (years) | 1985-94
Age group (years) | n | Rate ^b^ | 95 % CI
35-44 | 70 | 131.0 | 102.1-165.5
45-54 | 92 | 268.4 | 216.3-329.1
55-64 | 157 | 605.3 | 514.4-707.8
65-74 | 148 | 671.0 | 567.3-788.3
75-84 | 147 | 811.3 | 685.5-953.6
>85 | 82 | 864.1 | 687.2-1072
Subtotal ^c^ | 696 | 421.3 | 389.2-453.5
Total ^d^ | 841 | 287.4 | 267.7-307.1

a Data taken from Melton (1998)^20^

b Incidence per 100,000 person-years

c Incidence per 100,000 person-years directly age-adjusted to the population of 1990 U.S. whites

d Incidence per 100,000 person-years directly age- and sex-adjusted to the population structure of 1990 U.S. whites

CI = confidence interval

Sixteen percent of postmenopausal women have osteoporosis of the lumbar spine.^ 16 ^ Five percent of 50-year-old white women and 25 percent of 80-year-old women have had at least one vertebral fracture.^ 21 ^ Although many vertebral fractures are only incidentally detected on X-rays, some cause severe pain that leads to 150,000 hospital admissions per year in those over age 65, 161,000 physician office visits, and more than 5 million days of restricted activity in those age 45 or older.^ 22 ^ The age-adjusted annual discharge rate for hospitalizations due to vertebral fracture is 17.1 per 10,000 for white females, 9.9 per 10,000 for white males, 3.7 per 10,000 for black females, and 2.5 per 10,000 for black males.^ 23 ^ These rates underestimate the true impact of vertebral fractures because only about 8 percent of vertebral fractures result in hospitalization.

The functional impact of vertebral fracture on quality of life can be substantial, perhaps as great as that for hip fracture.^ 24 ^ In the Study of Osteoporotic Fractures (SOF) -- a large prospective cohort of nearly 10,000 U.S. women age 65 years or older -- women with at least one incident of vertebral fracture were more likely to have increased back pain than those without (odds ratio [OR] 2.4; CI 1.7-3.3).^ 25 ^ These women also had more back disability (OR 2.5; 1.9-3.7), and at least 1 day of bed rest due to back pain per year (OR 6.7; CI 4.4-10.2), and 7 days of limited activity due to back pain per year (OR 3.8; CI 2.7-5.0).

Vertebral fractures may alter lifestyles of affected women, although only 4 percent are unable to live independently because of these fractures.^ 26 ^ In one study, 60 percent or more of a cohort of 100 women with vertebral fractures reported limitations with daily activities such as housework, and 82 percent reported a fear of falling.^ 27 ^ Difficulties with other activities, including social and leisure activities, were reported less frequently, although these activities were rated as equally important as the others.

The burden of osteoporosis extends beyond the consequences of fracture. The process of diagnosis and treatment also can affect quality of life. An osteoporosis-targeted quality of life questionnaire was developed to assess the impact of the disease in women in the community, specifically focusing on physical difficulty with activities of daily living, necessary adaptations, and fears.^ 28 ^ Using this questionnaire, women with osteoporosis indicated significantly more difficulties with routine daily activities compared with women with osteopenia or normal bone density.^ 29 ^ Also, women who had osteoporosis had significantly more fears than women who had normal bone density. It is not clear how comorbidities influenced these differences in quality of life.

## Cost

The total direct medical expenditures for osteoporotic fractures in the United States in 1995 dollars were estimated at $13.8 billion.^ 30 ^ About 75 percent of these dollars were spent for white women, 18.4 percent for white men, 5.3 percent for nonwhite women, and 1.3 percent for nonwhite men. The majority of this total ($8.6 billion) was spent for inpatient care, about $3.9 billion was spent for nursing home care, and $1.3 billion was spent for outpatient services. Hip fracture accounted for $8.68 billion, with per-patient expenditures for hip fracture ranging from approximately $27,000 to $35,000. Fractures at other sites accounted for approximately 37 percent of the total expenditure (about $5.08 billion).

The average cost to society for treatment of a symptomatic vertebral fracture is estimated at $1,895 in 1996 Canadian dollars. Of these total dollars, 31 percent were attributed to hospitalizations, 37 percent to lost productivity, 22 percent to other outpatient costs, and 10 percent to caregiver productivity time lost.^ 31 ^

Distal radial fractures require hospitalization in perhaps 20 percent of cases and relatively little rehabilitation.^ 32 ^ Indirect costs (lost productivity) may well exceed the direct medical costs for these types of fractures.

## Bone Measurement Tests

Technologies used to measure bone are summarized in Table 6 and are reviewed in detail elsewhere.^33-36^ Single photon absorptiometry (SPA), first described in 1963, was based on the principle of measuring photons absorbed by mineral in the tissues.^ 37 ^ More recent densitometry techniques such as DXA are based on the same principle, but they have the advantages of access to axial sites, better precision, lower radiation exposure, shorter examination time, reduced influence of soft tissue thickness, and a more convenient or reliable source of photons. Results of these densitometry tests are expressed as grams of mineral in a projected area (g/cm^2^). Quantitative computed tomography (QCT), an alternative method of measuring axial bone density, is expressed as the grams of mineral in a volume of bone (g/cm^3^). QCT also provides a computed tomography image that radiologists can use to assess bone architecture and structural integrity.

Table 6. Characteristics of bone density and quantitative ultrasound tests

Test | Sites | Examination time, operator skill needed | Radiation exposure | Capital costs-technology purchase | Precision | Cost | Charges | Comments
| | minutes, skill level | | $U.S. | % | | $U.S.
Single photon absorptiometry (SPA) | Wrist, heel | 5-15, low | low | | | | $50-150 | Uses isotopes
Dual-energy photon absorptiometry (DPA) | Spine, proximal femur, whole body | 20-40 | low | $20,000 | 3-10 | inexpensive | $150-300 | Uses isotopes
Single X-ray absorptiometry (SXA) | Peripheral sites | | 0.08-4.6 uSv | $20,000 | 0.5-2 | | $50-150
Dual-energy X-ray absorptiometry (DEXA or DXA) | Lumbar spine, proximal femur | 5-10, high | 0.08-4.6 uSv (pencil beam) or 60 uSv (fan beam) | $100,000-200,000 | 1-5 | Fairly expensive | $136 ^a^ | Influenced by osteoarthritis
| Total body | | | | 0.5 | Expensive
Peripheral dual-energy X-ray absorptiometry (pDXA) | Peripheral (wrist, heel) | | | | 2-5 | Inexpensive
Quantitative computed tomography (QCT) | Spine | 10-30, high | 25-360 uSv | $5,000-15,000 | 2-5 | | $150-300 | Higher radiation exposure; Measures the true volumetric density
Quantitative ultrasonography (QUS) | Heel, fingers, tibia, patella | 5-10, low | none | $10,000-100,000 | 0.4-4 | | $35 ^a^ | Low cost, portable, no radiation
Radiographic absorptiometry (RA) & Quantitative microdenistometry (QMD) | Hand | 5-10, high | 0.08-4.6 uSv ^b^ | | 1-2 | | $90-160 | Low cost, portable

a Average Medicare reimbursement

b uses conventional CT or radiographic equipment

uSv = microSieverts

Densitometry devices that measure peripheral bone density are considerably less expensive to buy and use than axial DXA. Radiographic absorptiometry (RA) and quantitative microdensitometry (QMD) use computer software to estimate bone density from conventional radiographs of the hand. Other devices for measuring bone density in the arm or heel include single X-ray absorptiometry (SXA), peripheral dual X-ray absorptiometry (pDXA), and peripheral quantitative computed tomography (pQCT).

Quantitative ultrasound (QUS) devices report the way that bone attenuates sound waves and/or the speed with which sound travels through the bone.^ 38 ^ Commercial devices measure the "broadband ultrasonic attenuation" (BUA, expressed as decibels/megahertz [dB/MHz]), the speed of sound (SOS), and the "stiffness," a measure derived from the BUA and SOS. QUS does not measure bone mineral content and is categorized separately from the other technologies. While these measures are not highly correlated with measures of bone density made by DXA, some in vitro studies,^39-42^ but not all,^ 43 ^ suggest that QUS might reflect other aspects of bone structure that could be associated with fragility.

## Assessing the Performance of Bone Measurement Tests

Bone measurement tests are used to predict fracture, to aid the clinician to diagnose osteoporosis, and to select patients for treatment.^ 44 ^ In clinical centers that specialize in bone density measurement, DXA of the hip is used as the definitive test for determining whether a patient has osteoporosis. Among bone tests at various sites, DXA of the hip is the strongest predictor of hip fracture. Moreover, most recent randomized trials of pharmacotherapy for osteoporosis have used the results of DXA of the hip as a criterion for entry, making it difficult to determine the benefit for patients identified as having osteoporosis by other tests.

For these reasons, DXA of the hip is considered to be the "gold standard" test for assessing bone density, but it is expensive and somewhat inconvenient. Alternatives such as QUS of the heel, RA of the hand, or peripheral DXA of the hand, wrist, or heel have become popular because they are more convenient and have lower capital costs and examination costs. According to some researchers, these technologies reduce the cost of testing and increase access to densitometry in primary care settings and in underserved areas.^45,46^ Other experts argue that these tests cause confusion because they frequently disagree with the results of DXA of the hip and they do not predict hip fracture as well.^ 47 ^

Is it worthwhile to make fracture risk assessment more widely available, even if the assessment is sometimes less sensitive than DXA of the hip? In part, disagreement over this question arises from a discrepancy between information in the published literature and the information needed to assess the clinical value of different bone measurement tests. There is a wealth of data about the analytical performance of various devices to measure bone, but there are almost no data about the clinical effectiveness of different strategies for identifying patients who are likely to have the greatest benefit from treatment. For example, there are no data by which to judge whether a cheaper and more convenient, but less sensitive, test would provide a net benefit. As Steven Cummings, M.D., has pointed out, "At the moment, women at the greatest risk of fracture appear to be only slightly more likely to receive treatment that reduces fracture risk than women who are at low risk. This strategy seems likely to miss the vast majority of women who account for most of the hip fractures. On the other hand, the impact of strategies to reduce rates of hip fractures in populations critically depends on the reach of the program and adherence with treatment."^ 48 ^

Epidemiologic studies also provide many data on the association of bone measurements with fracture risk. A population-based study provides the best information about the importance of a risk factor, but it is not necessarily the best study design for assessing the performance of a test in everyday clinical settings. Most epidemiologic studies report the adjusted relative risk for fracture per one standard deviation change in bone density or bone ultrasound measurements. By this measure, bone measurements predict hip fracture in women over the age of 60 years better than diastolic blood pressure predicts stroke, or serum cholesterol and smoking predict the risk of coronary artery disease, at any age.^ 49 ^

This relative risk measure is of limited value in comparing the clinical performance of different tests. Absolute risk is preferable to relative risk. However, if relative risks are to be used, they should be adjusted to population risks.^ 13 ^ A clinician cannot easily determine the clinical significance of differences in the relative risk per standard deviation of bone density. In a clinical study of prediction, information about the pretest probability of a fracture would be combined with bone density results. In most epidemiologic studies, the reported adjusted relative risk is an average across groups of patients with different pretest probabilities of a fracture. These studies do not directly address the ability of bone tests to predict fracture or to judge the need for treatment in an individual patient. Potentially meaningful differences in tests may become clinically insignificant if assessment of the pretest probability of fracture is imprecise, or if the pretest probability is inaccurately combined with results of bone density or QUS testing.

Because the relative risk is difficult to interpret clinically, some analytical studies estimate the probability of a fracture during a given time period, such as over 5 years, 10 years, or a lifetime. This approach requires extrapolation from prospective studies and from randomized trials of drugs for osteoporosis, most of which follow individuals for fewer than 4 years.

Another approach is to calculate the sensitivity and specificity of bone measurement tests, considering the test to be a "true positive" if a person who has a low test result has a fracture, and a "false positive" if she does not have a fracture. The values of sensitivity and specificity at different cutoff values of the test are used to construct a "receiver operating characteristic" (ROC) curve. The area under the curve is a measure of discriminant value that can be used to compare the performance of different tests.

The main limitation of this approach is that the observed sensitivity and specificity depend on the length of the observation period.^ 50 ^ The test is false positive only in the sense that the patient has not yet fractured even though she has osteoporosis. This approach also requires a specified time period and a method to adjust the results of studies that use a different duration of followup.

Another objection is that this terminology, which usually is applied to the ability of a test to diagnose an existing condition, should not be used to assess the ability of a test to predict events in the future. A similar objection applies to assessment of the value of other risk factors and of risk assessment tools in identifying patients who have a high risk of fracture. This confusion arises because bone measurement tests are used for prediction of fractures in the future as well as for diagnosis of osteoporosis in the present. It is reasonable to measure the sensitivity and specificity, and use ROC analysis, of one bone measurement test when another test is considered to be the "gold standard" determination of whether a patient has osteoporosis. However, diagnostic disagreement of this type does not necessarily mean that one test is better at predicting fracture than another.

## Previous Systematic Reviews

Table 7 lists systematic reviews about osteoporosis published since 1996 and summarizes their conclusions about risk factors, choice of bone measurement tests, monitoring, markers, and cost-effectiveness. Five reviews were published by governmental agencies in the United States, Canada, and Europe; two were published by professional organizations; and two were published by the Blue Cross and Blue Shield Association Technology Evaluation Center. Six reviews addressed the value of risk factors and acknowledged their role in decisionmaking about testing or treatment options. Among those that drew conclusions regarding the choice of bone measurement tests, the two evaluations from professional organizations concluded that hip DXA was the best test, and several others found insufficient evidence to support the use of peripheral measures, including QUS, to assess bone density at the hip and spine. Three reviews concluded that use of biochemical markers in clinical practice is not yet supported by evidence.

Table 7. Recent systematic reviews on osteoporosis

Publication | Year | Organization Producing Report | Conclusions
| | | Risk factors | Choice of test | Monitoring | Use of markers | Cost-effectiveness
Bone density measurement - a systematic review ^ 426 ^ | 1997 | Swedish Council on Technology Assessment in Health Care | Must consider risk factors other than bone density alone to make decisions about testing or treatment. | BMD in hip or spine cannot be reliably estimated from measurements in arm or heel. | Measurements at intervals <2 years are unnecessary. | No documentation that repeated measurements of markers influence treatment in a way that improves long-term clinical outcomes.
Effectiveness of bone density measurement and associated treaments for prevention of fractures ^ 427 ^ | 1996 | International Network of Agencies for Health Technology Assessment | | The precision and accuracy of all BMD tests in community settings are unknown. Accuracy of ultrasound still not proven. | BMD would require minimum followup of 1 to 1.5 years to detect bone loss of 2 to 3%.
Bone mineral density testing: does the evidence support its selective use in well women? ^ 428 ^ | 1997 | British Columbia Office of Health Technology Assessment | Currently there are no validated risk assessment tools to select patients for BMD testing. In the general population, clinical assessment was no worse than BMD measurement in assessment of fracture risk. | Result of BMD test by any current technology is an unsuitable measure upon which to base clinical decisions. | | | Available economic evaluations are not adequate evidence that BMD testing is more cost-effective than universal hormone therapy or no intervention.
Osteoporosis: review of the evidence for prevention, diagnosis, and treatment and cost-effectiveness analysis ^ 8 ^ | 1998 | National Osteoporosis Foundation | Appropriateness of measuring BMD depends on fracture risk, determined by age and other risk factors, and treatment being considered. | Given the better predictive value of hip measurements for hip fractures, hip DXA should be the primary measurement. | The longer the interval between measurements, the more precise the estimate of changes in bone mass; effect of monitoring on treatment is unknown. | Biochemical markers are promising but their role in patient management is not yet known.
Quantitative ultrasound for bone density measurement ^ 429 ^ | 1998 | Alberta Heritage Foundation for Medical Research | | Quantitative calcaneal ultrasound is a promising diagnostic technology, but its role in osteoporosis diagnosis is unclear. Good evidence that ultrasound can identify increased risk of fracture in populations but not individuals.
Selective testing with bone density measurement ^ 430 ^ | 1999 | Alberta Heritage Foundation for Medical Research | There is potential for selective use of BMD in association with appraisal of other risk factors. Assessment protocols for such an approach have promise as a useful tool for selecting whom to test. Advice on treatment options should consider evidence of efficacy and effectiveness in terms of absolute reduction in risk of fracture, long-term compliance, and adverse effects. | Substantial uncertainty with the performance of BMD in correctly classifying an individual as osteoporotic. Ultrasound is less precise than DXA. | Minimum acceptable interval between measurements may be as long as 2 years.
Ultrasonography of the heel for diagnostic osteoporosis and selecting patients for pharmacologic treatment ^ 431 ^ | 1999 | Blue Cross and Blue Shield Association | | Use of ultrasound to direct treatment may result in a substantially smaller health outcome benefit as compared to DXA. 43 to 76% of patients benefiting from treatment would be identified by ultrasound (sensitivity); 75 to 90% of patients not benefiting by treatment would be identified by ultrasound (specificity).
Osteoporosis: clinical guidelines for prevention and treatment ^ 432 ^ | 1999 | Royal College of Physicians | Recommends selective testing in women with risk factors (based not on evidence but on expert opinion). | DXA at the hip is preferred because of higher predictive value for fracture risk. | Optimal use of BMD measurements in monitoring response to treatment is uncertain, recommend future research. | Until biochemical markers become more widely established and supported by evidence, their use in clinical practice will remain limited. | The cost-effectiveness of BMD measurements improves as the expense of the therapy goes up.
Consensus statement on prevention and treatment of osteoporosis ^ 433 ^ | 1999 | Israel Center for Technology Assessment in Health Care/Israel Ministry of Health/Israel Medical Association | Physician's responsibility to estimate risk of osteoporosis and fractures and to consider performing additional tests; based on some risk factors, report recommends BMD every 2 years. | Recommends DXA done at facilities with quality control and following regulations on operations and interpretation of results; additional technologies to be considered if efficiency proven compared to DXA. | Calls for publicly funded BMD in women over 65 every 5 years; in postmenopausal women over 50 every 2 years if certain risk factors present; in those with disease entailing increased risk of osteoporosis, no limit on age or frequency of test.
Monitoring of bone density to assess active treatment of osteoporosis ^ 434 ^ | 2000 | Blue Cross and Blue Shield Association | | | Insufficient evidence to determine if BMD monitoring in patients under treatment improves net health outcomes.

BMD = bone mineral density; DXA = dual-energy X-ray absorptiometry

## Conceptual Model

### The Evidence-based Approach

An evidence report focuses attention on the strength and limits of evidence from published studies about the effectiveness of a clinical intervention. The development of an evidence report begins with a careful formulation of the problem. In this phase, a preliminary review of the literature and input from experts, stakeholders, and patients may be used to identify the patient populations, interventions, health outcomes, and harms. These parameters are summarized in an analytic framework, which is used in turn to generate a list of key questions to examine in a systematic review of the published literature.

This evidence report emphasizes the patient's perspective in the choice of outcome measures. Studies that measure health outcomes (events or conditions that the patient can feel, such as quality of life, functional status, and fractures) are emphasized over studies of intermediate outcomes (such as changes in bone density). Such a report also emphasizes measures that are easily interpreted in a clinical context. Specifically, measures of absolute risk or the probability of disease are preferred to epidemiologic measures such as relative risk or events per 1,000 women-years.

An evidence report also emphasizes the quality of the evidence, giving more weight to studies that meet high methodological standards that reduce the likelihood of biased results. In general, the results of well-done, randomized controlled trials are regarded as better evidence than results of cohort, case-control, or cross-sectional studies. These studies, in turn, are considered better evidence than uncontrolled trials or case series. An evidence report pays particular attention to the generalizability of efficacy studies performed in controlled or academic settings. Studies that reflect actual clinical effectiveness in unselected patients and community practice settings are highlighted. Finally, an evidence report considers the net benefit, after a thorough effort to assess both the benefits and the harms of a service or technology.

In the context of developing clinical guidelines, evidence reports are useful because they define the limits of the evidence, clarifying when the assertions about the value of the intervention are based on strong evidence from clinical studies. The quality of the evidence on effectiveness is a key component, but not the only component, in making decisions about clinical policies. Additional criteria include acceptability to physicians or patients, the potential for unrecognized harms, and cost-effectiveness.

### Osteoporosis Analytic Framework and Key Questions

An analytic framework is a schematic representation of the strategy used to organize topic areas and guide the literature search. The framework identifies the critical preventive or treatment interventions and links them to outcomes. After a preliminary review of the literature and discussion with local experts (Appendix A), we developed the analytic framework in Figure 1. It was refined further during the course of the project. The analytic framework shows the relationship of the six topics of this review to clinical decisionmaking for postmenopausal women. Questions related to links in the analytic framework include the following.

Figure 1. Osteoporosis diagnosis and monitoring analytic framework

#### Arrow 1

- What risk factors predict bone density, bone loss, and fractures?
- Are tools for assessing risk factors accurate in identifying women at risk for fractures?

#### Arrow 2

- How well do the different bone measurement tests at different sites predict fractures?
- What factors related to bone measurement testing influence diagnosis?
- Can biochemical markers be used instead of bone measurement tests in identifying women at risk for osteoporosis?
- How well do markers predict fractures?

#### Arrow 3

- Are risk factors useful in treatment decisions?
- How do bone measurement test results affect patients' and physicians' decisions and actions?
- Are bone measurement tests effective for monitoring response to therapy and for guiding decisions about changes in management?
- Can markers help select patients for treatment?
- What are the adverse effects of using biochemical markers to identify women at risk for osteoporosis?
- Can markers predict response to therapy?
- What diagnostic or laboratory tests are appropriate for evaluating patients with osteoporosis for secondary causes?

#### Arrow 4

- What are the costs and cost-effectiveness of diagnostic strategies for identifying women with osteoporosis?

### Rationale

Practicing clinicians often initiate an evaluation for osteoporosis with an assessment of risk factors for individual patients. Arrow 1 in the analytic framework addresses the role of risk factors in identifying women at high risk for osteoporosis. This review includes a survey of the medical literature identifying risk factors predictive of bone density, bone loss, and fractures. It also evaluates evidence of the usefulness of risk factor assessment tools in identifying women at risk for fractures.

We also examined how well the various techniques for measuring bone at different anatomic sites predict fractures, and what effect the choice of test has on the diagnosis of osteoporosis (Arrow 2). We reviewed the ability of markers of bone turnover to identify women at high risk of fractures.

Women eligible for treatment based on risk factors, bone measurement tests, or marker studies would then undergo further evaluation for secondary causes, selection and initiation of medical therapies, and subsequent monitoring if indicated. Arrow 3 in the analytic framework represents several questions relating to treatment and monitoring, including: (1) the role of risk factors and bone measurement tests in guiding initial treatment decisions, (2) the appropriateness of diagnostic or laboratory tests for evaluating patients with osteoporosis for secondary causes, (3) the role of markers of bone turnover in selecting patients for treatment, (4) the role of markers of bone turnover for monitoring response to therapy, and (5) the effectiveness of bone measurement tests for monitoring response to treatment and for guiding decisions about changes in management. Arrow 4 represents how the choice of diagnostic strategy affects the costs of care.