# Appendix E. Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality

ALP: alkaline phosphatase

ARR: adjusted relative risk

BALP: bone-specific alkaline phosphatase

BMC: bone mineral content

BMD: bone mineral density

BMI: body mass index

BUA: broadband ultrasound attenuation

C/E: cost-effectiveness

CAPE: Clifton Assessment Procedure for the Elderly

CI: confidence interval

CTX: type I collagen cross-linked C-telopeptide

CV: coefficient of variation

D-PYR: deoxypyridinoline

DbMHz: decibels/megahertz

DOM: Diagnostisch Onderzoek Mammacarcinoom

DPA: dual photon absorptiometry

DPX: dual photon X-ray

DXA: dual-energy X-ray absorptiometry

ELISA: enzyme-linked immunosorbent assay

EPIDOS: Epidemiologie de l=Osteoporose

FIT: Fracture Intervention Trial

HMO: health maintenance organization

HOS: Hawaii Osteoporosis Study

HPR: hydroxyproline

HRT: hormone replacement therapy

ICTP: type I collagen carboxyterminal telopeptide

LR: likelihood ratio

MA: Mexican American

NHANES: National Health and Nutrition Examination Survey

NHB: non-Hispanic black

NHW: non-Hispanic white

NSAID: nonsteroidal anti-inflammatory drug

NTX: type I collagen cross-linked N-telopeptide

OFELY: l'Os des Femmes de Lyon

OR: odds ratio

pDXA: peripheral dual-energy X-ray absorptiometry

PICP: carboxyterminal propeptide of type I procollagen

PINP: aminoterminal propeptide of type I collagen

pQCT: peripheral quantitative computed tomography

PYR: pyridinoline

QCT: quantitative computed tomography

QDR: quantitative digital radiography

QMD: quantitative microdensitometry