# Appendix D. Evaluation of Secondary Causes guidelines spreadsheet

| | | | | | | | | | | | | Chemistry Battery
Organization, Author, or Reference | Title | Year | Audience | Development | Population | Statement of Philosophy | Secondary Disorders | Complete blood count | Erythrocyte sedimentation rate | Urinalysis | Urine pH | Standard chemistry battery | Calcium | Phosphorus | Alkaline phosphatatase | Blood urea nitro-gen | Albumin | Liver enzymes | Electrolytes | Protein | Creatinine | Protein electrophoresis | Urinary calcium | 24-hour creatinine clearance | Ionized calcium | Parathyroid hormone | 25 (OH) vitamin D | 1,25(OH)2 vitamin D | Thyroid function tests | Cortisol | Testosterone | Folicle stimulating hormone | Bone-specific alkaline phos-phatase | Urine pyridinoline crosslinks | Urine N-telopeptide | Osteocalcin | Bone biopsy | Miscellaneous
Practice Guidelines
National Osteoporosis Foundation^ 454 ^ | Physician's guide to prevention and treatment of osteoporosis | 1999 | Physicians reviewed and developed in collaboration with 9 professional societies | Evidence-based review | Women, primary care (?) | "Be alert to see causes of osteoporosis, which include a broad range of disease states and therapeutic drugs. Limited biochemical testing may be required in some cases." | Acromegaly, adrenal atrophy and Addison's disease, amyloidosis, chronic obstructive pulmonary disease, congenital porphyria, Cushing's syndrome, endometriosis, epidermolysis bullosa, gastrectomy, gonadal insufficiency, hemochromatosis, hemophilia, hyperparathyroidism, hypophosphatasia, idiopathic scoliosis, insulin-dependent diabetes mellitus, lymphoma and leukemia, malabsorption syndromes, mastocytosis, multiple myeloma, multiple sclerosis, nutritional disorders, osteogenesis imperfecta, parenteral nutrition, pernicious anemia, rheumatoid arthritis, sarcoidosis, severe liver disease, thalassemia, thyrotoxicosis, tumor secretion of parathyroid hormone-related peptide | | | | | | | | | | | | | | | Limited | Limited | | | Limited | Limited | | Limited | Limited
Foundation for Osteoporosis Research and Education^ 456 ^ | Section III: Guidelines of care on osteoporosis (sic) for primary care physicians | 1997 | Primary care physicians | Expert opinion | Men and women in primary care | "…the work up of secondary causes of osteoporosis can be extensive…" | Multiple myeloma, vitamin D deficiency, hyperparathyroidism, hypercalcemia, bowel disorders, renal tubular acidosis | | Additional initial study | | Depending on individual aspects of case | | Routine | Routine | Routine | | Routine | | | Routine | Routine | Depending on individual aspects of case | Depending on individual aspects of case | Depending on individual aspects of case | Depending on individual aspects of case | Depending on individual aspects of case | Depending on individual aspects of case | Depending on individual aspects of case | Additional initial study | | | | Depending on individual aspects of case | Depending on individual aspects of case | Depending on individual aspects of case | Depending on individual aspects of case | | Antigliadin antibodies, anti-endomysial antibodies may be necessary in some patients
American Association of Clinical Endocrinologists^ 456 ^ | AACE clinical practice guidelines for the prevention and treatment of postmenopausal osteoporosis | 1996 | Endocrinologists | Expert opinion | Postmenopausal women | "Many patients with osteoporosis take medications or have coexisting diseases that cause or aggravate bone loss, and primary postmenopausal osteoporosis cannot be diagnosed or appropriately treated until these possibilities are eliminated." | Hypogonadism, hyperadrenocortism, thyrotoxicosis, anorexia nervosa, hyperprolactinemia, systemic mastocytosis, porphyria, hypophosphatemia in adults, type I diabetes mellitus, thalassemia, pregnancy, hyperparathyroidism, acromegaly, malabsorption syndromes and malnutrition, chronic liver disease, gastric operations, vitamin D deficiency, calcium deficiency, alcoholism, osteogensis imperfecta, homocystinuria due to cystathione deficiency, Ehlers-Danlos syndrome, Marfan syndrome, rheumatoid arthritis, myeloma and some cancers, immobilization, renal tubular acidosis, hypercalciuria | Routine | Depending on individual aspects of case | Routine | Routine | | Routine | Routine | Routine | | | Routine | Routine | | | Depending on individual aspects of case | Depending on individual aspects of case | | | Depending on individual aspects of case | Depending on individual aspects of case | | Depending on individual aspects of case | | | | | | | | Depending on individual aspects of case | If other causes for bone loss are suspected, additional evaluations may include acid-base studies, dexamethasone suppression, or bone marrow exam. Undecalcified iliac bone biopsy with double tetracycline labeling may be considered when there is no response to therapy or no apparent cause for osteoporosis.
American College of Rheumatology Task Force on Osteoporosis Guidelines^ 457 ^ | Recommendations for the prevention and treatment of glucocorticoid-induced osteoporosis | 1996 | Patients of rheumatologists on long-term glucocorticoid therapy | Expert opinion | Men and women receiving moderate to high dose glucocorticoids with or without osteoporotic fracture | "Laboratory tests should focus on identifying secondary causes of osteoporosis and assessing urinary calcium excretion." | Hyperparathyroidism, osteomalacia, thyroid disease, over supplementation with thyroid medication, renal osteodystrophy syndromes, multiple myeloma | Routine | Routine | | | | Routine | Routine | Routine | | Routine | Routine | Routine | | Routine | Measure if total protein or serum globulin elevated | Routine | | | Measure only if serum calcium high, serum phosphorus low, urinary calcium low | Routine, and measure if serum calcium low, serum phosphorus low, urinary calcium low | | If patient on thyroid replacement | | Routine | | | | | | | Routinely measure leutenizing hormone in women
Scientific Advisory Board, Osteoporosis Society of Canada^ 458 ^ | Clinical practice guidelines for the diagnosis and management of osteoporosis | 1996 | Primary care | Evidence-based review, guidelines tested through focus groups | Men and women in primary care | "The laboratory investigations shown … should be used to exclude secondary causes of osteoporosis." | Hyperparathyroidism, metastatic cancer, multiple myeloma, osteomalacia, liver disease, renal impairment | Routine | | | | | Routine | | Routine | | | | | | Routine | Routine
European Foundation for Osteoporosis and Bone Disease^ 459 ^ | Guidelines for diagnosis and management of osteoporosis | 1997 | Primary care physicians | Expert opinion | Men and women in primary care | "The range of clinical and biological tests will depend on the severity of the disease, the age at presentation, and the presence of vertebral fractures." | Anorexia nervosa, malabsorption due to gastrointestinal and hepatobiliary diseases, primary hyperparathyrodism, thyrotoxicosis, primary hypogonadism, prolactinoma, hypercortisolism, osteogenesis imperfecta, rheumatoid arthritis, chronic obstructive lung disease, chronic neurological disorders, chronic renal failure, mastocytosis, Type I diabetes, post-transplantation, hyperthyroidism, Cushing's syndrome | Routine | Routine | Routine | | | Routine | Routine | Routine | | Routine | Routine | | | | Routine | | | | Optional | Optional | | | Optional | Optional | Routine in men only | | Optional | Optional | Optional | Optional | Bone marrow, cancer markers, gonadotrophins are optional.
Advisory Group on Osteoporosis, Royal College of Physicians^ 460 ^ | Summary and recommendations of the report "Osteoporosis -- clinical guidelines for the prevention and treatment" | 1999 | Primary care | Evidence-based review | Men and women in primary care | "Diagnostic assessment of individuals with osteoporosis should include not only the assessment of BMD … but also the exclusion of diseases that mimic osteoporosis and the management of any associated morbidity." | Hyperparathyroidism, renal osteodystrophy, osteomalacia, alcohol abuse, multiple myeloma, hyperthyroidism, hypothyroidism | | If elevated plasma electrophoresis | | | | Routine | Routine | Routine | Routine | | Routine | Routine | | | | | | | | | | Routine
Society of Obstetricians and Gynecologists of Canada^ 461 ^ | Canadian consensus conference on menopause: osteoporosis | 1998 | Obstetrics/Gynecology | Expert opinion | Women | "Laboratory investigations should be carried out in every patient with established osteoporosis to exclude secondary causes of osteoporosis." | Hyperparathyroidism, metastatic cancer, multiple myeloma, osteomalacia, liver disease, renal impairment | | | | | | Routine | | Routine | | | | | | Routine | Routine
Australian National Consensus Conference^ 462 ^ | The prevention and management of osteoporosis | 1997 | Primary care | Expert opinion | Men and women in primary care | "The extent to which investigations are necessary is determined by the clinical picture, but the index of suspicion for secondary causes of osteoporosis should increase in patients with severe bone loss for age (e.g. bone density lower than 2.0 standard deviations below the age-related mean)." | Vitamin D deficiency, hyperthyroidism, hypogonadism, hyperparathyroidism, alcoholism, liver disease, multiple myeloma | Routine | Routine | | | | Routine | | Routine | | | Depending on individual aspects of case | | | Routine | Depending on individual aspects of case | | | | Depending on individual aspects of case | Depending on individual aspects of case | | Depending on individual aspects of case | | If hypo-gonadism is suspected | If hypogonadism is suspected | | | | | | Sex steroids if hypogonadism is suspected
University of California at San Diego^ 463 ^ | UCSD Medical Group osteoporosis guidelines | 1998 | | Uncertain | Peri- and postmenopausal women | If T score <-2.5 SD on DEXA, then conduct additional workup. | Malignancy, myeloma, Cushing's disease, hyperthyroidism, hyperparathyroidism, osteomalacia, hypogonadism | Consider | | Consider | | | Routine if T-score <-2.5 SD on DEXA | Routine if T-score <-2.5 SD on DEXA | Routine if T-score <-2.5 SD on DEXA | Routine if T-score <-2.5 SD on DEXA | | | | | Routine if T-score <-2.5 SD on DEXA | | Consider
MR McClung^ 464 ^ Osteoporosis | Nonpharmacologic management of osteoporosis | 1994 | Uncertain | Expert opinion | Men and women suspected of or referred for treatment of osteoporosis | "In patients found to have osteoporosis, correctable factors that may contribute to bone loss and skeletal fragility must be identified." | Endogenous or exogenous hyperthyroidism and cortisol excess, hyperparathyroidism, androgen deficiency, chronic liver or renal insufficiency, multiple myeloma, other hematopoietic malignancies, alterations in vitamin D metabolism and calcium balance, renal calcium wasting | Routine | | | | Routine | | | | | | | | | | | | | | | | | | | | | | | | | | "Laboratory screening for specific medical problems that may cause bone loss depends on the comfort of the clinician with the clinical recognition of these abnormalities."
PD Miller^ 465 ^ Adv Intern Med | Management of osteoporosis | 1999 | Primary care | Expert opinion | | "A substantial number of patients with low bone mass, who on the surface appear to have postmenopausal osteoporosis, need workups for secondary causes of bone loss. The intensity of the workup should be a clinical judgement based on the individual patient's history and physical examination." | Hypogonadism, osteoporosis of pregnancy, multiple myeloma, hyperthyroidism, hyperparathyroidism, mastocytosis, chronic renal failure, homocystinuria, osteogenesis imperfecta, inflammatory bowel disorders, celiac disease | Routine | | | | Routine | | | | | | | | | | May be helpful in individual cases | May be helpful in individual cases | May be helpful in individual cases | | | | May be helpful in individual cases | Routine | May be helpful in some cases | May be helpful in individual cases | May be helpful in individual cases | | | | | May be helpful in individual cases | The following may be helpful in individual cases: serum estradiol, and prolactin; antigliadin and aniendomesial antibodies; small intestinal biopsy; 24-hour urine phosphorus; collagen amino acid sequencing or fibroblast (skin) culture.
A Juby^ 466 ^ Can Fam Physician | Managing elderly people's osteoporosis | 1999 | Family practice | Evidence-based review | Elderly men and women seen by family practitioners | "Having decided who is most likely to be at risk of osteoporosis leads to the important issue of differentiating primary from secondary causes of osteoporosis." "…it is important to be aware of secondary causes of osteoporosis, particularly for patients who do not seem to be responding to therapy as predicted." | Diabetes mellitus, hypogonadism, hyperthyroidism, hyperprolactinemia, hyperparathyroidism, hypercortisolism, multiple myeloma, rheumatoid arthritis, immobilization, osteomalacia, chronic renal failure, systemic mastocytosis, hepatic disease, osteogenesis imperfecta, scurvy, malabsorption syndrome, sarcoidosis, chronic obstructive lung disease | Routine | | | | | Routine | Routine | Routine | | | | Routine | | Routine
Osteoporosis: Diagnostic and Therapeutic Principles CJ Rosen,^ 467 ^ ed. | The diagnosis and treatment of postmenopausal osteoporosis | 1996 | Primary care | Expert opinion | Postmenopausal women | | | Routine | | | | | Routine | | Routine | | | | | Routine | | Optional | | | | | Routine | | Routine | | | Routine | | | | | Consider
Primary Care of Women ^ 468 ^ DP Lemcke et al., eds. | Section IV: metabolic and endocrine disorders, osteoporosis DP Lemcke | 1995 | Primary care | Expert opinion | Women, primary care | "In a patient who has documented osteoporosis, a careful history and physical examination and several laboratory tests should be performed to rule out secondary causes of osteoporosis." | Endocrinopathies: hypogonadism, hyperthyroidism, hyperparathyroidism, Cushing's syndrome, hyperprolactinemia, acromegaly. Gastrointestinal diseases: malabsorption syndromes, chronic obstructive jaundice, primary biliary cirrhosis, subtotal gastrectomy | Routine | | | | Routine | | | | | | | | | Routine | If indicated from initial lab tests | Routine | | | If indicated from initial lab tests | If indicated from initial lab tests | | If indicated from initial lab tests
Primary Care of Women ^ 469 ^ KJ Carlson et al., eds. | Section III: Endocrinology, Osteoporosis DM Slovik | 1995 | Primary care | Expert opinion | Women, primary care | "A detailed history and physical examination is necessary to identify risk factors and the secondary causes of osteoporosis." | | Routine | Routine | | | Routine | | | | | | | | | | Routine | Helpful | Helpful | | If hyperpara-thyroidism is suspected | If vitamin D deficiency is suspected | | Routine
A Clinical Guide for the Care of Older Women ^ 470 ^ RL Byyny, L Speroff, eds. | "Osteoporosis" | 1996 | Primary care | Expert opinion | Older women | "Patients with osteoporosis should be screened for other conditions that lead to osteoporosis." | Hyperparathyroidism, chronic renal failure, multiple myeloma, leukemia, lymphoma, hyperthyroidism, alcohol abuse, metastatic cancer, hypercortosolism | Routine | Routine | | | | Routine | Routine | Routine | Routine | | | | | Routine | Routine | | | | Routine | | | Routine | When indicated by exam
Harrison's Principles of Internal Medicine ^ 471 ^ AS Fauci et al., eds. | Chapter 355. Metabolic bone disease SM Krane et al. | 1998 | Primary care | Expert opinion | Men and women | "Since decrease in skeletal mass is a universal feature of aging, it is difficult to evaluate asymptomatic decreased bone density, determined radiographically, in older women, especially when not accompanied by marked increase in biconcavity of vertebral bodies or fractures." | Hypogonadism, hyperadrenocorticism, hyperparathyroidism, thyrotoxicosis, malabsorption, scurvy, calcium deficiency, immobilization, systemic mastocytosis, adult hypophosphatasia, metabolic bone disease, osteogenesis imperfecta, homocystinuria due to cystathione synthase deficiency, Ehlers-Danlos syndrome, Marfan's syndrome, rheumatoid arthritis, malnutrition, alcoholism, epilepsy, primary biliary cirrhosis, chronic obstructive pulmonary disease, Menkes' syndrome | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | No specific recommendations for testing are made.
Manual of Medical Therapeutics ^ 472 ^ GA Ewald, CR McKenzie, eds. | Chapter 23. Mineral and metabolic bone disease, S Dagogo-Jack et al. | 1995 | Primary care | Expert opinion | Men and women | "Diagnosis of primary osteoporosis requires exclusion of secondary forms of osteoporosis and other causes of osteopenia. The history, physical examination, and a few basic laboratory tests are usually diagnostic." | Cushing's syndrome, hyperthyroidism, hypogonadism in men, immobilization, osteogenesis and related disorders, primary hyperparathyroidism, osteomalacia, myeloma, mastocytosis, renal osteodystrophy | Routine | | Routine | | Routine | | | | | | | | | | Routine | | | | | | | Routine | | | | | | | | If usual features present
Internal Medicine ^ 473 ^ JH Stein, ed. | Chapter 181. Osteoporosis LG Reisz | 1998 | Primary care | Expert opinion | Men and women | "In the typical case of a postmenopausal woman with a crush fracture, a careful history and physical examination and limited laboratory studies are usually sufficient to rule out diseases that mimic or aggravate primary osteoporosis." "Routine laboratory studies in otherwise healthy patients with low bone mineral density should include a measurement of serum calcium." | Mainly primary hyperparathyroidism, osteomalacia, hyperthyroidism, multiple myeloma, and Cushing's syndrome. Gastrointestinal or renal disease predispose to osteomalacia or secondary hyperparathyroidism as well as osteoporosis | | | | | | Routine | Routine | Routine | | Routine | | | | Routine | Routine | | | | | Routine if history or exam suggestive of vitamin D deficiency | | Routine | Routine if signs of Cushing's syndrome present | | | | Can be used | Can be used | Can be used | May be indicated in severe or atypical cases
Cecil Essentials of Medicine ^ 474 ^ TE Andreoli et al., eds. | "Osteoporosis" | 1997 | Primary care | Expert opinion | Men and women in primary care | "Secondary causes of osteoporosis should be sought in patients with an established diagnosis of osteoporosis, particularly when the bone density is significantly lower than that of age- and sex-matched individuals." | Endocrine disease: hyperprolactinemia, hypothalamic amenorrhea, anorexia nervosa, premature and primary ovarian failure, primary and secondary gonadal failures, delayed puberty, hyperthyroidism, hyperparathyroidism, hypercortisolism, growth hormone deficiency; Gastrointestinal disease: subtotal gastrectomy, malabsorption syndromes, chronic obstructive jaundice, primary biliary cirrhosis, alactasia; Bone marrow disorders: multiple myeloma, lymphoma, leukemia, hemolytic anemia, systemic mastocytosis, disseminated carcinoma. Connective tissue disease: osteogenesis imperfecta, Ehlers-Danlos syndrome, Marfan's syndrome, homocystinuria. Miscellaneous: immobilization, rheumatoid arthritis | Routine | | | | | Routine | Routine | Routine | | Routine | Routine | | | Routine | | | | | Routine | Routine | | If clinical suspicion exists | | Routine | | | | | | In selected patients
Endocrinology ^ 475 ^ LJ De Groot , ed. | Chapter 73. Osteoporosis RM Neer | 1995 | Primary care, endocrinology | Expert opinion | Men and women | "..when osteopenia is present, one can establish whether it is worse than expected for the age and sex of the patient. This information is invaluable to assessing the effects of endocrine and other diseases on the skeleton. It also helps guide the extent (and therefore the expense) of additional laboratory evaluations in patients with osteoporosis." | Primary ovarian failure, gonadotropin deficiency, hypothalamic pituitary dysrhythmia, androgen deficiency, glucocorticoid excess, growth hormone or IGF deficiency, thyroid hormone excess, PTH excess, vitamin D deficiency, anorexia nervosa, exercise-induced amenorrhea, delayed puberty | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Specific testing not noted.
Williams Textbook of Endocrinology ^ 476 ^ JD Wilson et al., eds. | "Primary osteoporosis" | 1998 | Primary care, endocrinology | Expert opinion | Men and women | "Because primary osteoporosis is a diagnosis of exclusion, secondary forms of bone loss should be excluded. Secondary forms of osteoporosis should be suspected in groups with a low prevalence of the primary form of the disease (i.e. white men, young white women, and black persons of both sexes and all ages)." | Thyrotoxicosis, multiple myeloma, cortisol excess, primary hyperparathyroidism, osteomalacia | | | | | | Routine | Routine | Routine | | | | | | | Routine | | | | Routine | Routine | Routine | Routine | Routine | | | | | | | In certain cases
Principles and Practice of Endocrinology and Metabolism ^ 477 ^ KL Becker, ed. | Chapter 63. Osteoporosis JF Tohme et al. | 1995 | Primary care, endocrinology | Expert opinion | Men and women | "The diagnosis of osteoporosis is a diagnosis of exclusion. An intensive search should be undertaken to exclude secondary causes of osteoporosis, particularly in patients who are neither postmenopausal women nor elderly." | Cushing's syndrome, hypogonadism, hyperthyroidism, hyperparathyroidism, diabetes mellitus, acromegaly, hyperprolactinemia, osteogenesis imperfecta, homocystinuria, Ehlers-Danlos syndrome, Marfan's syndrome, Menke steely hair disease, Riley-Day syndrome, Gaucher disease and other glycogen storage disorders, sickle-cell anemia, thalassemia, hypophosphatasia, alcohol abuse, multiple myeloma, gastrointestinal disease, chronic liver disease, pregnancy, chronic obstructive pulmonary disease, rheumatoid arthritis, malnutrition, diffuse cancer, systemic mastocytosis, amyloid disease, hemochromatosis | Routine | Routine | | | | Routine | Routine | Routine | Routine | | Routine | | | Routine | Routine | | | | If hypercalcemia, hypercalciuria, or high-normal calcium levels present | In elderly patients, those on antiepileptic drugs, or with intestinal or liver disease | | | If adrenocortical hyperfunction is suspected
Basic and Clinical Endocrinology ^ 478 ^ FS Greenspan, GJ Strewler, eds. | Chapter 17. Mineral metabolism and metabolic bone disease GJ Strewler | 1997 | Primary care | Expert opinion | Men and women in primary care | | Hyperthyroidism, diabetes mellitus, osteogenesis imperfecta, Ehlers-Danlos syndrome, homocystinuria, Menkes syndrome, Marfan's syndrome, multiple myeloma, systemic mastocytosis, hypogonadism, hypercortisolism, hyperparthyroidism, malabsorption syndrome, sustotal gastrectomy, obstructive jaundice, biliary cirrhosis, renal tubular acidosis | Routine | | Routine | | | Routine | Routine | Routine | | | | Routine | | Routine | Routine | | | | | | | Routine