# Appendix B: Search Strategies for Individual Topics

## Risk Factors

1 exp osteoporosis osteoporosis, postmenopausal

2 bone density

3 1 or 2

4 exp risk

logistic models | risk assessment
risk factors

5 3 and 4

6 exp transplantation

cell transplantation | transplantation, autologous
organ transplantation | transplantation, heterologous
replantation | transplantation, heterotopic
tissue transplantation | transplantation, homologous

7 exp kidney failure

kidney failure, acute | diabetes insipidus, nephrogenic
kidney failure, chronic

8 su.fs. (Surgery as a subheading anywhere in the article)

9 athletic injuries

10 exp sports

baseball | basketball | bicycling
boxing | golf | football
gymnastics | hockey | mountaineering
racquetball | running | martial arts
skating | skiing | track and field
soccer | swimming | weight lifting
walking | wrestling

11 exp fractures/dt,su,th (limited to surgery and other therapies)

femoral fractures | fractures, closed
fractures, comminuted | fractures, malunited
fractures, open | fractures, spontaneous
fractures, stress | fractures, ununited
humeral fractures | radius fractures
rib fractures | shoulder fractures
skull fractures | spinal fractures
tibial fractures | ulna fractures

12 orthopedic$.mp. (As a textword anywhere)

13 6 or 7 or 8 or 9 or 10 or 11 or 12

14 5 not 13 (statements 6 through 12 were excluded from the study)

15 limit 13 to female

16 limit 14 to human

17 limit 15 to english language

18 looked at english abstracts of foreign articles

19 exp fractures or exp osteoporosis or bone density

20 exp risk (terms as in 4)

21 19 and 20

22 exp cohort studies longitudional studies follow-up studies prospective studies

23 meta-analysis

24 exp case control studies retrospective studies

25 predictive value of tests

26 evidence-based medicine

27 22 or 23 or 24 or 25 or 26

28 21 and 27

29 limit 28 to human

30 limit 29 to english language

## Bone Density and Quantitative Ultrasound Testing

1 exp osteoporosis osteoporosis, postmenopausal

2 bone density

3 1 or 2

4 densitometry, x-ray

5 exp ultrasonography

echocardiography | ultrasonography, doppler
echoencephalography | ultrasonography, interventional
endosonography | ultrasonography, mammary

6 calcaneous/us (us = ultrasonics)

7 (dxa or sxa or bua or qct or qus or mxa or mrx or ra or dip or sos or ubps or spa or dpa).tw.

8 exp osteoporosis/us (us = ultrasonics)

9 4 or 5 or 6 or 7 or 8

10 3 and 9

11 limit 10 to human

12 limit 11 to english language

13 looked at english abstracts of foreign articles

## Monitoring

1 exp osteoporosis/ osteoporosis, postmenopausal

2 bone density/

3 1 or 2

4 monitoring

5 densitometry, x-ray/

6 exp ultrasonography/

echocardiography | ultrasonography, doppler
echoencephalography | ultrasonography, interventional
endosonography | ultrasonography, mammary

7 calcaneus/us

8 4 or 5 or 6 or 7

9 3 and 8

10 exp osteoporosis/dh,dt,th

11 9 and 10

12 limit 11 to human

## Biochemical Markers

1 exp osteoporosis osteoporosis, postmenopausal

2 bone density

3 1 or 2

4 exp biological markers genetic markers

5 marker$.tw. (markers as a word in the title or abstract)

6 (bap or ctx or dpd or ntx or pyd).tw. (marker abbrev. in title and abstract)

7 4 or 5 or 6

8 3 and 7

9 limit 8 to human

10 limit 9 to english language

11 limit 10 to female

12 looked at english abstracts of foreign articles

## Cost

1 exp osteoporosis

2 ec.fs. (ec=economics)

3 exp costs and cost analysis

cost allocation | cost-benefit analysis
cost control | cost of illness
cost sharing | health care costs
health expenditures

4 exp economics

costs and cost analysis | economic competition
economic value of life | economics, dental
economics, hospital | economics, medical
economics, nursing | economics, pharmaceutical
fees and charges | financial management
financial support | financing, organized
financing, personal | health care sector
inflation, economic | investments
medical indigency | raxes

5 2 or 3 or 4

6 1 and 5

7 limit 6 to english language

8 looked at english abstracts of foreign articles