# Appendix A. Project Personnel, Local Panel and National Panel, and Peer Reviewers

## Oregon Health & Science University Evidence-based Practice Center Osteoporosis Task Order Research Team

### Principal Investigator

- Heidi D. Nelson, M.D., M.P.H.
- Associate Professor of Medicine and Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

### EPC Director/Co-investigator

- Mark Helfand, M.D., M.P.H.
- Evidence-based Practice Center Director
- Associate Professor of Medicine and Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

### Research Coordinator

- Margaret M. Nygren, M.A.
- Division of Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

### Co-investigators

- Cynthia D. Morris, Ph.D., M.P.H.
- Professor of Medicine and Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

- Nancy Carney, Ph.D.
- Assistant Professor of Emergency Medicine
- Oregon Health & Science University
- Portland, Oregon

- Dale F. Kraemer, Ph.D.
- Assistant Professor of Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

- Susan Mahon, M.P.H.
- Division of Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

### EPC Administrator

- Kathryn Pyle Krages, AMLS, M.A.
- Division of Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

### Research Assistant

- Piper Hackett, B.S.
- Division of Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

### Librarian

- Patty Davies, M.S.
- OHSU Library
- Oregon Health & Science University
- Portland, Oregon

### Graduate Research Assistant

- Alix Seif, M.A.
- Division of Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

### Volunteer Research Assistant

- Connie Levesque, B.S.
- Division of Medical Informatics & Outcomes Research
- Oregon Health & Science University
- Portland, Oregon

## Local Panel

### Osteoporosis Specialist

- Eric Orwoll, M.D.
- Professor of Medicine
- Head, Bone, and Mineral Section
- Division of Endocrinology
- Oregon Health & Science University
- Portland, Oregon

### Geriatrician

- Melinda Lee, M.D.
- ElderPlace in Cully
- Portland, Oregon

### Primary Care Physician

- Elizabeth Eckstrom, M.D., M.P.H.
- Department of Medicine
- Good Samaritan Hospital
- Portland, Oregon

### Health Plan Representative

- Peter I. Juhn, M.D., M.P.H.
- Executive Director, Care Management Institute
- Kaiser Permanente
- Oakland, California

### Patient Perspective

- Louise Pyle
- Tigard, Oregon

### Osteoporosis Educator/Therapist/National Osteoporosis Foundation Representative

- Lauren Rykert, OTR/L
- Occupational Therapist
- Portland, Oregon

### National Panel

- Steven R. Cummings, M.D.
- Professor of Medicine, Epidemiology, and Biostatistics
- Assistant Dean for Clinical Research
- Department of Medicine
- University of California, San Francisco
- San Francisco, California

- C. Conrad Johnston, Jr., M.D.
- Distinguished Professor
- Indiana University School of Medicine
- Indianapolis, Indiana

- L. Joseph Melton III, M.D.
- Michael M. Eisenberg Professor
- Department of Health Services Research
- Mayo Clinic and Mayo Foundation
- Rochester, Minnesota

### Peer Reviewers

- Douglas C. Bauer, M.D.
- Assistant Professor of Medicine
- University of California, San Francisco
- San Francisco, California

- Cathleen Colon-Emeric, M.D.
- Duke University Medical Center
- Durham, North Carolina
- (Representing the American Geriatrics Society)

- Latha Dulip-Singh, M.D.
- Bone Unit
- Department of Medicine
- New Britain General Hospital
- New Britain, Connecticut
- (Representing the American College of Physicians)

- Ken Faulkner, Ph.D.
- Director of Osteoporosis Research
- Synarc
- Portland, Oregon

- Murray J. Favus, M.D.
- University of Chicago
- Chicago, Illinois

- Patrick Garnero, Ph.D.
- Synarc
- Lyon, France

- Evan C. Hadley, M.D.
- Associate Director (Geriatrics)
- National Institute on Aging
- National Institutes of Health
- Bethesda, Maryland

- C. Conrad Johnston, Jr., M.D.
- Distinguished Professor
- School of Medicine
- Indiana University
- Indianapolis, Indiana

- John Kanis, M.D.
- Center for Metabolic Bone Diseases
- Department of Human Metabolism and Clinical Biochemistry
- Medical School
- University of Sheffield
- Sheffield, United Kingdom

- Kenneth Lyles, M.D.
- Associate Professor of Medicine
- Duke University
- Durham, North Carolina
- (Representing the American Geriatrics Society)

- Saralyn Mark, M.D.
- Senior Medical Advisor
- Office on Women's Health
- Department of Health and Human Services
- National Aeronautics and Space Administration
- Washington, DC

- Joan A. McGowan, Ph.D.
- Chief
- Musculoskeletal Diseases Branch
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- National Institutes of Health
- Bethesda, Maryland

- L. Joseph Melton III, M.D.
- Michael M. Eisenberg Professor
- Department of Health & Science Research
- Mayo Clinic
- Rochester, Minnesota

- Kenneth Mickelson, Ph.D.
- Senior Staff Scientist
- Bayer Diagnostics, Research and Development
- Tarrytown, New York

- Isaac Mizrahi, Ph.D.
- Manager
- Clinical and Regulatory Affairs (Skeletal Diagnostics)
- Beckman Coulter, Inc.
- San Diego, California

- Joyce M. Paucek
- Marketing Director
- Norland Medical Systems, Inc.
- Fort Atkinson, Wisconsin

- William Sacks, Ph.D., M.D.
- Medical Officer
- Radiological Devices Branch
- Office of Device Evaluation
- Division of Reproductive, Abdominal, and Radiological Devices
- Center for Devices and Radiological Health
- U.S. Food and Drug Administration
- Washington, DC

- Ronald B. Staron, M.D.
- Department of Radiology
- Columbia University
- New York, New York
- (Representing the American College of Radiology)

- Steven M. Teutsch, M.D., M.P.H.
- Senior Director
- Outcomes Research & Management
- U.S. Human Health
- Merck & Co., Inc.
- West Point, Pennsylvania

- Anna Tosteson, Sc.D.
- Associate Professor of Medicine and Associate Professor of Community and Family Medicine
- Dartmouth-Hitchcock Medical Center
- Lebanon, New Hampshire

- Eric von Stetten, Ph.D.
- Scientific Director
- Hologic, Inc.
- Bedford, Massachusetts

- Marie D. Zinninger
- Associate Executive Director
- American College of Radiology
- Reston, Virginia