# Appendixes

Appendix A. Project Personnel, Local Panel and National Panel, and Peer Reviewers

Appendix B: Search Strategies for Individual Topics

Appendix C: Criteria for Grading the Internal Validity of Individual Studies

Appendix D. Evaluation of Secondary Causes guidelines spreadsheet

Appendix E. Acronyms and Abbreviations