# Evidence Tables

## Abbreviations Used In Evidence Tables

ABG: arterial blood gas

AbWts: abdominal weights

admiss.: admission

amt: amount

ANOVA: analysis of variance

approx: approximately

ARDS: acute respiratory distress syndrome

Arith.: arithmetic

ASAP: as soon as possible

ASIA: American Spinal Injury Association

ATS: American Thoracic Society

av.: average

BiPAP: biphasic positive airway pressure

Bronch.: bronchodilator

C: cervical

cc: cubic centimeter

CI: confidence interval

cm: centimeter

COPD: chronic obstructive pulmonary disease

CPAP: continuous positive airway pressure

CT: computerized tomography

CV: closing volume

EBEV: extrapolated back expiratory volume

ED: emergency department

EEG: electroencephalogram

EMG: electromyogram

EPAP: expiratory positive airway pressure

EPR: electrophrenic respirator/respiration

ERV: expiratory reserve volume

F: female

FEF: forced expiratory flow

FEF25-75: forced expiratory flow between 25% and 75% of the exhaled volume

FEV: forced expiratory volume

FEV1: forced expiratory volume in 1 second

FIF: forced inspiratory flow

FIV: forced inspiratory volume

FIVC: forced inspiratory vital capacity

FRC: functional residual capacity

FVC: forced vital capacity

Geo.: geometric

GPB: glossopharyngeal breathing

GPmaxSBC: glossopharyngeal maximum single-breath capacity

grp: group

hr: hour

HV: high-volume

Hz: hertz

IAPR: intermittent abdominal pressure respiration

IAPV: intermittent abdominal pressure ventilation

IC: inspiratory capacity

ICD-9: International Classification of Diseases

ICU: intensive care unit

IM: intramuscular

IMT: inspiratory resistive muscle training

IMV: intermittent mandatory ventilation

infect: infection

IPAP: inspiratory positive airway pressure

IPPB: intermittent positive pressure breathing

kg: kilogram

kPa: kilopascal

KTT: kinetic treatment table

L: liter or lumbar

L/s: liter per second

LV: low-volume

M: male

MEF: maximal expiratory flow

mg: milligram

min: minute

MIP: maximum inspiratory mouth pressure

mL: milliliter

mm Hg: millimeters of mercury

MMEF: maximal mid-expiratory flow

mo: month

MV: mechanical ventilation/ventilator

MVV: maximal voluntary ventilation

N: number of pts in population; n = no. of pts in sample; no

N/A: not applicable

Neurol.: neurological

no.: number

N/R: nonresponder

n.s.: not significant

N/S: not specified

NVA: noninvasive ventilatory assistance

OPH: orthostatic position of head

OR: odds ratio

p: probability

PC20: provocative concentration (of methacholine or histamine) that caused a 20% decrease in FEV1

pCO2: partial pressure of carbon dioxide

PEF: peak expiratory flow

PEFR: peak expiratory flow rate

Pemax: increased expiratory mouth pressure

PEP: positive expiratory pressure

PFT: pulmonary function test

PI: principal investigator

PIF: peak inspiratory flow

Pimax: increased inspiratory mouth pressure

PLL: posterior longitudinal ligament

PLV: pressure-limiting ventilator

PO: per os (orally)

pO2: partial pressure of oxygen

Post-tx: post-treatment

PPV: positive pressure ventilation/ventilator

Pre-tx: pre-treatment

PVFB: progressive ventilator-free breathing

pt: patient

PVFB: progressive ventilator-free breathing

r: symbol for correlation coefficient

R: responder

RCT: randomized controlled trial

rehab: rehabilitation

RR: relative risk

RV: residual volume

resp: respiratory

SaO2: arterial oxygen saturation

SCI: spinal cord injury

SD: standard deviation

sec: second

SEM: standard error of the mean

SIP: sustainable inspiratory mouth pressure

SONI: strapless oral/nasal interface

synd: syndrome

T: thoracic

Te: expiratory time

Ti: inspiratory time

TLC: total lung capacity

Ttot: time of total inspiratory and expiratory cycle

TPPV: tracheostomy positive pressure ventilation

tx: treatment

VC: vital capacity

VE or Ve: expiratory volume

VFSS: videofluoroscopic swallowing study

Vt: tidal volume

wk: week

WTD: wedge turning device

X-ray: chest radiograph

Y: yes

yr: year

% incr.: percentage increase

% pred.: percent of predicted normal

4-AP: 4-aminopyridine

µg: microgram

µs: microsecond

Evidence Table 1. Ventilation Management^1^

Study | Design and Quality | Patient Population | Study Protocol/Interventions | Results/Outcomes
PREDICTORS OF NEED FOR MECHANICAL VENTILATION
Cahan, Gothe, Decker et al., 1993 | Design: Prospective concurrent cohort comparison Quality Internal validity Level III External validity 1-Y 2-N 3-Y 4-N 5-N | N = 16 Neurol. status Time since injury: 14 ± 10 yrs, hypoxic grp; 14 ± 11 yrs, normoxic grp Level of injury: 19% C4-C5; 56% C5, C6, C5-C6; 25% T3-T5; all pts quadriplegic Completeness of injury: N/S Pulmonary status: N/S Age: 49 (range:23-64), hypoxic grp; 48 (range: 21-78), normoxic grp Sex: 100% M Race: N/S | Evaluation of arterial oxygen saturation (SaO_2_) over 24 hrs, using pulse oximetry, to determine if clinical history correlated with SaO_2_. Pts also asked if they had history of snoring, excessive daytime sleepiness, and existing or previous lung disease. 2 grps of pts were then compared:; - Pts with normal SaO_2_ values while awake and asleep (n = 10); - Pts with normal SaO_2_ values while awake but with cyclical desaturations (> 4%) while asleep (n = 6); To further define respiratory events during sleep, an additional study was performed of 7/16 pts (44%) who were willing to undergo polysomnography. Predictors considered: Level of injury, age, time after injury, medication use, medical history of snoring, increased daytime sleepiness, acute respiratory illness, historical data Analytic method(s) used: Student's t-test (for nonpaired samples) | Predictors of hypoxia: None of the predictors (at left) were significant. Overall no. of pts with positive medical histories of snoring and increased daytime sleepiness: 12/16 (75%); - In hypoxic grp: 5/6 (83%); - In normoxic grp: 7/10 (70%); No. of pts who underwent polysomnography who were found to have sleep-disordered breathing: 3/7 (43%); not specified whether these 7 pts had nocturnal desaturations on SaO_2_ monitoring Other outcomes reported: No. of pts with SaO_2_ values within normal range No. of pts with SaO_2_ profiles outside of normal range Amt. of cyclic desaturation of SaO_2_ during periods of sleep/wakefulness Mean total oximetry recording time Percentage of oximetry data that was technically acceptable Mean SaO_2_ ± 1 SD at each 10th percentile Percentage of recorded time that was spent with SaO_2_ values less than those of control grp (for all pts, for 6 with cyclic desaturations) Comparison of SaO_2_ values during wakefulness between quadriplegics and controls
Claxton, Wong, Chung et al., 1998 | Design: Retrospective case series Quality Internal validity Level V External validity 1-Y 2-Y 3-Y 4-N 5-Y | N = 72 Neurol. status Time since injury: Acute (56 pts admitted within 24 hrs of injury) Level of injury: C2-C8 (3 of whom had associated thoracic injuries); 43/72 pts (60%) had injuries at C5 and above. Determination of level was based on ICD-9 codes for cervical spinal cord injury (SCI) without evidence of spinal bone injury (952-00 to 952-09) and for cervical SCI with fracture of vertebral column (806-00 and 806-09). Completeness of injury: Complete (ASIA class A), 39/72 pts (54%); incomplete (ASIA classes B through D), 33/72 pts (46%). All pts had "cervical SCIs with neurological deficits" and were managed in neurosurgical ICU. Pulmonary status: 41/72 pts (57%) received mechanical ventilation (MV), 29 of whom (70%) were ventilated due to respiratory failure Age: 48 (range:15-83) Sex: 86% M, 14% F Race: N/S | Retrospective review of hospital charts to identify predictors of (1) death and (2) need for MV within the first 3 mos of hospitalization. Outcome(s) of interest: No. of pts receiving MV within first 3 mos of hospitalization (except for those needing MV for < 24 hrs after surgical procedures), hospital mortality within 3 mos of admission, forced vital capacity (FVC) in first week for survivors vs. nonsurvivors Predictors considered: Neurological level at C5 and above, neurological level below C5 (multivariable analysis only), complete level of injury, copious sputum in week 1, pneumonia, lung collapse, smoking, heart and chest disease, associated injuries of head or chest, FVC, ability to cough Analytic methods; - Univariable analysis (unpaired t-test for parametric data; chisquare analysis or Fisher's Exact test for categorical data); - Multivariable logistic regression analysis | No. of pts receiving MV within first 3 mos of hospitalization (except for those needing MV < 24 hrs after surgical procedures): 57% (41/72) Predictors of need for MV within first 3 mos of hospitalization (univariable analysis):; - Neurological level at C5 and above (69% with variable present vs. 39% with variable absent, p = 0.002); - Complete level of injury (72% with variable present vs. 13% with variable absent, p = 0.01); - Copious sputum in week 1 (96% with variable present vs. 44% with variable absent, p = 0.001); - Pneumonia (91% with variable present vs. 26% with variable absent, p = 0.001); - Lung collapse (95% with variable present vs. 43% with variable absent, p = 0.0001); Predictors of need for MV within first 3 mos of hospitalization (multivariable analysis):; - Copious sputum in week 1 (OR = 7.13, 95% \ CI = 1.1, 160); - Pneumonia (OR = 11.1, 95% CI = 2.0, 104.5); - Neurological level -- stratified into C5 and above vs. below C5, though results were reported combined (borderline statistical significance, OR = 4.44, 95% CI = 0.9, 27.1); Hospital mortality within 3 mos of admission: 21% (15/72) FVC in first week for survivors vs. nonsurvivors: Survivors, 2.11 ± 1.99 (SD) L vs. nonsurvivors, 0.62 ± 0.57 L (p = 0.02) Other outcomes reported: Mortality; - No. of deaths occurring in intensive care unit (ICU); - No. of deaths occurring outside of ICU; - Cause of death; - Predictors of mortality; MV; - Reason for initiating MV; - Time from injury to need for MV; - Duration of MV; Hospitalization; - No. of pts admitted within 24 hrs of injury; - No. of pts managed in ICU; - No. of pts discharged from hospital who continued to need MV; - Duration of stay in hospital; Complications; - Respiratory; - Cardiovascular; - Multiorgan system failure; Types of SCI-associated injuries
Myllynen, Kivioja, Rokkanen et al., 1989 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-Y 5-N | N = 54 Neurol. status Time since injury: N/S, but all injuries "acute," and all pts treated in intensive care unit Level of injury: C1-C7 Completeness of injury: 74% complete, 26% incomplete; degree of cord injury was graded on 3-point scale, where 1 = some motor function left, 2 = only some sensory function left, and 3 = complete spinal cord lesion in injured segment; all pts described as tetraplegic Pulmonary status: On admission, 5/54 pts (9%) had marked hypoxemia (pO_2_ < 60 mm Hg) and 10/54 (19%) had moderate hypoxemia (pO_2_, 61-79 mm Hg); average pO_2_ was below normal (75 ± 2 mm Hg) but mean pCO_2_ was normal (39 mm Hg). Age: 36 (range:13-73) Sex: 89% M, 11% F Race: N/S | Study of predictors of respiratory (and other) complications and mortality of pts during "early hospital treatment."Interventions for treating respiratory complications included ventilatory assistance (respirator treatment) and tracheostomy. No further details provided. Interventions for nonrespiratory complications:; - Atropine (for bradycardia); - Sympathomimetics (for hypotonia); - Nasogastric suction; - Parenteral nutrition; - Fluid therapy; Outcome(s) of interest: No. of pts needing ventilatory support (respirators) during intensive care, no. of deaths Predictors considered: Age, previous diseases, level and degree of SCI, no. of respiratory complications during initial treatment, initial blood pressure, heart rate, respiratory rate, blood gas analysis, respirator treatment, tracheostomy, duration of nasogastric suction, duration of parenteral nutrition Analytic method(s):; - Univariable analysis (Student's t-test, chisquare, Pearson's product moment correlation, Spearman's rank correlation tests) | No. of pts needing ventilatory support (respirators) during intensive care: 43/54 (80%); - By level of injury: 100% C2 (2/2); 70% C4 (7/10); 50% C5 (10/20); 42% C6 (5/12); 43% C7 (3/7); Predictors of need for ventilatory support:; - Level of cord injury (r = 0.317, p < 0.05); - Completeness of cord injury (r = 0.419, p < 0.01); No. of pts with respiratory complications during initial treatment: Respiratory infection, 44% (24/54); pulmonary atelectasis, 44% (24/54); thromboembolism, 13% (7/54) Predictors of later respiratory complications (univariable analysis):; - Respiratory rate on admission (r = 0.444, p < 0.001); - Initial tachypnea (r = 0.444, p < 0.001); No. of deaths: 8/54 (15%); - By level of injury: 100% (all 8) had injuries at C4 to C5; Other Outcomes Reported Respiratory complications; - Duration of ventilatory support; - No. of pts with pneumonia, atelectasis, or respiratory infections; Mortality; - Cause of death; - Risk of death; Predictors of mortality
MECHANICAL VENTILATION ASSISTANCE Acute Ventilation Management
Carter, 1979 37 of the pts described in this study were also included in Carter, Donovan, Halstead et al., 1987 Possible overlap with Carter, 1993 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-Y 2-Y 3-Y 4-N 5-Y | N = 67 (37 of whom were also described in a later study; see note at left) Neurol. status Time since injury: (pts with C4 injuries) Initial VC < 1,000 cc (n = 26) -- "Most" admitted within first 3 weeks after injury Initial VC > 1,000 cc (n = 19) -- "Most" admitted within 60 days of injury Level of injury: C4 and above (20 of whom were C3 and above). All pts showed no greater change than 2 neurological levels from admission to discharge. Completeness of injury: Complete (all pts) Pulmonary status: The 20 pts with C3 and above levels were apneic; of the 47 others, 26 had initial VC < 1,000 cc, 19 had initial VC above 1,000 cc, and 2 had insufficient respiratory data Age: 23 (range:4-70) Sex: 88% M, 12% F Race: N/S | Retrospective review of medical records to determine and analyze outcomes at right. Several subgroups were analyzed:; - C3 and above (n = 20); - C4 with initial VC < 1,000 cc (n = 26); - C4 with initial VC > 1,000 cc (n = 19); - C4 with insufficient respiratory data (n = 2) | Percentage of pts who died from 1963-69: 40% (6/15) Percentage of pts who died from 1970-77: 23% (12/52) Other outcomes reported: Etiology of injury No. of pts regaining some spontaneous respiration (due to drop in motor level) Tracheostomies; - No. of pts requiring tracheostomies; - Duration between placement and removal of tracheostomies; - Length of time tracheostomies remained open before being removed; VC; - Initial VC; - Final VC; - Maximum VC; - Average gain in VC per patient; - Average time interval from initial to average gain in VC; - Average time interval from initial to maximum VC; Discharge status (see also "Mortality" below); - No. of deaths at discharge; - Time elapsed from injury to death; - No. of pts using -- equipment for respiration -- EPR (and types of EPR) -- no equipment; Mortality (see also "Discharge status" above); - Place where death occurred; - Causes of death; Survival curves for 2 separate time ranges, 1963-69 and 1970-77 (dates when pts admitted)
Carter, 1993 and Carter, Donovan, Halstead et al., 1987 Possible overlap with Carter, 1979 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-Y 2-N 3-N 4-N 5-N | N = 42 (see "Note" at right) Neurol. status Time since injury: Years (mean no. N/S, but study ranged from 1968-1992) Level of injury: High spinal cord injury Completeness of injury: N/S Pulmonary status: All pts apneic. 2 grps: pts who had EPRs at time of discharge (EPRs); pts who required 24 hrs/day on MV at time of discharge (MVs) Age: EPRs, 20 (range:4-54); MVs, N/S Sex: EPRs (57% M, 43% F); MVs (89% M, 11% F) Race: N/S | Retrospective study of medical records of 2 groups:; - EPRs (n = 23); - MVs (n = 19); Note: 4 pts lost to followup and presumed (by investigators) to be dead were excluded from survival calculations. | Percentages of pts who died:; - EPR, 39% (9/23); - MV, 63% (12/19); - (no p-values reported); Av. time from onset to present (for living pts):; - EPR, 108.3 mos (n = 12); - MV, 96 mos (n = 7); - (no p-values reported); Av. time from onset to death (for dead pts):; - EPR, 62.5 mos (n = 9); - MV, 28 mos (n = 8, including 4 pts lost to followup and presumed dead) (no p-values reported); Other outcomes reported: Av. survival time Cause of death In pts with EPR implants at end of study; - No. of pts with implants; - Hrs/day of EPR usage; - Hrs/day of ventilator usage; No. of pts with bilateral EPRs implanted Discharge plan; - No. and residence of discharged pts (home, nursing facility, etc.); - No. of pts discharged to and remaining at home
DeVivo and Ivie, 1995 | Design: Cohort study Quality: Internal validity Level V External validity 1-Y 2-Y 3-Y 4-N 5-Y | N = 435 Neurol. status Time since injury: < 1 yr; all pts must have survived at least 24 hrs after injury. Level of injury: C1 (15.6%); C2 (19.8%); C3 (18.2%); C4 (18.2%); C5 (9.4%); C6 (7.3%); C7 (2.4%); C8 (0.5%).8.6% with injuries at T1 and below. Completeness of injury: Neurologically complete (71.1%); sensory sparing below the injury level (11.5%); nonfunctional motor capability (8.5%); functional motor capability (8.9%) Pulmonary status: Ventilator-dependent (defined as requiring either partial or total respiratory support on a daily basis); pts with electrophrenic pacers implanted prior to discharge were excluded Age: 40 (range:1 to > 61) Sex: 81% M, 19% Race: White (75.4%); African-American (18.2%); Hispanic (5.3%); other racial/ethnic groups (1.1%) | Retrospective study of medical records (and other sources) of persons who were ventilator-dependent at time of discharge from rehabilitation center or who died prior to discharge while still ventilator-dependent. | Survival rates within the following time periods:; - 1 yr - 49.7% (excluding pts admitted within 24 hrs) - 25.4% (for pts admitted within 24 hrs); - 15 yrs - 30.5% (excluding pts admitted within 24 hrs) - 16.8% (for pts admitted within 24 hrs); Among pts who survived the first year, cumulative survival over the next 14 yrs was 61.4%; among those who survived the first 2 yrs, cumulative survival for the next 13 yrs was 70.7%. Causes of deaths (respiratory-related):; - Pneumonia, 27.3%; - Symptoms and ill-defined conditions (called "always respiratory" by investigators), 12.3%; - Other respiratory diseases, 6.2%; Relative risks (RR) and 95% CIs of mortality for each prognostic factor (based on proportional hazards regression analysis) for pts with C1-C3 injuries:; - Total sample (n = 435), RR = 0.54 (95% CI, 0.41-0.71); - Day 1 admit (n = 203); RR = 0.76 (95% CI, 0.51-1.11); - Yr 1 survivors (n = 201); RR = 2.41 (95% CI, 0.99-5.85); - Yr 2 survivors (n = 155); RR = 3.14 (95% CI, 0.73-13.56)
Gardner, Theocle-ous, Watt et al., 1985 The 37 pts described in this article are also included in the series of 44 pts described in Gardner, Watt, and Krishnan, 1986 | Design: Case series Quality: Internal validity Level V External validity 1-Y 2 N 3-Y 4-N 5-N | N = 37 patients, plus their 37 "nearest caring relatives" (1 per patient) Neurol. status Time since injury: 51% of pts were ventilated 1 day after injury; 14% on day 2; 3% each on days 3 and 4; 11% on day 5; 3% on day 6; and 16% more than 6 days after injury. Pts injured from 1969 through 1983; study conducted in 1984. Level of injury: 5% C2, 5% C3, 43% C4, 38% C5-C7; 3% (1 pt) each T3, T6, and T8. Completeness of injury: N/S Pulmonary status: All pts had been ventilated at some point in their treatment; some had been successfully weaned by time data collected (1984) Age: 39 (at time of injury) Sex: N/S Race: N/S | Treatment protocol not described. All pts had been ventilated during the course of their treatment. Some had been successfully weaned by time data collected (1984). Each surviving patient and his/her nearest caring relative, along with the nearest caring relative of each patient who had died, were questioned separately about whether they were glad the patient had been ventilated rather than being allowed to die, and about the effects (psychological, social, and economic) of this decision on their lives. Predictors considered (analytic method N/S): Sex, socioeconomic class, previous social behavior, personality traits before the injury, initial neurological level, age | No. of pts who had died by 1984, along with their status at the time of death (on ventilator; off ventilator, but still in hospital; at home):; - Total deaths by 1984 - 16/37 (43%); - Deaths on ventilator, in hospital - 8/16; - Deaths off ventilator, in hospital - 5/16; - Deaths on ventilator, at home - 0 (no pts were discharged home on ventilators); - Deaths off ventilator, at home - 3/16; Duration of survival for pts still alive: Mean, 5.4 yrs (range, 1-15 yrs) Responses to questions about decision to ventilate and its effects (results follow this list):; - From surviving patients; - From relatives of surviving pts; - From relatives of pts who died after discharge home; - From relatives of pts who died in hospital during initial admission after being weaned; - From relatives of pts who died in hospital during initial admission while still being ventilated; 18/21 surviving pts (86%) said they would wish to be temporarily ventilated again; 1/21 (5%) would wish to be allowed to die; 2/21 (9%) were undecided. 16/21 relatives of surviving pts (76%) were glad about the decision to ventilate; 4/21 (19%) were not glad; 1 answer was "unknown." Number of pts with poor outcome, where "poor outcome" defined as "the patient dying while still on the ventilator, the patient regretting having received ventilation, or the [patient's] relatives not being glad that the patient was ventilated": 16 pts Predictors of poor outcome: Age > 59 yrs (3/7 pts died; 2/7 had relatives who were not glad about the decision to ventilate; 2/7 had good outcomes) Other outcomes reported: Status of pts still alive (in hospital, at home, preparing to go home) Total days (all pts combined) spent in hospital (on and off ventilator) and at home Estimated no. of additional nursing and physiotherapy hours per week required to provide care to ventilated pts
Gardner, Watt, and Krishnan, 1986 37 pts from this series of 44 also described in Gardner, Theocleous, Watt et al., 1985 | Design: Case series Quality: Internal validity Level V External validity 1-Y 2 N 3-N 4-Y 5-Y | N = 44 Neurol. status Time since injury: 55% of pts were ventilated 1 day after injury; 11% on day 2; 5% day 3; 2% on day 4; 9% on day 5; 2% on day 6; and 16% more than 6 days after injury. Pts injured from 1969 through 1984; study conducted in 1985. Level of injury: 5% C2, 7% C3, 43% C4, 36% C5-C7; 2% (1 pt) each T3, T6, T8, and L1. Completeness of injury: N/S, though all pts described as "tetraplegic" Pulmonary status: All pts had been ventilated at some point in their treatment; most had been successfully weaned by time data collected (1985) Age: 38.6 (at time of injury) Sex: 84% M, 16% F Race: N/S | All pts had been ventilated during the course of their treatment. Most had been successfully weaned by time data collected (1985). Authors describe indications for ventilation, methods of ventilation, and methods of weaning used for each patient in the series. | Overall mortality rate (cervical pts) by 1985: 42% (17/40) Causes of death: Respiratory, 16; cardiovascular, 10; other, 4. All 4 "other" deaths were directly related to being ventilated: 1 cases of innominate artery erosion from tracheostomy tube, 1 case of septicemia associated with etomidate-induced adrenocortical suppression, and 2 more cases due to inadequate ventilation during transfer. Time on ventilator before weaning commenced: No. of pts (for whom adequate documentation was available and whose weaning commenced within 3 wks) successfully weaned within nine days of commencement of weaning: Reported as "half" (exact no. N/S); estimated as 9/18 (50%) No of pts successfully weaned within 9 days who were on full-time ventilation for > 3 wks: 0/12; denominator N/S, so "12" is based on estimate Complications (no. of cases) of ventilation: Significant infection, 5/19 (26%); cardiovascular, 4/19 (21%); pulmonary collapse, 4/19 (21%); failure of spontaneous closure of tracheostomy, 3/19 (16%); excessive tracheal granulation tissue, 2/19 (11%); major hemorrhage (innominate artery erosion), 1/19 (5%) Total days (all pts combined) spent in hospital (on and off ventilator, including readmissions) and at home (pt-days at risk): Total days in hospital:18,545 On ventilator: 3,352 Off ventilator: 15,193 During readmissions:2,058 Total days at home:35,289 Outcome of treatment (cervical pts): One of the following for each pt:; - Early death during first admission whilst on full-time ventilation - 4/40 (10%); - Early death during first admission off all ventilation - 1/40 (2%); - Early death during first admission whilst being weaned - 1/40 (2%); - Late death during first admission whilst on full-time ventilation - 0; - Late death during first admission off all ventilation - 4/40 (10%); - Late death at home off all ventilation - 3/40 (7%); - Late death during readmission off all ventilation - 2/40 (5%); - Late death during first admission whilst being weaned - 1/40 (2%); - Late death at home on night ventilation - 1/40 (2%); - Alive at home on night ventilation - 1/40 (2%); - Alive at home off all ventilation - 20/40 (50%); - Alive in hospital off ventilator awaiting discharge during first admission - 1/40 (2%); - Alive at home off all ventilation, but with tracheostomy tube in situ - 1/40 (2%); Other outcomes reported: No. of pts who had died by 1985, along with their status at the time of death (on ventilator; off ventilator, but still in hospital; at home) Status of pts still alive (at home off ventilator, at home on nighttime ventilation, awaiting discharge on whole-time electrophrenic respiration)
  < 8 wks | 25/31 pts (81%)
  > 8 wks | 6/31 pts (19%)
  (6 other cases were not reported.)
Tromans, Mecci, Barrett et al., 1998 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-Y 2-Y 3-Y 4-Y 5-N | N = 14 pts received BiPAP to avoid full ventilation (prophylactic grp); 4 pts received BiPAP both to avoid full ventilation and for weaning Neurol. status Time since injury: N/S, but all pts defined as "acute"; more than half been admitted within 24 hrs of injury Level of injury: Prophylactic grp: C4 29%, C5 36%, C6 29%, C8 7% Completeness of injury: Prophylactic grp: Initial Frankel grade A, 71%; B, 14%; C, 14% Pulmonary status: Initial VC: Prophlyactic grp: 1.22 L (data from 1/14 pts not available) Age: Prophylactic grp:38 (range:22-66) Sex: N/S Race: N/S | Retrospective review of medical records of acutely injured pts to determine degree to which a biphasic positive airway pressure (BiPAP) system could be used to avoid the need for full ventilation (prophylactic grp, n = 14) BiPAP Mode Used The "spontaneous" mode of BiPAP was used, i.e., both inspiratory positive airway pressure (IPAP) and expiratory positive airway pressure (EPAP), cycling spontaneously in response to the pt's own respiratory needs. A pressure difference between IPAP and EPAP of at least 8 cm H_2_O was used. | Prophylactic grp (n = 14); - No. of pts using BiPAP to avoid need for full ventilation: - Successful: 8/14 (57%) - Not successful: 6/14 (43%); - Mean total no. of days on BiPAP: 5 days; - Mean VC immediately before commencing BiPAP: 0.75 L; Other outcomes reported: None
MECHANICAL VENTILATION ASSISTANCE Acute Ventilation Management Weaning Techniques
Bach, 1991 and Bach and Alba, 1990a Possible overlap with Bach, Alba, and Saporito, 1993, and Bach and Tilton, 1994 | Design: Retrospective case series Quality: Internal validity Level V External validity | N = 34 Neurol. status Time since injury: Years (mean no. of years N/S, but dates of initial injury ranged from 1957 to 1988) Level of injury: Traumatic high-level quadriplegia Completeness of injury: N/S Pulmonary status: Chronic ventilatory dependence; on admission, 30/34 pts (88%) were on PPV via tracheostomy with cuff inflated up to 24 hrs/day; 4/34 pts (12%) had no measurable VC (2 of whom presented with late-onset respiratory failure). Of the 4, 1 was on PPV via nasotracheal intubation and 1 had been placed directly on a Chest Shell ventilator. Of the 2 in respiratory failure, 1 was placed on an Iron Lung and 1 on a Chest Shell ventilator. Age: 29 (range: 14-72) (enrolled pts) Sex: N/S Race: N/S | Rehabilitation program allowing pts to become increasingly ventilator independent (weaned, in some cases) using following methods (among others):; - Intermittent cuff deflation; - Intermittent abdominal pressure ventilation (IAPV); - Daytime mouth PPV (positive pressure ventilation); - Nighttime PPV with various types of seals; - Body ventilators (Iron Lung, Chest Shell, Pulmowrap); - Chest wall stretching program; - Respiratory muscle strengthening exercises; - Increasing periods of autonomous ventilation; - Glossopharyngeal breathing (GPB); - Closure of tracheostomy sites; Other interventions:; - Manual assisted coughing; - Mechanical assisted coughing; - Antibiotics | No. of pts weaned from assisted ventilation without resort to noninvasive methods of ventilatory support other than daytime PPV: 10/34 (29%) Tracheostomy No. of pts on PPV via tracheostomy who were converted to noninvasive ventilatory support methods and had their tracheostomy sites closed: 20/34 (59%); - No. of pts with tracheostomies closed: 24/34 (71%); - No. of hrs of free time (off ventilator) when tracheostomy site allowed to close: "Most" of 24 pts had < 3 hrs of free time; 11/24 (46%) had no free time; No. of pts using combination of daytime mouth PPV and IAPV with Iron Lung overnight: 15/24 (62%) No. of pts using IAPV predominantly for daytime support: 7/24 (29%) VC; - Average VC at time of tracheostomy closure and/or conversion to solely noninvasive methods of ventilatory support: 606 ± 458 mL (n = 24); GPB "6 pts with < 600 mL of VC and no significant free time learned GPB. 5/6 had GP_max_SBC of 2,205 mL, despite an average VC of 402 mL and used GPB successfully for free time and as a backup in the event of ventilator failure."; - Amt of free time (from ventilator) with and without GPB: 2/5 pts had no free time without GPB but were free "all day" with GPB; 1/5 had no free time without GPB but 5 min with GPB; 1/5 had 15 min free without GPB but 2 hrs with GPB; - Community disposition of pts using GPB: 1/5; - predominantly institutionalized; 2/5 used GPB from 12/84 to "present" (time of publication date -- presumed to be approx. 1990); 1/5 used GPB from 5/86 to present; 1/5 used it from 5/89 to present; - GP_max_SBC (mL) (glossopharyngeal maximum single-breath capacity): 3,000 mL, 2/5 pts; 1,475 mL, 1/5 pts; 2,350 mL, 1/5 pts; 1,200 mL & improving, 1/5 pts; Time to mastery of mouth PPV: 1 day (approx. half of 24 pts); within 1 mo, 100% (n = 24) No. of months in intensive rehabilitation before returning to community: Av. of 3/5 mos, 96% (23/24 pts) Adverse events (complications): Investigators reported that there were "no significant complications reported over 45 patient-yrs . . . except for 2 readmissions for pulmonary complications since stomal closure." Mortality: 3/24 (12%) Other outcomes reported:; - No. of pts requiring surgical closure of tracheostomy sites; - No. of pts electing replacement of tracheostomy; - No. of years of successful use of NVA; - Measured during sleep: - Oxyhemoglobin saturations (SaO_2_) - End-tidal pCO_2_
Lamid, Ragalie, and Welter, 1985 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-Y 2-Y 3-Y 4-N 5-N | N = 13 Neurol. status Time since injury: N/S Level of injury: C3-C4 or C4 46%, C5 31%, C6 15%, C7 8% Completeness of injury: Complete, 5/13 (38%); incomplete, 6/13 (46%); not defined, 2/13 (15%) (1 C4, 1 C5) Pulmonary status: All pts were ventilator-dependent and had failed previous weaning attempts; at baseline, 6/13 (46%) had atelectasis, 1 of whom also had ARDS and 1 of whom also had pneumonia; 1/13 (8%) had pneumonia alone Age: 38 (range:19-61) Sex: 92% M, 8% F Race: 85% Caucasian, 15% black | Individualized weaning program for pts who had failed previous weaning attempts Weaning attempts commenced when the following were met:; - VC > 10 mL/kg of body weight; - Tidal volume > 5 mL/kg of body weight; - Peak inspiratory pressure > −20 cm H_2_O; - Minute volume < 10 L/min; - Respiratory rate < 30 breaths/min; Above parameters were measured; - while pts were on respirators and; - during weaning attempts after 1, 5, 15, 20, 30, 40, 50, 60, and 75 min off of ventilation; Other criteria used to determine when to attempt complete weaning:; - ABGs (measured during weaning); - Absence of acute infection or cardiopulmonary problems; Techniques for respiratory muscle conditioning, secretion management, etc., were not described. | Weaning; - No. of pts successfully weaned: 13/13 (100%); - Time until successful wean: Range, 2 days to 14 mos; - Factors predicting successful wean: Investigators concluded that there were 4 primary factors that were predictive of successful weaning: "(1) alleviation of anxiety and depression, (2) family support, (3) close working relationship between staff, (4) prevention of complications such as pneumonia and urinary tract infections" (p. 33).; Functional status; - No. of pts achieving some measure of independent living (in eating, dressing, feeding, etc.): 9/13 (69%); - No. of pts requiring total care: 4/13 (31%); Tracheostomies; - No. of pts requiring tracheostomies (at discharge): 2/13 (15%); Complications; - No. of pts with complications during weaning: 7/13 (54%); - No. of complications & no. of pts with each complication: Given in table below. Some pts had multiple complications, so the no. of pts is greater than 7.; Other outcomes reported: Where pts discharged to (home, etc.) Amt. of survival time after injury No. (and timing and cause) of deaths
  | # Comp's | # Pts (%)
  Urinary tract infection | 4 | 4/13 (31%)
  Pneumonia | 3 | 3/13 (23%)
  Bronchospasm | 2 | 2/13 (15%)
  Bronchitis | 1 | 1/13 (8%)
  Depression | 1 | 1/13 (8%)
Lesoin, Delandsheer, Lozes et al., 1983 | Design: Prospective case series Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-N 5-N | N = 10 Neurol. status Time since injury: Mean time N/S, but pts described as "at the acute stage" Level of injury: C4-C5 60%, C6 and below 40% Completeness of injury: Complete Pulmonary status: All on MV Age: N/S Sex: N/S Race: N/S | Test of whether an electromyogram (EMG) of the diaphragm was predictive of eventual recovery of respiratory function. EMG procedure (retrosternal method): EMG performed until first expiratory, then inspiratory activity was picked up (shown by bursts of motor unit potential responses corresponding to the diaphragm). As a test, the phrenic nerve was then stimulated electrically at the pts' neck on the same side as the tip of the electrode. | EMG activity/results; - No. of pts in whom EMG activity was detected: 3/10 (30%); - No. of pts in whom no EMG activity was detected: 7/10 (70%); Recovery of respiratory function; - No. of pts who recovered respiratory function: 3/10 (30%) - 3/3 (100%) of pts in whom EMG activity was detected - 0/7 of pts in whom no EMG activity was detected (6/7 died in first week on MV; 1/7 failed attempt to wean at 2 wks); - No. of pts who did not recover respiratory function: 7/10 (70%)
Peterson, Barbalata, Brooks et al., 1999 13 pts added to series after this article accepted for publication. Results from the expanded series (n = 55) reported (very briefly) in Peterson, Brooks, Mellick et al., 1997 | Design: Retrospective concurrent cohort comparison Quality: Internal validity Level V External validity 1-Y 2-Y 3-Y 4-Y 5-Y | N = 55 (42 from 1999 report, plus 13 from 1997 report; demographic and time since injury data below refer to 42 pts from 1999 report) Neurol. status Time since injury: Mean, 52.7 days (range: 0-178 days) Level of injury: C3-C4 Completeness of injury: Functional bilateral trapezius muscle strength (grades of "fair" or better), but nonfunctional distal musculature (grade of "poor" or less, including deltoids and biceps) Pulmonary status: All pts had required full-time mechanical ventilation on admission, but had successfully weaned by discharge Age: 29.9 (range:15-60) Sex: 88% M, 12% F Race: N/S | Two therapies (used during treatment and weaning) compared:; 1. High-tidal-volume assist/control ventilation (mean at 2 wks, 25.3 mL/kg; range, 20.03 to 32.2 mL/kg) (n = 23); 2. Low-tidal-volume assist/control ventilation (mean at 2 wks, 15.5 mL/kg; range, 11.6 to 19.4 mL/kg) (n = 19); Both types of pts weaned using progressive ventilator-free breathing technique, according to the same protocol | Results below reported as means followed by standard deviations (SD) in parentheses. Time from admission to successful wean (days): Spontaneous vital capacity at end of study (p = 0.56): HV 1.51 (0.53) LV 1.51 (0.50) Percentage of pts with atelectasis; - At admission (p = 0.003): HV 84% (16/19) LV 39% (9/23); - At start of wean (p = 0.80): HV 53% (10/19) LV 48% (11/23); - 2 weeks after admission (p = 0.01): HV 16% (3/19) LV 52% (12/23); - New cases in pts who were clear at admission (p = 0.05): HV 33% (1/3 pts) LV 86% (12/14 pts); Percentage of pts with complications: Peak pressure (cm H_2_O) (p < 0.001): HV 35.2 (5.11) LV 28.83 (5.09) Dynamic compliance (mL/cm H_2_O) (p = 0.013): HV 50 (11.7) LV 42 (8.07) Other outcomes reported: Predictors of length of time to wean (1997 report only)
  High-volume (HV) | 37.6 (21.38)
  Low-volume (LV) | 58.7 (33.03)
  HV weaned significantly faster than LV (p = 0.02)
  Pneumonia at rehab admiss.
  | HV | 5% (1/19)
  | LV | 9% (2/23)
  | (p = 0.67)
  New diagnosis of pneumonia | HV | 5% (1/19)
  | LV | 13% (3/23)
  | (p = 0.39)
  Chest tubes | HV | 5% (1/19)
  | LV | 0
  | (p = 0.27)
  Adult respiratory distress synd. | HV | 0
  | LV | 4% (1/23)
  | (p = 0.36)
Peterson, Charlifue, Gerhart et al., 1994 Study also described (briefly) in Peterson, Brooks, Mellick et al., 1997 | Design: Retrospective chart review (case series) Quality: Internal validity Level V External validity 1-Y 2 ± N 3-N 4-Y 5-Y | N = 52 pts with 82 separate weaning attempts. Analysis focused on the 26 weaning attempts that used IMV and the 34 that used PVFB (remaining 22 attempts used wide variety of methods). Neurol. status Time since injury: N/S, but hospital admission during which weaning was attempted had to be part of pt's initial post-spinal cord injury acute care and rehabilitation Level of injury: C3 or C4 Completeness of injury: N/S Pulmonary status: Pts on mechanical ventilator at time of admission or had been successfully weaned from a ventilator at a referring facility Age: N/S Sex: N/S Race: N/S | Two methods of weaning:; 1. Intermittent mandatory ventilation (IMV); 2. Progressive ventilator-free breathing (PVFB); Some pts (n = 17) underwent PVFB weaning attempts after failing IMV | No. (and %) of successful wean attempts (= removed from ventilator full-time for 2 wks or more): The success rate for PVFB was significantly higher than that for IMV (p = 0.02). No. (and %) of wean attempts where pts were discharged without complete success: Both methods resulted in an essentially equal no. of discharges with partial success (no p-value reported). No. (and %) of wean attempts that failed (= wean attempt abandoned and not restarted within 14 days): Investigators did not report having directly compared the 2 methods for this measure. Time elapsed to complete independence from ventilator (cumulative % of pts off ventilator, by method and week of attempt): Investigators stated that IMV had a slightly greater success rate for this outcome in the first 4 wks, but that PVFB successes surpassed those of IMV after the fourth wk.
  IMV | 9/26 (35%)
  PVFB | 23/34 (68%)
  IMV | 5/26 (19%)
  PVFB | 6/34 (18%)
  IMV | 12/26 (46%)
  PVFB | 5/34 (15%)
  | IMV | PVFB
  Wk 3 | 15% | 9%
  Wk 8 | 31% | 41%
  Wk 11 | 35% | 59%
  Wk 17 | 0 | 68%
Sortor, 1992 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-N | N = 22 (see "Note" at right) Neurol. status Time since injury: Chronic (mean yrs N/S, but records from as far back as 1984 were reviewed) Level of injury: 68% C3 and above, 18% C4, 14% C5 Completeness of injury: N/S, but all pts described as having "traumatic quadriplegia" Pulmonary status: All ventilator-dependent; 20/22 pts (91%) admitted with tracheostomies and requiring 24-hr ventilatory support Age: N/S Sex: N/S Race: N/S | Description of evaluation methods and treatment protocol for addressing pulmonary concerns in quadriplegic pts. Evaluation methods:; - Physical assessment of breathing patterns and cough effectiveness; - Pulmonary function testing in both sitting and supine positions of the following: - Flow volume loop - Volitional lung volumes - Inspiratory and expiratory force measurements; - Measurement of "mechanical" inspiratory capacity (to determine degree of chest wall restriction); - Oximetry (arterial blood gases, pulse oximetry with end-tidal CO2 or transcutaneous CO2); Treatment protocol:; - Chest wall stretching/hyperinflation; - Assisted coughing when needed; - Assisted ventilation when appropriate; - Aggressive pulmonary hygiene during chest infections | No. of pts requiring tracheostomies at discharge: 7/22 (32%) No. of hrs of ventilatory support required at discharge: 24 hrs - 7/22 pts (32%) 18-24 hrs - 10/22 pts (45%) 8-12 hrs - 4/22 pts (18%) 0 hrs - 1 pt who needed ventilatory support and a tracheostomy at discharge refused them and is presumed to have died - 1/22 (4%) No. of pts discharged to home: 18/22 (82%) No. of pts discharged to skilled nursing facilities: 4/22 (18%) No. of pts requiring 18-24 hrs of support who had tracheostomies reinserted within 1 yr of discharge: 2/10 (20%) Methods of ventilatory support used by discharged pts:; - Tracheostomies - 7/22 (32%); - Nontracheostomized - 15/22 (68%); - Mask ventilation for nocturnal support (SONI, 3; Lyon masks, 5; Respironics^®^, 1) - 9; - Negative pressure systems (pneumosuits or pulmowraps for nocturnal support)- 5; - Lost to followup, 1; - 10/15 (67%) of the nontracheostomized pts who required 18-24 hrs of support used the following:; - Exsufflation belts during daytime−9; - Mouthpiece - 1; Mortality: 5/22 (23%)
Note: The 22 pts were a subset with traumatic injuries of a larger grp of 62 ventilator-dependent quadriplegics, 40 with neuromuscular disorder (20 polio, 3 amyotrophic lateral sclerosis, 2 spina bifida, 9 muscular dystrophy, 6 spinal muscular atrophy)
Splaingard, Frates, Harrison et al., 1983 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-Y | N = 17 (pts of age 15-70 with cervical-level injuries from a larger grp of 47 that included 8 children of age < 15, 1 adult with thoracic injury, and 21 adults/children with other neurological diseases) Neurol. status Time since injury: Chronic (all pts had been discharged from hospital) Level of injury: C1 6%, C2 47%, C3 35%, C4 12% Completeness of injury: N/S Pulmonary status: All pts had "chronic respiratory failure"; all had been discharged home ventilator-dependent and with tracheostomies Age: 21 (range: 15-35) Sex: N/S Race: N/S | Retrospective review of medical charts of pts with tracheostomies who had been discharged home on positive pressure ventilators | No. of pts weaned: 4/17 (24%) No. of pts placed on full- or part-time electrophrenic pacing: 3/17 (18%) Mortality; - No. of deaths overall: 5/17 (29%); - No. of deaths within 1st yr: 2/17 (12%); Other outcomes reported: No. of pts discharged from hospital to home Level of care given at home (professionals vs. family/friends) Cost
Tromans, Mecci, Barrett et al., 1998 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-Y 2-y 3-Y 4-Y 5-N | N = 12 received it for weaning (weaning grp); 4 pts received BiPAP for both weaning and to avoid full ventilation Neurol. status Time since injury: N/S, but all pts defined as "acute"; more than half been admitted within 24 hrs of injury Level of injury: Weaning grp: C2 8%, C4 50%, C5, 25%, C6 17% Completeness of injury: Weaning grp: Initial Frankel grade A, 67%; B, 8%; C, 25% Pulmonary status: Initial VC: Weaning grp: N/S Age: Weaning grp:36 (range:22-66) Sex: N/S Race: N/S | Retrospective review of medical records of acutely injured pts to determine degree to which a biphasic positive airway pressure (BiPAP) system could be used to enable pts to be weaned from full ventilation (weaning grp, n = 12) Weaning Procedure BiPAP was initiated when patients met certain clinical conditions (e.g., experienced decreasing VC even though receiving oxygen therapy, pt was heavy smoker or had COPD, etc.) BiPAP was used to wean pts from full ventilation when the following criteria were met:; 1. Formal ventilation was uncomplicated.; 2. Ventilation was via a pressure support cycle.; 3. Pressure support required was within the BiPAP range (2-22 cm H_2_O).; 4. Pt was able to tolerate and be adequately ventilated on BiPAP.; Pts were weaned from BiPAP when:; 1. Pt was stable with the current level of support from BiPAP.; 2. Assisted and unassisted VC were measured on and off the BiPAP.; 3. IPAP was reduced by 2 cm H_2_O for increasing periods.; 4. IPAP was also reduced by 6-8 cm H_2_O for 10 breaths several times daily.; 5. Once IPAP had been reduced by 2 cm H_2_O for 24 hrs, the cycle was begun again and repeated until pt was fully weaned.; 6. EPAP requirements did not exceed (generally) 4 cm H_2_O pressure. | Weaning grp (n = 12); - No. of pts using BiPAP to wean from full ventilation: - Successful: 10/12 (83%) - Not successful: 2/12 (17%); - Mean total no. of days on BiPAP: 38 days; - Mean total days on full ventilation: 17 days; Other outcomes reported: None
Viroslav, Rosen-blatt, and Tomazevic, 1996 | Design: Case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-N | N = 76 Neurol. status Time since injury: N/S, though pts evaluated and treated "after completing rehabilitation at other centers" Level of injury: N/S; all pts tetraplegic Completeness of injury: N/S; all pts tetraplegic Pulmonary status: All pts required ventilatory assistance at baseline: 85% had indwelling tracheostomy tubes, 11% had translaryngeal endoctracheal tubes, and 6% were using some type of noninvasive ventilatory assistance Age: N/S Sex: N/S Race: N/S | Not described in detail. Authors describe general treatment approach of particular clinic. Approach characterized as "an aggressive program for patients with spinal cord injury to either delay or eliminate the need for tracheostomy or to quickly decannulate tracheostomized patients for transition to the use of noninvasive methods of ventilatory assistance." (p. 314) Interventions employed at clinic include:; - Intermittent positive pressure breathing (IPPB); - Manually assisted coughing (manual resuscitator or IPPB, followed by forceful abdominal thrust with glottic opening); - Transfer to noninvasive ventilation; - Breathing exercises; - Glossopharyngeal breathing (for individuals requiring full-time ventilatory assistance) | During treatment at inpatient facility; - No. of pts moved from indwelling tracheostomy tubes to noninvasive methods of ventilatory assistance: 56/76 (74%); - No. of pts moved from translaryngeal endotracheal tubes to noninvasive methods of ventilatory assistance: 7/76 (9%); At time of discharge; - No. of pts still requiring full-time ventilatory assistance: 33/76 (43%); - No. of pts requiring less-than-full-time ventilatory assistance (12-14 hrs per day): 23/76 (30%); - No. of pts completely weaned from ventilatory assistance: 20/76 (26%); During followup (mean 50 months, range 6-130 months); - Mortality: 10/76 (13%); - No. of pts requiring reinsertion of tracheostomy tube: 0; Other outcomes reported: No. of hospital readmissions for respiratory diseases and infections
MECHANICAL VENTILATION ASSISTANCE Chronic Ventilation Management Chronic NIPPV
Bach, 1991 and Bach and Alba, 1990a | | Described previously under Weaning Techniques
Bach, Alba, and Saporito, 1993 Possible overlap with Bach and Alba, 1990a; Bach, 1991; and Bach and Tilton, 1994 | Design: Retrospective case series Quality: Internal validity Level V External validity | N = 31 Neurol. status Time since injury: Mean no. of years N/S (but study covered 39 yrs) Level of injury: Traumatic high-level quadriplegia Completeness of injury: N/S Pulmonary status: Ventilator-dependent for up to 24-hrs/day (with acute or chronic ventilatory insufficiency); no significant obstructive or intrinsic pulmonary disease (except for 3 pts); little history of smoking in population Age: 31 Sex: N/S Race: N/S | Study of persons using noninvasive ventilatory assistance (NVA) methods, either mouth PPV alone or in combination with other NVA methods, for up to 24 hrs/day. Methods used (among others):; - Daytime mouth PPV; - Nocturnal PPV (using mouthpiece with lipseal or custom orthodontic interfaces); - Portable volume preset ventilators used in assist control or control modes; - Pressure preset ventilators; - Tracheostomy PPV; Other aid used: Mechanical exsufflation | No. of pts having tracheostomies removed in favor of NVA support: 24/31 (77%) No. of pts having tracheostomies placed after using NVA support: 7/31 (23%) No. of pts who used mouth PPV for at least daytime support who; - required 10-20 hrs/day of ventilatory support: 7/31 (23%); - required 20-24 hrs/day of ventilatory support: 20/31 (65%); Daytime mouth PPV; - No. of pts using it: 31/31 (100%); Nocturnal mouth PPV:; - No. of pts using it: 19/31 (61%); - VC, mL (% pred): 779 mL (17.9 % pred.); Patient preference for type of ventilatory support: "Almost invariably" mouth PPV (among ventilator-assisted pts who had used assisted ventilation for at least 1 month via an indwelling tracheostomy and via noninvasive methods of support, including mouth PPV) Most recent maximum tolerated free time off ventilator (among 20 pts requiring 20-24 hrs ventilatory support who used mouth PPV for at least daytime support): < 60 min, 15/20 pts (75); < 10 min, 11/20 pts (55%) Mortality (no. of deaths, reasons): 5/31 (16%) (3/5 "possibly associated" with ventilation; 2/5 "not associated" with ventilation) Other outcomes reported: For pts converted to tracheostomy PPV, reasons for:; - Hospitalization; - Intubation; No. of pts with access to mechanical exsufflation who:; - underwent permanent tracheostomy; - returned to use of NVA after intubation for surgical procedures; Daytime mouth PPV:; - Duration of use; - No. of pts using it for >10 yrs; Nocturnal mouth PPV:; - Duration of use; - No. of pts using it for >10 yrs; Nocturnal end-tidal pCO_2_ and/or oxyhemoglobin saturation (SaO_2_) monitoring
Bach, Alba, and Saporito, 1993 | | Described previously under Weaning Techniques
Bach, Rajaraman, Ballanger et al., 1998 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-Y 2-N 3-N 4-N 5-N | N = 52 (subset of larger group - see "Note" on next page) Neurol. status Time since injury: Years Level of injury: N/S Completeness of injury: N/S Pulmonary status: Users of assisted ventilation using: indwelling tracheostomy tubes, tracheostomy or other noninvasive home MV methods, or oxygen therapy Age: N/S Sex: N/S Race: N/S | A survey was sent to users of mechanical ventilators requesting a chronological listing of:; - Ventilation methods; - Periods of oxygen use; - No. of hospitalizations; - No. of occurrences of pneumonia; - No. of occurrences of translaryngeal intubation; - Precipitators of need for ventilator use; - Time when need for ventilator use increased permanently to 8 to 16 hrs/day; - Time when need for ventilator use increased permanently to > 15 hrs/day; 2 telephone followup calls were made by medical students, once in 1991 and once in 1995. Investigators compared types of ventilatory assistance used with (1) incidence of pneumonia and (2) hospitalizations occurring from 1991 to 1995. Types of ventilatory assistance used for which results were reported:; - Part- or full-time noninvasive ventilation; - Tracheostomy PPV; Note: These 52 pts were from a larger group of 684 ventilator users, 18 of whom had neuromuscular conditions and gastrostomy tubes and 12 of whom had COPD. | Incidence of pneumonia overall: Significantly lower for noninvasive ventilation users (part- or full-time) than for tracheostomy PPV users (p < 0.05). Incidence of pneumonia in hospital vs. at home for the 2 types of ventilation: Compared with in-hospital ventilatory support period, the incidence of pneumonia was reduced significantly during home ventilation for noninvasive ventilation users (p < 0.05), but not for tracheostomy PPV users. No. of hospitalizations: Significantly reduced by use of part- or full-time noninvasive ventilation but not compared to use of tracheostomy PPV (p < 0.05)
Tromans, Mecci, Barrett et al, 1998 | | Discussed previously in Acute Ventilation Management and in Weaning
MECHANICAL VENTILATION ASSISTANCE Chronic Ventilation Management Diaphragm Pacing (Electrophrenic Respiration)
Bach and Tilton, 1994 Possible overlap with Bach and Alba, 1990a; Bach, 1991; and Bach, Alba, and Saporito, 1993 | Design: Case series Quality: Internal validity Level V External validity 1-Y 2-N 3-Y 4-N 5-Y | N = 87 Neurol. status Time since injury: Ventilator-assisted, 13.4 yrs; autonomously breathing, 8.9 yrs Level of injury: Complete traumatic tetraplegia Completeness of injury: Frankel Class A or B Pulmonary status: Ventilator-assisted: on ventilatory support for > 2 yrs post-injury for > 8 hrs/day; autonomously breathing: > 2 yrs post-injury with no history of ventilatory support beyond acute post-injury period Age: Ventilator-assisted, 33 (range: 17-73); controls, 33 (range:21-59); autonomously breathing, 37 (range:22-73) Sex: Ventilator-assisted (64% M, 33% F, 2% N/S); autonomously breathing (76% M, 22% F, 2% N/S); controls (15% M, 85% F) Race: N/S | Experimental (1): Ventilator-assisted (n = 42) Experimental (2): Autonomously breathing (n = 45) Control (1): Health care professionals (n = 273) Control (2): Same health care professionals responding as if they were ventilator-assisted (same n = 273 above) 3 psychosocial instruments were administered to assess quality of life:; 1. Scale of Life Domain Satisfaction; 2. Semantic Differential Scale of General Affect; 3. The Relative Importance of Respiratory and Extremity Function Scale | Overall life satisfaction (Instrument 1): Ventilator-assisted subjects were significantly more satisfied with housing, family, life, etc., than were the autonomously breathing subjects. Controls and ventilator-assisted subjects (15 of whom were working) were both more satisfied with their jobs (p < 0.0005 and 0.02, respectively) and with their family lives (p = 0.02 and 0.04, respectively) than were autonomously breathing subjects. Controls were significantly more satisfied with most of the variables than was either SCI group. General affect (well-being) (Instrument 2): Both SCI groups' responses were "generally positive." The controls rated their own lives as significantly (p < 0.05) more interesting, more enjoyable, etc., than did either SCI group. Controls very significantly (p < 0.0005) underestimated the positive nature of the ventilator-assisted group's responses. Level of distress over ventilator dependence vs. distress over loss of extremity function (Instrument 3): Ventilator-assisted subjects with no upper extremity use placed significantly more emphasis on having upper extremity function and less on autonomous breathing than the autonomously breathing subjects predicted they would. The control group also rated upper extremity function significantly lower than did the ventilator-assisted group. No. of years (and hrs/day) of ventilator use: Ventilator-assisted, 9.7 yrs (17.6 hrs/day); other groups, none Other outcomes reported: Age at time of study No. of years of formal education Percentage of pts for whom religion was important Marital status (divorce rate after injury, new marriage rate) Employment status at time of survey Rates of response to survey
Carter, 1993 | | Described previously under Acute Ventilation Management
DeVivo and Ivie, 1995 | | Described previously under Acute Ventilation Management
Fodstad, 1989 | Design: Case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-N | N = 15 Neurol. status Time since injury: N/S Level of injury: All injuries were high cervical cord lesions "mainly" of traumatic origin (C1-C5) Completeness of injury: N/S Pulmonary status: All with partial or total respiratory paralysis; mean amt of preoperative respirator support, 39 mos (range:2-288) Age: Age at time of EPR operation, 24 (range:3-69) Sex: 73% M, 27% F Race: N/S | Implantation of phrenic nerve pacemaker (unilateral or bilateral). After implantation operation, no EPR pacing was done for 10 days. Initially, the phrenic nerves were stimulated every hr for 3-min periods, with the minute volume being measured at beginning and end of each period. Pacing was gradually increased until (after a period from 2 wks to 2 mos long) the pt's respiration was controlled by EPR for < 24 hrs. | EPR/MV use at followup (mean of 45 mos [range: 2 -96 mos]); - No. of pts using EPR pacing with no MV support: 4/15 (27%); - No. of pts using EPR pacing with only nighttime MV support: 6/15 (40%); - No. of pts who ceased EPR pacing: 5/15 (33%) - Duration of EPR use before they ceased: 3 mos to 3 yrs - Level/type of injury of those who ceased EPR use: All (5/15 [33%]) with level of injury at C3-C5 with partial injury to the phrenic motor neurons; No. of deaths at followup: 0/15
Glenn, Holcomb, Shaw et al., 1976 | Design: Case series Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-N 5-N | N = 37 (34 with spinal cord injury, 2 with ischemia of spinal cord following surgical procedures, and 1 with syringomyelia) Neurol. status Time since injury: 2 mos-11 yrs Level of injury: 73% C1-C2; 27% C3-C5 Completeness of injury: Complete quadriplegia in all pts except pt with syringomyelia Pulmonary status: All pts had "respiratory paralysis"; no further details provided Age: Mean N/S (range:4-71, with 62% of pts age 15-30) Sex: 65% M, 35% F Race: N/S | Diaphragm pacing via electrical stimulation of the phrenic nerves | No. of pts achieving full-time ventilatory support by diaphragm pacing: 13/37 (35%) No. of pts achieving at least half-time ventilatory support by diaphragm pacing: 10/37 (27%) No. of pts who could not be paced successfully: 14/37 (38%) Duration of pacing among pts (n = 13) achieving full-time ventilatory support: Av. of 26 mos Time from implantation of device to beginning of full support: Usually 2-4 mos, but could not always be verified Arterial blood gases (measured only among pts at one site who were paced 50%-100% of the time [n = 7]): "Nearly normal" at beginning and end of any 12-hr pacing period Minute volumes in pts totally supported by pacing (n = 2): "Usually" within normal range (5-10 L/min) Complications; - Operation-related: - Probable phrenic nerve injury - 11 cases - Infection - 5 cases; - Equipment failure - 17 cases; Mortality: 10/37 (27%) Other outcomes reported: Longest period of continuous support
Miller, Farmer, Stuart et al., 1990 | Design: Case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-N | N = 23 (21 with trauma, 2 with demyelinating disease) Neurol. status Time since injury: 12-16 weeks Level of injury: C1, 2 pts; C2, 5 pts; C3, 9 pts; C4, 7 pts; C5, 2 pts Completeness of injury: N/S; all pts quadriplegic Pulmonary status: Pts ventilator-dependent; all had failed previous attempts at weaning from ventilator Age: 31 (range:17-63) Sex: 43% M, 57% F Race: N/S | Implantation of phrenic nerve pacemaker (unilateral or bilateral) | Overall assessment of efficacy of pacing: Rated as:; - Excellent: Goal of complete ventilatory independence achieved - 8/23 pts (35%); - Good: Significant gain achieved, but another mode of support, generally the respirator, required in addition to pacing - 9/23 pts (39%); - Moderate: Not defined - 3/23 pts (13%); - Poor: Ventilatory support required; pacing not able to sustain time off respirator - 3/23 pts (13%); Complications: Significant pneumonia, 3/23 pts (13%) No. of pts with component failure: 3/23 pts (13%) 12-mo mortality: 2/23 pts (9%)
Weese-Mayer, Silvestri, Kenny et al., 1996 | Design: Retrospective cohort study; data collected via a questionnaire submitted to PIs and/or physicians responsible for implanting device, coupled with information from Atrotech Registry Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-N | N = 29 (26 pts with high cervical spinal cord injury, plus 1 pt each with brainstem tumor, diffuse neurological disease with gliomatosis, and pituitary dysfunction) Neurol. status Time since injury: N/S Level of injury: "High cervical spinal cord injury"; no further details provided Completeness of injury: N/S, but all pts tetraplegic Pulmonary status: Pts not ventilator-dependent; 86% had had a tracheostomy at some point in their management, and all but 1 maintained the tracheostomy at time of questionnaire Age: 33.1 (range:18-62) Sex: 76% M, 24% F Race: 83% Caucasian, 3% "other," 14% unknown | Implantation of quadripolar phrenic nerve electrode diaphragm pacer system | Duration of pacing (in years) at time of questionnaire: Av. of 2.2 ± 1.1 yrs Complications (non-equipment-related); - Percentage of pts with infection: None; - Percentage of pts with mechanical trauma to phrenic nerves: 10% (3/29); - Percentage of pts with flutter of diaphragm: 3% (1/29); Complications (equipment-related); - No. of electrode failures: 2/29 (7%) (in 2 pts); - No. of receiver failures: 3/29 (10%) (in 3 pts); - No. of nonfunctioning electrode combinations: 9/29 (17%) (in 5 pts); Percentage of pts with successful pacing with no complications: 52% (15/29) Percentage of pts with successful pacing in spite of < 4 electrodes functioning on given phrenic nerve: 10% (3/29) Overall percentage of pts successfully paced (whether with or without complications): 86% (25/29) Mortality :3% (1/29)
MECHANICAL VENTILATION ASSISTANCE Chronic Ventilation Management Intermittent Abdominal Pressure Respirator (IAPR)
Miller, Thomas, and Wilmot, 1988 | Design: Retrospective case series, prospective survey Quality: Internal validity Level V External validity 1-Y 2-Y 3-N 4-N 5-N | N = 21 IAPR users (subset of grp of 23, 21 with SCI, 2 with polio) were studied retrospectively; of the 23, 13 were also reviewed at followup using a prospective survey Neurol. status Time since injury: N/S, but all 21 pts in retrospective study were in an acute rehabilitation facility Level of injury: 71% C3 & higher (3 of whom also had brainstem dysfunction with injuries at C1-C2); 14% C4-C7; 14% N/S (these were 3/21 pts with incomplete injuries) Completeness of injury: 86% complete, 14% incomplete Pulmonary status: All on MV with tracheostomies (retrospective study) Age: 25 (range:8-47) Sex: 76% M, 24% F Race: N/S | Two-part study of IAPR use:; 1. Retrospective study of patterns of IAPR use among inpatients (n = 21) at acute rehabilitation facility. Provided a brief description of IAPR fitting process and training program (see below).; 2. Prospective survey used to gather followup data on 13/23 pts (57%) after discharge from facility (results not reported separately for traumatically injured pts vs. others). Of the original 23 pts, 3 were awaiting discharge arrangements, 3 had died, 2 had severe brainstem injuries, and 2 had recovered diaphragmatic function. Only 10/13 pts (77%) responded to the survey. These pts were questioned regarding patterns of current IAPR use, attitudes about the device, advantages and disadvantages of using it, and quality of life.; Description of IAPR The IAPR is an inflatable flat bladder that allows for ventilation without a tracheostomy. The device assists expiration rather than inspiration. It is inflated by use of a portable pressure ventilator pump that should provide up to 18 breaths per minute and pressures up to 80 cm of water. IAPR training program Not described in detail. Pts must have been able to sit to at least 90° and breathe room air. IAPR was fitted while pt was supine; then pt was repositioned in wheelchair. Respiratory therapist described program, and experienced IAPR users were introduced whenever possible. Each pt was given an IAPR trial of 20-30 min while arterial blood gases were being monitored. Periods of use were extended thereafter according to: patient's ability to tolerate device, exhaled volumes, and serial blood gases. | Retrospective study (n = 21) Time after injury that IAPR was fitted: Average of 3-6 mos (range:7 wks - 9 yrs) No. of hrs/day of continuous, generally all-day, use, of IAPR:; - 4 hrs/day, 12/21 pts (57%) during study; 1/21 (5%) after discharge; - 2 hrs/day, 8/21 pts (38%); Prospective study (n = 13; 10 responders) Results were not reported separately for traumatically injured pts vs. others. No. of pts still using IAPR at discharge :11/13 (85%) Global assessment of satisfaction: Investigators reported according to the 10/13 pts (77%) responding to the survey, there was a "high level of satisfaction" with the device. Other outcomes reported: Mortality
MECHANICAL VENTILATION ASSISTANCE Weaning Techniques
Gardner, Watt, and Krishnan, 1986 - | | Described previously under Acute Ventilation Management
Tromans, Mecci, Barrett et al., 1998 | | Described previously in Acute Ventilation Management
NONMECHANICAL VENTILATION ASSISTANCE Respiratory Muscle Conditioning
Cheshire and Flack, 1978 | Design: Prospective case series Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-Y 5-Y | N = 12 Neurol. status Time since injury: 3-9 wks, MV grp; 1-12 wks, no-MV grp; 113-208 wks, old lesions grp Level of injury: MV grp, 100% C4; no-MV grp, C4-C6; old lesions grp, C5 & C6 (1 each) Completeness of injury: Complete Pulmonary status: 5/12 (42%) on MV (1 of whom had diaphragmattic hemiparesis); 5/12 (42%) not on MV; 2/12 (17%), not specified whether on or off MV, but all were experiencing acute respiratory illness Age: 25 (range:14-41) Sex: 50% M, 50% F Race: N/S | Incentive spirometry program:; - Spirometer (Spirocare Incentive Breathing Exerciser) had flashing colored lights rather than numbers to more clearly indicate success to the pt.; - Various health care professionals enthusiastically encouraged success and discouraged incorrect behavior. Contests were also conducted so pts would compete to improve spirometric values.; Three groups evaluated:; 1. MV - Pts with new lesions who required MV at start of treatment (n = 5); 2. No-MV - Pts with new lesions who did not require MV (n = 5); 3. Old lesions - Pts with old lesions who received incentive spirometry after being treated for acute respiratory illness (n = 2) | Difference between mean pre- and post-treatment FVC values (mL): Mean FVC values increased at post-treatment for each of the groups. Investigators did not directly compare the results. Other outcomes reported: Duration of treatment % predicted FVC (mL)
  | Post-tx | Pre-tx
  MV grp (n = 5) | 2465 | 370
  No-MV grp (n = 5) | 3,000 | 1,630
  Old lesions grp (n = 2) | 2,262 | 1,300
Derrickson, Ciesla, Simpson et al., 1992 | Design: RCT Quality: Internal validity Level II External validity 1-Y 2-Y 3-Y 4-Y 5-N | N = 11 (completed trial) Neurol. status Time since injury: Mean, 18.2 days (range: 2-74 days) Level of injury: 45% C4-C5, 18% C6, 36% C7 Completeness of injury: All pts met ASIA standards of complete injury Pulmonary status: 45% of pts had been on mechanical ventilation prior to admission to study; exercise programs started only after pts had been breathing spontaneously for at least 24 hours and when free from active pulmonary disease Age: 27.8 (range:16-41) Sex: 82% M, 18% F Race: N/S | Experimental: Inspiratory resistive muscle training (IMT) (n = 6) Control: Abdominal weights training (AbWts) (n = 5) Pts in both groups received two 15-min training sessions per day, 5 days per week, for 7 weeks | All of the below outcomes were measured at 1 and 7 wks after pts were admitted to the study. (Results are reported as means followed by standard deviations in parentheses.) An ANOVA analysis showed no differences between treatment groups for any of the outcomes. However, there were significant differences within groups for all outcomes, with the exception of inspiratory capacity. Forced vital capacity (FVC) (L): Maximal voluntary ventilation (MVV) (L/min): Peak expiratory flow rate (PEFR) (L/s): Increased inspiratory mouth pressure (P_Imax_) (cm H_2_O): Inspiratory capacity (IC) (mL):
  | Wk 1 | Wk 7 | W/in Grp p-value
  IMT | 1.36 (0.50) | 2.60 (0.73) | < 0.001
  AbWts | 1.18 (0.61) | 1.68 (0.32) | < 0.001
  | Wk 1 | Wk 7 | W/in Grp p-value
  IMT | 42.80 (28.00) | 59.50 (22.00) | < 0.05
  AbWts | 23.60 (12.00) | 30.20 (8.00) | < 0.001
  | Wk 1 | Wk 7 | W/in Grp p-value
  IMT | 1.40 (0.62) | 3.17 (1.00) | < 0.01
  AbWts | 1.54 (0.71) | 2.43 (1.00) | < 0.001
  | Wk 1 | Wk 7 | W/in Grp p-value
  IMT | −34.83 (17.00) | −58.17 (12.00) | < 0.001
  AbWts | −20.80 (13.00) | −43.40 (13.00) | < 0.001
  | Wk 1 | Wk 7 | W/in Grp p-value
  IMT | 1.61 (0.47) | 2.09 (0.71) | < 0.05
  AbWts | 1.24 (0.54) | 1.41 (0.20)
DiPasquale, 1986 | Design: Case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-N/A | N = 56 Neurol. status Time since injury: N/S Level of injury: C1-C4 Completeness of injury: "Most" pts had neurologically complete injuries Pulmonary status: "Not all" pts ventilator-dependent Age: N/S Sex: N/S Race: N/S | "Exhaler class" = a multidisciplinary program designed to meet the physical, psychosocial, and educational needs specific to high quadriplegic pts through a group format. Program involved 15 min of warm-up exercises, followed by 30 min of educational sessions, 5 days per week for 6 weeks. Monthly outings also organized. | Quantitative data reported for the following outcomes only: Percentage of pts who completed course evaluation: 10% (6/56) Average increase in vital capacity: 0.5 L (unclear whether n is 20 or 53) Note: Extremely low response rate suggests bias. Results for VC may be unreliable because article gives conflicting data on no. of patients from whom VC data were available.
Huldtgren, Fugl-Meyer, Jonasson et al., 1980 | Design: Prospective case series Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-Y 5-N | N = 12 (an additional 23 untrained pts were also described) Neurol. status Time since injury: 5 mos Level of injury: Not reported separately for the 12 trained pts; combined pts: C4 and C5, 7/35 (20%); C5-C6 and C6, 16/35 (46%); C6-C7 and C7, 6/35 (17%); C8, 6/35 (17%); Completeness of injury: Complete Pulmonary status: None with previous history of obstructive lung disease; chest fluoroscopy of pts with injuries > C6 showed "normal diaphragmatic amplitudes at rest and during VC maneuvers"; VC, 42% predicted normal (all pts) Age: 21 (range:16-36) Sex: N/S Race: N/S | Comparison of PFT results before and after completion of a respiratory training program. Training program (15 min/day for 6 wks): Insufflation - Pts (in supine position) received insufflation of air using a manually operated pump 10 x/day. The insufflated volume was increased every other day by 25% of the difference between measured and predicted TLC until predicted TLC was achieved (8 weekdays). The pt's abdomen was firmly strapped to achieve the greatest amt of rib-cage movement possible. Resistance training - Same pts then performed forced voluntary expirations and inspirations against resistance (allowing maximum flows in the order of 0.1 - 0.4 L/sec). Expirations were performed 10 times from spontaneous TLC and 10 times from maximum insufflated TLC. Inspirations were performed from RV through the same resistance for 10 times. PFTs were measured before and after training. | Pre- to post-training pulmonary function tests (VC, TLC, ERV, P_e_max, P_i_max): All results were reported graphically and exact numbers could not be determined. Investigators reported that "the markedly reduced TLC, VC, ERV, and maximum static respiratory pressures [P_i_max and P_e_max] all improved significantly upon treatment. The lung volumes remained improved in the 11 pts who were restudied after about 1 yr and in the 5 pts who were restudied after about 5 yrs. However, maximum static respiratory pressures appeared to have decreased at the last followup study compared with those immediately after treatment" (p. 347).
Loveridge, Badour, and Dubo, 1989 | Design: RCT Quality: Internal validity Level II External validity 1-Y 2-Y 3-Y 4-Y 5-Y | N = 12 Neurol. status Time since injury:> 1 year Level of injury: C6-C7 Completeness of injury: Complete motor loss below the lesion level Pulmonary status: Not ventilator-dependent; baseline FVC 67.5% predicted Age: 33 Sex: N/S Race: N/S | Ventilatory muscle endurance training (n = 6): Using an inspiratory resistor; training conducted twice daily for 15 minutes, 5 days per week, for 8 weeks Control (n = 6): No ventilatory muscle endurance training | Maximum inspiratory mouth pressure (MIP) (-cm H_2_O pressure): Both groups significantly improved MIP from pre- to post-training (p < 0.05, each), but there were no significant differences between groups (no p-value reported). Results reported as means followed by SDs. Sustainable inspiratory mouth pressure (SIP): Both groups significantly improved SIP from pre- to post-training (p < 0.05, each), but there were no significant differences between groups (no p-value reported). Results reported as means followed by SDs. Total lung capacity (TLC) (% pred.): No significant changes from pre- to post-training (no p-values given); investigators did not directly compare the groups. Inspiratory capacity (IC) (% pred.): No significant changes from pre- to post-training (no p-values given); investigators did not directly compare the groups. Forced vital capacity (FVC) (% pred.): No significant changes from pre- to post-training (no p-values given); investigators did not directly compare the groups. Other outcomes reported: Residual volume (RV) Functional residual capacity (FRC) Arterial blood gases Frequency of respiration (resting breathing pattern) Tidal volume (V_t_) (resting breathing pattern) Inspiratory time (T_i_) Expiratory time (T_e_) Expiratory volume (Ve) V_t_/T_i_ T_i_/T_tot_(T_tot_ = time of total inspiratory and expiratory cycle)
  | Pre-training | Post-training
  Trainers | 72.3 (± 17.3) | 100.7 (± 19.3)
  Controls | 81.7 (± 21.9) | 105.3 (± 16.3)
  | Pre-training | Post-training
  Trainers | 50.2 (± 12.1) | 76.5 (± 15.2)
  Controls | 56.2 (± 15.4) | 71.8 (± 10.5)
  | Pre-training | Post-training
  Trainers | 77.3 (± 9.5) | 82 (± 6.9)
  Controls | 91.6 (± 17) | 91.6 (± 17)
  | Pre-training | Post-training
  Trainers | 80 (± 12) | 95 (± 15)
  Controls | 9 (± 25) | 104 (± 27)
  | Pre-training | Post-training
  Trainers | 63 (± 20) | 64 (± 10)
  Controls | 72 (± 23) | 75 (± 23)
Walker and Cooney, 1987 | Design: Prospective single subject design clinical trial Quality: Internal validity Level V External validity 1-N 2-N 3-Y 4-Y 5-Y | N = 15 Neurol. status Time since injury: N/S, but all pts "chronic" Level of injury: C4-C5 20%, C5-C6 47%, C6-C7 27%, C7-C8 7% Completeness of injury: N/SB Pulmonary status: Mean VC at baseline, 2.6 L Age: 24 (range:17-33) Sex: 73% M, 27% F Race: N/S | Prospective study of combined pulmonary therapy (incentive spirometry) and resistance exercise (arm ergometer). All pts participated in both types of training. Respiratory training program (n = 15); - Incentive spirometry: 15 min/day for 3-5 days/wk for 7-12 wks; - Arm ergometer: Pts pedaled for up to 30 min, 3 x/wk for 7-12 wks; resistance on the arm ergometer was increased as pt's tolerance increased. | Mean change in expiratory volume (max VE) from pre- to post-training: Expiratory volume increased by a mean of 14.33 L/min (SD:7.09) from pre- to post-training. Investigators did not directly compare the results (no p-values reported). Mean change in vital capacity (VC) from pre- to post-training: Vital capacity increased by a mean of 657 mL (SD:339) from pre- to post-training. Investigators did not directly compare the results (no p-values reported). Other outcomes reported: Increase in maximum exercise power output
  Pre-training max VE | 20.61
  Post-training max VE | 34.94 L/min
  Pre-training max VC | 2,603
  Post-training max VC | 3,260 L
NONMECHANICAL VENTILATION ASSISTANCE Glossopharyngeal Breathing (GPB)
Montero, Feldman, and Montero, 1967 | Design: Prospective single subject design clinical trial Quality: Internal validity Level V External validity 1-Y 2-Y 3-Y 4-Y 5-Y | N = 14 Neurol. status Time since injury: Mean N/S (range:6 mos - 3 yrs) Level of injury: C5-C7 Completeness of injury: Complete Pulmonary status: All pts free from respiratory infections during test period; all accomplished respiration by "normally innervated diaphragm with minimal assistance from the neck accessory muscles" (p. 651). All pts had been in an intensive rehabilitation program prior to this study and all were believed to have achieved maximum neuromuscular recovery. Age: Mean N/S (range:15-37) Sex: N/S Race: N/S | Glossopharyngeal breathing (GPB) training program to improve respiratory function. Training program; - GPB breathing: All pts given 30-60 min of individual instruction, 3 x/wk, until each could add 700-1000 cc of air to VC with 10 to 20 GPB "gulps" (from 1-6 wks). Once the technique was learned, pts practiced unsupervised for 10 min/day, 2-3 x/day until (1) he/she could use GPB breathing to cough with sufficient force to remove mucous from upper respiratory tract, and (2) when VC remained stable for 2 wks. Once these 2 criteria were met, training was discontinued.; - Expansion of thorax and lungs: Once GPB breathing was perfected, pt was asked to take his/her deepest voluntary breath, then to add GPB breathing until he/she felt great pressure in throat and upper chest. Pt was then asked to count aloud as the air was expelled. With next breath, pt was asked to hold maximal GPB breath for count of 10. On another occasion pt was told to blow air out through pursed lips or a whistle.; Pulmonary function tests (PFTs) Complete PFTs were performed before and after training (i.e., once pts met the criteria for success described above under "GPB breathing"). Vital capacity and maximum GPB breaths were measured using a portable respirometer at beginning and end of each session. The following were measured:; - Expiratory reserve volume (ERV); - Breath holding time; - Maximum breathing capacity; - Vital capacity (VC); - Maximum expiratory flow; - Timed vital capacity; - Respiratory rate; - Tidal volume; - Ability to cough; - Ability to raise voice | Change in average PFT values (% pred.) from pre- to post-training for the following:; - Breath holding time: Increased from 30% to 93% of predicted normal.; - Maximum breathing capacity: Increased from 33% to 49% of predicted normal.; - Vital capacity (VC): Increased from 35% to 65% of predicted normal.; - Maximum expiratory flow: Increased from 39% to 92% of predicted normal.; Investigators did not directly compare results for the above outcomes (no p-values reported). No significant changes occurred from pre- to post-training for the following 4 outcomes (results provided only graphically; no p-values reported):; - Expiratory reserve volume (ERV); - Timed vital capacity; - Respiratory rate; - Tidal volume; Ability to raise voice: Investigators reported that all patients learned to use GPB breathing to clear their throats or raise their voices loud enough "to gain the attention of a nurse at the far end of a hospital corridor" (p. 652). Other outcomes reported: Ability to cough
NONMECHANICAL VENTILATION ASSISTANCE Continuous Positive Airway Pressure (CPAP)
Gothe and Maximin, Sajkow et al., 1999 | Design: Prospective case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-Y 5-N | N = 14 (these pts were a subset who had abnormal tracings from a larger group of 17; not explicitly stated whether pts had traumatic injuries or not) Neurol. status Time since injury: Mean N/S (range: 2 mos - 39 yrs); < 10 yrs in half of pts (combined pts) Level of injury: N/S, but all defined as "tetraplegic" Completeness of injury: N/S Pulmonary status: N/S Age: Mean N/S (range: 23-71); "about half" were < 50 yrs old (combined pts) Sex: N/S Race: N/S | Study of pts believed to be at risk from nocturnal hypoxemia. Nocturnal oxygen saturation profiles were obtained and found to be "abnormal" in 14/17 pts (82%). Abnormal was defined as "tracings with episodic or sustained oscillatory falls of oxygen saturation. "Oximetry and further in-depth evaluations (not described) were then performed to determine which pts to treat further. Pts received treatment at home. Treated grp: CPAP, supplemental oxygen, or a combination of both (n = 6): Untreated grp: n = 8 | No. of deaths at followup: 9/13 (69%) Duration of time between diagnosis of nocturnal hypoxemia and death: Av. of 30 mos (range:3-62 mos) Status at followup Of 6 pts treated with CPAP:; - 2 died unexpectedly at home at night (1 had used nasal CPAP successfully for > 3 yrs; the other "declined a tracheostomy, could not tolerate nasal CPAP, and was then treated with a uvulopalatoplasty which failed" [p. 71]);; - 2 died of progressive heart failure (after having used CPAP and oxygen successfully);; - only 1 pt was alive on CPAP and oxygen after more than 5 yrs (after having had at least 1 episode of respiratory insufficiency that required intubation and MV during a lengthy hospitalization); and; - 1 pt was not described.; Of 7 pts not treated with CPAP:; - only 1 died of unrelated causes;; - 2 were lost to followup;; - 2 were alive and well at home; and; - 2 were not described.; Note: Report does not clearly account for outcomes in all pts described.
Harvey and Ellis, 1996 | Design: Prospective single subject design clinical trial Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-N 5-N | N = 10 Neurol. status Time since injury: All injured for 5 yrs (median, 12 mos); all described as "recently injured" pts who were either inpatients or had recently been discharged from a specialist SCI unit Level of injury: C4 20%, C5 50%, C7 10%, C8 20% Completeness of injury: Complete (motor only); 2/10 (20%) had sensory incomplete injuries Pulmonary status: None had history of respiratory diseases Age: 33 Sex: 100% M Race: N/S | Test of the effects of continuous positive airway pressure (CPAP) on PFT measurements. Three types of CPAP airway pressure were administered:; - Zero end-expiratory pressure; - 5 cm H_2_O of CPAP; - 10 cm H_2_O of CPAP; CPAP design Two identical CPAP systems were set up so that CPAP would be maintained both when subjects were breathing 100% O_2_for FRC and CV (closing volume) measurements and when they were breathing room air between these tests. A continuous CPAP flow of 60 L/min was maintained. Pts were instructed to try to maintain an expiratory pressure of between 0.3 and 0.6 L/min. PFT measurements PFTs were measured on each of 3 separate visits, with a different CPAP airway pressure being given at each visit. Visits were separated by > 24 hrs but < 1 wk (with 2 exceptions). PFTs were measured before, during, and after 32 min administration of CPAP. Tests were performed with pts seated in wheelchairs. VC, CV, and FRC were measured at each visit, with 2 consecutive measurements being taken of each lung volume and later averaged. FRC was measured by open-circuit nitrogen washout method, CV by the single-breath nitrogen washout method. There were 2 min between CV and FRC measurements and 5 min between subsequent measurements of FRC. CV and FRC were measured 8 and 12 min after administration of CPAP, respectively. CV was measured again at 20 min, FRC again at 22 min. FRC was then measured at 1 and 21 min after CPAP was removed; CV was measured at 11 and 31 min after CPAP was removed. | Mean FRC (and % pred.) at basline: Mean FRC (and % pred.) after application of zero end-expiratory pressure, 5 cm H_2_O of CPAP, and 10 cm H_2_O of CPAP: Results were reported graphically and exact means could not be determined. CPAP at both 5 and 10 cm H_2_O caused significant increases in FRC (mean increases of 9 and 34% for 5 and 10 cm, respectively). After 5 and 10 cm of H_2_O of CPAP were removed, FRC returned to pre-CPAP values by the first minute. Other outcomes reported: Effects of the following on FRC:; - Pressure; - Time; - Interaction of pressure and time
  Pre-tx FRC: | 3.83 ± 1.22 (SD)m
  Pre-tx % pred. FRC: | 110.3 ± 30.5
NONMECHANICAL VENTILATION ASSISTANCE Posture
Amodie-Storey, Nash, Roussell et al., 1996 | Design: Prospective single-subjects design clinical trial Quality: Internal validity Level V External validity 1-Y 2-Y 3-Y 4-Y 5-N | N = 15 Neurol. status Time since injury: Mean, 4.2 (3.3) (SD) yrs (range:0.7-13); none with injuries < 3 mos Level of injury: 7% C3-C4; 20% C4 or C4-C5; 73% C5, C5-6, C6, or C6-7 Completeness of injury: Frankel grades A-C (defined as "tetraplegias") Pulmonary status: N/S; none with MV support within 8 wks of study testing, artificial airway, history of COPD, asthma, or pneumonia within 2 wks of testing Age: 26 (range:18-31) Sex: 93% M, 7% F Race: N/S | Tested the effect of altering habitual head posture on PFTs in 2 grps: pts with heads habitually held forward (n = 12) and pts with heads habitually not held forward (n = 3). "Forward" was defined as orthostatic position of head (OPH) > 6 cm, and "not-forward" as OPH < 6 cm. Heads habitually held forward were moved back (to OPH < 6 cm); heads habitually held not-forward were moved forward (to OPH > 6 cm). Pts performed 3 PFTs in 1 posture (habitual or altered), with 2 min between each trial. A 10-min rest period followed and then pts underwent one 12-sec MVV challenge. After another 10-min rest period, rolled towels were placed in the lumbar- to mid-thoracic spinal regions to move a pt's head forward or in the mid- to upper-thoracic region to move a pt's head backward. Three PFTs and 1 MVV trial were then repeated in the second posture. | Best of 3 trials under each test condition used for analysis. Difference in mean FVC between habitual and altered positions: For pts with habitual head-forward posture (n = 12), mean FVC significantly better in habitual posture than in altered posture (p < 0.05). For pts with heads not forward habitually (n = 3), no significant differences between habitual and altered postures (p 0.05). Difference in mean MVV (12-sec challenge) between habitual and altered positions: For pts with habitual head-forward posture (n = 12), mean MVV significantly better in habitual posture than in altered posture (p < 0.05). For pts with heads not forward habitually (n = 3), no significant differences between habitual and altered postures (p 0.05). Difference in pulmonary volumes for FVC and MVV: Pulmonary volumes for FVC and MVV averaged 8.5% and 14.5% greater in the habitual than altered position, respectively. Difference in mean FIVC between habitual and altered positions (all pts, n = 15): There were no significant differences between habitual and altered positions for mean FIVC. Difference in mean FEF_25-75_ between habitual and altered positions (all pts, n = 15): There were no significant differences between habitual and altered positions for mean FEF_25-75_. Other outcomes reported: None
  Habitual: Altered: | 2.62 (0.8) (SD) L 2.4 (0.7) L
  Habitual: Altered: | 2.5 (0.2) L 2.3 (0.1) L
  Habitual: Altered: | 97.0 (40.9) L/min 84.7 (28.8) L/min
  Habitual: Altered: | 93.3 (6.3) L/min 81.7 (9.2) L/min
  Habitual: Altered: | 2.5 (0.8) L 2.3 (0.6) L
  Habitual: Altered: | 3.4 (1.2) L/min 3.2 (1.1) L/min
Chen, Lien, and Wu, 1990 | Design: Prospective single subject design trial Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-Y 5-Y | N = 12 (see "Note" at right) Neurol. status Time since injury: > 6 mos Level of injury: C4-C8 Completeness of injury: Complete Pulmonary status: N/S, but none had cardiopulmonary problems Age: 33 (range: 20-50) (combined pts) Sex: N/S Race: N/S | Test to determine differences in PFTs obtained by spirometry with pts in 3 different positions:; - Lying supine; - Sitting upright; - Standing (used tilting board); Spinal braces were removed during the test. Note: Subset of larger grp containing 19 paraplegics | Difference in mean FVC % pred. between supine vs. erect (sitting + standing) postures: FVC % predicted was significantly better in the supine position (57%) than in the erect position (sitting + standing combined) (p < 0.05). The % predicted values were as follows: Correlation between FVC % pred. and level of injury in each of the 3 positions: There was a significant correlation between FVC % pred. and level of injury in all positions (p < 0.05, all 3 comparisons); the higher the cord damage, the more severe the impairment of respiratory function noted. The r-values were as follows: Other outcomes reported: Difference in mean FEV_1_/FVC between supine, sitting, and standing postures Difference in diaphragmatic excursion shown on chest X-rays (of 4/12 pts) taken during maximal inspiration and expiration with pt in supine and sitting positions
  Supine Sitting Standing | 57.1 ± 13.5 (± 1 SD) 45.9 ± 14.6 43.6 ± 4.3
  Supine Sitting Standing | r = 0.71 r = 0.83 r = 0.82
Estenne and De Troyer, 1987 | Design: Prospective single subject design clinical trial Quality: Internal validity Level V External validity 1-Y 2-N 3-Y 4-Y 5-Y | N = 14 Neurol. status Time since injury: 49 mos (range: 4-216) Level of injury: C4-C5 or C5 21%; C5-6 or C6 50%; C6-C7 or C7 29% Completeness of injury: N/S Pulmonary status: All were free of respiratory symptoms Age: 33 (range:17-64) Sex: 86% M, 14% F Race: N/S | Comparison of static lung volume measurements taken with pts first in a seated position, then supine, then returned to a seated position. PFT measurement procedure:; - Slow VC was measured in each posture using low-resistance recording spirometry (used best results of > 6 trials).; - FRC was determined by closed-circuit helium dilution technique.; - TLC and RV were calculated from these measurements.; Two additional substudies were performed:; 1. Leg cuffs - In 6/14 cervical-injured pts, the above procedure was repeated, with the exception that blood pressure cuffs were placed at the base of a pt's legs and inflated to diastolic pressure before the pt assumed a supine position.; 2. Abdominal binding - In 10/14 cervical-injured pts, static lung volumes were measured in seated and supine postures both before and after elastic straps were fitted around the pt's abdomen when he/she was lying down and was at end-expiration. Straps were adjusted to maintain constant abdominal dimensions during the postural changes. | Cervical-injured only VC; - VC (% pred.) in seated pts: 48.4% of predicted normal values; - Mean increase in VC in supine compared with seated posture: 0.41 ± 0.07 (SEM) L; this was 16% of the seated value and was a significant increase (p < 0.001).; - No. of pts with an increase in VC when changing from seated to supine posture: 12/14 (86%); TLC; - TLC (% pred.) in seated pts: 28.5% of predicted normal values; - No. of pts with a reduction in TLC when changing from seated to supine posture: 13/14 (93%); RV; - RV (% pred.): 140% of predicted normal values in 10/14 pts (71%); "not elevated" in 4/14 pts (29%); - Mean reduction in RV in supine posture compared with seated posture: 0.72 ± 0.06 L; this was 29% of the seated value and was a significant reduction (p < 0.001).; Combined pts Decrease in mean TLC in supine compared with seated posture: Significantly smaller (by 0.28 ± 0.05 L) in supine posture than in seated posture (p < 0.001); this was 5.5% of the seated value. Two substudies Effect on RV (sitting vs. supine postures) caused by (1) use of blood pressure cuffs on legs or (2) abdominal binding: The reduction in RV achieved when changing from sitting to supine position was not significantly affected when blood pressure leg cuffs were added prior to assumption of supine position. The postural dependence of RV was, however, eliminated by abdominal binding. Other outcomes reported: ERV (% pred.)
Forner, Llombart, and Valledor, 1977 Possible overlap with Forner, 1980 | Design: Prospective single-subject design clinical trial Quality: Internal validity Level III External validity 1-N 2-Y 3-Y 4-Y 5-N | N = 20 (18 with injury due to trauma, 1 with transverse myelitis, 1 with arachnoiditis) (see "Note" on next page) Neurol. status Time since injury: 5 mos (all pts described as "up and about") Level of injury: 5% C4, 20% C5, 30% C6, 40% C7, 5% C8 (level of injuries described as "below" C4, C5, etc.) Completeness of injury: Complete Pulmonary status: 6 pts had had tracheostomies performed during acute phase due to respiratory insufficiency; all pts "free from respiratory disturbance" at time of examination Age: 33 (range:21-57) Sex: 80% M, 20% F Race: N/S | Test to determine pulmonary flow-volume curves and maximum flow-volume loop, based on position, in this population. Pts performed a maneuver consisting of a maximal inspiration followed by a forced and complete expiration (forced vital capacity, FVC) and this immediately followed by a forced inspiration. FVC was measured with a wire-mesh screen pneumatograph and flow-volume curves generated were directly recorded in a Hewlett-Packard XY Recorder 7.045-A. This maneuver was performed over several days (exact no. not specified), with pts in 3 positions:; - Sitting; - Supine; - Trendelenberg (20° head down); The above maneuver was repeated until it was done correctly. Investigators retained the curve that showed the highest value. Spirometry was performed on Day 1 before pts performed above maneuver. Note: Data from unspecified no. of pts who "did not cooperate sufficiently" were excluded from analyses. | Changes in FVC, PEF, and PIF based on position (sitting, supine, 20° head down) and mean % predicted values for each outcome:; - Mean forced vital capacity (FVC) (mL): n = 20; - Mean % pred. FVC: 49.9 (16.7) (about half of normal values); Mean values of FVC were reduced in the sitting position to approximately 50% of the predicted normal values. In the other 2 positions, the mean values were significantly higher than in the sitting position (approx. 300 mL higher) (no p-value reported).; - Mean peak expiratory flow (PEF) (L/s):; - Mean % pred. PEF: 54.8 (17.2); - Mean peak inspiratory flow (PIF) (L/s):; - Mean % pred. PIF: 58.8 (24.0); Comparison between PIF and PEF: PIF is less reduced than PEF, but the difference is not statistically significant. Other outcomes reported:; - Maximum expiratory flow at 75%, 50%, 25% of FVC (MEF_75_, MEF_50_, MEF_25_); - Maximum inspiratory flow at 50% (MIF_50_); - For the above measures, comparisons with predicted normal values
  Sitting | 2195 (950) (SD)
  Supine | 2470 (765)
  20° head down | 2485 (780)
  Sitting | 4.13 (1.62)
  Supine | 3.94 (1.40)
  20° head down | 3.87 (1.21)
  Sitting | 2.93 (1.23)
  Supine | 2.87 (1.18)
  20° head down | 2.82 (1.15)
Fugl-Meyer, 1971 | Design: Case series Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-Y 5-Y | N = 26 (subgroup with cervical-level injuries from larger study population of 40) Neurol. status Time since injury: 27% < 2 yrs; 50% 2-5 yrs; 23% > 5 yrs Level of injury: 1 pt (4%) C4, rest C5-C8 Completeness of injury: All pts had "complete traumatic transection of the spinal cord"; "most" had loss of sensibility corresponding to the level of their injury Pulmonary status: Pts breathing spontaneously and clinically free of respiratory infections Age: N/S Sex: 82.5% M, 17.5% F (larger study population) Race: N/S | Study tested effect of body position on respiratory function. Positions tested were: seated in wheelchair, supine, and tilted at various angles using tilting board. From supine position (defined as 0°), 10/26 pts tilted to head-up position of 25°, 50°, and 75° | Lung volumes; - Total lung capacity (TLC): Mean, 5.2 L (69% pred.) (n = 17); - Vital capacity (VC): Mean, 2.3 (42% pred.) (n = 17); - Forced expiratory volume (FEV)% (= FEV_1_/VC x 100): 85% (n = 24); - Forced inspiratory volume (FIV)% (= FEV_1_/VC x 100): 86% (n = 12); Maximal respiratory pressure; - Expiratory (P_e_max): 32 (n = 19); - Inspiratory (P_i_max): 75 (n = 12); Comparison between TLC (and VC) results for sitting vs. supine positions: There was little difference in TLC for sitting vs. supine positions, but there was a significant difference in VC (p < 0.001), which was an average of 28% greater in the supine position. Mean change in TLC (n = 10) in different head-up tilted positions (25°, 50°, 75°), expressed as percent change of those obtained in supine (0°) position: Investigators reported that "[t]here were no systematic changes in TLC when tetraplegics were tilted from 0° to 25°. In most pts, the TLC was decreased at greater tilting angles, but the mean change was small" (p. 144). Mean change in VC (n = 10) in different head-up tilted positions (25°, 50°, 75°), expressed as percent change of those obtained in supine (0°) position: Investigators did not report comparisons for this measure. Other outcomes reported: Lung volumes: Functional residual capacity (FRC) Expiratory reserve volume (ERV) Residual volume (RV) Correlation between smoking habits and static lung volumes, FEV_1_, and PEFR Correlation between level of injury and lung volume measurements (in particular, maximal respiratory pressure)
  25° | −3
  50° | −1
  75° | −6
  25° | −8
  50° | −26
  75° | −45
Maeda, Baydur, Waters et al., 1990 | Design: Prospective single subject design trial Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-Y 5-N | N = 10 Neurol. status Time since injury: Mean N/S; range:3-135 mos Level of injury: C5 40%, C6 40%, T1 20% Completeness of injury: Complete Pulmonary status: Mean baseline VC (supine, without halovest), 65.3 ± 12.3% pred. normal Age: 28 (range:19-40) Sex: 70% M, 30% F Race: N/S | Investigation of the effect of body position (supine vs. sitting) on vital capacity (VC) when pts were either wearing or not wearing a halovest. Abdominal binders were not worn during testing, and no pts required use of cervical orthosis for bony stability at time of testing. Halo ring, skull pins, and vertical bar assembly were not applied with halovest, for ethical reasons. VC was measured using dry rolling seal spirometer. Two tests were performed in each position, with and without body vest (with best of the 2 efforts being selected automatically by computer). Measurements were taken in the following positions, in the order given:; - Supine without halovest; - Sitting without halovest; - Supine with halovest; - Sitting with halovest | Effect of body position on VC; - Without halovest, sitting vs. supine: Mean VC (% pred. ± SEM) in the sitting position without halovest was significantly lower (worse) (57.1 ± 17.1% of predicted normal) than it was in the supine position without halovest (65.3 ± 12.3% of predicted normal) (p = 0.015).; - With halovest, sitting vs. supine: Mean VC (% pred.) in the sitting position with halovest was lower (worse) (54.6 ± 15.7% of predicted normal) than it was in the supine positionwith halovest (59.2 ± 9.8% of predicted normal). The difference was not significant (no p-value reported).; Effect of halovest on VC; - Supine, with vs. without halovest: Mean VC (% pred.) in supine pts without halovest was 65.3 ± 12.3% of predicted normal and decreased (worsened) to 59.2 ± 9.8% of predicted normal in supine pts with halovest. The difference in decline between the 2 conditions was significant (p = 0.01).; - Sitting, with vs. without halovest: Mean VC (% pred.) in sitting pts without halovest was 57.1 ± 17.1% of predicted normal and decreased (worsened) to 54.6 ± 15.7% of predicted normal in sitting pts with halovest. The difference in decline between the 2 conditions was not significant (p = 0.10).

1 See Abbreviations Used in Evidence Tables (preceding these tables) for a list of abbreviations, acronyms, and symbols.

2 Internal validity rating (Levels I-V): I = Large randomized trials with clear-cut results (and low risk of error); II = small randomized trials with uncertain results (and moderate to high risk of error); III = nonrandomized trials with concurrent or contemporaneous controls; IV = nonrandomized trials with historical controls; V = case series with no controls.

3 External validity rating (yes or no for each): 1 = Were the criteria for selection of patients described? 2 = Were patients included in the study adequately characterized with regard to level and completeness of SCI? 3 = Were criteria for outcomes clearly defined (e.g., timing, measurement, reliability)? 4 = Was the clinical care of patients adequately described to be able to reproduce? 5 = Were results given reported according to level of injury (minimum high cervical [C4 or above] versus low cervical [below C4]) or ventilation status (independently breathing versus ventilator-dependent)?

Evidence Table 2. Clinical Monitoring and Diagnostic Procedures^1^

Study | Design and Quality | Patient Population | Study Protocol/Interventions | Results/Outcomes
PULMONARY FUNCTION MEASURES (PFTs)
Ashba, Garshick, Tun et al., 1993 | Design: Prospective single-subject design study Quality: Internal validity ^2^ N/A External validity ^3^ 1-Y 2-Y 3-Y 4-Y 5-N/A | N = 12 (see "Note," below) Neurol. Status Time since injury: N/S Level of injury: C6-C8 Completeness of injury: Complete Pulmonary status: N/S Age: N/S Sex: 100% M Race: N/S | Comparison of subjects' ability to meet the ATS spirometry criteria for acceptability and reproducibility of FVC and FEV_1_ tests vs. their ability to meet 2 sets of requirements that were less stringent (see "Modifications 1 and 2" below). Data obtained by questionnaire regarding respiratory symptoms (chronic cough, chronic phlegm, persistent wheeze, any wheeze). Subjects also performed pulmonary function tests (described after definitions below). Acceptability definitions; 1. ATS-Must obtain > 3 acceptable efforts for FVC, with "acceptable effort" defined as "minimum exhalation time of 6 sec; must appear maximal to the technician; and must be free of nasal or mouth leaks, cough, or other problems (e.g., glottis closures)."; 2. Modification No. 1-Criteria less stringent than those of ATS were used for acceptability, whereby the no. of acceptable efforts was limited to a minimum of 2, and EBEV (extrapolated back expiratory volume) was allowed if the efforts appeared maximal.; 3. Modification No. 2-Includes efforts acceptable using ATS criteria, but efforts with EBEV and/or exhalation times of < 6 sec (but with a plateau of < 0.5 sec) were allowed if these were the only reasons for unacceptable efforts and the effort appeared maximal.; Reproducibility definition ATS-The 2 best FVCs and the 2 best FEV_1_'s must be within 5% or 100 cc, whichever is greater. Definition of back extrapolated volume ATS-Must be less than 5% or within 100 cc of FVC. Otherwise it is considered an "excessive back exhalation" or false start, causing an overestimation of FEV_1_ using this method. Pulmonary function tests:; - Baseline total lung capacity (TLC) and its subdivisions (including FEV_1_); - Minimum of 2 forced vital capacity (FVC) trials performed. The technician determined whether the efforts were acceptable by observing the subject and the volume-time displays of each FVC maneuver. If the 2 FVCs or the 2 FEV_1_'s were not reproducible (within 5% or 100 cc of each other), additional trials were performed until the subject achieved reproducibility or appeared tired. | No. of subjects achieving 2 or more acceptable efforts at performing PFT test using 3 sets of criteria (defined at left): No. of subjects achieving 2 or more reproducible efforts at performing PFT tests (FVC and FEV_1_) using 3 sets of criteria (defined at left):; 1. ATS:; 2. Modification No. 1:; 3. Modification No. 2; Correlations between age, level of injury, respiratory symptoms, and muscle fatigue and acceptability and reproducibility: Investigators reported that "among individuals with complete SCI [n = 39], spirometry acceptability and FEV_1_ reproducibility decreased with higher levels of injury . . . ." (p. 202) Age, respiratory symptoms, and muscle fatigue were not found to correlate with acceptability and reproducibility. Note: The 12 pts were the cervical-injured subset of a larger grp of 78 subjects, 39 with complete, 39 with incomplete injuries. Of the 78, 26 were in-hospital, while 52 were solicited by mail.
  1. | ATS: | 8/12 (67%)
  2. | Modification No. 1: | 11/12 (92%)
  3. | Modification No. 2 | 11/12 (92%)
  | FVC | 7/12 (58%)
  | FEV_1_ | 6/12 (50%)
  | FVC | 10/12 (83%)
  | FEV_1_ | 9/12 (75%)
  | FVC | 10/12 (83%)
  | FEV_1_ | 9/12 (75%)
RADIOGRAPHY
Bain, Bodley, Jamous et al., 1995 | Design: Prospective diagnostic test study Quality: Internal validity N/A External validity 1-Y 2-N 3-Y 4-N/A 5-N | N = 60 Neurol. status Time since injury: Investigations "mostly" performed within 2 wks of injury Level of injury: 31 pts had cervical injuries, 29 thoracic or thoraco-lumbar; no further information provided Completeness of injury: 45 pts had "complete" lesions, 15 "incomplete"; no further information provided Pulmonary status: N/S Age: Mode, 22 (range:17-66) Sex: 83% M, 17% F Race: N/S | Chest radiograph (X-ray) vs. computerized tomography (CT) Study assessed the relative accuracy of the chest X-ray and CT in assessing lung changes in pts with acute spinal injuries, using CT as gold standard X-ray taken with pt in supine position and assessed blindly, on two separate occasions, by both a physician and a radiologist; correlated with CT findings each time. Any abnormalities observed on X-ray classified as:; - Small effusion - apical cap only or < 2 mm lateral fluid thickness; - Medium effusion - apical cap and/or 2-7 mm lateral fluid thickness; - Large effusion - apical cap and/or > 7 mm lateral fluid thickness; CT scans taken through the fracture level and at three additional levels (level of the right hemidiaphragm, 5 cm above this level, and through the arch of the aorta). Any abnormalities observed classified as:; - Small effusion - < 5 mm fluid thickness; - Medium effusion - fluid level up to the level of the posterior longitudinal ligament (PLL); - Large effusion - fluid level above the level of the PLL | No. of pts for whom chest X-ray diagnosis was normal: 19/60 (32%) No. of pts for whom CT diagnosis was normal: 12/60 (20%) Agreement of interpretation between chest X-ray and CT (using results of second viewing); - No. of cases in which X-ray and CT results agreed precisely (including on the degree of abnormality, if any): 12/60 (20%); - No. of cases in which X-ray underestimated the changes demonstrated on CT: 35/60 (58%); - No. of cases in which X-ray overestimated the changes demonstrated on CT: 13/60 (22%); No. of pts with cervical-level injuries and no chest trauma who nonetheless showed lung changes on CT: 13/20 (65%) No. of pts with thoracic injuries who had no significant lung changes on CT: 2/29 (7%)
Roth, Lu, Primack et al., 1997 The 52 pts described in this article are the same as those described in Roth, Nussbaum, Berkowitz et al., 1995 | Design: Diagnostic test study Quality: Internal validity N/A External validity 1-Y 2-Y 3-Y 4-N 5-Y | N = 52 (44 with cervical injuries [C4-C8], 8 with thoracic injuries [T1-T6]) Neurol. status Time since injury: mean, 77 days (between injury and PTF testing); < 6 mos for all Level of injury: 13% C4, 15% C5, 35% C6, 19% C7, 2% C8, 10% T1, 6% T2-T6 Completeness of injury: Complete motor traumatic cervical or thoracic injuries (per ASIA criteria); 81% also had complete sensory injuries Pulmonary status: All pts had "full, spontaneous ventilation." None had open tracheostomies or acute pneumonia at time of testing (though 42% had required tracheostomies and 40% had had pneumonia before enrolling in study) Age: Mean 30 (range:16-60) Sex: 79% M, 21% F Race: N/S | Medical records reviewed and pts interviewed to obtain clinical information. Pts then given neurological examination and pulmonary function tests (PFTs). PFTs performed < 5 days after neurological examination. Neurological examination (performed by 1 of 3 trained examiners):; 1. Assessed directly-; - Completeness of sensory injury; - Limb muscle strength; - Limb muscle tone (measured by Ashworth tone rating scale, used to rate severity of spasticity); 2. Assessed indirectly-; - Chest wall muscle strength (assumed to be related to injury level); - Chest wall muscle tone (estimated by tone in the limbs); For PFTs, pts were seated upright. Three trials of PFTs performed, with maximum results of the 3 attempts being recorded. PFTs performed:; - Vital capacity (VC); - Forced expiratory volume in 1 sec (FEV_1_); - FEV_1_/VC ratio; - Inspiratory capacity; - Expiratory reserve volume; - Total lung capacity (TLC); - Functional residual capacity; - Residual volume (RV); - RV/TLC ratio | Correlation between level of injury and PFTs: Level of injury was found to be significantly correlated with ERV (and % pred. ERV), RV/TLC, and negative inspiratory pressure; it was not significantly correlated with VC, FEV_1_, FEV_1_/VC, IC, TLC, FRC, RV, or PEP. Correlation between muscle tone ratings and PFTs: Significant correlations were found between tone ratings and negative inspiratory pressure, but not between tone ratings and any of the other PFTs. Investigators surmised that "muscle strength may be a more important factor than muscle tone in determining pulmonary function in spinal cord-injured patients and that both strength and tone are closely related to negative inspiratory pressure" (p. 262). Correlation between level of injury and VC (and % pred. VC) (Spearman's correlation analysis): There were no significant correlations between level of injury and VC or % pred. VC. Correlation between level of injury and FEV_1_ (and % pred. FEV_1_) (Spearman's correlation analysis): There were no significant correlations between level of injury and FEV_1_ or % pred. FEV_1_. Correlation between negative inspiratory pressure and ERV, % pred. ERV, RV/TLC, and PEP (linear regression analysis): There were significant correlations between negative inspiratory pressure and all 4 of the measurements below. Other outcomes reported: Correlation between negative inspiratory pressure and other PFTs (not listed above) Correlation between limb muscle strength and PFTs Correlation between Ashworth scale tone ratings (of limb muscle tone) and PFTs Correlation between Ashworth scale tone ratings and level of injury No. of pts with each Ashworth scale tone ratings of 1, 2, 3, or 4 Correlation between VC and 9 other PFTs (from 1995 study)
  | C4 (n = 7) | C5 (n = 8) | C6 (n = 18) | C7 (n = 10)
  VC (L) % pred. VC | 1.6 35 | 1.8 39 | 2.0 39 | 2.0 45
  | C4 (n = 7) | C5 (n = 8) | C6 (n = 18) | C7 (n = 10)
  FEV_1_ (L) % pred. FEV_1_ | 1.5 39 | 1.7 43 | 1.7 42 | 1.8 48
  ERV % pred. ERV RV/TLC PEP | R^2^ 0.13 0.14 0.09 0.19 | P-value 0.02 0.02 0.06 < 0.01
Ryan, Klein, and Bongard, 1993 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-N | N = 13 (the cervical-injured pts of a larger group of 24, 10 with thoracic, 1 with lumbar injuries) Neurol. status Time since injury: N/S, but study covered a 9-yr period Level of injury: C2-C7 Completeness of injury: N/S Pulmonary status: N/S Age: 35 (range:19-76) (all pts) Sex: 96% M, 4% F (all pts) Race: N/S | Retrospective chart review to determine prevalence of injuries associated with SCI that had been overlooked at admission. | No. of pts with overlooked injuries: 6/13 (46%); - No. with pulmonary injuries: 3/6 (50%); - No. with spinal injuries: 3/6 (50%); No. and types of injuries:; - Pulmonary: 2 pneumothorax, 1 paralyzed hemidiaphragm (1 injury per pt); - Spinal: 1 C4 fracture, 1 C5-C6 fracture, 1 C5-C6 subluxation (1 injury per pt); Length of time to identify overlooked injuries:2 days for 3/3 (100%) pulmonary injuries; 5/6 (83%) of all overlooked injuries; the 6th injury (C5-C6 subluxation) was detected 30 days after injury when the patient re-presented with clonus after discharge. Investigators reported that "in this case, the spinal injury was the missed injury" (p. 372). Other outcomes reported: Mortality Average Glasgow Coma Scale score Mean Revised Trauma Scores Length of hospital stay Need for surgery
Scher, 1982 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-N 2-N 3-N 4-N 5-N | N =50 Neurol. status Time since injury: N/S, but all pts had acute injuries Level of injury: N/S, but all pts had tetraplegia Completeness of injury: 60% complete, 40% incomplete Pulmonary status:N/S Age:N/S Sex: N/S Race: N/S | Retrospective survey to determine no. of pulmonary lesions (not defined) that could be ascertained by chest radiography. | Pulmonary complications; - No. (and %) of pts who had chest lesions ascertainable by chest radiography: - All pts -14/50 (28%) - With complete injuries -12/30 (40%) - With incomplete injuries -2/20 (10%) Mortality; - No. (and %) of pts who died: - All pts -7/50 (14%) - With complete injuries -6/30 (20%) - With incomplete injuries -1/20 (5%)
SWALLOWING STUDY
Kirshblum, Johnston, Brown et al, 1999 | Design: Retrospective case-control diagnostic test study Quality: Internal validity Level V External validity 1-Y 2-Y 3-Y 4-Y 5-Y | N =187 screened; 42 verified between Jan 1994 and Dec 1997 Neurol. Status Time since injury: N/S, but all pts had acute injuries Level of injury: Motor level: C2 and above 5.4% C3 9.1% C4 13.9% C5 44.9% C6 17.1% C7 and below 9.6% Completeness of injury: 38% complete Pulmonary status: 35/187 required ventilatory support Age: 44.3; range 15-86 Sex: 156/187 83.4% men Race: N/S | Study sought to determine incidence of dysphagia and the positive predictive value of a positive screen for dysphagia. All patients underwent a bedside swallowing evaluation at admission to rehabilitation hospital (test of oral-motor strength, range of motion of the tongue and lips, ability to swallow on command, a dry swallow, trial swallow with solids and liquids, and/or a swallow with adjusting of the position of the head as tolerated). Patients with a positive screen (delay in initiation of the swallow, wet voice quality, frank coughing) (n=42) underwent a videofluoroscopic swallowing study (VFSS). VFSS was considered positive if it demonstrated poor pharyngeal stripping action, sluggish or inefficient opening of the cricopharyngeus, excessive pooling in the piriform sinus, delayed laryngeal elevation, or frank penetration or aspiration. Multiple logistic regression was used to identify possible predictors of dysphagia. Possible antecedents of dysphagia were recorded from the medical record including previous history of spine surgery, surgical approach and technique, tracheostomy and ventilator status, neurologic level of injury, ASIA impairment classification, orthosis, etiology of injury, age, and gender. | Proportion of patients with symptoms of dysphagia on screening at admission: 22.5% (42/187) Proportion of patients with dysphagia confirmed by VFSS: 73.8% (31/42) Significant independent predictors of risk for dysphagia: Tracheostomy with mechanical ventilation (p < .001) Spinal surgery by anterior cervical approach (p < .016) Older age (p < .028) Other variables analyzed had no significant association with dysphagia. The combination of tracheostomy at rehabilitation admission and anterior surgical approach had an extremely high rate of dysphagia (48%).

1 See Abbreviations Used in Evidence Tables (preceding these tables) for a list of abbreviations, acronyms, and symbols.

2 Internal validity rating (Levels I-V): I = Large randomized trials with clear-cut results (and low risk of error); II = small randomized trials with uncertain results (and moderate to high risk of error); III = nonrandomized trials with concurrent or contemporaneous controls; IV = nonrandomized trials with historical controls; V = case series with no controls.

3 External validity rating (yes or no for each): 1 = Were the criteria for selection of patients described? 2 = Were patients included in the study adequately characterized with regard to level and completeness of SCI? 3 = Were criteria for outcomes clearly defined (e.g., timing, measurement, reliability)? 4 = Was the clinical care of patients adequately described to be able to reproduce? 5 = Were results given reported according to level of injury (minimum high cervical [C4 or above] versus low cervical [below C4]) or ventilation status (independently breathing versus ventilator-dependent)?

Evidence Table 3. Drug Therapies^1^

Study | Design and Quality | Patient Population | Study Protocol/Interventions | Results/Outcomes
BRONCHODILATORS
Almenoff, Alexander, Spungen et al., 1995 Possible overlap with DeLuca, Grimm, Lesser et al., 1999 and Singas, Grimm, Almenoff et al., 1999 | Design: Single-subject design clinical trial Quality: Internal validity ^2^ Level V External validity ^3^ 1-Y 2-Y 3-Y 4-Y 5-N | N= 25 Neurol. status Time since injury: 11 ± 2 (SEM) yrs (chronic) Level of injury: Cervical Completeness of injury: 24% complete, 76% incomplete (complete motor and sensory loss, 6 pts; complete motor and incomplete sensory loss, 17 pts; incomplete motor and sensory loss, 2 pts) Pulmonary status: 28% with dyspnea at rest, 72% without; no pts with evidence of respiratory tract infections or other acute pulmonary symptoms; none reporting history of asthma or allergies Age: 43 Sex: 100% M Race: N/S | Prospective test conducted to determine if "administration of a cholinergic antagonist alters resting airway tone." A single group of pts were given 1 dose of aerosolized 72 µg ipratropium bromide (4 puffs), inhaled via a spacer device. With pts seated upright in wheelchairs, spirometric values were measured (using dry rolling seal spirometer) once before and 45 min after pt given ipratropium bromide. | FEV_1_:; - No. (and percentage) of pts achieving 12% improvement from pre- to post-bronchodilator: 12/25 (48%); - Mean improvement from pre-to post-bronchodilator (only p-value reported): p = 0.0036; FVC:; - No. (and percentage) of pts achieving 12% improvement from pre- to post-bronchodilator: 12/25 (48%); - Mean improvement from pre-to post-bronchodilator (only p-value reported): p = 0.0084
DeLuca, Grimm, Lesser et al., 1999 Possible overlap with Almenoff, Alexander, Spungen et al., 1995 and Singas, Grimm, Almenoff et al., 1999 | Design: Prospective single-subject design clinical trial Quality:Internal validity Level III External validity 1-Y 2-Y 3-Y 4-Y 5-Y | Neurol. status Time since injury: Mean, 10 yrs (range:2-30) Level of injury: 4% C4, 24% C5, 56% C6, 16% C7 Completeness of injury: 28% complete injury, 72% incomplete injury Pulmonary status: No subjects required mechanical ventilation; all had "previously demonstrat[ed] airway hyperreactivity to methacholine or histamine"; none reported history of asthma, allergies, or recent respiratory tract infections or other acute pulmonary symptoms Age: 40 Sex: 100% M Race: N/S | Preventive test to determine whether or not pre-treatment with a beta_2_-agonist (metaproterenol sulfate) to relax airway smooth muscle would reduce airway hyperresponsiveness from either inhaled methacholine or inhaled histamine. Experimental: Nebulized metaproterenol sulfate, 2.5 mL of a 0.6% solution, via nebulizer with flow rate of 8 L/min; not administered on initial study day, but given 1x on second study day (< 2 wks later), 25 min before administration of methacholine or histamine Group 1: Inhaled methacholine, dose ranging from 0.025 to 25 mg/mL, with concentration being increased logarithmically (0.025, 0.25, 2.5, 10, and 25 mg/mL) until either PC_20_ (defined at right) or maximal concentration of methacholine reached; administered twice, once on initial study day and once (< 2 wks later) after metaproterenol administered (n = 9; see note below) (Note: Subjects who used baclofen or oxybutynin as long-term therapies were not given methacholine.) Group 2: Inhaled histamine, dose ranging from 0.025 to 25 mg/mL, with concentration being increased logarithmically (0.025, 0.25, 2.5, 10, and 25 mg/mL) until either PC_20_ (defined at right) or maximal concentration of histamine reached; administered twice, once on initial study day and once (< 2 wks later) after metaproterenol administered (n = 16) On initial study day, subjects performed 5 slow inhalations of aerosolized normal saline solution from functional residual capacity (FRC) to total lung capacity (TLC). All subjects instructed not to hold their breath at TLC and to exhale slowly. Normal saline solution was administered via a nebulizer containing 4 mL of solution driven by air at a flow rate of 8 L/min with an output of 0.35 mL/min. On initiation of each breath, nebulization was achieved by manual occlusion of a thumbport for approximately 5 sec. Subsequently, by use of same methods, nonresponders to normal saline solution were given increasing concentrations of methacholine or histamine until either PC_20_ (defined at right) or maximal concentration of methacholine or histamine were reached. Subjects returned within 2 wks of initial test and were given nebulized metaproterenol sulfate; 25 min later, they were given either methacholine or histamine using same methods as were used in initial test. With subjects seated in wheelchairs, spirometry was performed 2 min after each administration of methacholine or histamine, or sooner if subjects experienced cough or chest tightness. Spirometry was performed again 20 min after administration of metaproterenol sulfate. | Change in "provocative concentration of methacholine or histamine that caused a 20% decrease in FEV_1_" (PC_20_): Administration of metaproterenol sulfate reduced methacholine- and histamine-induced bronchoconstriction significantly. It caused a 20% decrease in FEV_1_ (PC_20_) values (geometric mean) from 1.01 ± 2.76 (SD) to 19.34 ± 6.24 mg/mL for methacholine and from 2.29 ± 2.26 to 18.86 ± 5.93 mg/mL for histamine (p < 0.05, both comparisons). Correlation between PC_20_ values and baseline FEV_1_ percent: Investigators found no correlation between PC_20_ values for individual subjects and % improvement in FEV_1_ after inhalation of metaproterenol sulfate and between PC_20_ values and baseline FEV_1_ %.
Dicpinigaitis, Spungen, Bauman et al., 1994 | Design: Prospective concurrent cohort comparison Quality: Internal validity Level V External validity 1-Y 2-N 3-Y 4-Y 5-N | N = 14 Neurol. status Time since injury: 17 ± 9 yrs, baclofen grp; 9 ± 7 yrs, no-baclofen grp Level of injury: 14% C4-C5; 57% C5-C6; 29% C6-C7 Completeness of injury: N/S Pulmonary status: All were without respiratory complaints or evidence of recent or current infection at time of study Age: 38 (range: 23-57) Sex: 100% M Race: N/S | Test to determine if chronic baclofen treatment inhibits airway hyperresponsiveness caused by inhaled methacholine. Experimental: Baclofen, 30-120 mg/day for > 2 yrs (range of use: 2-20 yrs) (n = 6) Control: No-baclofen (n = 8) (see "Note" below) Subjects inhaled 5 breaths from FRC to TLC of saline solution, followed by progressively increasing concentrations of methacholine (0.025, 0.25, 2.5, 10, and 25 mg/mL) administered via a nebulizer. Nebulizer was driven by air at a flow rate of 8 L/min. On initiation of each breath, nebulization was achieved by manual occlusion of a thumbport. Spirometry was performed 5 min after inhalation of saline and after each concentration of methacholine, or sooner if subject experienced dyspnea or chest tightness. Test Drug: Aerosolized methacholine, with concentration increased (0.025, 0.25, 2.5, 10, 25 mg/mL) until either PC_20_ (defined at right) or maximal concentration (25 mg/mL) were reached Spirometry was performed before bronchodilation and 5 min after inhalation of saline and after bronchodilation with each incremental concentration of methacholine. Note: 1 pt in no-baclofen grp took 5 mg/day of prazosin, which is reported to have bronchodilator activity after oral administration. | Mean "concentration of provocative agent causing a decrease in FEV_1_ by 20%" (PC_20_): Mean PC_20_ for the baclofen grp was significantly higher than that for the no-baclofen grp (p = 0.001), indicating that chronic baclofen therapy is effective in inhibiting bronchial hyperresponsiveness. Values were as follows: Note: For subjects not responding to 25 mg/mL of methacholine, a PC_20_ value of 25 was used in the calculation of mean PC_20_. No. of pts in baclofen grp with positive or negative challenge tests to methacholine, where "positive challenge" was defined as PC_20_ < 8 mg/mL: Correlation between values of PC_20_ and either dosage or duration of baclofen therapy: No correlations found for either comparison Other outcomes reported: Mean FEV_1_ (% pred.) Mean FVC (% pred.) Mean FEV_1_/FVC
  Baclofen: 15.0 ± 9.1 (SD) mg/mL No-baclofen: 1.42 ± 1.60
  Baclofen (33%) | 2/6
  No-baclofen (100%) | 8/8
Fein, Grimm, Lesser et al., 1998 | Design: Prospective single subject design clinical trial Quality:Internal validity Level V External validity 1-Y 2-Y 3-Y 4-Y 5-N | N = 15 Neurol. status Time since injury: 14 yrs (range:3-31) Level of injury: C4 7%, C5 40%, C6 20%, C7 33% Completeness of injury: Complete, 33%; incomplete, 67% Pulmonary status: N/S, but all free of recent or active pulmonary infections; baseline mean FEV_1_, 2.3; baseline mean FVC, 2.8 Age: 43 (range: 24-65) Sex: 100% M Race: N/S | Tested effectiveness of ipratropium bromide for preventing or reducing airway hyper-reponsiveness to histamine Experimental: Inhaled ipratropium bromide, 72 µg (4 puffs), administered via metered-dose inhaler with attached spacer device Test Drug: Inhaled histamine diphosphate, dose ranging from 0.025 to 25 mg/mL, with concentration being increased logarithmically (0.025, 0.25, 2.5, 10, and 25 mg/mL) until either PC_20_ (provocative concentration of histamine that caused a 20% decrease in FEV_1_) or maximal concentration of histamine reached; administered twice, once on initial study day and once (< 30 days later) 30 min after ipratropium bromide was administered Subjects performed 5 slow inhalations (inspiratory time, 5 sec) of saline solution or histamine from functional residual capacity (FRC) to total lung capacity (TLC) All instructed not to hold their breath at TLC and to exhale slowly (time between each inhalation, approx. 10 sec). Normal saline solution or histamine was administered via a nebulizer. Test was terminated (by inhalation of an unspecified beta_2_-agonist) when either FEV_1_ decreased 20% or more from baseline or maximal concentration of histamine was reached. Subjects who responded to histamine returned within 30 days of initial test and were given aerosolized ipratropium bromide; 30 min later, they were given aerosolized histamine using same methods as were used in initial test. Spirometry performed before histamine administered and 2-3 min after each set of 5 inhalations (or sooner if pt experienced dyspnea or chest tightness). Spirometry also performed before and after bronchodilation. | Investigators reported that "PC_20_ values were not significantly different before and after administration of ipratropium bromide, administered at a dosage that completely blocks methacholine responsiveness" (p. 53). No. of pts with significant response to histamine (defined as PC_20_ < 8 mg/mL):; - Histamine alone: 12/15 (80%) pts; - Histamine after pretreatment with ipratropium bromide: 12/15 (80%) pts (same pts as before, with some within-subject variability); Difference in mean PC_20_ values pre- to post-treatment with bronchodilator (responders only, n = 12) (expressed as geometric mean): There was no significant difference in PC_20_ from pre- to post-treatment with ipratropium bromide. Mean PC_20_ for responders (n = 12) vs. nonresponders (n = 3) to histamine only: Difference between mean values (arithmetic and geometric) for PC_20_ before and after treatment with bronchodilator (responders only): There were no significant differences in arithmetic mean values for PC_20_ from pre- to post-treatment (p > 0.05) or in geometric mean values (p > 0.05). Other outcomes reported: Mean FVC (% pred.) Mean FEV_1_ (% pred.) FEV_1_/FVC
  | Pre-bronch. | Post-bronch.
  Geo. mean: | 1.27 | 1.50
  | Responders | Nonresponders
  Geo. mean | 1.27 | 25
  | Pre-bronch. | Post-bronch.
  Arith. mean | 1.94 ± 1.67 | 2.97 ±2.24
  Geo. mean | 1.27 | 1.50
Grimm, DeLuca, Lesser et al., 1997 | Design: Prospective concurrent cohort study Quality: Internal validity Level III External validity 1-N 2-N 3-N 4-Y 5-N | N = 24 Neurol. status Time since injury: 13 yrs (range: 2-30) Level of injury: C4 4%, C5 29%, C6 46%, C7 21% Completeness of injury: N/S Pulmonary status: No pts reported recent or active pulmonary infections; none had preinjury history of pulmonary disease or respiratory symptoms Age: 41 (range: 23-64) Sex: 100% M Race: N/S | Test to determine if chronic baclofen treatment inhibits airway hyperresponsiveness caused by inhaled histamine. Experimental: Baclofen, mean of 66 mg/day (range: 30-160) for > 1 yr (range: 1-15) (n = 14) Control: No-baclofen (n = 10) Subjects inhaled 5 breaths (inspiratory time, 5 sec) from FRC to TLC of saline solution, followed by progressively increasing concentrations of histamine (0.025, 0.25, 2.5, 10, and 25 mg/mL) administered via a nebulizer. All instructed not to hold their breath at TLC and to exhale slowly (time between each inhalation, approx. 10 sec). Nebulizer containing 4 mL of solution was driven by air at a flow rate of 8 L/min (output of 0.35 mL/min). On initiation of each breath, nebulization was achieved by manual occlusion of a thumbport. Histamine administered until PC_20_ (defined below) or 25 mg/mL reached. Pts with significant response to histamine immediately inhaled a beta_2_-agonist (not identified). Spirometry performed before histamine administered and 2-3 min after inhalation of saline and each concentration of histamine, or sooner if subject experienced dyspnea or chest tightness. Test drug: Aerosolized histamine, with concentration increased (0.025, 0.25, 2.5, 10, and 25 mg/mL) until either PC_20_ (concentration of provocative agent causing a decrease in FEV_1_ by 20%) or maximal concentration (25 mg/mL) were reached | No. of pts with significant bronchoconstrictor response to histamine (defined as PC_20_ < 8 mg/mL): Mean PC_20_ (concentration of histamine causing a 20% decrease in FEV_1_) of responders: There were no significant differences in mean PC_20_ between responders (n = 11/14) in the baclofen grp and those (n = 8/10) in the no-baclofen group (p > 0.05). Means (arithmetic) were as follows: Note: For subjects not responding to 25 mg/mL of histamine, a PC_20_ value of 25 mL was used in the calculation of mean PC_20_. Mean PC_20_ of combined responders/ and nonresponders: There were no significant differences between the 2 grps. Means (arithmetic) were as follows: Correlations between PC_20_ values and either dosage or duration of baclofen therapy: No significant correlations observed for either comparison. Other outcomes reported: FEV_1_ (% pred.) FVC (% pred.) FEV_1_/FVC
  Baclofen: 11/14 (78%) No-baclofen: 8/10 (80%)
  Baclofen: 2.91 ± 2.3 (SD) mg/mL No-baclofen: 2.18 ± 1.9
  Baclofen: 6.69 ± 7.8 No-baclofen: 6.74 ± 9.8
Singas, Grimm, Almenoff et al., 1999 Possible overlap with DeLuca, Grimm, Lesser et al., 1999 and Almenoff, Alexander, Spungen et al., 1995 | Design: Prospective non-randomized clinical trial Quality: Internal validity Level III External validity 1-Y 2-Y 3-Y 4-Y 5-Y | N = 25 Neurol. Status Time since injury (yrs): Oxybutynin-treated methacholine grp, 19; controls for that grp, 18. Oxybutynin-treated histamine grp, 14; controls for that grp, 10. Level of injury: 12% C4, 16% C5, 48% C6, 24% C7 Completeness of injury: 40% complete, 60% incomplete Pulmonary status: No subjects had history of pulmonary disease or respiratory symptoms, recent viral syndrome or respiratory tract infection, and seasonal allergy Age: Oxybutynin-treated methacholine grp, 46; controls for that grp, 47. Oxybutynin-treated histamine grp, 39; controls for that grp, 38. Sex: 100% M Race: N/S | Test to determine if chronic oxybutynin chloride treatment inhibits airway hyperresponsiveness caused by either inhaled methacholine or inhaled histamine. All controls were age-matched with oxybutynin-treated subjects and were not taking (had not been taking) oxybutynin. Half of subjects in the experimental grp and half of those in the control grp were challenged with methacholine; the other half of the experimental and control grps were challenged with histamine. Experimental: Inhaled oxybutynin chloride, 10-15 mg/day for > 1 yr (av. range of use: 1-15 yrs) (n = 12) Control: Non-oxybutynin users (n = 13) Subjects performed 5 slow inhalations (inspiratory time, 5 sec) of saline solution, methacholine, or histamine from functional residual capacity (FRC) to total lung capacity (TLC). All instructed not to hold breath at TLC and to exhale slowly (time between each inhalation, ≈ 10 sec). Normal saline solution, methacholine, or histamine were administered via a nebulizer containing 4 mL of solution driven by air at a flow rate of 8 L/min with an output of 0.35 mL/min. On initiation of each breath, nebulization was achieved by manual occlusion of a thumbport. Spirometry was performed 2-3 min after each set of 5 inhalations (saline, histamine, or methacholine), or sooner if subject experienced cough or chest tightness. | Mean change in "concentration of provocative agent causing a decrease in FEV_1_ by 20%" (PC_20_):; - Methacholine: Investigators reported that "the bronchoconstrictor effects of methacholine were blocked by oxybutynin chloride" (p. 279). Oxybutynin/methacholine 25 mg/mL Control/methacholine 2.0 ± 1.1 (SD); - Histamine: The bronchoconstrictor effects of histamine were not blocked by oxybutynin. Oxybutynin/histamine 3.4 ± 2.9 mg/mL Control/histamine 3.4 ± 1.4; - No. of subjects with significant bronchoconstrictor responses (defined as PC_20_ < 8 mg/mL): 6/12 (50%) of the oxybutynin grp (all histamine subjects) and all 13 subjects (100%) of the control grp had significant bronchoconstrictor responses (defined above).; Differences between responders and nonresponders with respect to spirometry parameters (above), level of injury, duration of injury, or smoking status: No significant differences were found between responders and nonresponders for these variables (p-values not reported).
| | | Test Drug 1: Aerosolized methacholine, with concentration increased (0.025, 0.25, 2.5, 10, 25 mg/mL) until either PC_20_ (defined at right) or maximal concentration (25 mg/mL) were reached (n = 6) Test Drug 2: Aerosolized histamine diphosphate, with concentration increased (0.025, 0.25, 2.5, 10, 25 mg/mL) until either PC_20_ (defined at right) or maximal concentration (25 mg/mL) were reached (n = 6)
Spungen, Dicpinigaitis, Almenoff et al., 1993 | Design: Prospective single subject design clinical trial Quality: Internal validity Level III External validity 1-N 2-N 3-Y 4-Y 5-N | N = 34 Neurol. status Time since injury: Mean, 11.8 yrs (range:1-37 yrs) Level of injury: N/S; all pts quadraplegic Completeness of injury: All pts had complete motor injuries; 29 (85%) had incomplete sensory injuries and 5 (15%) had complete sensory injuries Pulmonary status: Pts not ventilated Age: 45.2 Sex: 100% M Race: N/S | Inhaled metaproterenol sulfate (0.6%), 2.5 mL Spirometry performed before and after bronchodilation | Percentage of pts who were responders to bronchodilator, where "response" defined as an improvement in FEV_1_ of > 12% post-bronchodilator (broken down according to smoking status of pts): 5/12 (42%) of nonsmokers and 9/22 (41%) of smokers were responders Pulmonary function tests (mean pre-bronchodilator, post-bronchodilator, and % change scores reported; all results broken down according to smoking status of pts [12 non-smokers, 22 smokers]):; - FEV_1_; Results below are reported as mean ± SEM. R = responders; NR = nonresponders.; - FVC; Other outcomes reported: Pulmonary function tests (mean pre-bronchodilator, post-bronchodilator, and % change scores reported; all results broken down according to smoking status of pts [12 non-smokers, 22 smokers]):; - FEV_1_/FVC; - Forced expiratory flow between 25% and 75% of the exhaled volume (FEF_25-75_); Correlation between level of cervical spinal injury and FVC, FEV_1_, and FEF_25-75_ (broken down according to smoking status of pts)
  Nonsmokers
  (n) | Pre | Post | % Change
  R (5) | 2.30 ± 0.40 | 2.63 ± 0.43 | 16 ± 3
  NR (7) | 2.41 ± 0.23 | 2.42 ± 0.23 | < 1 ± 1
  Smokers
  (n) | Pre | Post | % Change
  R (9) | 2.11 ± 0.31 | 2.33 ± 0.34 | 16 ± 2
  NR (13) | 2.50 ± 0.22 | 2.60 ± 0.23 | 4 ± 1
  Nonsmokers
  (n) | Pre | Post | % Change
  R (5) | 2.71 ± 0.45 | 2.91 ± 0.41 | 10 ± 5
  NR (7) | 2.68 ± 0.27 | 2.69 ± 0.26 | < 1 ± 1
  Smokers
  (n) | Pre | Post | % Change
  R (9) | 2.84 ± 0.35 | 2.98 ± 0.36 | 6 ± 2
  NR (13) | 3.23 ± 0.23 | 3.35 ± 0.21 | 5 ± 2
PNEUMOCOCCAL VACCINATION
Darouiche, Groover, Rowland et al., 1993 | Design: Prospecting uncontrolled clinical trial Quality: Internal validityLevel III External validity 1-N 2-N 3-Y 4-Y 5-N | N = 80 (40 with spinal cord injury; 40 age-matched, able-bodied controls) Neurol. status Time since injury: 17/40 SCI pts (42.5%) studied within 1 yr of injury, remaining 23 (57.5%) more than 1 yr after injury Level of injury: 18/40 SCI pts (45%) quadriplegic Completeness of injury: N/S Pulmonary status: N/S Age: 50.6 (SCI grp) and 50.65 (able-bodied grp) Sex: 100% M (both grps) Race: N/S | 23-valent pneumococcal polysaccharide vaccine (IM), 0.5 mL | Mean antibody concentrations, measured pre-treatment and at 4-6 weeks; immune response to 5 pneumococcal polysaccharides (3, 4, 6A, 8, 23) of Streptococcus pneumoniae evaluated: There were no significant differences between the SCI and the control groups for this outcome. Percentage of pts responding to the 5 pneumococcal polysaccharides at 4-6 weeks (criteria for determining which pts were "responders" N/S): There were no significant differences between the SCI and the control groups for this outcome. The overall response rates were 77.5% for the SCI pts vs. 84% for the control grp. Effect of following factors on immune response (among pts with SCI only):; - Age (< 55 yrs vs. > 55 yrs); - Time since injury (< 1 yr vs. > 1 yr); - Level of injury (quadriplegia vs. paraplegia); Regarding the above outcome, investigators reported that "among SCI patients, the antibody response was generally not affected by age, time since injury, or level of lesion" (p. 1354). The only exception was that there was a higher antibody response to polysaccharide 8 in paraplegic versus quadriplegic subjects (p = 0.02). Adverse reactions to vaccination: Approximately 1/3 of all subjects had "transient mild pain or erythema at the site of vaccine injection, but none had systemic reaction to vaccination" (p. 1355).
Waites, Canupp, Edwards et al., 1998 | Design: RCT Quality: Internal validity Level I External validity 1-Y 2-Y 3-Y 4-Y 5-N | N = 91 received treatment; 4 lost to follow-up; 87 included in analysis Neurol. status Time since injury: All pts had "recent" spinal cord injury; see times for administration of study drug under "Interventions/Comparison Grps" Level of injury: Not described in detail; 47% of pts were tetraplegic Completeness of injury: 63% of pts had "complete" injuries. Inclusion criteria required pts to be classified as Frankel grade A, B, or C; number of pts in each category N/S. Pulmonary status: N/S Age: 33 (range: 16-61) Sex: N/S Race: 53% Caucasian | 23-valent pneumococcal vaccine (IM), administered 16-18 days post-injury 23-valent pneumococcal vaccine (IM), administered 4-6 months post-injury Placebo (IM), administered 16-18 days post-injury Placebo (IM), administered 4-6 months post-injury | Mean antibody concentrations, measured pre-treatment and at 1, 2, and 12 months; immune response to 5 serotypes of Streptococcus pneumoniae (3, 4, 14, 19F, 23F) evaluated: From abstract of article: "Most participants developed an immune response to at least 1 serotype that was maintained for at least 12 mos. Immune response varied according to serotype" (p. 1504). Effect of timing of vaccination (16-18 days post-injury vs. 4-6 months) on mean antibody concentrations at 1, 2, and 12 months: Investigators reported that "timing of vaccination did not influence mean antibody concentrations for any serotype (p > 0.05)" (p. 1504). Percentage of pts with a twofold or greater increase (compared to baseline) in antibody concentration for one or more serotypes at 1, 2, and 12 months: 95% of vaccinated pts (n = 41) versus 35% of placebo group (n = 46) had "twofold or greater increases in antibody concentration for at least 1 serotype when measured 2 months after vaccination (p < 0.01). After 12 mos, 93% of vaccinated persons in both groups maintained antibody concentrations twofold or greater than baseline values" (p. 1504). Adverse effects associated with vaccination: There were "some [unspecified number] naturally occurring pneumococcal infections in the placebo groups during the 12 mos after enrollment" (p. 1506). Investigators did not report if the vaccinated group had any adverse effects.
OTHER
Hart, Strauss, and Riker, 1984 | Design: Prospective single subject design clinical trial Quality: Internal validity Level III External validity 1-N 2-Y 3-Y 4-Y 5-Y | N = 22 Neurol. status Time since injury: Mean, 16 mos (range: 4-84 mos); pts described as "fully rehabilitated [quadriplegics in] chronic phase of their injury" Level of injury: 4% C4, 14% C4-5, 55% C5, 23% C5-6, 4% C6 (level described as "level of function at time of trial") Completeness of injury: Complete physiological transection of spinal cord Pulmonary status: No pts had any known contraindications to hyperbaric oxygen Age: 23 Sex: 77% M, 23% F Race: N/S | 2-yr trial of effect of hyperbaric oxygen on VC:; - Hyperbaric oxygen, given at 2 Alimentary Toxic Aleukia 2 hrs/day x 21 consecutive days in 2 different years; Pulmonary function tests (PFTs) were measured with pts in sitting positions before each trial with hyperbaric oxygen; PFTs also measured weekly after each trial (for 3 wks). Pts who desired to repeat the trial or trials were allowed to do so at least 4 wks after first trial. Trial was discontinued if pts were claustrophobic, contraindications arose during trial, or a marked decrease in VC was noted during trial. | Vital capacity:; - Mean VC (L) pre- and post-trial (and % pred.): No statistical comparisons were made.; - No. (and %) of pts who improved, showed no changed or had decrease in VC: No. (%) improved 16/22 (73%) No. (%) with no change 2/22 (9%) No. (%) with decrease 4/22 (18%); - No. of pts with significant improvement in VC (> 10% improvement in < 3 wks of treatment): 10/22 (45%); - Average time from injury to trial for pts with improvement (or decrease) in VC: 18 mos (for 16/22 pts with improvement), 15 mos (for 4/22 pts with decrease); Complications:; - No. of pts with (and type of) complications: 15 pts had increased distal spasticity but responded to antispastic medications; 8 had urinary tract infections; 5 had Grade 1 barotrauma (reddened eardrums) and required nasal spray decongestants; 2 had Grade 2 barotrauma and required both spray and by-mouth decongestants; 1 "suffered a seizure during the study and EEG revealed a left temporal focus of irritation" (p. 9); 1 developed confinement anxiety; Other outcomes reported: No. of pts requesting further trials For Year 2 pts,; - Inspiratory forces; - Expiratory forces
  | (L) (% pred.)
  Pre-trial (SD) 47% | 2.38 L (0.88)
  Post-trial | 2.60 L (0.87) 51%
Segal and Brunnemann, 1997 | Design: Prospective single subject design clinical trial Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-N 5-Y | N = 11 (cervical-injured pts of larger group of 17, 6 with thoracic or lumbar injuries) Neurol. status Time since injury: Mean, 14 yrs (range: 3-28) Level of injury: C2 9%; C4-C5 or C5 alone, 36%; C5-C6 36%; C6-C7 or C7 alone, 18% Completeness of injury: 27% complete, 73% incomplete Pulmonary status: Mean baseline FVC, 2.61 L Age: 40 (range: 26-60) Sex: 82% M, 18% F Race: N/S | 4-aminopyridine (4-AP), single oral dose of 10 mg of an immediate-release formulation Procedure Pts instructed to fast overnight prior to day of study. On study day, baseline spirometry was performed and then pt was given 10 mg of oral study medication. Spirometry was performed at 4, 6, 8, 10, 12, and 24 hrs. Best of 3 attempts were recorded at each timepoint. Pts instructed to wait 3 hrs before resuming their usual "sleep-wake cycles, levels of function, eating patterns, and daily activities." All pts were tested at the same time of day to minimize effect of circadian variability. | FEV_1_: Mean FEV_1_ increased significantly from pretreatment (2.18 L) to 6 hrs after treatment (p < 0.05); this increase remained significant 12 hrs after study med administered (p < 0.05). The maximum FEV_1_ achieved during the 24-hr period was 2.59 L. FVC: Mean FVC increased significantly from pretreatment (2.61 L) to 6 hrs after treatment (p < 0.05); this increase remained significant 12 hrs after study med administered (p < 0.05). The maximum FVC achieved during the 24-hr period was 3.05 L. MEP: Mean MEP increased significantly (by 22%) from pretreatment (52.80 cm H_2_O) to 10 hrs after treatment (p = 0.03); 12 hrs after treatment, the increase of 14% (compared with pretreatment) remained significant (p < 0.05). The maximum MEP achieved during the 24-hr period was 73.24 cm H_2_O. MIP: Mean MIP (negative pressure) increased significantly (by 20%) from pretreatment (60.26 -cm H_2_O) to 8 hrs after treatment (p = 0.06); 12 hrs after treatment, the increase of 13% (compared with pretreatment) remained significant (p < 0.05). The maximum MIP achieved during the 24-hr period was 79.17 - cm H_2_O. Investigators reported that all of the above outcomes were still numerically, if not statistically, increased at 24 hrs after treatment. Correlation between level of injury and FEV_1_ (pretreatment FEV_1_ as % of predicted FEV_1_) in pts with incomplete injuries: Investigators found a significant correlation between these 2 variables (r = −0.86, p = 0.006). Correlation between level of injury and % increase in MEP in pts with incomplete injuries: Investigators found a significant correlation between these 2 variables (r = 0.82, p = 0.012). Other outcomes reported: FEV_1_/FVC
Spungen, Grimm, Strakhan et al., 1999 | Design: Prospective single subject design clinical trial Quality: Internal validity Level III External validity 1-Y 2-Y 3-Y 4-Y 5-N/A | N = 10 Neurol. status Time since injury: Mean, 16 yrs (range, 7 to 31); inclusion criteria required pts to have sustained their injury > 1 yr before start of study Level of injury: 3 pts, C4; 7 pts, C5 Completeness of injury: All pts had complete motor tetraplegia; 4 had complete sensory and 6 had incomplete sensory SCI Pulmonary status: Pts not ventilated Age: 41 (range: 26-51) Sex: 100% M Race: N/S | Oxandrolone (PO), 20 mg per day for 1 month Pts also instructed to eat a minimum of 1 g per kg per day of protein during the treatment months | Pulmonary function tests (mean baseline, post-treatment, and within-pt differences from pre- to post-treatment (1 mo) reported for all tests):; - FVC: Mean FVC values improved significantly (p < 0.005) from baseline to post-treatment.; - FEV_1_ _:_ Mean FEV_1_ values improved significantly (p < 0.005) from baseline to post-treatment.; - Forced inspiratory vital capacity (FIVC): Mean FIVC values improved significantly (p < 0.05) from baseline to post-treatment.; - Maximal inspiratory pressure (P_i_max): P_i_max increased significantly from baseline to post-treatment (p < 0.005).; - Maximal expiratory pressure (P_e_max): P_e_max increased significantly from baseline to post-treatment (p < 0.05).; Change in subjective symptoms of resting dyspnea from pre- to post-treatment (dyspnea graded on Borg scale): Resting dyspnea was significantly reduced from pre- to post-treatment by 37 ± 28%, a half-point reduction on the Borg scale (2.0 ± 2.0 vs. 1.5 ± 2.0, p < 0.05). Mean weight gain from pre- to post-treatment (1 month): Mean weight increased significantly from 76.9 ± 18.3 kg at pre-treatment to 78.3 ± 18.9 kg post-treatment (p < 0.05). Other outcomes reported: Pulmonary function tests (mean baseline, post-treatment, and within-pt differences from pre- to post-treatment reported for all tests):; - FEV_1_/FVC; - Forced expiratory flow between 25% and 75% of the FVC (FEF_25-75_); - PEFR; Liver function tests
  Baseline | (L) Post-tx (L) | Within-pt (L)
  2.79 ± 0.95 | 2.99 ± 1.01 | 0.196 ± 0.167
  Baseline | (L) Post-tx (L) | Within-pt (L)
  2.23 ± 0.73 | 2.36 ± 0.71 | 0.122 ± 0.970
  Baseline | (L) Post-tx (L) | Within-pt (L)
  2.53 ± 0.90 | 2.71 ± 0.93 | 0.178 ± 0.187
  Baseline | (L) Post-tx (L) | Within-pt (L)
  74 ± 22 | 81 ± 24 | 7 ± 5
  Baseline | (L) Post-tx (L) | Within-pt (L)
  34 ± 29 | 39 ± 31 | 5 ± 7

1 See Abbreviations Used in Evidence Tables (preceding these tables) for a list of abbreviations, acronyms, and symbols.

2 Internal validity rating (Levels I-V): I = Large randomized trials with clear-cut results (and low risk of error); II = small randomized trials with uncertain results (and moderate to high risk of error); III = nonrandomized trials with concurrent or contemporaneous controls; IV = nonrandomized trials with historical controls; V = case series with no controls.

3 External validity rating (yes or no for each): 1 = Were the criteria for selection of patients described? 2 = Were patients included in the study adequately characterized with regard to level and completeness of SCI? 3 = Were criteria for outcomes clearly defined (e.g., timing, measurement, reliability)? 4 = Was the clinical care of patients adequately described to be able to reproduce? 5 = Were results given reported according to level of injury (minimum high cervical [C4 or above] versus low cervical [below C4]) or ventilation status (independently breathing versus ventilator-dependent)?

Evidence Table 4. Secretion Management^1^

Study | Design and Quality | Patient Population | Study Protocol/Interventions | Results/Outcomes
ROTATING BEDS
Borkowski, 1989 | Design: Retrospective historical cohort comparison Quality: Internal validity ^2^ Level IV External validity ^3^ 1-Y 2-Y 3-Y 4-Y 5-N | N = 22 Neurol. status Time since injury: N/S, but all pts treated in a neurosurgical ICU (acute) Level of injury: 13/22 pts (59%), cervical (6 pts of whom were C5-C6; also, 6 and 7 pts with cervical injuries were in the KTT and WTD groups, respectively); 9/22 pts (41%), thoracic Completeness of injury: Complete transection of cord Pulmonary status: 1 pt had pneumothorax, 2 had pulmonary contusions Age: Mean N/S (range:16-79) Sex: 68% M, 32% F Race: N/S | Retrospective survey of medical charts to compare the incidence of pulmonary complications and length of stay in an intensive care unit (ICU) between 2 groups of pts, those using a kinetic treatment table (KTT) and those using a wedge turning device (WTD). The WTD was used prior to October 1984; the KTT was used after that date. The KTT is an intensive care bed which allows immobilization of the pt and also places him/her in perpetual motion with a turning frequency of > 200 times per day. Bed construction also allows access to all areas of the body so that therapists can perform necessary care and treatment. The WTD (Stryker or Foster frame) is the traditionally used immobilization device, a device enabling 1 person to turn a pt without lifting him/her. 2 grps compared:; - KTT-treated pts (n = 11); - WTD-treated pts (n = 11) | Cervical-injured pts No. of pts requiring endotracheal intubation (pts with cervical spine injuries): 9/12 (75%) No. of pts requiring subsequent tracheostomies (pts with cervical fractures): 6/12 (50%) No. of deaths: 2/11 (18.2%) of WTD-treated pts died (1 of whom had a cervical-level injury; cause N/S); none of the 11 KTT-treated pts died All pts No. of pts requiring endotracheal intubation (combined pts): 15/22 (68.2%). A greater number of pts in the WTD grp (8/11 [72.7%]) were given this procedure than pts in the KTT grp (7/11 [63.6%]). No. of pts requiring tracheostomies: 45% of pts treated with WTD required tracheostomies vs. 27% in the KTT grp (no p-value reported). Incidence of pulmonary infection: The KTT grp had a lower incidence of pulmonary infections than did pts in the WTD grp (p < 0.05). Time on mechanical ventilation: KTT grp required less time on mechanical ventilation than did pts in the WTD grp (p < 0.05). Length of ICU stay: There were no significant differences between the 2 grps for this outcome (no p-value reported). Length of hospitalization: There were no significant differences between the 2 grps for this outcome (no p-value reported).
Green, Green, and Klose, 1980 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-N 2-N 3-Y 4-Y 5-N | N = 105 Neurol. status Time since injury: Acute Level of injury: N/S, but see "completeness of injury" Completeness of injury: 90%, quadriplegics; 10%, paraplegics Pulmonary status: N/S, except that some pts had pre-existing respiratory complications Age: Mean N/S (range:6-82, with "few patients at either extreme") Sex: "Most" males (no. N/S) Race: N/S | Kinetic bed: Retrospective review, over a 42-month period, of pts who were placed on a Roto-Rest Mark I bed. This bed allows immobilization of the pt and also places him/her in perpetual motion with a turning frequency of > 200 times per day. Bed construction also allows access to all areas of the body so that therapists can perform necessary care and treatment. Length of bed use ranged from "a few hrs in pts who died shortly after admission to several yrs in the cases of a few high cervical injured quadriplegics." | No. of pts developing respiratory complications: 2/105 (2%) developed pneumonitis or atelectasis Investigators reported that the kinetic bed led to "diminishing stasis of respiratory secretions" and "was shown to be of particular benefit to pts with significant pulmonary shunts." There also were few cases of thrombophlebitis or pulmonary embolus. Mortality; - No. (and cause) of deaths: 7/105 (7%) pts, all quadriplegics with severe multiple injuries, died from cardiopulmonary complications; - Time from admission to death: Within 1 wk following admission, 5/105 (5%); > 6 mos after admission, 2/105 (2%); all 7 were quadriplegics
Lemons and Wagner, 1994 | Design: Historical cohort comparison Quality: Internal validity Level IV External validity 1-Y 2-Y 3-Y 4-Y 5-N/A | N = 63 (see "Note" on next page) Neurol. status Time since injury: All pts had acute injuries. Though time since injury was not specified, 30 pts with complete and 33 pts with incomplete injuries spent 30 and 9 days, respectively, in ICU. Records also studied beyond acute phase (study dates: June 1986 through May 1990). Level of injury: 63% C4-C5, 37% C6-T1. Lowest functioning spinal cord segment was recorded. Completeness of injury: 48% complete, 52% incomplete. Of pts with incomplete injuries 11/33 (33%) were diagnosed with central cord injuries 4/33 (12%) with Brown-Sequard myelopathies, and 4/33 (12%) with anterior spinal cord syndromes. Pulmonary status: 39/63 pts (62%) developed respiratory complications during hospitalization immediately after their accident. 31/63 of these pts (49%) required mechanical ventilation. Age: 32 (range:14-93) Sex: N/S Race: N/S | Respiratory care protocol (including immobilization procedures) described in 2 parts:; 1. June 1986 to June 1987-Standardized respiratory protocol; 2. July 1987 through May 1990-Use of rotating bed and chest physical therapy added to standard respiratory protocol; Standardized respiratory protocol (consisted of the following, as appropriate):; - Intubation; - Mechanical ventilation; - Fiberoptic bronchoscopy; - Antibiotics; - Tracheostomy; - Supplemental humidified oxygen; - Tracheal/bronchial suctioning; - Serial spirometry; - Intermittent positive pressure breathing; - Manually assisted cough; - Bronchodilators and expectorants; - Respiratory therapist assessment; - Deep venous thrombosis prophylaxis; - Ventilatory weaning; - Extubation; The above respiratory protocol also included immobilization of cervical injuries by; - Cervical traction; - Cervical orthosis, or; - Surgery; Therapies added after June 1987:; - Rotating bed, with pt in cervical traction until fracture was stabilized; - Chest physical therapy, with pt in prone position, after fracture was stabilized; Pts were also mobilized after fracture was stabilized. Predictors considered: Age, preexisting cardiac or pulmonary disease, significant accompanying cranial or thoracoabdominal injuries, level of injury, completeness of injury, return of lower extremity deep tendon reflexes Analytic method(s): Nonparametric tests: Fisher exact test, Mann-Whitney U test, rank analysis of covariance Note: Results for 2 additional pts were excluded from analysis because they suffered high cervical myelopathy with no significant return of diaphragmatic function. | Comparison of early (n = 13) vs. late periods (n = 50) (standardized protocol vs. rotating bed and chest percussiontherapy) for; - Incidence of pneumonia: Pts treated with rotating bed and chest percussion therapy (later period) had somewhat fewer episodes of pneumonia than pts not receiving those therapies (early period) (p = 0.043).; - No. of days in ICU: Pts treated with rotating bed and chest percussion therapy (later period) had somewhat fewer days in the ICU than pts not receiving those therapies (early period) (p = 0.032).; - Incidence and duration of respiratory insufficiency: There were no significant differences in the incidence or duration of respiratory insufficiency in pts managed in the early vs. the late periods (p > 0.50).; Respiratory complications; - No. (and %) of pts developing respiratory complications during hospitalization immediately after injury: 39/63 (62%); - No. of pts with complete myelopathy developing respiratory complications: 28/30 (93%); - No. pts with incomplete myelopathy developing respiratory complications: 11/33 (33%); No. of pts who required readmission to hospital after acute hospitalization: 3/63 (5%) No. of deaths (and causes) during acute hospitalization: 3/63 (5%) pts died from respiratory complications. Frequency of respiratory complications:; - No. of cases of - Respiratory insufficiency requiring MV: 31/95 (33%) - Pneumonia treated with a full course of antibiotics: 34/95 (36%) - Lobar atelectasis requiring therapeutic bronchoscopy: 28/95 (29%) - Pulmonary embolism: 2/95 (2%); - No. of respiratory complications occurring during acute hospitalization: 95 cases; Predictors of frequency or severity (estimated by no. of days on MV and no. of days in ICU for pulmonary-related problems) of respiratory complications: Overall; - Greater severity of injury (p < 0.004); In pts with complete injuries; - Comorbid medical disease (p = 0.11); In pts with incomplete injuries; - Areflexia at 24 hrs post-injury (p < 0.05); - Less distal neural function (p < 0.05); - Comorbid cardiopulmonary disease (p < 0.05); - Associated major injuries (p < 0.05); Correlation between level of injury and incidence or severity of respiratory complications: Level of injury failed to correlate significantly with incidence or severity of respiratory complications (p > 0.12). Other outcomes reported: Severity of respiratory complications:; - No. of days in ICU; - No. of days on mechanical ventilation
ASSISTED COUGH
Jaeger, Turba, Yarkony et al., 1993 Possible overlap with Wang, Jaeger, Yarkony et al., 1997 | Design: Prospective single-subject design clinical trial Reports preliminary results Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-Y 5-Y | N = 24 (see "Note" at right) Neurol. status Time since injury: Mean, 20 mos (range: 1-86 mos); 14/24 pts (58%) < 1 yr; population described as "both inpatients and outpatients" Level of injury: 8% C4, 33% C5, 42% C6, 17% C7 Completeness of injury: Frankel grades: A, 13/24 pts (54%); B, 8/24 (33%); C, 2/24 (8%); D, 1/24 (4%) Pulmonary status: N/S, though all pts described as "tetraplegic" Age: 35 (range:22-68) Sex: 79% M, 21% F Race: N/S | Compared effectiveness of 3 types of coughs for increasing peak expiratory flow rates (PEFRs) in a single group of pts:; - Voluntary (with no assistance); - Manual assistance; - Electrical stimulation of abdominal muscles; The 3 types of cough were alternately measured (i.e., voluntary, manual assistance, electrical stimulation) for 5 repetitions each (15 measurements/pt). From 30 secs to 1 min of rest were given between coughs, depending on pt's ability and comfort level. Measurements were taken with pts lying in a flat bed. | Note: For some outcomes, data from only 14/24 pts (58%) were included in the analyses. Data from 10/24 pts (42%) were excluded from analysis because 5 pts were unable to tolerate the electrical stimulation and 5 were unable to obtain sufficiently strong muscle contractions from electrical stimulation. Mean PEFRs of; - Pts who responded to electrical stimulation (n = 14) (normalized with respect to voluntary PEFRs, unnormalized):; ANOVA of the normalized data provided F = 15.31, p < 0.0001, indicating that there was a significant difference among the PEFRs (coughs) produced by the 3 grps. Investigators reported that "[b]oth manually assisted and electrically stimulated coughs had higher peak flow rates than volitional coughs. The manually assisted coughs had higher peak flows than the electrically stimulated coughs." (p. 1360) Response to electrical stimulation:; - No. of pts able to tolerate it: 19/24 (79%); - No. of pts with inadequate response: 5/24 (21%)
  Unnormalized: | Voluntary: | 203 (52) (SD)
  Unnormalized: | Manual: | 238 (67)
  Unnormalized: | Electrical: | 230 (64)
  Normalized: | Voluntary: | 1.0
  Normalized: | Manual: | 1.15
  Normalized: | Electrical: | 1.08
Kirby, Barnerias, and Siebens, 1966 | Design: Prospective single subject design clinical trial Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-Y 5-Y | N = 10 Neurol. status Time since injury: N/S Level of injury: C5 20%, C6 80% Completeness of injury: N/S, but all had quadriparesis and paralysis of intercostal and abdominal muscles Pulmonary status: No pts had roentgenographic evidence of parenchymal abnormalities or obstructive pulmonary disease; 1 pt had impaired diaphragmatic function with intact laryngeal and pharyngeal musculature Age: 23 (range:16-31) Sex: 80% M, 20% F Race: N/S | Prospective study of various types of assisted coughing techniques. Experimental conditions:; - Unassisted cough, with corset; - Manual assistance, no corset (given by 2 persons); - Oral positive pressure, no corset; - Oral positive pressure, with corset; - Oral positive pressure, manual assistance, no corset; Control condition: Unassisted cough, no corset Room air at pressures 50 cm of water were delivered continuously through a mouthpiece by a positive-pressure pump. A thoraco-abdominal corset was applied or removed as needed. Coughs of all pts were measured in the supine position; coughs of 8/10 pts (80%) were measured with pt upright in wheelchair. Pt was instructed to cough as forcefully as possible in 1 sustained expiration. With nose sealed with a nose clip, pt breathed through a 3-way valve with a tap to the spirometer. Valve was turned to spirometer to measure cough performance. When positive pressure was being administered, pt inflated lungs maximally, closed the glottis, exchanged the mouthpiece of the pump for the mouthpiece of the spirometer, and then coughed. Volume and flow were recorded after each series of coughing under a given circumstance. Pts coughed from 3-8 times for each circumstance. | Investigators reported finding that "cough is not affected by a corset, but is affected by manual compression and insufflation by positive pressure. Optimal cough resulted from combining positive pressure insufflation with manual assistance; cough volume and flow were normal in a number of patients under these circumstances. Cough was comparable in the sitting and supine positions and was improved after insufflation with positive pressure" (p. 710). Results were not directly compared (no p-values reported). Coughs measured in supine position (n = 10) Maximum flow compared with "unassisted cough, no corset" condition [3.9 L/sec, 100%]): Unassisted cough, with corset: 107% Manual assistance, no corset: 133% Oral positive pressure, no corset: 137% Oral positive pressure, with corset: 145% Oral positive pressure, manual assistance, no corset: 178% No. of pts who improved maximum flow compared with "unassisted cough, no corset" condition: Maximum volume compared with "unassisted cough, no corset" condition [2.0 L/sec, 100%]): Unassisted cough, with corset: 108% Manual assistance, no corset: 131% Oral positive pressure, no corset: 163% Oral positive pressure, with corset: 162% Oral positive pressure, manual assistance, no corset: 180% No. of pts who improved maximum volume in comparison with control: Effect of oral positive pressure (sitting position, with corset) on 8/10 pts: Other outcomes reported: Maximum flow and volume of 6/12 pts (50%) compared with that of 3 normal individuals
  Unassist. cough, w/ corset | 7/10 (70%)
  Manual assist., no corset | 10/10 (100%)
  Oral pos. press., no corset | 9/10 (90%)
  Oral pos. press, w/ corset | 9/10 (90%)
  Oral pos. press., manual assist., no corset | 10/10 (100%)
  Unassisted cough | 5/10 (50%)
  Manual assistance | 10/10 (100%)
  Oral pos. press., no corset | 9/10 (90%)
  Oral pos. press, w/ corset | 8/10 (80%)
  Oral pos. press., manual assist., no corset | 9/10 (90%)
  Maximum flow | 25% increase
  Maximum volume | 48% increase
Lin, Lai, Wu et al., 1998 | Design: Prospective single subject design clinical trial Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-Y 5-N | N = 12 Neurol. status Time since injury: Mean, 9.8 yrs Level of injury: C4-C8 Completeness of injury: Complete Pulmonary status: All pts breathing without ventilatory support; no pts had primary lung disease Age: 36 (range: N/S) Sex: N/S Race: N/S | Test to determine effect of abdominal binder, with or without electrical stimulation, on PEFR (used as a proxy for cough). In seated position, pts coughed forcefully in 1 sustained expiration. PEFR was measured before and after each cough using a spirometer. All pts performed all 3 of the below maneuvers, with a 10-min rest period between any 2 maneuvers. Abdominal binder was placed between xiphoid process and pubis, to decrease abdominal girth by approximately 10%. Electrical stimulator (50 Hz with 300 µs pulse width) was applied to abdominal wall 3 cm from umbilicus using 4 high-conductivity surface electrodes. Intensity of electrical stimulation was adjusted to obtain maximal muscle contraction without discomfort to pts. Entire stimulation limited to 10 min, to avoid fatiguing pts. Experimental (1): Voluntary coughing with abdominal binder, with electrical stimulation (2 coughs) Experimental (2): Voluntary coughing with abdominal binder, without electrical stimulation (2 coughs) Control: Voluntary coughing alone (2 coughs) | PEFR: Use of abdominal binding alone increased PEFR by 2% over voluntary coughing alone (no binding, no coughing), but this increase was not was not statistically significant (p > 0.05). Adding electrical stimulation to abdominal binding caused an 18% increase in PEFR over voluntary coughing, an increase that was statistically significant(p < 0.01). The difference in PEFR(16%) between the use of abdominal binding with electrical stimulation versus without such stimulation was also significant (p < 0.01). The mean values (± SEM) are as follows: Investigators reported that the average PEFR was below normal range during voluntary coughing, but increased to within normal range with use of abdominal binder and electrical stimulation. They also stated that electrical stimulation plus abdominal binding improved cough ability, but use of the binder alone added little benefit.
  • | Voluntary coughing alone | 4.52 ± 0.25
  • | With abdominal binder | 4.59 ± 0.25
  • | With abdominal binder plus electrical stimulation | 5.32 ± 0.27
Wang, Jaeger, Yarkony et al., 1997 Possible overlap with Jaeger, Turba, Yarkony et al., 1993 | Design: Diagnostic test study Quality: Internal validity N/A External validity 1-Y 2-Y 3-Y 4-N/A 5-Y | N = 95 (of larger grp of 181 pts, 86 of whom had injuries at T1-L4) Neurol. status Time since injury: < 1 yr, 10%; < 5 yrs, 54% Level of injury: 10% C4, 23% C5, 20% C6, 40% C7, 7% C8 Completeness of injury: ASIA (Frankel) grades: A ≈ 97 pts, B ≈ 38 pts, C ≈ 33 pts, D ≈ 34 pts (numbers approximated from graph; numbers tally to N = 202, the no. of enrolled pts) Pulmonary status: No pts were on respirators or had tracheostomies. Age: Median, 34 (range: 18-76) Sex: 85% M, 15% F Race: N/S | Test to determine if motor level and peak expiratory flow (PEF) during coughing are correlated. Corsets, abdominal binders, or other devices that could alter breathing were removed prior to study. Volitional coughs, for 5 repetitions each, were measured using a peak expiratory flowmeter while pts were seated at 90°. Between coughs, from 10 sec to 1 min of rest were given, depending on patient's ability and comfort level. Note: The modeling was performed on all 181 subjects, not just on the subjects with cervical-level injuries. | Mean peak expiratory flow rate (L/min) by motor level: Correlation between level of injury and incidence of pulmonary complications (based on "existing data"): Complications were found to be "greatest in higher motor levels" and "lower in lower motor levels."No details provided. Correlation between PEF and motor level (combined pts): Investigators reported that there was a significant correlation between PEF and motor level for all pts (p < 0.01). Correlation between peak flow versus motor level for subjects with ASIA grade A only: This correlation was also significant (p-value not reported). Other outcomes reported: Correlation between peak flow and ASIA grades, height, weight, age, and year post-injury
  C4 (n = 9) | 1.72 (81) (SD)
  C5 (n = 22) | 281 (118)
  C6 (n = 19) | 297 (108)
  C7 (n = 38) | 355 (116)
  C8 (n = 7) | 319 (104)
MULTIMODAL PULMONARY THERAPY
McMichan, Michel, and West-brook, 1980 | Design: Historical cohort comparison; prospective series of pts compared (for some outcomes only) to retrospective survey of 22 comparable pts Quality: Internal validity Level IV External validity 1-Y 2-N 3-Y 4-Y 5-N | N = 22 (prospective series); 22 (retrospective series) Neurol. status Time since injury: All pts admitted to hospital within 24 hrs of acute traumatic quadraplegia. Respiratory care plan initiated ASAP thereafter. Level of injury: C4-C8 in all pts except one retrospective pt, in whom the level of injury was C3 Completeness of injury: N/S Pulmonary status: In prospective series, 14 pts (64%) breathing room air on arrival at ED, rest receiving oxygen by nasal cannula or face mask Age: 24 (prospective), 29 (retrospective) Sex: 82% M, 18% F (prospective); 91% M, 9% F (retrospective) Race: N/S | Respiratory care program focusing on:; 1. Usual care (prevention of secretion retention): This involved changing the patient's position every two hours and instituting a 4-hourly program of deep breathing exercises, incentive spirometry, chest percussion, and assisted coughing.; 2. Aggressive care: This involved treatment of secretion retention via intermittent positive pressure breathing, aerosolized bronchodilator treatment, bronchial lavage, chest percussion, changing patient's position, and incentive spirometry, as indicated | Prospective and retrospective pts compared for following outcomes:; - Mortality Aggressive (prospective) grp, 0/22 Usual care (retrospective) grp, 9/22 (41%); - Pulmonary complications (secretion retention and atelectasis) Aggressive (prospective) grp, 4 cases Usual care (retrospective) grp, 12 cases; - Need for mechanical ventilation Aggressive (prospective) grp, 3/22 (14%) Usual care (retrospective) grp, 9/22 (41%); - Tracheostomy Aggressive (prospective) grp, 2/22 (9%) Usual care (retrospective) grp, 6/22 (27%); Other outcomes reported: Following outcomes assessed (prospective group only) at initial assessment in ED, at 9 wks (in halo cast), and at 18 wks (no cervical immobilization):; - Total lung capacity (TLC); - Vital capacity (VC); - Residual volume (RV); - Functional residual capacity (FRC); - Expiratory reserve volume (ERV); - FEV_1_; - Forced expiratory flow 25%-75% VC; - Forced expiratory flow (FEF); - Forced inspiratory flow (FIF); - Maximal voluntary ventilation; - Maximum inspiratory pressure; - Maximum expiratory pressure; Prospective and retrospective pts compared for following outcomes:; - Need for cervical traction
Sugarman, 1985 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-N 2-N 3-Y 4-Y 5-N | N = ? (see "Note" at right) Neurol. status Time since injury: 57/128 admissions (45%) were due to initial injury and occurred days to months after injury (median, 18 days); all pts had received medical stabilization prior to admission Level of injury: N/S, but all pts were quadriplegics Completeness of injury: 49 pts, "complete motor and sensory"; unknown no. of pts, incomplete Pulmonary status: On admission, 16 pts had tracheostomies and 1 received this procedure after admission; 2 pts were on ventilators; "some" pts had dyspnea. After admission, 6 pts developed atelectasis on left side, with or without apparent pulmonary infiltrate or pleural effusion (5 of these 6 pts had tracheostomies and 3 had complete injuries) Age: "Mostly adult" Sex: "Mostly male" Race: N/S | Describes protocol for "vigorous pulmonary therapy" to treat atelectasis (particularly that of the left bronchus). Atelectasis defined as:; 1. A chest radiograph suggesting lung collapse, with or without apparent infiltrates or pleural effusion,; 2. Complete resolution of these abnormalities within 24 hrs after vigorous pulmonary therapy or bronchoscopy, and; 3. No known anatomic injury that caused the atelectasis.; Protocol for prevention of atelectasis:; - Suctioning (at least daily); - Assisted coughing (routinely); - Incentive spirometry (routinely); - Both assisted coughing and incentive spirometry when necessary; Protocol for treatment of atelectasis:; - "More vigorous" assisted coughing (sufficient to treat 2 pts); - Deep breathing (sufficient to treat 2 pts); - Incentive spirometry (sufficient to treat 2 pts); - More frequent suctioning; - When suctioning, leaving catheter down pharynx for a few seconds to induce best possible cough; - Valsalva-type maneuver if pt could not cough (turning pts' head prior to suctioning, or using curved catheters (or both) in an attempt to suction left bronchus); - Bronchoscopy; Note: 128 admissions of quadriplegic pts, but total no. of pts is unclear. 49 pts had complete injuries, but no. of pts with incomplete injuries N/S. The 6 pts described here were a subset of a larger group of spinal cord-injured pts (N = 243, 271 admissions). | The results below are for the 6 pts who developed atelectasis. Pulmonary function tests (PFTs):; - Pre- to post-treatment improvement in - Tidal volume: 4/6 (67%) - Forced vital capacity: 4/6 (67%); - No. of pts with decline in follow-up PFTs: 2/6 (33%); No. of pts for whom chest radiograph returned to normal within 24 hrs after therapy initiated: 6/6 (100%) No. of pts requiring suctioning (at least daily) prior to diagnosis of atelectasis: 4/6 pts (67%), 2 of whom required "much more frequent suctioning" No. of pts with resolution of dyspnea: 4/6 (67%) Atelectasis:; - No. of pts who developed atelectasis (defined at left) at any time during hospitalization: 6/6 (100%); - Recurrence of atelectasis: - No. of recurrences: 7 - No. of pts with recurrences: 3/6 pts (50%); - No. of pts free of atelectasis at discharge: 5/6 (83%); the other pt died; Mortality: 1/6 (17%)

1 See Abbreviations Used in Evidence Tables (preceding these tables) for a list of abbreviations, acronyms, and symbols.

2 Internal validity rating (Levels I-V): I = Large randomized trials with clear-cut results (and low risk of error); II = small randomized trials with uncertain results (and moderate to high risk of error); III = nonrandomized trials with concurrent or contemporaneous controls; IV = nonrandomized trials with historical controls; V = case series with no controls.

2 External validity rating (yes or no for each): 1 = Were the criteria for selection of patients described? 2 = Were patients included in the study adequately characterized with regard to level and completeness of SCI? 3 = Were criteria for outcomes clearly defined (e.g., timing, measurement, reliability)? 4 = Was the clinical care of patients adequately described to be able to reproduce? 5 = Were results given reported according to level of injury (minimum high cervical [C4 or above] versus low cervical [below C4]) or ventilation status (independently breathing versus ventilator-dependent)?

Evidence Table 5. Airway Management^1^

Study | Design and Quality | Patient Population | Study Protocol/Interventions | Results/Outcomes
Bach and Alba, 1990b | Design: Retrospective case series Quality: Internal validity ^1^ Level V External validity ^2^ 1-N 2-N 3-N 4-Y 5-N | N = 10 spinal-cord-injured pts from a larger grp of 21 pts (11 with neuromuscular myelopathies) on deflated/cuffless TPPV; the 21 pts were selected because they had agreed to allow daytime and overnight oximetry to be performed; all were from a larger group of 104 with inflated/partially inflated cuffs Neurol. status Time since injury: Mean N/S; range, 1-12 yrs Level of injury: N/S, but all defined as "SCI" with high-level quadriplegia Completeness of injury: N/S Pulmonary status: All pts ventilator-dependent; all using TPPV continuously (day and night), 40% with deflated cuffs, 60% cuffless; all placed on TPPV in same year as injury occurred; range of TPPV use, 1-12 yrs Age: N/S Sex: N/S Race: N/S | Study of effectiveness of tracheostomy intermittent positive pressure ventilation (TPPV) with deflated cuffs (4/10 or 40%) or cuffless (6/10 or 60%). Described procedures used to convert pts from inflated to deflated cuff/cuffless ventilation. Portable volume ventilators were used from time of admission. TPPV transition procedures Some pts (n = 10) were immediately converted from TPPV with inflated cuffs to various methods of noninvasive ventilation. For the others, the following procedures were used:; - Cuffs deflated for short but increasingly longer periods during day; - Volume adjusted so that ventilatory pressures and blood gases during deflated/cuffless periods were equivalent to those during inflated cuff periods; - Delivered volumes adjusted if necessary to compensate for insufflation leak; - Supplemental oxygen used if necessary to maintain pCO_2_ levels; - Continuous monitoring of finger pulse SaO_2_ and end-tidal pCO_2_; - ABGs measured; - Pts trained to use leak across vocal cords to aid in speech; - Smaller tracheostomy tubes inserted if pts needed them for effective speech; Once pts could tolerate deflated cuffs during day, they were converted to using such cuffs overnight. Full cuff deflation/removal usually took 1-2 wks. | VC; - Mean VC (% pred.): 22.6% of predicted normal (n = 10 - No. of pts with VC < 20% of predicted normal: 5/10 (50%) - No. of pts with VC > 20% but < 50% predicted normal: 5/10 (50%); Weaning; - No. of pts who were weaned: 1/10 (10%); Free time off ventilator; - No. of pts/amt of free time: See table below.; Blood gas measurements: Investigators reported that "ABGs, daytime SaO_2_ and endtidal pCO_2_ were within normal limits for all pts" (p. 679). See below for more details. SaO_2_; - Mean SaO_2_ (%): 96.9% (range: 94-98); - Mean low SaO_2_ (%): 88.3% (range: 73-95); - % of time that SaO_2_ was < 90%: In 8/10 pts (80%), SaO_2_ was never < 90%; in 2/10 pts (20%), it was < 90% for 2% and 3% of the time, respectively.; Desaturations/hr: No. of times per hour that O_2_ saturation decreased by 4% or more: Mean, 0.93 (range: 0 to 2.6)
  Time free | No. pts (%)
  Daytime (not overnight) | 5/10 (50%)
  20 min | 3/10 (30%)
  > 20 but 60 min | 2/10 (20%)
| | | | Maximum pCO_2_; - No. of pts with pCO_2_ > 47 mm Hg: 1/10 (10%); - Mean pCO_2_: 41.2 mm Hg; Other outcomes reported: VC in supine position (mL)
Bellamy, Pitts, and Stauffer, 1973 | Design: Retrospective case series Quality: Internal validity Level V External validity 1-N 2-Y 3-Y 4-N 5-Y | N = 54 (of larger grp of 531 pts with cervical spine fractures or dislocations) Neurol. status Time since injury: N/S Level of injury: 1 pt, C3; 7 pts, C4; 13 pts, C5; 6 pts, C6; 3 pts, C7 (level of injury only provided for the 30 pts with complete injuries) Completeness of injury: Complete, 30/54 pts (56%); incomplete, 24/54 (44%); some injuries originally thought to be complete later proved to have sacral sensory sparing, but were still classified as complete by investigators; all pts described as quadriplegics Pulmonary status: N/S Age: 36 pts < 40 yrs, 18 pts > 40 yrs (range:3-78) Sex: 81% M, 19% F Race: N/S | Retrospective review of 20 yrs of medical charts to determine correlations between tracheostomy, surgery, overhydration, advanced age, severity of neurological injury, and corticosteroid therapy with pulmonary complications. Predictors considered: Nonsurgery, surgery within 1st month after injury, surgery > 1 month after injury, posterior cervical spine surgery, anterior cervical fusion, associated disease or trauma, no associated disease, prior cardiopulmonary disease, advanced age, corticosteroid therapy Analytic method(s): N/S | Pulmonary complications; - No. of complications overall: 64; - No. of complications after tracheostomy: 47; Tracheostomies:; - No. of pts with tracheostomies: 31/54 (57%); - Timing: 3 days, 28/32 cases (87%); > 3 days, 4/32 (12%); - No. and type of pulmonary complications after tracheostomy: 2 complications out of 33 procedures (6%): 1 instance of minor bleeding, 1 instance of tracheal stenosis following removal of tracheostomy tube; Mortality; - No. of deaths: 43/54 (80%); - No. of deaths within the first year: 17/54 (31%); - Cause of death: Not clearly specified, except that 1 pt had cardiac arrest caused by tracheal suctioning and of 16 pts autopsied, all died of causes that were "[p]ulmonary in most cases . . . with uniformly edematous and congested lungs" (p. 599).; Predictors of pulmonary complications and death: Severity of neurological deficit had the most important correlation with pulmonary complications and adverse outcome [death and tracheostomy]; associated trauma, prior cardiopulmonary disease, and advanced age were also correlated with those outcomes (no p-values reported). Other outcomes reported: Pulmonary complications; - No. of cases after tracheostomy; - No. of cases within 14 days of corticosteroid therapy; No. of deaths within 14 days of corticosteroid therapy
Biering-Sørensen and Biering-Sørensen, 1992 | Design: Case series (retrospective chart review) Quality: Internal validity Level V External validity 1-Y 2-N 3-N 4-N 5-N | N = 600 total pts considered, 288 of whom had cervical spinal injuries; most of the analysis focused on the 67 pts who had a tracheostomy performed, 46 of whom had cervical spinal injuries Neurol. status Time since injury: N/S, though population characterized as "acute spinal cord injured patients" Level of injury: Overall, 288/600 pts (48%) had cervical spinal injuries, 200/600 (33%) had thoracic spinal injuries, and 112/600 (19%) had lumbar spinal injuries. Among tracheostomized pts, 46/67 (69%) had cervical spinal injuries, 18/67 (27%) had thoracic spinal injuries, and 3/67 (4%) had lumbar spinal injuries. Completeness of injury: Scored on Frankel scale and reported for latest followup examination. Cervical pts: A, 71/288 (25%); B, 48/288 (17%); C, 27/288 (9%); D, 103/288 (36%); E, 39/288 (14%). Pulmonary status: N/S Age: Information provided only for tracheostomized pts: Median age at time of injury, 34.4 (range: 5-69) Sex: Information provided only for tracheostomized pts: 84% M, 16% F Race: N/S | Tracheostomy Predictors of mortality (several considered) (tracheostomized pts only): Age at injury before vs. after followup, neurological level at injury, frequency of thoracic trauma or spinal fractures, cause of injury, Frankel class, periods from injury to tracheostomy and from tracheostomy to decannulation between those who died and those where were still alive at followup Analytic method(s): Fisher's exact test, Chi square, Mann-Whitney rank-sum tests | Percentage of pts who had a tracheostomy performed:; - Overall: 67/600 (11%); - Cervical-injured pts: 46/288 (16%); - Broken down by Frankel score: 23% (16/71), A; 17% (8/48), B; 26% (7/27), C; 14% (14/103), D; 3% (1/39), E; among pts with cervical-level injuries, tracheostomies were significantly more frequent (p = 0.01) among those with the more severe injuries, based on Frankel classification.; Percentage of tracheostomized pts with cervical-level injuries who also had concomitant thoracic trauma: 9/46 (20%) Complications of tracheostomy: Of all pts combined, 3 pts had each of the following early complications of tracheostomy: bleeding from stoma, pneumothorax, and pneumomediastinum Mortality (tracheostomized pts only): 20/67 (30%) Predictors of mortality (several considered) (tracheostomized pts only): Age at injury before vs. after followup Cause of death (tracheostomized pts only): 17/67 (25%) died from cardiorespiratory problems: pneumonia (6); respiratory insufficiency, 4 (1 with chronic bronchitis, 1 who was intubated shortly before death, 1 with cardiac arrhythmia); acute myocardial infarction, 3 (1 who also had aggressive chronic lymphatic leukemia), pulmonary edema, 2 (1 with acute tracheobronchitis & incompensated heart, 1 with "heart stop"); 1 died from septicemia due to a sacral decubitus, but who also had at time of death bilateral bronchopneumonia; 1 died with hyperpyrexia of unknown etiology, but had a decubitus and pulmonary stasis; 1 died 2 days after a cerebral hemorrhage. Note: Reported deaths by cause total 18. Assessed at followup by questionnaire or phone call (n = 43 respondents from among 47 survivors; median time from injury to followup = 10.4 years):; - Percentage of pts reporting "any inconvenience or trouble because of the tracheostomy": 47% (20/43); - No. of pts reporting respiratory stenosis problems: 1/43 (2%); - No. of pts reporting "cosmetic inconvenience": 12/43 (28%); - No. of pts reporting tightness relating to scar and/or difficulty swallowing: 10/43 (23%); Other outcomes reported: Time from injury to death (tracheostomized pts only)
Meschino, Devitt, Koch et al., 1992 | Design: Case series (retrospective chart review) Quality: Internal validity Level V External validity 1-N 2-N 3-Y 4-Y 5-N | N = 454 (165 in case group = pts who were intubated; 289 controls = pts who were not intubated) Neurol. status Time since injury: All pts in case group were intubated within 2 months of injury Level of injury: All pts had cervical spine injuries "with or without spinal cord injury"; no. of pts with and without spinal cord injury N/S Completeness of injury: Severity of injury graded on scale of 1 to 10: (1) complete motor loss; complete sensory loss; (2) complete motor loss, incomplete sensory loss; (3) incomplete motor useless; complete sensory loss; (4) incomplete motor useless; incomplete sensory loss; (5) incomplete motor useless; normal sensory; (6) incomplete motor useful; complete sensory loss; (7) incomplete motor useful; incomplete sensory loss; (8) incomplete motor useful; normal sensory; (9) normal motor; incomplete sensory loss; (10) normal motor; normal sensory. Baseline scores of case and control groups N/S. Pulmonary status: Pts requiring or receiving intubation under general anesthesia were excluded, as were pts requiring an urgent surgical airway (tracheostomy or cricothyrotomy) Age: 37.0 Sex: N/S Race: N/S | Tracheal intubation of conscious, non-sedated patients Techniques used: Fiberoptic bronchoscope, oral or nasal (46%); blind nasal tracheal (32%); direct laryngoscopy, oral (22%). Regional block or local anesthesia used in 83% of cases. Indications for intubation: Preparation for administration of surgical general anesthesia (62%); respiratory failure (27%); airway protection (8%); tracheobronchial toilet (3%). | Proportion of pts demonstrating neurological worsening (defined as a change to a lower grade on the 1-10 scale described at left) between admission and discharge: Both groups worsened by the same percentage (2%). There was no significant difference between the 2 grps(no p-value reported) (95% CI: ± 0.029). No. of cases in which pulmonary aspiration of gastric contents was a complication of intubation: None
  | Not-intubated grp (n = 289) | 7/289 (2%)
  | Intubated grp (n = 165): | 4/165(2%)

1 Internal validity rating (Levels I-V): I = Large randomized trials with clear-cut results (and low risk of error); II = small randomized trials with uncertain results (and moderate to high risk of error); III = nonrandomized trials with concurrent or contemporaneous controls; IV = nonrandomized trials with historical controls; V = case series with no controls.

2 External validity rating (yes or no for each): 1 = Were the criteria for selection of patients described? 2 = Were patients included in the study adequately characterized with regard to level and completeness of SCI? 3 = Were criteria for outcomes clearly defined (e.g., timing, measurement, reliability)? 4 = Was the clinical care of patients adequately described to be able to reproduce? 5 = Were results given reported according to level of injury (minimum high cervical [C4 or above] versus low cervical [below C4]) or ventilation status (independently breathing versus ventilator-dependent)?