# Bibliography

Abelson H, Brewer K Inspiratory muscle training in the mechanically ventilated patient Physiotherapy Can 1987 39(5):305 7
Acton PA, Farley T, Freni LW, et al Traumatic spinal cord injury in Arkansas, 1980 to 1989 Arch Phys Med Rehabil 1993 74(10):1035 40 8215853
(formerly U. S. Agency for Health Care Policy and Research). Hospital Inpatient Statistics, 1996. Healthcare Cost and Utilization Project Research Note. The Agency. 1999. AHCPR No. 99-0034.
Ahmed AB, Bogod DG Anaesthetic management of a quadriplegic patient with severe respiratory insufficiency undergoing caesarean section Anaesthesia 1996 51(11):1043 5 8943597
Al-Kaisy AA, Kent AP, Watt JWH Maintaining ventilation through the Montgomery t-tube Can J Anaesth 1997 44(3):
Alba AS. Concepts in pulmonary rehabilitation. In: Braddom RL, Buschbacher RM, editors. Physical Medicine and Rehabilitation. Philadelphia: Saunders. 1996:p.671-85.
Albin MS, Hung TK, Babinski M The patient with spinal cord injury. Epidemiology, emergency and acute care: advances in physiopathology and treatment Curr Probl Surg 1980 17(4):190 204 6768496
Alfaro J, Varela G, De-Miguel E, et al Successful management of a tracheo-innominate artery fistula following placement of a wire self-expandable tracheal Gianturco stent Eur J Cardiothorac Surg 1993 7(11):615 6 8297617
Ali J, Qi W Pulmonary function and posture in traumatic quadriplegia J Trauma 1995 39(2):334 7 7674404
Almenoff PL, Alexander LR, Spungen AM, et al Bronchodilatory effects of ipratropium bromide in patients with tetraplegia Paraplegia 1995 33(5):274 7 7630654
Almenoff PL, Spungen AM, Lesser M, et al Pulmonary function survey in spinal cord injury: influences of smoking and level and completeness of injury Lung 1995 173(5):297 306 7564488
Alvarez SE, Peterson M, Lunsford BR Respiratory treatment of the adult patient with spinal cord injury Phys Ther 1981 61(12):1737 45 7312946
Ambrosino N, Vitacca M, Rampulla C Standards for rehabilitative strategies in respiratory diseases Monaldi Arch Chest Dis 1995 50(4):293 318 7550210
Lung function testing: selection of reference values and interpretative strategies Am Rev Respir Dis 1991 144(5):1202 18 1952453
Amodie-Storey C, Nash MS, Roussell PM, et al Head position and its effect on pulmonary function in tetraplegic patients Spinal Cord 1996 34(10):602 7 8896126
Andersson G The Swedish modification of the tracheostomy tube to permit speech Paraplegia 1993 31(4):203 6 8493034
Anke A, Aksnes AK, Stanghelle JK, et al Lung volumes in tetraplegic patients according to cervical spinal cord injury level Scand J Rehabil Med 1993 25(2):73 7 8341994
Anonymous When all else failed, Pavulon therapy worked. Nursing grand rounds Nursing 1981 11(10):53 7
Anonymous Phrenic nerve pacing in quadriplegia Lancet 1990 336(8707):88 90 1975327
Anonymous Phrenic nerve stimulation in quadriplegia [letter] Lancet 1990 336(8712):446 7
Anonymous Pneumococcal vaccination in patients with spinal injury Am Fam Physician 1994 49(6):
Anonymous Levcromakalim Drugs Fut 1996 21(3):323 4
Applebaum EL Laryngeal and tracheal problems in patients with central nervous system and spinal disorders Otolaryngol Clin North Am 1979 12(4):829 35 542305
Arima T, Noguchi T, Mochida J, et al Problems of long-term hospitalised cervical spinal cord injury patients in university hospitals Paraplegia 1994 32(1):19 24 8015831
Armitage JM, Pyne A, Williams SJ, et al Respiratory problems of air travel in patients with spinal cord injuries BMJ 1990 300(6738):1498 9 2372601 1663189
Ashba J, Garshick E, Tun CG, et al Spirometry--acceptability and reproducibility in spinal cord injured subjects J Am Paraplegia Soc 1993 16(4):197 203 8270915
Ashworth B. Preliminary trial of carisoprodol in multiple sclerosis. Practitioner. 1964;192:540-2. [pmid: 14143329].
Auerbach AA, Dobelle WH Transtelephonic monitoring of patients with implanted neurostimulators Lancet 1987 1(8526):224 5
Austin RT Tracheostomy and prolonged intubation in the management of trauma Injury 1971 2(3):191 8 5118779
Axen K Ventilatory responses to mechanical loads in cervical cord-injured humans J Appl Physiol 1982 52(3):748 56 7068491
Axen K, Pineda H, Shunfenthal I, et al Diaphragmatic function following cervical cord injury: neurally mediated improvement Arch Phys Med Rehabil 1985 66(4):219 22 3985772
Babinski MF Anesthetic considerations in the patient with acute spinal cord injury Crit Care Clin 1987 3(3):619 36 3332217
Bach JR New approaches in the rehabilitation of the traumatic high level quadriplegic Am J Phys Med Rehabil 1991 70(1):13 9 1994965
Bach JR Ventilatory support alternatives to tracheostomy and intubation: current status of the application of this technology Conn Med 1991 55(6):323 9 1935054
Bach JR Alternative methods of ventilatory support for the patient with ventilatory failure due to spinal cord injury J Am Paraplegia Soc 1991 14(4):158 74 1960533
Bach JR Inappropriate weaning and late onset ventilatory failure of individuals with traumatic spinal cord injury Paraplegia 1993 31(7):430 8 8371934
Bach JR Mechanical insufflation-exsufflation. Comparison of peak expiratory flows with manually assisted and unassisted coughing techniques Chest 1993 104(5):1553 62 8222823
Bach JR Cough in SCI patients [letter] Arch Phys Med Rehabil 1994 75(5):
Bach JR Introduction to rehabilitation of neuromuscular disorders Semin Neurol 1995 15(1):1 5 7638452
Bach JR Respiratory muscle aids for the prevention of pulmonary morbidity and mortality Semin Neurol 1995 15(1):72 83 7638462
Bach JR Indications for tracheostomy and decannulation of tracheostomized ventilator users Monaldi Arch Chest Dis 1995 50(3):223 7 7663495
Bach JR Chronic alveolar hypoventilation as a late complication of spinal cord injury [letter] J Spinal Cord Med 1995 18(4):
Bach JR. Case studies of respiratory management. In: Bach JR, ed. Pulmonary Rehabilitation: The Obstructive and Paralytic Conditions. Philadelphia: Haney & Belfus. 1996:331-46.
Bach JR A historical perspective on the use of noninvasive ventilatory support alternatives Respiratory Care Clinics of North America 1996 2(2):161 81 9390877
Bach JR, Alba AS Noninvasive options for ventilatory support of the traumatic high level quadriplegic patient Chest 1990a 98(3):613 9 2203616
Bach JR, Alba AS Tracheostomy ventilation. A study of efficacy with deflated cuffs and cuffless tubes Chest 1990b 97(3):679 83 2407453
Bach JR, Alba AS Intermittent abdominal pressure ventilator in a regimen of noninvasive ventilatory support Chest 1991 99(3):630 6 1899821
Bach JR, Alba AS, Saporito LR Intermittent positive pressure ventilation via the mouth as an alternative to tracheostomy for 257 ventilator users Chest 1993 103(1):174 82 8417874
Bach JR, Lee HJ New therapeutic techniques and strategies in pulmonary rehabilitation Yonsei Med J 1993 34(3):201 11 8259697
Bach JR, McDermott IG Strapless oral-nasal interface for positive-pressure ventilation Arch Phys Med Rehabil 1990 71(11):910 3 2222161
Bach JR, O'Connor K Electrophrenic ventilation: a different perspective J Am Paraplegia Soc 1991 14(1):9 17 2022962
Bach JR, Rajaraman R, Ballanger F, et al Neuromuscular ventilatory insufficiency: effect of home mechanical ventilator use v oxygen therapy on pneumonia and hospitalization rates Am J Phys Med Rehabil 1998 77(1):8 19 9482374
Bach JR, Saporito LR Criteria for extubation and tracheostomy tube removal for patients with ventilatory failure. A different approach to weaning Chest 1996 110(6):1566 71 8989078
Bach JR, Tilton MC Life satisfaction and well-being measures in ventilator assisted individuals with traumatic tetraplegia Arch Phys Med Rehabil 1994 75(6):626 32 8002759
Bach JR, Valenza JP The patient with paralytic or restrictive pulmonary dysfunction: Standards of care, assistive technology, and ethics Phys Med Rehabil Clin North Am 1996 7(2):367 88
Bach JR, Wang TG Pulmonary function and sleep disordered breathing in patients with traumatic tetraplegia: a longitudinal study Arch Phys Med Rehabil 1994 75(3):279 84 8129579
Baer GA, Talonen PP International Symposium on Implanted Phrenic Nerve Stimulators for Respiratory Insufficiency Ann Clin Res 1987 19(6):399 402 3502521
Baer GA, Talonen PP, Shneerson JM, et al Phrenic nerve stimulation for central ventilatory failure with bipolar and four-pole electrode systems Pacing Clin Electrophysiol 1990 13(8):1061 72 1697953
Bain G, Bodley R, Jamous A, et al A comparison of the chest radiograph and computerised tomography in assessing lung changes in acute spinal injuries--an assessment of their prevalence and the accuracy of the chest X-ray compared with CT in their assessment Paraplegia 1995 33(3):121 5 7784112
Bake B, Fugl-Meyer AR, Grimby G Breathing patterns and regional ventilation distribution in tetraplegic patients and in normal subjects Clin Sci 1972 42(2):117 28 5058561
Banzett RB, Lansing RW, Reid MB, et al 'Air hunger' arising from increased PCO2 in mechanically ventilated quadriplegics Respir Physiol 1989 76(1):53 67 2499025
Barthel J, Coe M, Chen J, et al What strategies are effective in communicating with ventilated and later trached quadriplegic patients? SCI Nurs 1996 13(3):82 3 8900670
Becker BE, DeLisa JA. Model spinal cord injury system trends, and implications for the future. Arch Phys Med Rehabil. 1999;80:1514-21. [pmid: 10569449].
Bedbrook GM, Sedgley GI The management of spinal injuries--past and present Int Rehabil Med 1980 2(2):45 61 7005138
Bednar DA, Parikh J, Hummel J Management of type II odontoid process fractures in geriatric patients; a prospective study of sequential cohorts with attention to survivorship J Spinal Disord 1995 8(2):166 9 7606126
Bell SD Use of Passy-Muir tracheostomy speaking valve in mechanically ventilated neurological patients Crit Care Nurse 1996 16(1):63 8 8697778
Bellamy R, Pitts FW, Stauffer ES Respiratory complications in traumatic quadriplegia. Analysis of 20 years' experience J Neurosurg 1973 39(5):596 600 4743566
Bellemare JF, Tepas III JJ, Imami ER, et al Complications of trauma care: Risk analysis of pneumonia in 10,001 adult trauma patients Am Surg 1996 62(3):207 11 8607580
Benvenuti CS Independence for the quadriplegic: the Bantam respirator Am J Nurs 1979 79(5):918 20 219692
Beraldo PS, Neves EG, Alves CM, et al Pyrexia in hospitalised spinal cord injury patients Paraplegia 1993 31(3):186 91 8479785
Bergman SB, Yarkony GM, Stiens SA Spinal cord injury rehabilitation. 2. Medical complications Arch Phys Med Rehabil 1997 78(3 Suppl):S53 8 9084368
Berk JL, Levy MN Profound reflex bradycardia produced by transient hypoxia or hypercapnia in man Eur Surg Res 1977 9(2):75 84 852474
Berkowitz M, O'Leary PK, Kruse DL et al. Spinal Cord Injury: An analysis of Medical and Social Costs. New York: Demos; 1998.
Berrouane Y, Daudenthun I, Riegel B, et al Early onset pneumonia in neurosurgical intensive care unit patients J Hosp Infect 1998 40(4):275 80 9868618
Biering-Sorensen M, Biering-Sorensen F Tracheostomy in spinal cord injured: frequency and follow up Paraplegia 1992 30(9):656 60 1408343
Biering-Sorensen M, Norup PW, Jacobsen E, et al Treatment of sleep apnoea in spinal cord injured patients Paraplegia 1995 33(5):271 3 7630653
Bingley JD Southport experience with domiciliary ventilation Paraplegia 1993 31(3):154 6 8479779
Bohn D, Armstrong D, Becker L, et al Cervical spine injuries in children J Trauma 1990 30(4):463 9 2325177
Borel CO, Guy J Ventilatory management in critical neurologic illness Neurol Clin 1995 13(3):627 44 7476821
Borkowski C A comparison of pulmonary complications in spinal cord-injured patients treated with two modes of spinal immobilization J Neurosci Nurs 1989 21(2):79 85 2523453
Botel U, Glaser E, Niedeggen A, et al The cost of ventilator-dependent spinal cord injuries-patients in the hospital and at home Spinal Cord 1997 35(1):40 2 9025219
Bracken MB, Shepard MJ, Holford TR, et al Administration of methylprednisolone for 24 or 48 hours or tirilazad mesylate for 48 hours in the treatment of acute spinal cord injury: Results of the Third National Acute Spinal Cord Injury randomized controlled trial JAMA 1997 277(20):1597 604 9168289
Bracken MB, Shepard MJ, Holford TR, et al Methylprednisolone or tirilazad mesylate administration after acute spinal cord injury: 1-year follow up: Results of the third national acute spinal cord injury randomized controlled trial J Neurosurg 1998 89(5):699 706 9817404
Brackett T, Condon A Comparison of the wedge turning frame and kinetic treatment table in the acute care of spinal cord injury patients ICU Forum 1984 4(5):1 7
Branscomb BV, Stover SL, DeVivo MJ et al. (University of Alabama School of Medicine, Birmingham, AL). Final Report: the pathophysiology of respiratory complications in spinal cord injury patients (unpublished). Birmingham, AL. 1984. [pmcid: 345031].
Braun SR, Giovannoni R, O'Connor M Improving the cough in patients with spinal cord injury Am J Phys Med 1984 63(1):1 10 6703028
Brouillette RT, Ilbawi MN, Klemka-Walden L, et al Stimulus parameters for phrenic nerve pacing in infants and children Pediatr Pulmonol 1988 4(1):33 8 3257820
Brouillette RT, Marzocchi M Diaphragm pacing: clinical and experimental results Biol Neonate 1994 65(3-4):265 71 8038293
Burnett P, Sutton RA A portable electronic 'calling device' as an aid to 'weaning' ventilator-dependent tetraplegic patients from intermittent positive pressure ventilation Paraplegia 1979 17(4):452 5 392411
Cahan C, Gothe B, Decker MJ, et al Arterial oxygen saturation over time and sleep studies in quadriplegic patients Paraplegia 1993 31(3):172 9 8479783
Cahill JL, Okamoto GA, Higgins T, et al Experiences with phrenic nerve pacing in children J Pediatr Surg 1983 18(6):851 4 6607333
Campbell DA, Homan SD, McCulloch GA, et al Phrenic nerve pacing in two young quadriplegic ventilator-dependent patients Aust N Z J Med 1992 22(5):463 8 1445036
Cantu RC Value of myelography in thoracic spinal cord injuries Int Surg 1971 56(1):23 6 5563417
Cardenas DD, Doctor JN Cost-effectiveness of rehabilitation after spinal cord injury Crit Rev Phys Rehabil Med 1998 10(4):359 67
Carter RE. Medical management of pulmonary complications of spinal cord injury. Adv Neurol. 1979;22:261-9. [pmid: 484337].
Carter RE Experiences with high tetraplegics Paraplegia 1979 17(2):140 6 492754
Carter RE Unilateral diaphragmatic paralysis in spinal cord injury patients Paraplegia 1980 18(4):267 74 7422343
Carter RE Respiratory aspects of spinal cord injury management Paraplegia 1987 25(3):262 6 3601438
Carter RE Experience with ventilator dependent patients Paraplegia 1993 31(3):150 3 8479778
Carter RE, Donovan WH, Halstead L, et al Comparative study of electrophrenic nerve stimulation and mechanical ventilatory support in traumatic spinal cord injury Paraplegia 1987 25(2):86 91 3495773
Chantraine A Traumatic spinal cord injury: Sequelae and rehabilitation Curr Opin Neurol Neurosurg 1990 3(5):729 32
Charlifue SW, Weitzenkamp DA, Whiteneck GG. Longitudinal outcomes in spinal cord injury: aging, secondary conditions, and well-being. Arch Phys Med Rehabil. 1999;80:1429-34. [pmid: 10569437].
Chawla JC Rehabilitation of spinal cord injured patients on long term ventilation Paraplegia 1993 31(2):88 92 8446461
Chen CF, Lien IN Spinal cord injuries in Taipei, Taiwan, 1978-1981 Paraplegia 1985 23(6):364 70 4080413
Chen CF, Lien IN, Wu MC Respiratory function in patients with spinal cord injuries: effects of posture Paraplegia 1990 28(2):81 6 2235026
Chen D, Apple DF, Hudson LM, et al. Medical complications during acute rehabilitation following spinal cord injury--current experience of the Model Systems. Arch Phys Med Rehabil. 1999;80:1397-401. [pmid: 10569433].
Chervin RD, Guilleminault C Diaphragm pacing for respiratory insufficiency J Clin Neurophysiol 1997 14(5):369 77 9415384
Cheshire DJ, Coats DA Respiratory and metabolic management in acute tetraplegia Paraplegia 1966 4(1):1 23 5336086
Cheshire DJ, Flack WJ The use of operant conditioning techniques in the respiratory rehabilitation of the tetraplegic Paraplegia 1978 16(2):162 74 733296
Chevrolet JC, Deleamont P Repeated vital capacity measurements as predictive parameters for mechanical ventilation need and weaning success in the Guillain-Barre syndrome Am Rev Respir Dis 1991 144(4):814 8 1928954
CINAHL Information Service, 1983-. Updated monthly. Available from CINAHL Information Service, Glendale, CA; Ovid Technologies, Inc., New York, NY.
Claxton AR, Wong DT, Chung F, et al Predictors of hospital mortality and mechanical ventilation in patients with cervical spinal cord injury Can J Anaesth 1998 45(2):144 9 9512849
Clough P Glossopharyngeal breathing: its application with a traumatic quadriplegic patient Arch Phys Med Rehabil 1983 64(8):384 5 6882178
Clough P, Lindenauer D, Hayes M, et al Guidelines for routine respiratory care of patients with spinal cord injury A clinical report. Phys Ther 1986 66(9):1395 402
Cohn JR, Steiner RM, Posuniak E Jr, et al Obstructive emphysema due to mucus plugging in quadriplegia Arch Phys Med Rehabil 1987 68(5 Pt 1):315 7 3579540
Colachis III S, Murray KD Esophageal perforation: A delayed complication following traumatic spinal cord injury. Case report Paraplegia 1992 30(6):449 53 1635797
Colachis SC 3rd, Otis SM Occurrence of fever associated with thermoregulatory dysfunction after acute traumatic spinal cord injury Am J Phys Med Rehabil 1995 74(2):114 9 7710724
Outcomes following traumatic spinal cord injury: clinical practice guidelines for health-care professionals. Washington, DC: Paralyzed Veterans of America. 1999. [pmcid: 325679].
Cooper RA, Baldini FD, Langbein WE, et al Prediction of pulmonary function in wheelchair users Paraplegia 1993 31(9):560 70 8247598
Creasey G, Elefteriades J, DiMarco A, et al Electrical stimulation to restore respiration J Rehabil Res Dev 1996 33(2):123 32 8724168
Crosby ET Tracheal intubation in the cervical spine-injured patient [editorial] Can J Anaesth 1992 39(2):105 9 1544189
Dane TEB, King EG A prospective study of complications after tracheostomy for assisted ventilation Chest 1975 67(4):398 404 1122767
Danon J, Druz WS, Goldberg NB, et al Function of the isolated paced diaphragm and the cervical accessory muscles in C1 quadriplegics Am Rev Respir Dis 1979 119(6):909 19 453711
Darouiche RO, Groover J, Rowland J, et al Pneumococcal vaccination for patients with spinal cord injury Arch Phys Med Rehabil 1993 74(12):1354 7 8259905
Davenport LF. Inhalation therapy in quadriplegic patients. Proc Annu Clin Spinal Cord Inj Conf. 1964;13:45-7. [pmid: 5855187].
Daverat P, Gagnon M, Dartigues JF, et al Initial factors predicting survival in patients with a spinal cord injury J Neurol Neurosurg Psychiatry 1989 52(3):403 6 2926429
Davis GM Exercise capacity of individuals with paraplegia Med Sci Sports Exerc 1993 25(4):423 32 8479296
Davis MK Anesthesia and the neurosurgical patient: Part III--acute spinal cord injury AANA J 1982 50(4):358 62 7148355
De Boeck H, Vincken W, Cham B, et al Diaphragmatic pacing in the treatment of chronic respiratory insufficiency of quadriplegic patients Acta Chir Belg 1989 89(5):276 80 2816210
De Troyer A, Estenne M, Heilporn A Mechanism of active expiration in tetraplegic subjects N Engl J Med 1986 314(12):740 4 3951503
De Vivo MJ, Richards JS, Stover SL, et al Spinal cord injury. Rehabilitation adds life to years West J Med 1991 154(5):602 6 1866959 1002842
Dee PM, Suratt PM, Bray ST, et al Mucous plugging simulating pulmonary embolism in patients with quadriplegia Chest 1984 85(3):363 6 6697793
Dejoya GD, Darby J Pulmonary complications following spinal cord injury Curr Opin Orthop 1997 8(2):28 32
deLacy JL Intubation in cervical spine injury [letter] Anaesth Intensive Care 1987 15(1):
DeLisa JA Clinical rehabilitation research advances in spinal cord injury Paraplegia 1992 30(1):73 4 1589281
DeLuca RV, Grimm DR, Lesser M, et al Effects of a beta-2-agonist on airway hyperreactivity in subjects with cervical spinal cord injury Chest 1999 115(6):1533 8 10378545
Spinal Cord Care: Clinical Practice Guidelines. Available from Eastern Paralyzed Veterans Association, Jackson Heights, NY.
Derrickson J, Ciesla N, Simpson N, et al A comparison of two breathing exercise programs for patients with quadriplegia Phys Ther 1992 72(11):763 9 1409873
Devine A, Watt JW Anaesthesia and diaphragmatic pacing in patients with tetraplegia. A review of peri-operative management in patients over a 10-year period Eur J Anaesthesiol 1996 13(6):553 61 8958485
DeVivo MJ Discharge disposition from model spinal cord injury care system rehabilitation programs Arch Phys Med Rehabil 1999 80(7):785 90 10414763
DeVivo MJ, Black KJ, Stover SL Causes of death during the first 12 years after spinal cord injury Arch Phys Med Rehabil 1993 74(3):248 54 8439250
DeVivo MJ, Fine PR, Maetz HM, et al Prevalence of spinal cord injury: a reestimation employing life table techniques Arch Neurol 1980 37(11):707 8 7436813
DeVivo MJ, Ivie CS 3rd Life expectancy of ventilator-dependent persons with spinal cord injuries Chest 1995 108(1):226 32 7606963
DeVivo MJ, Jackson AB, Dijkers MP, et al. Current research outcomes form the model spinal cord injury systems. Arch Phys Med Rehabil. 1999;80:1363-64. [pmid: 10569428].
DeVivo MJ, Kartus PL, Stover SL, et al Cause of death for patients with spinal cord injuries Arch Intern Med 1989 149(8):1761 6 2669663
DeVivo MJ, Krause S, Lammertse DP. Recent trends in mortality and causes of death among persons with spinal cord injury. Arch Phys Med Rehabil. 1999;80:1411-19. [pmid: 10569435].
DeVivo MJ, Rutt RD, Black KJ, et al Trends in spinal cord injury demographics and treatment outcomes between 1973 and 1986 Arch Phys Med Rehabil 1992 73(5):424 30 1580768
DeVivo MJ, Shewchuk RM, Stover SL, et al A cross-sectional study of the relationship between age and current health status for persons with spinal cord injuries Paraplegia 1992 30(12):820 7 1287535
DeVivo MJ, Stover SL, Black KJ Prognostic factors for 12-year survival after spinal cord injury Arch Phys Med Rehabil 1992 73(2):156 62 1543411
DeVivo MJ, Whiteneck GG, Charles ED Jr. The economic impact of spinal cord injury. In: Stover SL, DeLisa JA, Whiteneck GG, editors. Spinal cord injury: clinical outcomes from the Model Systems. Gaithersburg: Aspen. 1995:p. 234-71.
Dicpinigaitis PV, Grimm DR, Lesser M Cough reflex sensitivity in subjects with cervical spinal cord injury Am J Respir Crit Care Med 1999 159(5 Pt 1):1660 2 10228141
Dicpinigaitis PV, Spungen AM, Bauman WA, et al Bronchial hyperresponsiveness after cervical spinal cord injury Chest 1994 105(4):1073 6 8162727
Dicpinigaitis PV, Spungen AM, Bauman WA, et al Inhibition of bronchial hyperresponsiveness by the GABA-agonist baclofen Chest 1994 106(3):758 61 8082355
Dietz JM, Bertschy M, Gschaedler R, et al Reflections on the intensive care of 106 acute cervical spinal cord injury patients in the resuscitation unit of a general traumatology centre Paraplegia 1986 24(6):343 9 3492700
Dijkers MPJM, Yavuzer G. Short versions of the telephone motor functional independence measure for use with persons with spinal cord injury. Arch Phys Med Rehabil. 1999;80:1477-84. [pmid: 10569444].
DiMarco AF Diaphragm pacing in patients with spinal cord injury Top Spinal Cord Inj Rehabil 1999 5(1):6 20
DiMarco AF, Supinski GS, Petro JA, et al Evaluation of intercostal pacing to provide artificial ventilation in quadriplegics Am J Respir Crit Care Med 1994 150(4):934 40 7921466
DiMarco AF, Wolfson DA, Gottfried SB, et al Sensation of inspired volume in normal subjects and quadriplegic patients J Appl Physiol 1982 53(6):1481 6 7153146
Dingemans LM, Hawn JM Mobility and equipment for the ventilator-dependent tetraplegic Paraplegia 1978 16(2):175 83 733297
DiPasquale PA Exhaler class: a multidisciplinary program for high quadriplegic patients Am J Occup Ther 1986 40(7):482 5 3740200
Ditunno Jr JF, Formal CS Chronic spinal cord injury N Engl J Med 1994 330(8):550 6 8302323
Dollfus P, Gschaedler R Initial hospital care of spinal cord injury patients Paraplegia 1987 25(3):241 3 3601435
Donovan WH, Bedbrook G Comprehensive management of spinal cord injury Clin Symp 1982 34(2):2 36
Donovan WH, Dwyer AP An update on the early management of traumatic paraplegia (nonoperative and operative management) Clin Orthop 1984(189):12 21
Donovan WH, Taylor N Ventilatory assistance in quadriplegia Arch Phys Med Rehabil 1973 54(10):485 8 4582714
Downs JB, Perkins HM, Sutton WW Successful weaning after five years of mechanical ventilation Anesthesiology 1974 40(6):602 3 4597943
Drummond JC Tracheal intubation and cervical injury [letter] Can J Anaesth 1992 39(9):1000 1 1451212
Ducker TB, Zeidman SM Spinal cord injury: Role of steroid therapy Spine 1994 19(20):2281 7 7846572
Duhon DR, Gordon DS Night sweats: Two other causes JAMA 1994 271(20):
Dunagan D, Chin R An abnormal chest film after spinal cord injury J Respir Dis 1996 17(5):
Eastwood EA, Hagglund KJ, Ragnarsson KT, et al. Medical rehabilitation length of stay and outcomes for persons with traumatic spinal cord injury -- 1990-1997. Arch Phys Med Rehabil. 1999;80:1457-63. [pmid: 10569441].
Edlich RF, Jane JA, Crosby IK, et al Initial management of the multiple trauma patient Compr Ther 1981 7(9):31 48
El Masri WS, Short DJ Current concepts: Spinal injuries and rehabilitation Curr Opin Neurol 1997 10(6):484 92 9490147
Elefteriades JA, Hogan JF, Handler A, et al Long-term follow-up of bilateral pacing of the diaphragm in quadriplegia [letter] N Engl J Med 1992 326(21):1433 4 1569991
New York (NY): Elsevier Science Secondary Publishing Division, 1974-. Upated weekly. Available from: Elsevier Science Secondary Publishing Division, New York, New York; DIALOG Information Services, Inc., Palo Alto, CA.
Engel P, Hildebrandt G Long-term spiroergometric studies of paraplegics during the clinical period of rehabilitation Paraplegia 1973 11(2):105 10 4750960
Epstein SW, Vanderlinden RG, Man SF, et al Lung function in diaphragm pacing Can Med Assoc J 1979 120(11):1360 8 313237 1819325
Esclarin A, Bravo P, Arroyo O, et al Tracheostomy ventilation versus diaphragmatic pacemaker ventilation in high spinal cord injury Paraplegia 1994 32(10):687 93 7831076
Estenne M, De Troyer A The effects of tetraplegia on chest wall statics Am Rev Respir Dis 1986 134(1):121 4 2942066
Estenne M, De Troyer A Mechanism of the postural dependence of vital capacity in tetraplegic subjects Am Rev Respir Dis 1987 135(2):367 71 3813198
Estenne M, De Troyer A Cough in tetraplegic subjects: an active process Ann Intern Med 1990 112(1):22 8 2293817
Estenne M, Gorini M Action of the diaphragm during cough in tetraplegic subjects J Appl Physiol 1992 72(3):1074 80 1568963
Estenne M, Knoop C, Vanvaerenbergh J, et al The effect of pectoralis muscle training in tetraplegic subjects Am Rev Respir Dis 1989 139(5):1218 22 2712449
Fabian TC, Boucher BA, Croce MA, et al Pneumonia and stress ulceration in severely injured patients. A prospective evaluation of the effects of stress ulcer prophylaxis Arch Surg 1993 128(2):185 91 discussion 191 2 8431119
Fairshter RD, Vaziri ND, Gordon S Frequency and spectrum of pulmonary diseases in patients with chronic renal failure associated with spinal cord injury Respiration 1983 44(1):58 62 6828807
Fehlings MG, Louw D Initial stabilization and medical management of acute spinal cord injury Am Fam Physician 1996 54(1):155 62 8677831
Fein ED, Grimm DR, Lesser M, et al The effects of ipratropium bromide on histamine-induced bronchoconstriction in subjects with cervical spinal cord injury J Asthma 1998 35(1):49 55 9513582
Fiedler IG, Laud PW, Maiman DJ, et al. Economics of managed care in spinal cord injury. Arch Phys Med Rehabil. 1999;80:1441-9. [pmid: 10569439].
Fischer DA Long-term management of the ventilator patient in the home Cleve Clin Q 1985 52(3):303 6 4064311
Fishburn MJ, Marino RJ, Ditunno JF Jr Atelectasis and pneumonia in acute spinal cord injury Arch Phys Med Rehabil 1990 71(3):197 200 2317137
Fletcher DJ, Taddonio RF, Byrne DW, et al Incidence of acute care complications in vertebral column fracture patients with and without spinal cord injury Spine 1995 20(10):1136 46 7638656
Fodstad H Pacing of the diaphragm to control breathing in patients with paralysis of central nervous system origin Stereotact Funct Neurosurg 1989 53(4):209 22 2518591
Forner JV Lung volumes and mechanics of breathing in tetraplegics Paraplegia 1980 18(4):258 66 7422342
Forner JV, Llombart RL, Valledor MC The flow-volume loop in tetraplegics Paraplegia 1977 15(3):245 51 593715
Forner Valero JV Postural variations of the capacity in tetraplegics Paraplegia 1970 8(3):
Franek A, Turczynski B, Opara J Treatment of spinal spasticity by electrical stimulation J Biomed Eng 1988 10(3):266 70 3260641
Frankel HL Tracheal stenosis following tracheostomy Paraplegia 1970 8(3):172 6 4926412
Frankel HL, Coll JR, Charlifue SW, et al Long-term survival in spinal cord injury: A fifty year investigation Spinal Cord 1998 36(4):266 74 9589527
Frankel HL, Guz A, Noble M Respiratory sensations in patients with cervical cord transection Paraplegia 1971 9(3):132 6 5129052
Frankel HL, Mathias CJ, Spalding JM Mechanisms of reflex cardiac arrest in tetraplegic patients Lancet 1975 2(7946):1183 5 53662
Fraser A, Edmonds-Seal J Spinal cord injuries. A review of the problems facing the anaesthetist Anaesthesia 1982 37(11):1084 98 6753639
Frates RC Jr, Splaingard ML, Smith EO, et al Outcome of home mechanical ventilation in children J Pediatr 1985 106(5):850 6 3858494
Frederick C Noninvasive mechanical ventilation with the iron lung Crit Care Nurs Clin North Am 1994 6(4):831 40 7766356
Frisbie JH, Kache A Increasing survival and changing causes of death in myelopathy patients J Am Paraplegia Soc 1983 6(3):51 6 6619834
Fromm B, Hundt G, Gerner HJ, et al Management of respiratory problems unique to high tetraplegia Spinal Cord 1999 37(4):239 44 10338342
Frost EA Respiratory management of the neurosurgical patient Int Anesthesiol Clin 1986 24(1):105 14 3512448
Fuchs G, Schwarz G, Baumgartner A, et al Fiberoptic intubation in 327 neurosurgical patients with lesions of the cervical spine J Neurosurg Anesthesiol 1999 11(1):11 6 9890380
Fugl-Meyer AR Effects of respiratory muscle paralysis in tetraplegic and paraplegic patients Scand J Rehabil Med 1971 3(4):141 50 5161287
Fugl-Meyer AR A model for treatment of impaired ventilatory function in tetraplegic patients Scand J Rehabil Med 1971 3(4):168 77 5161290
Fugl-Meyer AR, Grimby G Rib-cage and abdominal volume ventilation partitioning in tetraplegic patients Scand J Rehabil Med 1971 3(4):161 7 5161289
Fugl-Meyer AR, Grimby G Ventilatory function in tetraplegic patients Scand J Rehabil Med 1971 3(4):151 60 5161288
Fuhrer MJ, Carter RE, Donovan WH, et al Postdischarge outcomes for ventilator-dependent quadriplegics Arch Phys Med Rehabil 1987 68(6):353 6 3592948
Gabbott DA The effect of single-handed cricoid pressure on neck movement after applying manual in-line stabilisation Anaesthesia 1997 52(6):586 8 9203889
Galandiuk S, Raque G, Appel S, et al The two-edged sword of large-dose steroids for spinal cord trauma Ann Surg 1993 218(4):419 27 8215634 1242993
Gardner BP, Theocleous F, Watt JW, et al Ventilation or dignified death for patients with high tetraplegia BMJ 1985 291(6509):1620 2 3935213 1418404
Gardner BP, Watt JW, Krishnan KR The artificial ventilation of acute spinal cord damaged patients: a retrospective study of forty-four patients Paraplegia 1986 24(4):208 20 3531981
Garner SH, Bloch RF, Sutton JR Heart rate response to facial immersion and apnea in quadriplegia Arch Phys Med Rehabil 1985 66(11):763 7 4062529
Garrido-Garcia H, Martin-Escribano P, Palomera-Frade J, et al Transdiaphragmatic pressure in quadriplegic individuals ventilated by diaphragmatic pacemaker Thorax 1996 51(4):420 3 8733497
Garrido-Garcia H, Mazaira Alvarez J, Martin Escribano P, et al Treatment of chronic ventilatory failure using a diaphragmatic pacemaker Spinal Cord 1998 36(5):310 4 9601109
Garrido H, Mazaira J, Gutierrez P, et al Continuous respiratory support in quadriplegic children by bilateral phrenic nerve stimulation Thorax 1987 42(8):573 7 3499003
Garrido H, Mazaira J, Gutierrez P, et al Permanent artificial respiration by diaphragm pacemaker in tetraplegic children Paraplegia 1986 24(5):276 81 3774364
Garrison JH Emergency signaling for a person with quadriplegia and extraordinary respiratory risk Arch Phys Med Rehabil 1982 63(4):180 1 6211156
Gausch PA, Linder SH, Williams T, et al A functional classification of respiratory compromise in spinal cord injury SCI Nurs 1991 8(1):4 10 2011726
Geisler WO, Jousse AT, Wynne-Jones M Survival in traumatic transverse myelitis Paraplegia 1977 14(4):262 75 846754
Geisler WO, Jousse AT, Wynne-Jones M, et al Survival in traumatic spinal cord injury Paraplegia 1983 21(6):364 73 6664686
Gerndt SJ, Rodriguez JL, Pawlik JW, et al Consequences of high-dose steroid therapy for acute spinal cord injury J Trauma 1997 42(2):279 84 9042882
Gilbert J Critical care management of the patient with acute spinal cord injury Crit Care Clin 1987 3(3):549 67 3332214
Gilbert RD Depression of respiratory function by pneumatic antishock trousers in traumatic quadriplegia Ann Emerg Med 1983 12(6):378 81 6859634
Gilgoff IS, Barras DM, Jones MS, et al Neck breathing: a form of voluntary respiration for the spine-injured ventilator-dependent quadriplegic child Pediatrics 1988 82(5):741 5 3186354
Gilgoff IS, Peng RC, Keens TG Hypoventilation and apnea in children during mechanically assisted ventilation Chest 1992 101(6):1500 6 1600764
Gillis J, Tibballs J, McEniery J, et al Ventilator-dependent children Med J Aust 1989 150(1):10 4 2909835
Glass CA The impact of home based ventilator dependence on family life Paraplegia 1993 31(2):93 101 8446462
Glenn WW Diaphragm pacing: present status Pacing Clin Electrophysiol 1978 1(3):357 70 82954
Glenn WW, Hogan JF, Loke JS, et al Ventilatory support by pacing of the conditioned diaphragm in quadriplegia N Engl J Med 1984 310(18):1150 5 6608692
Glenn WW, Hogan JF, Phelps ML Ventilatory support of the quadriplegic patient with respiratory paralysis by diaphragm pacing Surg Clin North Am 1980 60(5):1055 78 6968983
Glenn WW, Holcomb WG, Hogan J, et al Diaphragm pacing by radiofrequency transmission in the treatment of chronic ventilatory insufficiency. Present status J Thorac Cardiovasc Surg 1973 66(4):505 20 4755442
Glenn WW, Holcomb WG, McLaughlin AJ, et al Total ventilatory support in a quadriplegic patient with radiofrequency electrophrenic respiration N Engl J Med 1972 286(10):513 6 4501052
Glenn WW, Holcomb WG, Shaw RK, et al Long-term ventilatory support by diaphragm pacing in quadriplegia Ann Surg 1976 183(5):566 77 1275596 1344348
Glenn WW, Phelps M, Gersten LM. Diaphragm pacing in the management of central alveolar hypoventilation. In: Guilleminault C, Dement WC, editors. Sleep apnea syndromes. New York: Liss. 1978:p.333-45.
Glenn WW, Phelps ML Diaphragm pacing by electrical stimulation of the phrenic nerve Neurosurgery 1985 17(6):974 84 3908966
Goldberg AI, Cane RD, Childress D, et al Combined nasal intermittent positive-pressure ventilation and rocking bed in chronic respiratory insufficiency. Nocturnal ventilatory support of a disabled person at home Chest 1991 99(3):627 9 1899820
Goldsmith HS, Saunders RL Low chest compression for removal of pulmonary secretions [letter] Surgery 1983 94(5):847 8
Gordon E, von Holst H, Rudehill A Outcome of head injury in 2298 patients treated in a single clinic during a 21-year period J Neurosurg Anesthesiol 1995 7(4):235 47 8563443
Gorton S, Burke C, Appleton DB Chronic diaphragmatic pacing in a quadriplegic boy J Paediatr Child Health 1993 29(1):66 7 8461185
Gothe B, Maximin A, Sajkov D, et al Cognitive disturbances and nocturnal hypoxemia in tetraplegic patients [letter] Spinal Cord 1999 37(1):71 2 10025702
Gower DJ, Davis CH Jr Home ventilator dependence after high cervical cord injury South Med J 1985 78(8):1010 1 4023771
Graf CJ, Rossi NP Pulmonary edema and the central nervous system: a clinico-pathological study Surg Neurol 1975 4(3):319 25 1179248
Grande CM, Barton CR, Stene JK Appropriate techniques for airway management of emergency patients with suspected spinal cord injury [letter] Anesth Analg 1988 67(7):714 5 3382051
Grassino A A rationale for training respiratory muscles Int Rehabil Med 1984 6(4):175 8 6396265
Graus F, Ribalta T, Ribera G, et al Acute necrotic myelopathy associated with influenza vaccination Lancet 1987 1(8545):1311 2
Graves DE, Frankiewicz RG, Carter E. Gain in functional ability during medical rehabilitation as related to rehabilitation process indices and neurologic measures. Arch Phys Med Rehabil. 1999;80:1464-70. [pmid: 10569442].
Green BA, Eismont FJ, O'Heir JT Pre-hospital management of spinal cord injuries Paraplegia 1987 25(3):229 38 3601433
Green BA, Green KL, Klose KJ Kinetic Nursing for acute spinal cord injury patients Paraplegia 1980 18(3):181 6 7413240
Grimm DR, DeLuca RV, Lesser M, et al Effects of GABA-B agonist baclofen on bronchial hyperreactivity to inhaled histamine in subjects with cervical spinal cord injury Lung 1997 175(5):333 41 9270990
Gronert GA Use of suxamethonium in cord patients--Whether and when Anaesthesia 1998 53(10):1035 6 9893563
Gross D, Ladd HW, Riley EJ, et al The effect of training on strength and endurance of the diaphragm in quadriplegia Am J Med 1980 68(1):27 35 7350802
Grundy D, Swain A, Russell J ABC of spinal cord injury: Early management and complications - I BMJ 1986 292(6512):44 7 3080062 1338987
Gschaedler R, Dollfus P, Mole JP, et al Reflections on the intensive care of acute cervical spinal cord injuries in a general traumatology centre Paraplegia 1979 17(1):58 61 492751
Guin P, Johnson M What financial resources are available for ventilator dependent quadriplegics who have no medical insurance and who are not veterans? SCI Nurs 1989 6(3):
Gupta A, McClelland MR, Evans A, et al Minitracheotomy in the early respiratory management of patients with spinal injuries Paraplegia 1989 27(4):269 77 2780082
Haas F, Axen K, Pineda H Aerobic capacity in spinal cord injured people Cent Nerv Syst Trauma 1986 3(1):77 91 3524869
Haas F, Axen K, Pineda H, et al Temporal pulmonary function changes in cervical cord injury Arch Phys Med Rehabil 1985 66(3):139 44 3977564
Hachen HJ Idealized care of the acutely injured spinal cord in Switzerland J Trauma 1977 17(12):931 6 592441
Hackler RH A 25-year prospective mortality study in the spinal cord injured patient: comparison with the long-term living paraplegic J Urol 1977 117(4):486 8 850323
Hai Minh Le, Aten JL, Chiang JT, et al Comparison between conventional cap and one-way valve in the decannulation of patients with long-term tracheostomies Respiratory Care 1993 38(11):1161 7
Hall JC, Douglas MC, Burke D Rupture of diaphragm associated with spinal cord injury Aust N Z J Surg 1981 51(6):594 7 6949559
Hall KM, Cohen ME, Wright J, et al. Characteristics of the functional independence measure in traumatic spinal cord injury. Arch Phys Med Rehabil. 1999;80:1471-6. [pmid: 10569443].
Hall KM, Knudsen ST, Wright J, et al. Follow-up study of individuals wit high tetraplegia (C1-C4) 14 to 24 years postinjury. Arch Phys Med Rehabil. 1999;80:1507-13. [pmid: 10569448].
Hambly PR, Martin B Anaesthesia for chronic spinal cord lesions Anaesthesia 1998 53(3):273 89 9613273
Hammon WE, Martin RJ Chest physical therapy for acute atelectasis. A report on its effectiveness Phys Ther 1981 61(2):217 20 7465624
Harlid R, Andersson G The Swedish experience in the organisation of domiciliary ventilation for patients with a high spinal cord injury Paraplegia 1993 31(3):157 9 8479780
Harpin RP, Gignac SP, Epstein SW, et al Diaphragm pacing and continuous positive airway pressure Am Rev Respir Dis 1986 134(6):1321 3 3538959
Harris P Associated injuries in traumatic paraplegia and tetraplegia Paraplegia 1968 5(4):215 20 5684477
Hart GB, Strauss MB, Riker J Vital capacity of quadriplegic patients treated with hyperbaric oxygen J Am Paraplegia Soc 1984 7(1):8 9 6707625
Hartkopp A, Bronnum-Hansen H, Seidenschnur AM, et al Survival and cause of death after traumatic spinal cord injury. A long-term epidemiological survey from Denmark Spinal Cord 1997 35(2):76 85 9044513
Harvey C, Rothschild BB, Asmann AJ, et al New estimates of traumatic SCI prevalence: a survey-based approach Paraplegia 1990 28(9):537 44 2287518
Harvey LA, Ellis ER The effect of continuous positive airway pressures on lung volumes in tetraplegic patients Paraplegia 1996 34(1):54 8 8848324
Hassan HG Letter: Anaesthesia in paraplegic patients Anaesthesia 1974 29(5):629 30 4611266
Hastings RH, Kelley SD Neurologic deterioration associated with airway management in a cervical spine-injured patient Anesthesiology 1993 78(3):580 3 8457057
National Library of Medicine jointly with American Hospital Association. 1975-. Updated monthly. Available from National Library of Medicine, Bethesda, MD; DIALOG Information Services, Palo Alto, CA; Ovid Technologies, Inc., New York, NY.
Herrin TJ, Brzustowicz R, Hendrickson M Anesthetic management of neck trauma South Med J 1979 72(9):1102 6 472830
Higgins MS, Clarkson KP, Blanks ST Combined use of indirect orotracheal intubation techniques Anesth Analg 1996 82(1):216 7 8712407
Hjeltnes N Cardiorespiratory capacity in tetra- and paraplegia shortly after injury Scand J Rehabil Med 1986 18(2):65 70 3775304
Hoang KD, Pollack Jr CV The utility of parenteral glucocorticoids in the emergency department J Emerg Med 1994 12(4):507 19 7963398
Hoffman MD Cardiorespiratory fitness and training in quadriplegics and paraplegics Sports Med 1986 3(5):312 30 3529281
Hopman MT, van der Woude LH, Dallmeijer AJ, et al Respiratory muscle strength and endurance in individuals with tetraplegia Spinal Cord 1997 35(2):104 8 9044518
Hoshi S Injuries of the cervical spine Asian Med J 1986 29(8):471 6
Hsu S, Dreisbach JN, Charlifue SW, et al Glottic and tracheal stenosis in spinal cord injured patients Paraplegia 1987 25(2):136 48 3588009
Huldtgren AC, Fugl-Meyer AR, Jonasson E, et al Ventilatory dysfunction and respiratory rehabilitation in post-traumatic quadriplegia Eur J Respir Dis 1980 61(6):347 56 7202607
Humphreys M Nursing care in paraplegia and tetraplegia Nurs Mirror Midwives J 1975 141(19):52 5 1042887
Hunt CE, Brouillette RT, Weese-Mayer DE, et al Diaphragm pacing in infants and children Pacing Clin Electrophysiol 1988 11(11 Pt 2):2135 41 2463600
Hussey RW, Rossier AB, Sarkarati M An algorithm or treatment plan for acute spinal cord injury J Am Paraplegia Soc 1983 6(2):27 32 6886690
Iida H, Tachibana S, Kitahara T, et al Association of head trauma with cervical spine injury, spinal cord injury, or both J Trauma 1999 46(3):450 2 10088849
Ivatury R, Siegel JH, Stahl WM, et al Percutaneous tracheostomy after trauma and critical illness J Trauma 1992 32(2):133 40 1740791
Ivy ME, Cohn SM Addressing the myths of cervical spine injury management Am J Emerg Med 1997 15(6):591 5 9337369
Jackson AB, Groomes TE Incidence of respiratory complications following spinal cord injury Arch Phys Med Rehabil 1994 75(3):270 5 8129577
Jackson AB, Wadley V. A multicenter study of women's self-reported reproductive health after spinal cord injury. Arch Phys Med Rehabil. 1999;80:1420-8. [pmid: 10569436].
Jaeger RJ, Turba RM, Yarkony GM, et al Cough in spinal cord injured patients: comparison of three methods to produce cough Arch Phys Med Rehabil 1993 74(12):1358 61 8018145
Janelli HV, Krouskop TA, Canzoneri J, et al Positive pressure respiratory assist for wheelchair-mobile persons Arch Phys Med Rehabil 1980 61(3):143 4 6989344
Jaspar N, Kruger M, Ectors P, et al Unilateral chest wall paradoxical motion mimicking a flail chest in a patient with hemilateral C7 spinal injury Intensive Care Med 1986 12(6):396 8 3794055
Johnson CD, Perea Lopez RM, Rodriguez L Acute spinal cord and head injury: case report and discussion of cardiac, respiratory and endocrine abnormalities Bol Asoc Med P R 1998 90(4-6):95 101 9866278
Johnson K, Grant T, Peterson P Ventilator weaning for the patient with high-level tetraplegia Top Spinal Cord Inj Rehabil 1997 2(3):11 20
Johnson RL, Brooks CA, Whiteneck GG Cost of traumatic spinal cord injury in a population-based registry Spinal Cord 1996 34(8):470 80 8856854
Jordan SA, Wellborn WR 3d, Kovnick J, et al Understanding and treating motivation difficulties in ventilator-dependent SCI patients Paraplegia 1991 29(7):431 42 1784509
Joyce SM Cervical immobilization during orotracheal intubation in trauma victims [editorial] Ann Emerg Med 1988 17(1):
Kaufman HH, Satterwhite T, McConnell BJ, et al Deep vein thrombosis and pulmonary embolism in head injured patients Angiology 1983 34(10):627 38 6226216
Kellman R The cervical spine in maxillofacial trauma. Assessment and airway management Otolaryngol Clin North Am 1991 24(1):1 13 2027690
Kelly BJ, Luce JM The diagnosis and management of neuromuscular diseases causing respiratory failure Chest 1991 99(6):1485 94 2036834
Keltz H, Kaplan S, Stone DJ Effect of quadriplegia and hemidiaphragmatic paralysis on thoraco-abdominal pressure during respiration Am J Phys Med 1969 48(3):109 15 4239698
Kendall RJ, Lafuente J, Hosie KB Central pontine myelinolysis after an operation J R Soc Med 1997 90(8):445 6 9306999 1296460
Khella L, Stoner EK 101 cases of spinal cord injury 15-year follow-up study in a large city hospital. Am J Phys Med 1977 56(1):21 32
King SA The tracheotomized patient. Tracheal toilet and speech [letter] Chest 1995 107(6):
Kirby NA The individual with high quadriplegia Nurs Clin North Am 1989 24(1):179 91 2522191
Kirby NA, Barnerias MJ, Siebens AA An evaluation of assisted cough in quadriparetic patients Arch Phys Med Rehabil 1966 47(11):705 10 5332775
Kirshblum S, Johnston MV, Brown J, et al Predictors of dysphagia after spinal cord injury Arch Phys Med Rehabil 1999 80(9):1101 5 10489016
Kish DL Prehospital management of spinal trauma: An evolution Crit Care Nurs Q 1999 22(2):36 43 10646441
Kiwerski J Respiratory problems in patients with high lesion quadriplegia Int J Rehabil Res 1992 15(1):49 52 1601568
Kiwerski J, Weiss M, Chrostowska T Analysis of mortality of patients after cervical spine trauma Paraplegia 1981 19(6):347 51 7312387
Kiwerski JE Factors contributing to the increased threat to life following spinal cord injury Paraplegia 1993 31(12):793 9 8115172
Klefbeck B, Sternhag M, Weinberg J, et al Obstructive sleep apneas in relation to severity of cervical spinal cord injury Spinal Cord 1998 36(9):621 8 9773446
Kocan MJ Pulmonary considerations in the critical care phase Crit Care Nurs Clin North Am 1990 2(3):369 74 2264959
Kokkola K, Moller K, Lehtonen T Pulmonary function in tetraplegic and paraplegic patients Ann Clin Res 1975 7(2):76 9 1181978
Kotze PL, Verster J, De Villiers SJ, et al Diaphragm pacing in the treatment of ventilatory failure S Afr Med J 1985 68(4):223 4 3875903
Kraus JF, Franti CE, Borhani NO, et al Survival with an acute spinal-cord injury J Chronic Dis 1979 32(3):269 83 429471
Krause JS, Coker J, Charlifue S, et al. Health behaviors among American Indians with spinal cord injury: comparison with data from the 1996 behavioral risk factor surveillance system. Arch Phys Med Rehabil. 1999;80:1435-40. [pmid: 10569438].
Krause JS, Kewman D, DeVivo MJ, et al. Employment after spinal cord injury: an analysis of cases from the model spinal cord injury systems. Arch Phys Med Rehabil. 1999;80:1492-500. [pmid: 10569446].
Krieger AJ, Detwiler JS, Fandozzi R Electrophrenic respiration: a breathing support system in quadriplegia Crit Care Med 1974 2(3):155 8 4837485
Krieger AJ, Gropper MR, Adler RJ Electrophrenic respiration after intercostal to phrenic nerve anastomosis in a patient with anterior spinal artery syndrome: technical case report Neurosurgery 1994 35(4):760 3 7808625
Krishnan KR Ventilation or dignified death for patients with high tetraplegia [letter] BMJ 1986 292(6520):
Krishnan KR Recommendations concerning the costing and management for patients requiring domiciliary ventilation Paraplegia 1993 31(5):276 9 8332372
Krishnan KR, Watt JW Ventilator dependence and high tetraplegia [editorial] Paraplegia 1993 31(3):141 2 8479775
Lamid S, Ragalie GF, Welter K Respirator-dependent quadriplegics: problems during the weaning period J Am Paraplegia Soc 1985 8(2):33 7 3842980
Lane CS Inspiratory muscle weight training and its effect on the vital capacity of patients with quadriplegia Cardiopulmonary Q 1982 5(10):
Lanig IS, Lammertse DP The respiratory system in spinal cord injury Phys Med Rehabil Clin North Am 1992 3(4):725 40
Lasfargues JE, Custis D, Morrone F, et al A model for estimating spinal cord injury prevalence in the United States Paraplegia 1995 33(2):62 8 7753569
Le CT, Price M Survival from spinal cord injury J Chronic Dis 1982 35(6):487 92 7076789
Leder SB Perceptual rankings of speech quality produced with one-way tracheostomy speaking valves J Speech Hear Res 1994 37(6):1308 12 7877289
Ledsome JR, Sharp JM Pulmonary function in acute cervical cord injury Am Rev Respir Dis 1981 124(1):41 4 7258818
Lehmann KG, Shandling AH, Yusi AU, et al Altered ventricular repolarization in central sympathetic dysfunction associated with spinal cord injury Am J Cardiol 1989 63(20):1498 504 2729138
Lemons VR, Wagner FC Jr Respiratory complications after cervical spinal cord injury Spine 1994 19(20):2315 20 7846577
Lerman RM, Weiss MS Progressive resistive exercise in weaning high quadriplegics from the ventilator Paraplegia 1987 25(2):130 5 3588008
Lesoin F, Delandsheer E, Lozes G, et al Electromyography of the diaphragm in patients with cervical spine lesions necessitating assisted ventilation [letter] Lancet 1983 1(8338):1385 6 6134162
Levine SP, Koester DJ, Kett RL Independently activated talking tracheostomy systems for quadriplegic patients Arch Phys Med Rehabil 1987 68(9):571 3 3632328
Levy LF, Couto MT, Dhaffala A Spinal column and cord injury in Harare Central Hospital Afr J Neurol Sci 1994 13(1):4 5
Lin KH, Lai YL, Wu HD, et al Effects of an abdominal binder and electrical stimulation on cough in patients with spinal cord injury J Formos Med Assoc 1998 97(4):292 5 9585684
Lind B, Bake B, Lundqvist C, et al Influence of halo vest treatment on vital capacity Spine 1987 12(5):449 52 3629395
Linder SH Functional electrical stimulation to enhance cough in quadriplegia Chest 1993 103(1):166 9 8417872
Loveridge B, Badour M, Dubo H Ventilatory muscle endurance training in quadriplegia: effects on breathing pattern Paraplegia 1989 27(5):329 39 2689970
Loveridge BM, Dubo HI Breathing pattern in chronic quadriplegia Arch Phys Med Rehabil 1990 71(7):495 9 2350219
Lozewicz S, Potter DR, Costello JF, et al Diaphragm pacing in ventilatory failure BMJ 1981 283(6298):1015 6 6794743 1507294
Luce JM Medical management of spinal cord injury Crit Care Med 1985 13(2):126 31 3881221
Luce JM, Culver BH Respiratory muscle function in health and disease Chest 1982 81(1):82 90 6459213
Lucke KT Pulmonary management following acute SCI J Neurosci Nurs 1998 30(2):91 104 9642617
MacKechnie J, Wade PA Case report: electrophrenic respiration and discharge planning with a C1 quadriplegic J Neurosurg Nurs 1984 16(6):347 52 6568261
Mackenzie CF, Shin B, Krishnaprasad D, et al Assessment of cardiac and respiratory function during surgery on patients with acute quadriplegia J Neurosurg 1985 62(6):843 9 3998833
MacLean IC, Mattioni TA Phrenic nerve conduction studies: a new technique and its application in quadriplegic patients Arch Phys Med Rehabil 1981 62(2):70 3 6972202
Maeda CJ, Baydur A, Waters RL, et al The effect of the halovest and body position on pulmonary function in quadriplegia J Spinal Disord 1990 3(1):47 51 2134410
Maeder K, Ginunas VJ, Montgomerie JZ, et al Methicillin-resistant Staphylococcus aureus (MRSA) colonization in patients with spinal cord injury Paraplegia 1993 31(10):639 44 8259326
Maglio A, Venerando A, Dal Monte A, et al Spiro-graphic and thoraco-metric studies in paraplegic patients Paraplegia 1966 4(2):116 21 5969401
Mandell GA, Harcke HT, Padman R, et al CT digital radiography: alternative technique for airway evaluation in physically disabled patients Pediatr Radiol 1987 17(6):505 8 3684366
Mangold H Principles of automatic processing of speech signals and their application in medical technology and for aids for handicapped Med Prog Technol 1988 14(1):39 56 2976877
Mansel JK, Norman JR Respiratory complications and management of spinal cord injuries Chest 1990 97(6):1446 52 2189697
Marcy TW, Loke JSO Diaphragm pacing for ventilatory insufficiency J Intensive Care Med 1987 2(6):345 53
Marinelli A, Garrard CS, Gold HO, et al Endotracheal prosthesis for positive pressure ventilation after tracheal injury Crit Care Med 1981 9(11):805 6 7297086
Marino RJ, Ditunno JF, Donovan WH, et al. Neurologic recovery after traumatic spinal cord injury: data from the model spinal cord injury systems. Arch Phys Med Rehabil. 1999;80:1391-6. [pmid: 10569432].
Marks RJ, Forrester PC, Calder I, et al Anaesthesia for transoral craniocervical surgery Anaesthesia 1986 41(10):1049 52 3789353
Massery M Manual breathing and coughing aids Phys Med Rehabil Clin North Am 1996 7(2):407 22
Maynard FM Responding to requests for ventilator removal from patients with quadriplegia West J Med 1991 154(5):617 9 1866963 1002847
Mayr W, Bijak M, Girsch W, et al Multichannel stimulation of phrenic nerves by epineural electrodes. Clinical experience and future developments ASAIO J 1993 39(3):M729 35 8268634
Mazzon D, Di Stefano E, Dametto G, et al Percutaneous dilational tracheostomy after anterior cervical spine fixation J Neurosurg Anesthesiol 1996 8(4):293 5 8884626
McCagg C Postoperative management and acute rehabilitation of patients with spinal cord injuries Orthop Clin North Am 1986 17(1):171 82 3945478
McCool FD, Mayewski RF, Shayne DS, et al Intermittent positive pressure breathing in patients with respiratory muscle weakness. Alterations in total respiratory system compliance Chest 1986 90(4):546 52 3530648
McCool FD, Pichurko BM, Slutsky AS, et al Changes in lung volume and rib cage configuration with abdominal binding in quadriplegia J Appl Physiol 1986 60(4):1198 202 3700303
McEvoy RD, Mykytyn I, Sajkov D, et al Sleep apnoea in patients with quadriplegia Thorax 1995 50(6):613 9 7638801
McEwen DR Diaphragmatic pacing. An option for patients with quadriplegic respiratory paralysis [published erratum appears in AORN J 1993 Nov;58(5):960] AORN J 1993 58(3):547 58 8285948
McKinley AC, Auchincloss JH Jr, Gilbert R, et al Pulmonary function, ventilatory control, and respiratory complications in quadriplegic subjects Am Rev Respir Dis 1969 100(4):526 32 5350017
McKinley WO, Huang ME, Brunsvold KT. Neoplastic versus traumatic spinal cord injury: an outcome comparison after inpatient rehabilitation. Arch Phys Med Rehabil. 1999;80:1253-7. [pmid: 10527083].
McKinley WO, Jackson AB, Cardenas DD, et al Long-term medical complications after traumatic spinal cord injury: a regional model systems analysis Arch Phys Med Rehabil 1999(80):1402 10
McKinley WO, Johns JS, Musgrove JJ Clinical presentations, medical complications, and functional outcomes of individuals with gunshot wound-induced spinal cord injury Am J Phys Med Rehabil 1999 78(2):102 7 10088582
McMichan JC, Michel L, Westbrook PR Pulmonary dysfunction following traumatic quadriplegia. Recognition, prevention, and treatment JAMA 1980 243(6):528 31 7351783
Mead J, Banzett RB, Lehr J, et al Effect of posture on upper and lower rib cage motion and tidal volume during diaphragm pacing Am Rev Respir Dis 1984 130(2):320 1 6331777
Bethesda (MD): National Library of Medicine, 1966-. Updated weekly. Available from: National Library of Medicine; DIALOG Information Services, Inc., Palo Alto, CA: Ovid Technologies, Inc., New York, NY.
Mehnert JH, Dupont TJ, Rose DH Intermittent epidural morphine instillation for control of postoperative pain Am J Surg 1983 146(1):145 51 6869673
Mendez N, Mora F, Passariello G, et al Applying vowel sounds to command support systems for motor-impaired people Med Biol Eng Comput 1987 25(5):520 6 2965780
Menter RR, Bach J, Brown DJ, et al A review of the respiratory management of a patient with high level tetraplegia Spinal Cord 1997 35(12):805 8 9429258
Meschino A, Devitt JH, Koch JP, et al The safety of awake tracheal intubation in cervical spine injury Can J Anaesth 1992 39(2):114 7 1544191
Metcalf JA Acute phase management of persons with spinal cord injury: a nursing diagnosis perspective Nurs Clin North Am 1986 21(4):589 98 3641256
Metcalf VA Vital capacity and glossopharyngeal breathing in traumatic quadriplegia Phys Ther 1966 46(8):835 8 5945677
Meyers AR, Bisbee A, Winter M. The 'Boston Model' of managed care spinal cord injury: a cross-sectional study of the outcomes of risk-based, prepaid, managed care. Arch Phys Med Rehabil. 1999;80:1450-6. [pmid: 10569440].
Mikawa Y, Yamaoka T, Watanabe R Compression of the spinal cord due to destructive spondyloarthropathy of the atlanto-axial joints: A case report J Bone Joint Surg Am 1996 78(12):1911 4 8986670
Miller HJ, Thomas E, Wilmot CB Pneumobelt use among high quadriplegic population Arch Phys Med Rehabil 1988 69(5):369 72 3163246
Miller JI, Farmer JA, Stuart W, et al Phrenic nerve pacing of the quadriplegic patient J Thorac Cardiovasc Surg 1990 99(1):35 9 discussion 39 40 2294363
Miller JM 3d, Downey JA, Darling RC The cardiovascular effects of breathing 5 per cent carbon dioxide Arch Phys Med Rehabil 1969 50(8):442 7 5806087
Minaire P, Demolin P, Bourret J, et al Life expectancy following spinal cord injury: a ten-years survey in the Rhone-Alpes Region, France, 1969-1980 Paraplegia 1983 21(1):11 5 6835687
Mitcho K, Yanko JR Acute care management of spinal cord injuries Crit Care Nurs Q 1999 22(2):60 79 10646444
Montero JC, Feldman DJ, Montero D Effects of glossopharyngeal breathing on respiratory function after cervical cord transection Arch Phys Med Rehabil 1967 48(12):650 3 5235188
Moore DC. Complications of regional anesthesia. Clin Anesth. 1969;2:218-51. [pmid: 4253502].
Mortola JP, Sant'Ambrogio G Motion of the rib cage and the abdomen in tetraplegic patients Clin Sci Mol Med 1978 54(1):25 32 620490
Mortola JP, Sant'Ambrogio G Mechanics of breathing in tetraplegics Am Rev Respir Dis 1979 119(2 Pt 2):131 4 154861
Moseley RV, Doty DB Hypoxemia during the first twelve hours after battle injury Surgery 1970 67(5):765 72 5438676
Moulton A, Silver JR Chest movements in patients with traumatic injuries of the cervical cord Clin Sci 1970 39(3):407 22 5459168
Moxham J, Potter D Diaphragm pacing Thorax 1988 43(3):161 2 3261459
Moxham J, Shneerson JM Diaphragmatic pacing Am Rev Respir Dis 1993 148(2):533 6 8342921
Muckart DJ, Bhagwanjee S, van der Merwe R Spinal cord injury as a result of endotracheal intubation in patients with undiagnosed cervical spine fractures Anesthesiology 1997 87(2):418 20 9286906
Mugica J, Dejean D, Smits K, et al Direct diaphragm stimulation Pacing Clin Electrophysiol 1987 10(1 Pt 2):252 6 2436188
Mulroy SJ, Gronley JK, Newsam CJ, et al Electromyographic activity of shoulder muscles during wheelchair propulsion by paraplegic persons Arch Phys Med Rehabil 1996 77(2):187 93 8607745
Myllynen P, Kivioja A, Rokkanen P, et al Cervical spinal cord injury: the correlations of initial clinical features and blood gas analyses with early prognosis Paraplegia 1989 27(1):19 26 2493625
Naito Y, Mima H, Itaya T, et al Continuous oxygen insufflation using a speaking tracheostomy tube is effective in preventing aspiration during feeding Anesthesiology 1996 84(2):448 50 8602678
Nates JL, Cooper DJ, Day B, et al Acute weakness syndromes in critically ill patients--a reappraisal Anaesth Intensive Care 1997 25(5):502 13 9352763
Newsom-Davis J Neural control of the diaphragm. B. Sensory aspects. High cervical cord transection Am Rev Respir Dis 1979 119(2 Pt 2):
Noble MI, Eisele JR, Frankel HL, et. al The role of the diaphragm in the sensation of holding the breath Clin Sci 1971 41(3):275 83 5571505
Noble MI, Frankel HL, Else W, et al The ability of man to detect added resistive loads to breathing Clin Sci 1971 41(3):285 7 5571506
Nobunaga AI, Go GK, Karunas RB. Recent demographic and injury trends in people served by the model spinal cord injury systems. Arch Phys Med Rehabil. 1999;80:1372-82. [pmid: 10569430].
Nochomovitz ML, Hopkins M, Brodkey J, et al Conditioning of the diaphragm with phrenic nerve stimulation after prolonged disuse Am Rev Respir Dis 1984 130(4):685 8 6333194
Nochomovitz ML, Peterson DK, Stellato TA Electrical activation of the diaphragm Clin Chest Med 1988 9(2):349 58 3292133
Nyquist RH, Bors E Mortality and survival in traumatic myelopathy during nineteen years, from 1946 t0 1965 Paraplegia 1967 5(1):22 48 6033346
O'Connor JR, Leitner LA Traumatic quadriplegia. A comprehensive review J Rehabil 1971 37(3):14 20
Oakes DD, Wilmot CB, Halverson D, et al Neurogenic respiratory failure: a 5-year experience using implantable phrenic nerve stimulators Ann Thorac Surg 1980 30(2):118 21 6968185
Ohry A, Molho M, Rozin R Alterations of pulmonary function in spinal cord injured patients Paraplegia 1975 13(2):101 8 1178209
Okita Y, Takamoto S, Ando M, et al Repair for aneurysms of the entire descending thoracic aorta or thoracoabdominal aorta using a deep hypothermia Eur J Cardiothorac Surg 1997 12(1):120 6 9262092
Oku Y, Kurusu M, Hara Y, et al Ventilatory responses and subjective sensations during arm exercise and hypercapnia in patients with lower-cervical and upper-thoracic spinal cord injuries Intern Med 1997 36(11):776 80 9392348
Opaskar Hincman H, Ramakrishnan Bhaskar K DeFeudis O'Sullivan D, Brown R, et al Lipids in airway mucus of acute quadriplegic patients Exp Lung Res 1990 16(4):369 85 2394202
Pajareya K Traumatic spinal cord injuries in Thailand: An epidemiologic study in Siriraj Hospital, 1989-1994 Spinal Cord 1996 34(10):608 10 8896127
Papadopoulos SM Spinal cord injury Curr Opin Neurol Neurosurg 1992 5(4):554 7 1515694
Pentland B Quadriplegia and cardiorespiratory fitness Lancet 1993 341(8842):413 4 8094180
Peterson P. Pulmonary physiology and medical management. In: Whiteneck G, editor. The Management of High Quadriplegia. New York: Demos. 1989:p. 35-50.
Peterson P, Brooks CA, Mellick D, et al Protocol for ventilator management in high tetraplegia Top Spinal Cord Inj Rehabil 1997 2(3):101 6
Peterson W, Charlifue W, Gerhart A, et al Two methods of weaning persons with quadriplegia from mechanical ventilators Paraplegia 1994 32(2):98 103 8015852
Peterson WP, Barbalata L, Brooks CA, et al The effect of tidal volumes on the time to wean persons with high tetraplegia from ventilators Spinal Cord 1999 37(4):284 8 10338350
Peterson WP, Whiteneck GG, Gerhart KA Chest tubes, lung entrapment, and failure to wean from the ventilator. Report of three patients with quadriplegia Chest 1994 105(4):1292 4 8162779
Pitts LH Intensive care of neurologic diseases Curr Opin Neurol Neurosurg 1988 1(1):14 21
Platts RG, Fraser MH Assistive technology in the rehabilitation of patients with high spinal cord lesions Paraplegia 1993 31(5):280 7 8332373
Pokorski M, Morikawa T, Takaishi S, et al Ventilatory responses to chemosensory stimuli in quadriplegic subjects Eur Respir J 1990 3(8):891 900 2292285
Preston K, Coughlin R Phrenic nerve stimulators Rehabil Nurs 1984 9(1):17 22
Price C, Makintubee S, Herndon W, et al Epidemiology of traumatic spinal cord injury and acute hospitalization and rehabilitation charges for spinal cord injuries in Oklahoma, 1988-1990 Am J Epidemiol 1994 139(1):37 47 8296773
Price M Causes of death in 11 of 227 patients with traumatic spinal cord injury over period of nine years Paraplegia 1973 11(3):217 20 4764888
Quimby CW Jr, Williams RN, Greifenstein FE Anesthetic problems of the acute quandriplegic patient Anesth Analg 1973 52(3):333 40 4581766
Ragnarsson KT, Hall KM, Wilmot CB et al. Management of pulmonary, cardiovascular, and metabolic conditions after spinal cord injury. In: Stover SL, DeLisa JA, Whiteneck GG, editors. Spinal cord injury: clinical outcomes from the Model Systems. Gaithersburg: Aspen. 1995:p.79-99.
Ravichandran G, Silver JR Survival following traumatic tetraplegia Paraplegia 1982 20(5):264 9 7177691
Reines HD, Harris RC Pulmonary complications of acute spinal cord injuries Neurosurgery 1987 21(2):193 6 3658131
Rhodes EC, McKenzie DC, Coutts KD, et al A field test for the prediction of aerobic capacity in male paraplegics and quadraplegics Can J Appl Sport Sci 1981 6(4):182 6 7318135
Richard I, Giraud M, Perrouin-Verbe B, et al Laryngotracheal stenosis after intubation or tracheostomy in patients with neurological disease Arch Phys Med Rehabil 1996 77(5):493 6 8629927
Richards JS, Bombardier CH, Tate D, et al. Access to the environment and life satisfaction after spinal cord injury. Arch Phys Med Rehabil. 1999;60:1501-6.
Rimel R, Winn R, Rice P, et al Pre-hospital treatment of the spinal cord patient Resuscitation 1981 9(1):29 37 7255944
Roncoroni AJ Lack of breathlessness during apnea in a patient with high spinal cord transection Chest 1972 62(4):514 5 5078013
Roth EJ, Lu A, Primack S, et al Ventilatory function in cervical and high thoracic spinal cord injury. Relationship to level of injury and tone Am J Phys Med Rehabil 1997 76(4):262 7 9267184
Roth EJ, Nussbaum SB, Berkowitz M, et al Pulmonary function testing in spinal cord injury: correlation with vital capacity Paraplegia 1995 33(8):454 7 7478739
Ryan M, Klein S, Bongard F Missed injuries associated with spinal cord trauma Am Surg 1993 59(6):371 4 8507062
Sackett DL Rules of evidence and clinical recommendations on the use of antithrombotic agents Chest 1989 95(2 Suppl):2S 4S 2914516
Sajkov D, Marshall R, Walker P, et al Sleep apnoea related hypoxia is associated with cognitive disturbances in patients with tetraplegia Spinal Cord 1998 36(4):231 9 9589522
Saltzstein R, Melvin J Ventilatory compromise in spinal cord injury--a review J Am Paraplegia Soc 1986 9(1-2):6 9 3746293
Samsa G, Hoenig H, Carswell J, et al Developing a national registry of veterans with spinal cord dysfunction: experiences and implications Spinal Cord 1998 36(1):57 62 9471140
Samsa GP, Landsman PB, Hamilton B Inpatient hospital utilization among veterans with traumatic spinal cord injury Arch Phys Med Rehabil 1996 77(10):1037 43 8857883
Scher AT The radiology of pulmonary complications associated with acute spinal cord injury S Afr Med J 1982 62(10):321 4 7112294
Segal JL, Brunnemann SR 4-Aminopyridine improves pulmonary function in quadriplegic humans with longstanding spinal cord injury Pharmacotherapy 1997 17(3):415 23 9165545
Segal JL, Brunnemann SR, Gordon SK, et al The absolute bioavailability of oral theophylline in patients with spinal cord injury Pharmacotherapy 1986 6(1):26 9 3952003
Segal JL, Gordon SK, Eltorai IM Theophylline disposition in tetraplegic man South Med J 1987 80(6):720 4 3589764
Segal JL, Patel J, Gordon SK, et al Theophylline pharmacokinetics in spinal cord injury: a preliminary report J Am Paraplegia Soc 1985 8(2):23 4 3842977
Selecki BR, Berry G, Dan NG, et al Preventable causes of death and disability from neurotrauma Aust N Z J Surg 1986 56(7):529 34 2943259
Shatney CH, Brunner RD, Nguyen TQ The safety of orotracheal intubation in patients with unstable cervical spine fracture or high spinal cord injury Am J Surg 1995 170(6):676 9 discussion 679 80 7492025
Short DJ, Stradling JR, Williams SJ Prevalence of sleep apnoea in patients over 40 years of age with spinal cord lesions J Neurol Neurosurg Psychiatry 1992 55(11):1032 6 1469399
Shwiry B, Joseph S, Sullivan CA, et al A method of intubation for cervical spine injured patients AANA J 1983 51(4):403 5 6556877
Silver JR Chest injuries and complications in the early stages of spinal cord injury Paraplegia 1968 5(4):226 45 5684479
Silver JR Initial management of the chest in acute traumatic paraplegia Ann R Coll Surg Engl 1971 48(1):17 20 5572213
Silver JR A review of the respiratory management of a patient with high level tetraplegia [letter] Spinal Cord 1998 36(6):446 7 9648204
Silver JR, Abdel-Halim RE Chest movements and electromyography of the intercostal muscles in tetraplegic patients Paraplegia 1971 9(3):123 31 5129051
Silver JR, Gibbon NO Prognosis in tetraplegia BMJ 1968 4(623):79 83 5246699 1912127
Silver JR, Morris WR, Otfinowski JS Associated injuries in patients with spinal injury Injury 1980 12(3):291 24 7228385
Silver JR, Moulton A The physiological and pathological sequelae of paralysis of the intercostal and abdominal muscles in tetraplegic patients Paraplegia 1969 7(2):131 41 4241131
Singas E, Grimm DR, Almenoff PL, et al Inhibition of airway hyperreactivity by oxybutynin chloride in subjects with cervical spinal cord injury Spinal Cord 1999 37(4):279 83 10338349
Singas E, Lesser M, Spungen AM, et al Airway hyperresponsiveness to methacholine in subjects with spinal cord injury Chest 1996 110(4):911 5 8874244
Slack RS, Shucart W Respiratory dysfunction associated with traumatic injury to the central nervous system Clin Chest Med 1994 15(4):739 49 7867288
Sliwa JA, Mason K, Yarkony G, et al The value of routine chest roentgenograms on admission for rehabilitation after traumatic spinal cord injury Am J Phys Med Rehabil 1994 73(2):84 8 8148108
Smith AE, Nunn CK The phrenic nerve stimulator Crit Care Nurse 1982 2(3):78 81
Soderstrom CA, Brumback RJ Early care of the patient with cervical spine injury Orthop Clin North Am 1986 17(1):3 13 3945480
Sortor S Pulmonary issues in quadriplegia Eur Respir Rev 1992 2(10):330 4
Splaingard ML, Frates RC Jr, Harrison GM, et al Home positive-pressure ventilation. Twenty years' experience Chest 1983 84(4):376 82 6352194
Spungen AM, Dicpinigaitis PV, Almenoff PL, et al Pulmonary obstruction in individuals with cervical spinal cord lesions unmasked by bronchodilator administration Paraplegia 1993 31(6):404 7 8337005
Spungen AM, Grimm DR, Lesser M, et al Self-reported prevalence of pulmonary symptoms in subjects with spinal cord injury Spinal Cord 1997 35(10):652 7 9347593
Spungen AM, Grimm DR, Strakhan M, et al Treatment with an anabolic agent is associated with improvement in respiratory function in persons with tetraplegia: A pilot study Mt Sinai J Med 1999 66(3):201 5 10377553
Spungen AM, Lesser M, Almenoff PL, et al Prevalence of cigarette smoking in a group of male veterans with chronic spinal cord injury Mil Med 1995 160(6):308 11 7659231
Star AM, Osterman AL Sleep apnea syndrome after spinal cord injury. Report of a case and literature review Spine 1988 13(1):116 7 3381121
Stauffer ES, Bell GD Traumatic respiratory quadriplegia and pentaplegia Orthop Clin North Am 1978 9(4):1081 9 740375
Stern PH, Slattery K Spinal-cord injury rehabilitation. New approaches N Y State J Med 1975 75(7):1029 34 1056530
Stoboy H, Wilson-Rich B Muscle strength and electrical activity, heart rate and energy cost during isometric contractions in disabled and non-disabled Paraplegia 1971 8(4):217 22 4255793
Stoddart GL, Verrier M Economic implications of rehabilitation options for patients with quadriplegia Clin Invest Med 1980 3(3-4):245 52 6784992
Stover SL Spinal cord injury--update J Am Paraplegia Soc 1983 6(3):66 74 6413649
Stover SL 1993 Donald Munro Memorial Lecture of the American Paraplegia Society. Spinal cord injury: knowns and unknowns J Am Paraplegia Soc 1994 17(1):1 6 8169599
Stover SL Facts, figures, and trends on spinal cord injury Am Rehabil 1996 22(3):25 32
Stover SL, DeVivo MJ, Go BK. History, implementation, and current status of the National Spinal Cord Injury Database. Arch Phys Med Rehabil. 1999;80:1365-71. [pmid: 10569429].
Suderman VS, Crosby ET, Lui A Elective oral tracheal intubation in cervical spine-injured adults Can J Anaesth 1991 38(6):785 9 1914066
Sugarman B Medical complications of spinal cord injury Q J Med 1985 54(213):3 18 3883387
Sugarman B Atelectasis in spinal cord injured people after initial medical stabilization J Am Paraplegia Soc 1985 8(3):47 50 3842981
Sugarman B, Brown D, Musher D Fever and infection in spinal cord injury patients JAMA 1982 248(1):66 70 7087094
Talonen P, Malmivuo J, Baer G, et al Transcutaneous, dual channel phrenic nerve stimulator for diaphragm pacing Med Biol Eng Comput 1983 21(1):21 30 6602921
Tator CH, Duncan EG, Edmonds VE, et al Complications and costs of management of acute spinal cord injury Paraplegia 1993 31(11):700 14 8295780
Taylor N, Glenn WW Respiratory training for quadriplegics N Engl J Med 1972 286(23):1267 8
Taylor RG Spinal cord injury: its many complications Am Fam Physician 1973 8(4):138 46 4793095
Tepperman PS Primary care after spinal cord injury. What every physician should know Postgrad Med 1989 86(5):211 8 2678062
Thoma H, Gerner H, Holle J, et al The phrenic pacemaker. Substitution of paralyzed functions in tetraplegia ASAIO Trans 1987 33(3):472 9 3675976
Thomas E, Paulson SS Protocol for weaning the SCI patient SCI Nurs 1994 11(2):42 5 7863318
Thurman DJ, Burnett CL, Jeppson L, et al Surveillance of spinal cord injuries in Utah, USA Paraplegia 1994 32(10):665 9 7831072
Tibballs J Diaphragmatic pacing: an alternative to long-term mechanical ventilation Anaesth Intensive Care 1991 19(4):597 601 1750649
Tran NV, Vernick J, Cotler JM, et al Lateral tracheostomy in patients with cervical spinal cord injury Br J Surg 1995 82(3):412 3 7796029
Tromans AM, Mecci M, Barrett FH, et al The use of the BiPAP biphasic positive airway pressure system in acute spinal cord injury Spinal Cord 1998 36(7):481 4 9670384
Tryba M, Janssen S Prevention of pulmonary complications in long-term ventilated patients with alpha-chymotrypsin: A placebo-controlled study Clin Intensive Care 1992 3(5 Suppl):43 7
Unterborn JN, Hill NS Options for mechanical ventilation in neuromuscular diseases Clin Chest Med 1994 15(4):765 81 7867290
Guide to clinical preventive services. Baltimore: Williams & Wilkins, 1996.
Vaidyanathan S, Soni BM, Gopalan L, et al A review of the readmissions of patients with tetraplegia to the Regional Spinal Injuries Centre, Southport, United Kingdom, between January 1994 and December 1995 Spinal Cord 1998 36(12):838 46 9881733
Vanderlinden RG, Epstein SW, Hyland RH, et al Management of chronic ventilatory insufficiency with electrical diaphragm pacing Can J Neurol Sci 1988 15(1):63 7 3278781
Vanderlinden RG, Gilpin L, Harper J, et al Electrophrenic respiration in quadriplegia Can Nurse 1974 70(1):23 6
Vergith TS Mechanism of active expiration in tetraplegic subjects [letter] N Engl J Med 1986 315(19):
Viroslav J, Rosenblatt R, Tomazevic SM Respiratory management, survival, and quality of life for high-level traumatic tetraplegics Respir Care Clin North Am 1996 2(2):313 22
Waites KB, Canupp KC, Edwards K, et al Immunogenicity of pneumococcal vaccine in persons with spinal cord injury Arch Phys Med Rehabil 1998 79(12):1504 9 9862290
Walker J, Cooney M Improved respiratory function in quadriplegics after pulmonary therapy and arm ergometry [letter] N Engl J Med 1987 316(8):486 7 3807991
Wang AY, Jaeger RJ, Yarkony GM, et al Cough in spinal cord injured patients: the relationship between motor level and peak expiratory flow Spinal Cord 1997 35(5):299 302 9160454
Waters RL, Meyer PR, Adkins RH, et al. Emergency, acute, and surgical management of spine trauma. Arch Phys Med Rehabil. 1999;80:1383-90. [pmid: 10569431].
Watt JW, Devine A Does dead space ventilation always alleviate hypocapnia? Long-term ventilation with plain tracheostomy tubes Anaesthesia 1995 50(8):688 91 7645697
Watt JW, Fraser MH The effect of insufflation leaks in long-term ventilation. Waking and sleeping transcutaneous gas tensions in ventilator-dependent patients with an uncuffed tracheostomy tube Anaesthesia 1994 49(4):328 30 8179143
Webb DR, Fitzpatrick JM, O'Flynn JD A 15-year follow-up of 406 consecutive spinal cord injuries Br J Urol 1984 56(6):614 7 6534476
Weese-Mayer DE, Silvestri JM, Kenny AS, et al Diaphragm pacing with a quadripolar phrenic nerve electrode: an international study Pacing Clin Electrophysiol 1996 19(9):1311 9 8880794
Weingarden SI, Belen JG Alternative approach to the respiratory management of the high cervical spinal cord injury patient Int Disabil Stud 1987 9(3):132 3 3429397
Weiss D, Spill G, Gittler M, et al Acute spinal injury N Engl J Med 1996 334(26):1747 8 8637530
Whiteneck G, Tate D, Charlifue S. Predicting community reintegration after spinal cord injury from demographic and injury characteristics. Arch Phys Med Rehabil. 1999;80:1485-91. [pmid: 10569445].
Wicks AB, Menter RR Long-term outlook in quadriplegic patients with initial ventilator dependency Chest 1986 90(3):406 10 3743155
Wilcox NE, Stauffer ES Follow-up of 423 consecutive patients admitted to the spinal cord centre, Rancho Los Amigos hospital, 1 January to 31 December 1967 Paraplegia 1972 10(2):115 22 5073485
Williams MH Jr, Shim CS Ventilatory failure. Etiology and clinical forms Am J Med 1970 48(4):477 83 5444303
Woodruff BA, Baron RC A description of nonfatal spinal cord injury using a hospital-based registry Am J Prev Med 1994 10(1):10 4 8172725
Yamamoto H, Nakagawa H, Iwata K MRI findings in spinal cord injury patients who have respiratory distress Paraplegia 1994 32(5):323 9 8058349
Yarkony GM, Chen D. Rehabilitation of patients with spinal cord injuries. In: Braddom RL, Buschbacher RM, editors. Physical Medicine and Rehabilitation. Philadelphia: Saunders. 1996:p.1149-79.
Yarkony GM, Roth EJ, Cybulski GR, et al Neuromuscular stimulation in spinal cord injury. II: Prevention of secondary complications Arch Phys Med Rehabil 1992 73(2):195 200 1543418
Young JS. Spinal cord injury: associated general trauma and medical complications. Adv Neurol. 1979;22:255-60. [pmid: 484336].
Zifko U, Chen R The respiratory system Baillieres Clin Neurol 1996 5(3):477 95 9117072
Zupan A, Savrin R, Erjavec T, et al Effects of respiratory muscle training and electrical stimulation of abdominal muscles on respiratory capabilities in tetraplegic patients Spinal Cord 1997 35(8):540 5 9267921