# References

Acton PA, Farley T, Freni LW, et al Traumatic spinal cord injury in Arkansas, 1980 to 1989 Arch Phys Med Rehabil 1993 74(10):1035 40 8215853
(formerly U. S. Agency for Health Care Policy and Research). Hospital Inpatient Statistics, 1996. Healthcare Cost and Utilization Project Research Note. The Agency. 1999. AHCPR No. 99-0034.
Almenoff PL, Alexander LR, Spungen AM, et al Bronchodilatory effects of ipratropium bromide in patients with tetraplegia Paraplegia 1995 33(5):274 7 7630654
Lung function testing: selection of reference values and interpretative strategies Am Rev Respir Dis 1991 144(5):1202 18 1952453
Amodie-Storey C, Nash MS, Roussell PM, et al Head position and its effect on pulmonary function in tetraplegic patients Spinal Cord 1996 34(10):602 7 8896126
Ashba J, Garshick E, Tun CG, et al Spirometry--acceptability and reproducibility in spinal cord injured subjects J Am Paraplegia Soc 1993 16(4):197 203 8270915
Ashworth B. Preliminary trial of carisoprodol in multiple sclerosis. Practitioner. 1964;192:540-2. [pmid: 14143329].
Axen K, Pineda H, Shunfenthal I, et al Diaphragmatic function following cervical cord injury: neurally mediated improvement Arch Phys Med Rehabil 1985 66(4):219 22 3985772
Bach JR New approaches in the rehabilitation of the traumatic high level quadriplegic Am J Phys Med Rehabil 1991 70(1):13 9 1994965
Bach JR Inappropriate weaning and late onset ventilatory failure of individuals with traumatic spinal cord injury Paraplegia 1993 31(7):430 8 8371934
Bach JR. Case studies of respiratory management. In: Bach JR, ed. Pulmonary Rehabilitation: The Obstructive and Paralytic Conditions. Philadelphia: Haney & Belfus. 1996a:331-46.
Bach JR A historical perspective on the use of noninvasive ventilatory support alternatives Respiratory Care Clinics of North America 1996b 2(2):161 81 9390877
Bach JR, Alba AS Noninvasive options for ventilatory support of the traumatic high level quadriplegic patient Chest 1990a 98(3):613 9 2203616
Bach JR, Alba AS Tracheostomy ventilation. A study of efficacy with deflated cuffs and cuffless tubes Chest 1990b 97(3):679 83 2407453
Bach JR, Alba AS Intermittent abdominal pressure ventilator in a regimen of noninvasive ventilatory support Chest 1991 99(3):630 6 1899821
Bach JR, Alba AS, Saporito LR Intermittent positive pressure ventilation via the mouth as an alternative to tracheostomy for 257 ventilator users Chest 1993 103(1):174 82 8417874
Bach JR, Rajaraman R, Ballanger F, et al Neuromuscular ventilatory insufficiency: effect of home mechanical ventilator use v oxygen therapy on pneumonia and hospitalization rates Am J Phys Med Rehabil 1998 77(1):8 19 9482374
Bach JR, Saporito LR Criteria for extubation and tracheostomy tube removal for patients with ventilatory failure A different approach to weaning. Chest 1996 110(6):1566 71
Bach JR, Tilton MC Life satisfaction and well-being measures in ventilator assisted individuals with traumatic tetraplegia Arch Phys Med Rehabil 1994 75(6):626 32 8002759
Bain G, Bodley R, Jamous A, et al A comparison of the chest radiograph and computerised tomography in assessing lung changes in acute spinal injuries--an assessment of their prevalence and the accuracy of the chest X-ray compared with CT in their assessment Paraplegia 1995 33(3):121 5 7784112
Bellamy R, Pitts FW, Stauffer ES Respiratory complications in traumatic quadriplegia. Analysis of 20 years' experience J Neurosurg 1973 39(5):596 600 4743566
Berkowitz M, O'Leary PK, Kruse DL et al. Spinal Cord Injury: An analysis of Medical and Social Costs. New York: Demos. 1998. [pmcid: 325579].
Biering-Sorensen M, Biering-Sorensen F Tracheostomy in spinal cord injured: frequency and follow up Paraplegia 1992 30(9):656 60 1408343
Borkowski C A comparison of pulmonary complications in spinal cord-injured patients treated with two modes of spinal immobilization J Neurosci Nurs 1989 21(2):79 85 2523453
Brackett T, Condon A Comparison of the wedge turning frame and kinetic treatment table in the acute care of spinal cord injury patients ICU Forum 1984 4(5):1 7
Branscomb BV, Stover SL, DeVivo MJ, et al. (University of Alabama School of Medicine, Birmingham, AL). Final Report: the pathophysiology of respiratory complications in spinal cord injury patients (unpublished). Birmingham, AL. 1984.
Braun SR, Giovannoni R, O'Connor M Improving the cough in patients with spinal cord injury Am J Phys Med 1984 63(1):1 10 6703028
Cahan C, Gothe B, Decker MJ, et al Arterial oxygen saturation over time and sleep studies in quadriplegic patients Paraplegia 1993 31(3):172 9 8479783
Carter RE Experiences with high tetraplegics Paraplegia 1979 17(2):140 6 492754
Carter RE Unilateral diaphragmatic paralysis in spinal cord injury patients Paraplegia 1980 18(4):267 74 7422343
Carter RE Experience with ventilator dependent patients Paraplegia 1993 31(3):150 3 8479778
Carter RE, Donovan WH, Halstead L, et al Comparative study of electrophrenic nerve stimulation and mechanical ventilatory support in traumatic spinal cord injury Paraplegia 1987 25(2):86 91 3495773
Chen D, Apple DF, Hudson LM, et al. Medical complications during acute rehabilitation following spinal cord injury -- current experience of the Model Systems. Arch Phys Med Rehabil. 1999;80:1397-401. [pmid: 10569433].
Cheshire DJ, Flack WJ The use of operant conditioning techniques in the respiratory rehabilitation of the tetraplegic Paraplegia 1978 16(2):162 74 733296
CINAHL Information Service, 1983-. Updated monthly. Available from CINAHL Information Service, Glendale, CA; Ovid Technologies, Inc., New York, NY.
Claxton AR, Wong DT, Chung F, et al Predictors of hospital mortality and mechanical ventilation in patients with cervical spinal cord injury Can J Anaesth 1998 45(2):144 9 9512849
Clough P, Lindenauer D, Hayes M, et al Guidelines for routine respiratory care of patients with spinal cord injury A clinical report. Phys Ther 1986 66(9):1395 402
Outcomes following traumatic spinal cord injury: clinical practice guidelines for health-care professionals. Washington, DC: Paralyzed Veterans of America, 1999.
Darouiche RO, Groover J, Rowland J, et al Pneumococcal vaccination for patients with spinal cord injury Arch Phys Med Rehabil 1993 74(12):1354 7 8259905
De Vivo MJ, Richards JS, Stover SL, et al Spinal cord injury. Rehabilitation adds life to years West J Med 1991 154(5):602 6 1866959 1002842
DeLuca RV, Grimm DR, Lesser M, et al Effects of a beta-2-agonist on airway hyperreactivity in subjects with cervical spinal cord injury Chest 1999 115(6):1533 8 10378545
Spinal Cord Care: Clinical Practice Guidelines. Available from Eastern Paralyzed Veterans Association, Jackson Heights, NY.
Derrickson J, Ciesla N, Simpson N, et al A comparison of two breathing exercise programs for patients with quadriplegia Phys Ther 1992 72(11):763 9 1409873
DeVivo MJ Discharge disposition from model spinal cord injury care system rehabilitation programs Arch Phys Med Rehabil 1999 80(7):785 90 10414763
DeVivo MJ, Black KJ, Stover SL Causes of death during the first 12 years after spinal cord injury Arch Phys Med Rehabil 1993 74(3):248 54 8439250
DeVivo MJ, Fine PR, Maetz HM, et al Prevalence of spinal cord injury: a reestimation employing life table techniques Arch Neurol 1980 37(11):707 8 7436813
DeVivo MJ, Ivie CS 3rd Life expectancy of ventilator-dependent persons with spinal cord injuries Chest 1995 108(1):226 32 7606963
DeVivo MJ, Krause S, Lammertse DP. Recent trends in mortality and causes of death among persons with spinal cord injury. Arch Phys Med Rehabil. 1999;80:1411-19. [pmid: 10569435].
DeVivo MJ, Rutt RD, Black KJ, et al Trends in spinal cord injury demographics and treatment outcomes between 1973 and 1986 Arch Phys Med Rehabil 1992 73(5):424 30 1580768
Dicpinigaitis PV, Spungen AM, Bauman WA, et al Inhibition of bronchial hyperresponsiveness by the GABA-agonist baclofen Chest 1994 106(3):758 61 8082355
DiPasquale PA Exhaler class: a multidisciplinary program for high quadriplegic patients Am J Occup Ther 1986 40(7):482 5 3740200
New York (NY): Elsevier Science Secondary Publishing Division, 1974-. Upated weekly. Available from: Elsevier Science Secondary Publishing Division, New York, New York; DIALOG Information Services, Inc., Palo Alto, CA.
Estenne M, De Troyer A Mechanism of the postural dependence of vital capacity in tetraplegic subjects Am Rev Respir Dis 1987 135(2):367 71 3813198
Fein ED, Grimm DR, Lesser M, et al The effects of ipratropium bromide on histamine-induced bronchoconstriction in subjects with cervical spinal cord injury J Asthma 1998 35(1):49 55 9513582
Fishburn MJ, Marino RJ, Ditunno JF Jr Atelectasis and pneumonia in acute spinal cord injury Arch Phys Med Rehabil 1990 71(3):197 200 2317137
Fodstad H Pacing of the diaphragm to control breathing in patients with paralysis of central nervous system origin Stereotact Funct Neurosurg 1989 53(4):209 22 2518591
Forner JV Lung volumes and mechanics of breathing in tetraplegics Paraplegia 1980 18(4):258 66 7422342
Frankel HL, Coll JR, Charlifue SW, et al Long-term survival in spinal cord injury: A fifty year investigation Spinal Cord 1998 36(4):266 74 9589527
Fugl-Meyer AR Effects of respiratory muscle paralysis in tetraplegic and paraplegic patients Scand J Rehabil Med 1971 3(4):141 50 5161287
Fuhrer MJ, Carter RE, Donovan WH, et al Postdischarge outcomes for ventilator-dependent quadriplegics Arch Phys Med Rehabil 1987 68(6):353 6 3592948
Gardner BP, Theocleous F, Watt JW, et al Ventilation or dignified death for patients with high tetraplegia BMJ 1985 291(6509):1620 2 3935213 1418404
Gardner BP, Watt JW, Krishnan KR The artificial ventilation of acute spinal cord damaged patients: a retrospective study of forty-four patients Paraplegia 1986 24(4):208 20 3531981
Glenn WW, Holcomb WG, McLaughlin AJ, et al Total ventilatory support in a quadriplegic patient with radiofrequency electrophrenic respiration N Engl J Med 1972 286(10):513 6 4501052
Glenn WW, Holcomb WG, Shaw RK, et al Long-term ventilatory support by diaphragm pacing in quadriplegia Ann Surg 1976 183(5):566 77 1275596 1344348
Gothe B, Maximin A, Sajkov D, et al Cognitive disturbances and nocturnal hypoxemia in tetraplegic patients [letter] Spinal Cord 1999 37(1):71 2 10025702
Green BA, Green KL, Klose KJ Kinetic Nursing for acute spinal cord injury patients Paraplegia 1980 18(3):181 6 7413240
Grimm DR, DeLuca RV, Lesser M, et al Effects of GABA-B agonist baclofen on bronchial hyperreactivity to inhaled histamine in subjects with cervical spinal cord injury Lung 1997 175(5):333 41 9270990
Gross D, Ladd HW, Riley EJ, et al The effect of training on strength and endurance of the diaphragm in quadriplegia Am J Med 1980 68(1):27 35 7350802
Hart GB, Strauss MB, Riker J Vital capacity of quadriplegic patients treated with hyperbaric oxygen J Am Paraplegia Soc 1984 7(1):8 9 6707625
Harvey C, Rothschild BB, Asmann AJ, et al New estimates of traumatic SCI prevalence: a survey-based approach Paraplegia 1990 28(9):537 44 2287518
Harvey LA, Ellis ER The effect of continuous positive airway pressures on lung volumes in tetraplegic patients Paraplegia 1996 34(1):54 8 8848324
National Library of Medicine jointly with American Hospital Association. 1975-. Updated monthly. Available from National Library of Medicine, Bethesda, MD; DIALOG Information Services, Palo Alto, CA; Ovid Technologies, Inc., New York, NY.
Hsu S, Dreisbach JN, Charlifue SW, et al Glottic and tracheal stenosis in spinal cord injured patients Paraplegia 1987 25(2):136 48 3588009
Huldtgren AC, Fugl-Meyer AR, Jonasson E, et al Ventilatory dysfunction and respiratory rehabilitation in post-traumatic quadriplegia Eur J Respir Dis 1980 61(6):347 56 7202607
Jackson AB, Groomes TE Incidence of respiratory complications following spinal cord injury Arch Phys Med Rehabil 1994 75(3):270 5 8129577
Jaeger RJ, Turba RM, Yarkony GM, et al Cough in spinal cord injured patients: comparison of three methods to produce cough Arch Phys Med Rehabil 1993 74(12):1358 61 8018145
Johnson RL, Brooks CA, Whiteneck GG Cost of traumatic spinal cord injury in a population-based registry Spinal Cord 1996 34(8):470 80 8856854
Kendall RJ, Lafuente J, Hosie KB Central pontine myelinolysis after an operation J R Soc Med 1997 90(8):445 6 9306999 1296460
Kirby NA, Barnerias MJ, Siebens AA An evaluation of assisted cough in quadriparetic patients Arch Phys Med Rehabil 1966 47(11):705 10 5332775
Kirshblum S, Johnston MV, Brown J, et al Predictors of dysphagia after spinal cord injury Arch Phys Med Rehabil 1999 80(9):1101 5 10489016
Lamid S, Ragalie GF, Welter K Respirator-dependent quadriplegics: problems during the weaning period J Am Paraplegia Soc 1985 8(2):33 7 3842980
Lane CS Inspiratory muscle weight training and its effect on the vital capacity of patients with quadriplegia Cardiopulmonary Q 1982 5(10):
Lasfargues JE, Custis D, Morrone F, et al A model for estimating spinal cord injury prevalence in the United States Paraplegia 1995 33(2):62 8 7753569
Lemons VR, Wagner FC Jr Respiratory complications after cervical spinal cord injury Spine 1994 19(20):2315 20 7846577
Lesoin F, Delandsheer E, Lozes G, et al Electromyography of the diaphragm in patients with cervical spine lesions necessitating assisted ventilation [letter] Lancet 1983 1(8338):1385 6 6134162
Lin KH, Lai YL, Wu HD, et al Effects of an abdominal binder and electrical stimulation on cough in patients with spinal cord injury J Formos Med Assoc 1998 97(4):292 5 9585684
Lind B, Bake B, Lundqvist C, et al Influence of halo vest treatment on vital capacity Spine 1987 12(5):449 52 3629395
Loveridge B, Badour M, Dubo H Ventilatory muscle endurance training in quadriplegia: effects on breathing pattern Paraplegia 1989 27(5):329 39 2689970
Maeda CJ, Baydur A, Waters RL, et al The effect of the halovest and body position on pulmonary function in quadriplegia J Spinal Disord 1990 3(1):47 51 2134410
McKinley WO, Jackson AB, Cardenas DD, et al. Long-term medical complications after traumatic spinal cord injury: a regional model systems analysis. Arch Phys Med Rehabil. 1999;(80):1402-10. [pmid: 10569434].
McMichan JC, Michel L, Westbrook PR Pulmonary dysfunction following traumatic quadriplegia. Recognition, prevention, and treatment JAMA 1980 243(6):528 31 7351783
Bethesda (MD): National Library of Medicine, 1966-. Updated weekly. Available from: National Library of Medicine; DIALOG Information Services, Inc., Palo Alto, CA: Ovid Technologies, Inc., New York, NY.
Meschino A, Devitt JH, Koch JP, et al The safety of awake tracheal intubation in cervical spine injury Can J Anaesth 1992 39(2):114 7 1544191
Meyers AR, Bisbee A, Winter M. The "Boston Model" of managed care spinal cord injury: a cross-sectional study of the outcomes of risk-based, prepaid, managed care. Arch Phys Med Rehabil. 1999;80:1450-6. [pmid: 10569440].
Miller HJ, Thomas E, Wilmot CB Pneumobelt use among high quadriplegic population Arch Phys Med Rehabil 1988 69(5):369 72 3163246
Miller JI, Farmer JA, Stuart W, et al Phrenic nerve pacing of the quadriplegic patient J Thorac Cardiovasc Surg 1990 99(1):35 9 discussion 39 40 2294363
Montero JC, Feldman DJ, Montero D Effects of glossopharyngeal breathing on respiratory function after cervical cord transection Arch Phys Med Rehabil 1967 48(12):650 3 5235188
Myllynen P, Kivioja A, Rokkanen P, et al Cervical spinal cord injury: the correlations of initial clinical features and blood gas analyses with early prognosis Paraplegia 1989 27(1):19 26 2493625
Nobunaga AI, Go GK, Karunas RB. Recent demographic and injury trends in people served by the model spinal cord injury systems. Arch Phys Med Rehabil. 1999;80:1372-82. [pmid: 10569430].
Peterson P, Brooks CA, Mellick D, et al Protocol for ventilator management in high tetraplegia Top Spinal Cord Inj Rehabil 1997 2(3):101 6
Peterson W, Charlifue W, Gerhart A, et al Two methods of weaning persons with quadriplegia from mechanical ventilators Paraplegia 1994 32(2):98 103 8015852
Peterson WP, Barbalata L, Brooks CA, et al The effect of tidal volumes on the time to wean persons with high tetraplegia from ventilators Spinal Cord 1999 37(4):284 8 10338350
Price C, Makintubee S, Herndon W, et al Epidemiology of traumatic spinal cord injury and acute hospitalization and rehabilitation charges for spinal cord injuries in Oklahoma, 1988-1990 Am J Epidemiol 1994 139(1):37 47 8296773
Reines HD, Harris RC Pulmonary complications of acute spinal cord injuries Neurosurgery 1987 21(2):193 6 3658131
Roth EJ, Lu A, Primack S, et al Ventilatory function in cervical and high thoracic spinal cord injury. Relationship to level of injury and tone Am J Phys Med Rehabil 1997 76(4):262 7 9267184
Roth EJ, Nussbaum SB, Berkowitz M, et al Pulmonary function testing in spinal cord injury: correlation with vital capacity Paraplegia 1995 33(8):454 7 7478739
Ryan M, Klein S, Bongard F Missed injuries associated with spinal cord trauma Am Surg 1993 59(6):371 4 8507062
Sackett DL Rules of evidence and clinical recommendations on the use of antithrombotic agents Chest 1989 95(2 Suppl):2S 4S 2914516
Samsa G, Hoenig H, Carswell J, et al Developing a national registry of veterans with spinal cord dysfunction: experiences and implications Spinal Cord 1998 36(1):57 62 9471140
Samsa GP, Landsman PB, Hamilton B Inpatient hospital utilization among veterans with traumatic spinal cord injury Arch Phys Med Rehabil 1996 77(10):1037 43 8857883
Scher AT The radiology of pulmonary complications associated with acute spinal cord injury S Afr Med J 1982 62(10):321 4 7112294
Segal JL, Brunnemann SR 4-Aminopyridine improves pulmonary function in quadriplegic humans with longstanding spinal cord injury Pharmacotherapy 1997 17(3):415 23 9165545
Silver JR, Morris WR, Otfinowski JS Associated injuries in patients with spinal injury Injury 1980 12(3):291 24 7228385
Singas E, Grimm DR, Almenoff PL, et al Inhibition of airway hyperreactivity by oxybutynin chloride in subjects with cervical spinal cord injury Spinal Cord 1999 37(4):279 83 10338349
Splaingard ML, Frates RC Jr, Harrison GM, et al Home positive-pressure ventilation. Twenty years' experience Chest 1983 84(4):376 82 6352194
Spungen AM, Dicpinigaitis PV, Almenoff PL, et al Pulmonary obstruction in individuals with cervical spinal cord lesions unmasked by bronchodilator administration Paraplegia 1993 31(6):404 7 8337005
Spungen AM, Grimm DR, Lesser M, et al Self-reported prevalence of pulmonary symptoms in subjects with spinal cord injury Spinal Cord 1997 35(10):652 7 9347593
Spungen AM, Grimm DR, Strakhan M, et al Treatment with an anabolic agent is associated with improvement in respiratory function in persons with tetraplegia: A pilot study Mt Sinai J Med 1999 66(3):201 5 10377553
Sugarman B Atelectasis in spinal cord injured people after initial medical stabilization J Am Paraplegia Soc 1985 8(3):47 50 3842981
Sugarman B, Brown D, Musher D Fever and infection in spinal cord injury patients JAMA 1982 248(1):66 70 7087094
Tator CH, Duncan EG, Edmonds VE, et al Complications and costs of management of acute spinal cord injury Paraplegia 1993 31(11):700 14 8295780
Thurman DJ, Burnett CL, Jeppson L, et al Surveillance of spinal cord injuries in Utah, USA Paraplegia 1994 32(10):665 9 7831072
Tromans AM, Mecci M, Barrett FH, et al The use of the BiPAP biphasic positive airway pressure system in acute spinal cord injury Spinal Cord 1998 36(7):481 4 9670384
Guide to clinical preventive services. Baltimore: Williams & Wilkins, 1996.
Viroslav J, Rosenblatt R, Tomazevic SM Respiratory management, survival, and quality of life for high-level traumatic tetraplegics Respir Care Clin North Am 1996 2(2):313 22
Waites KB, Canupp KC, Edwards K, et al Immunogenicity of pneumococcal vaccine in persons with spinal cord injury Arch Phys Med Rehabil 1998 79(12):1504 9 9862290
Walker J, Cooney M Improved respiratory function in quadriplegics after pulmonary therapy and arm ergometry [letter] N Engl J Med 1987 316(8):486 7 3807991
Wang AY, Jaeger RJ, Yarkony GM, et al Cough in spinal cord injured patients: the relationship between motor level and peak expiratory flow Spinal Cord 1997 35(5):299 302 9160454
Waters RL, Meyer PR, Adkins RH, et al. Emergency, acute, and surgical management of spine trauma. Arch Phys Med Rehabil. 1999;80:1383-90. [pmid: 10569431].
Watt JW, Devine A Does dead space ventilation always alleviate hypocapnia? Long-term ventilation with plain tracheostomy tubes Anaesthesia 1995 50(8):688 91 7645697
Watt JW, Fraser MH The effect of insufflation leaks in long-term ventilation. Waking and sleeping transcutaneous gas tensions in ventilator-dependent patients with an uncuffed tracheostomy tube Anaesthesia 1994 49(4):328 30 8179143
Weese-Mayer DE, Silvestri JM, Kenny AS, et al Diaphragm pacing with a quadripolar phrenic nerve electrode: an international study Pacing Clin Electrophysiol 1996 19(9):1311 9 8880794
Woodruff BA, Baron RC A description of nonfatal spinal cord injury using a hospital-based registry Am J Prev Med 1994 10(1):10 4 8172725