# Future Research

Further research is needed to answer definitively questions about how to best care for patients with acute and chronic cervical SCI. The evidence base of clinical research on the management of pulmonary disease in this condition covers only a small number of many important management decisions. However, tetraplegia is associated with important barriers to conducting clinical research. These barriers include the relative rarity of the condition and the relative lack of funding for and expertise in clinical research in SCI care settings.

The U. S. Model Spinal Cord Injury Systems program is a network of (currently) 18 centers that work together to maintain a national database, provide continuing education, and participate in independent and collaborative research relating to SCI. The Model Systems database has contributed greatly to our knowledge regarding the prevalence, natural history, cost, and sequelae of SCI. The Model Systems data have clearly demonstrated improvement in survival of patients with SCI over the last few decades. Furthermore, the database, through measurement of incidence of complications, ventilator use at discharge, and other parameters, has been used to create benchmarks to guide the care of persons with SCI.

Currently the Model Systems database does not collect detailed clinical data of the type needed to examine how differences in clinical practice (e. g., ventilator settings, frequency and type of respiratory therapy) might influence clinical outcomes such as weaning success, time on MV, incidence of atelectasis, or mortality. Agreeing on specific detailed clinical data to collect on day-to-day management practices for persons with SCI, and expanding the Model Systems database to include such data, would make it possible to correlate clinical practices with the health outcomes already obtained in Model Systems data. This would seem a natural extension of the current effort and would facilitate inter-site collaboration in the design and conduct of prospective clinical trials, which would be necessary to definitively answer questions of clinical management.

The Department of Veterans Affairs (VA) network of 23 designated SCI centers handles approximately two-thirds of VA inpatient visits for persons with SCI (Samsa, Landsman, and Hamilton, 1996). The Department has recently developed a national registry of veterans with spinal cord dysfunction to allow more effective planning and administration for SCI care, both in the specialized centers and throughout the network of VA hospitals and clinics (Samsa, Hoenig, Carswell et al., 1998). Clinical data, obtained by linking data from the department's patient treatment file is, like the Model Systems database, insufficiently detailed for effective outcomes research.

Further queries of the Model Systems and VA databases are warranted to describe the occurrence of respiratory illnesses and complications in the course of care following SCI. Few of the currently available reports of Model Systems data have focused primarily on respiratory complications. Despite the lack of detailed data on treatment, the database does provide an opportunity to better describe the epidemiology of respiratory illness and complications. This more-detailed information could be useful for estimating the burden of illness, for modeling, or for cost-effectiveness analysis. These type of data, in turn, will provide motivation for funders to support collaborative clinical research efforts such as those described above.

An active clinical research network would offer the opportunity to implement protocols across multiple institutions, and to test for differences in outcomes associated with different protocols. A variety of management algorithms have been either described in the literature (Clough, Lindenauer, Hayes et al., 1986; Viroslav, Rosenblatt, and Tomazevic, 1996) or put to use within systems (Department of Veterans Affairs, 1994) or single institutions (Branscomb, Stover, DeVivo et al., 1984) (Peterson, personal communication). None of these guidelines was developed using an explicit evidence-based process and none has been rigorously tested in clinical practice. The evidence compiled in this report will be used by the Consortium for Spinal Cord Medicine in their efforts to develop a new guideline using a more explicit process linking recommendations to evidence. The Consortium, professional organizations and similar groups, after examining the current state of research in this area, would be in a good position to outline an agenda for future research by prioritizing questions that would be most useful in guiding clinical care.

Most of the published research on pulmonary disease in SCI focuses on care of acutely injured subjects. As acute SCI is the most expensive condition among all causes for hospitalization (AHRQ, 1999), the acute management phase should be a high priority for research. However, as long-term SCI survival has increased, the prevalence of patients with chronic SCI is growing ever larger. Pulmonary complications of chronic SCI will become of greater clinical importance. Currently, little data is available regarding the incidence of late respiratory failure, and even less is available on the effectiveness of therapies that may be effective to prevent it. In this instance, venues such as the VA Spinal Cord Injury centers and the Model Systems institutions (in which cohorts of patients with chronic cervical SCI are followed) might decide that the systematic collection of data about their patients' clinical care could be valuable.