# Conclusions

Patients with cervical SCI are at significant risk for ventilatory failure, and this risk differs by the level and completeness of injury. Ventilatory support is needed for a majority of patients with C5 and higher injuriesand virtually all patients with C3 and higher injuries and in the acute phase. Patients with lower-cervical SCI are less likely to require MV, as are those patients with greater FVC on presentation. The amount of secretions and serious pulmonary infection (pneumonia) are associated with the need for MV. This finding suggests that treatments aimed at improving ventilation, cough, and secretion clearance may reduce the need for MV.

MV for ventilatory failure is usually performed using invasive (endotracheal or nasotracheal) intubation. However, NPPV can be successful for short- and long-term ventilatory assistance when used properly, particularly when patients have spontaneous FVC approaching 1 liter. In patients with C4 LOI, weaning from MV is often a protracted process that is sometimes not successful. However, patients with C4-level SCI appear to have greater success when weaned by progressive ventilatory-free breathing than by synchronized intermittent mandatory ventilation techniques, which are more commonly used in patients with other causes for ventilatory failure. Furthermore, high ventilator volume (> 20 cc/kg) is associated with less atelectasis and faster weaning.

Evidence is available on a variety of therapeutic and clinical assessment strategies among patients with traumatic tetraplegia, including the following:

- Active respiratory muscle exercise with incentive spirometry, inspiratory resistance training, and abdominal weight training have all been associated with improvements in spontaneous VC in prospective case series. However, in small randomized controlled trials (RCTs) these techniques have not been shown to improve ventilation, nor have the trials shown any difference between inspiratory resistance training and abdominal weight training.
- Deflating cuffed tracheostomies or switching to cuffless tracheostomies is necessary to permit speech, but can cause hypocapnia as a result of increasing tidal volume to compensate for variable upper-airway leak. Adding dead space can increase pCO_2_ to near-normal levels, reducing hypocapnia during waking and sleeping periods. Speech valves are available to permit better speech.
- Electrophrenic respiration has been successfully used for chronic ventilatory support, most often for part-time ventilatory support. Technological advances in recent years appear to have improved the success of the technique, but reliability remains an important problem.
- The pneumobelt may be used for part-time ventilatory support or as an adjunct to full-time noninvasive ventilatory support.
- Noninvasive ventilation may reduce the risk of pneumonia compared with tracheostomy positive pressure ventilation for patients requiring chronic ventilatory support. This technique may also prevent the need for invasive ventilation in patients with acute ventilatory insufficiency.
- Glossopharyngeal breathing training can allow patients ventilator-free breathing for short periods and improve the effectiveness of cough and audibility of their voices.
- Cough is improved with manual assisted cough by 15 to 33 percent in two studies. Positive pressure insufflation can improve cough as well. These techniques used together provided near-normal cough peak flows. Although abdominal binding (corset) did not improve spontaneous cough when used alone, when used in conjunction with manual assisted cough, positive pressure insufflation, or both, a trend toward improvement was suggested by one study. It follows that cough can also be improved by mechanical insufflation-exsufflation, as this technique provides 10 liters/second of expiratory flow.
- Rotating beds have been associated with lower rates of pulmonary complications compared with less frequent turning with a wedge turning device in patients with cervical SCI in retrospective case series.
- Aggressive multimodal respiratory therapy interventions (including frequent turning, suctioning [and bronchial lavage], chest percussion and assisted coughing, inhaled bronchodilator treatments, deep breathing, and incentive spirometry) have been associated with improvements in atelectasis in a small case series. The interventions have also been associated with reduced mortality, atelectasis, need for MV, and tracheostomy in a larger historical cohort comparison.
- The reduction in VC associated with a change in position from supine to sitting is both statistically significant and clinically important. Hence, the seated position in which spirometric tests are usually performed is not optimal for patients with cervical SCI, in that FVC will be underestimated in this position.
- Periodic chest roentgenography often discloses lesions in patients with tetraplegia, even in the absence of symptoms. Conversely, normal upright chest roentgenograms are not sensitive enough to exclude pulmonary abnormalities, particularly pleural effusions (which can be seen on lateral decubitus views).
- In imaging the upper airway, tomography had better agreement with endoscopy for tracheal than glottic stenosis. Computed tomography was more accurate than tomography for diagnosing glottic stenosis, but was similarly accurate for grading the severity of tracheal stenosis.
- Studies of bronchodilator effects suggest potential therapeutic benefit from long-term prophylactic therapy with inhaled beta-agonists to reduce symptoms of breathlessness associated with airway reactivity in persons with tetraplegia. However, none of these studies evaluated the long-term efficacy of bronchodilator or other drug treatments on symptoms, pulmonary function, or the incidence of pulmonary complications.

We also conclude the following:

- Very little data are available with which to describe the risk of late ventilatory failure or the potential effectiveness of treatments to delay or prevent it.
- Despite the expectations of nondisabled persons, the long-term perceived quality of life and well-being are similar in ventilator-dependent and autonomously breathing patients with SCI.

There is a growing body of evidence on the care of persons with traumatic tetraplegia. Although the range of issues this literature addresses is broad, the quality of the literature is relatively low, with few studies using RCT or other designs to reduce bias. Clinical research on patients with cervical SCI has primarily been observational studies, and primarily retrospective case series. Determining the influences of the interventions is problematic for several reasons, including imprecise characterization of treatments and lack of appropriate controls. There is also a need for more precise and consistent characterization of the patients in terms of important prognostic features such as LOI, completeness, and time since injury. Most of the evidence comes from retrospective case series in which the intervention is difficult to characterize. In various studies, the method of clinical care is either not described or described individually for each patient in the series. In some studies that describe well the protocol for care, it is not possible to estimate the effects for individual components of care.

Few of the extant studies have any type of comparison group. Case series can provide rates of outcome events (e. g., complications, successful weaning) that can be compared across series (benchmarks). However, case series provide biased and imprecise estimates of relative effectiveness and are less powerful than study designs that offer internal comparisons (e. g., RCTs, concurrent cohort comparisons, and historical cohort comparisons).

Finally, many of the clinical studies had small sample sizes. A small size limits the generalizability of a case series. For more well-designed studies, the small sample sizes limit the statistical power; for example, the few RCTs identified in this study were negative and lacked the statistical power to show clinically important differences. Future studies should seek to improve both the generalizability and the statistical power by including more patients. Because of the relative rarity of the condition, it will be necessary to aggregate patients through merging standardized data sets from many institutions or developing multisite research networks.

Much of the justification for the current respiratory care of patients with tetraplegia comes from data on or experience with patients with other illnesses, thus guidelines on this topic will need to be based to a large extent on interpretation of these data. Explicit methods are needed for integrating data on related populations with our understanding of the pathophysiology of cervical SCI and other diseases.