# Results

In this section we describe the evidence meeting our inclusion criteria on ventilation management, clinical monitoring and assessment, drug treatment, secretion management, and airway management.

## Ventilation Management

Management of ventilatory insufficiency is the most urgent of pulmonary complications of acute SCI and the issue about which we identified the most empirical literature. Included in this category are interventions to improve ventilatory function or relieve ventilatory insufficiency, among both patients who require mechanical ventilatory assistance and those who do not.

The interventions for which we found supporting evidence that met study design and sample size (for case series) criteria include NPPV, respiratory muscle exercises, phrenic nerve stimulation respiration, various techniques for weaning from mechanical ventilatory support, respiratory care, and patient positioning. Efficacy data from the studies reviewed in this section of the report are summarized in Evidence Table 1.

### Predictors of Need for Mechanical Ventilation

Three studies described how individual patient characteristics could predict which patients would require some type of mechanical ventilatory assistance. Two of these studies described predictors of invasive MV following acute SCI (Claxton, Wong, Chung et al., 1998; Myllynen, Kivioja, Rokkanen et al., 1989) and one described predictors of nocturnal hypoxia in patients with chronic SCI (Cahan, Gothe, Decker et al., 1993).

In a retrospective study of 72 patients with acute cervical SCI, Claxton, Wong, Chung et al. (1998) assessed predictors of MV within 3 months of injury. Of the 72 patients, 15 died and 41 required MV within 3 months. Sixty percent of patients had injuries at C5 or higher, and more than two-thirds of them required MV, compared with only 39 percent of patients with lower-level cervical injuries. In univariable analysis, the predictors of need for MV include injury level C5 or higher, complete lesions, copious sputum in the first week after injury, pneumonia, and lung collapse. In a multivariable analysis, copious sputum and pneumonia proved to be independent predictors of need for MV, while neurological level C5 or above missed statistical significance.

Myllynen, Kivioja, Rokkanen et al. (1989) reported on the rate of various respiratory complications and on predictors of respiratory complications in a retrospective series of 54 patients with acute cervical SCI. The need for ventilatory support during initial intensive care treatment was predicted by the level of cord injury (r = 0.317, p < 0.05) and completeness of cord injury (r = 0.419, p < 0.01), but not by the first values of blood pressure, pulse rate, or blood gas analysis. However, the respiratory rate on admission was associated with having any of the following respiratory complications: atelectasis, pneumonia or other respiratory infection, MV, and pulmonary thromboembolism.

Branscomb, Stover, DeVivo et al. (1984) reported detailed data on a small prospective cohort of patients with traumatic cervical SCI. The need for MV (Table 8) and the incidence of a variety of complications (Table 9) were reported for patients with high lesions (C4 and above) and low lesions (C5 and below).

Table 8. Predictors of Need for Mechanical Ventilatory Assistance after Acute Cervical SCI^a^

Clinical Feature | Claxton, Wong, Chung et al. (1998) | Myllynen, Kivioja, Rokkanen et al. (1989) | Branscomb, Stover, DeVivo et al. (1984)
Level of injury C5 or above C6 or below Completeness of injury Complete Incomplete Copious sputum in week 1 Yes No Pneumonia Yes No Major lobe collapse Yes No | 29/42 (69%) 11/28 (39%) p < 0.002 uni; 0. 05 < p < 0.10 multi 28/39 (72%) 4/31 (13%) p = 0.01 uni; NS multi 22/23 (96%) 21/48 (44%) p = 0.001 uni; p < 0.05 multi 30/33 (91%) 10/39 (26%) p = 0.001 uni; NS multi 18/19 (95%) 22/51 (43%) p = 0.0001 uni; NS multi | 19/32 (59%) 8/19 (42%) p = 0.23 uni; p < 0.05 linear p < 0.01 linear Not reported Not reported Not reported | 6/11 (55%) (C4 or above)2/12 (17%) (C5 or below) p = 0.06 Not reported Not reported Not reported Not reported

a Linear = linear regression analysis; multi = multivariable analysis;NS = not significant; uni = univariable analysis.

Table 9. Level of Injury as a Predictor of Pulmonary Complications from Prospective Studies

Complication | High Cervical Injury (C4 and above) | Low-cervical Injury (C5 and below)
Atelectasis Pneumonia Pneumothorax Upper respiratory infection Pleural effusion | 5/11 (46%) 2/11 (18%) 1/11 (9%) 2/11 (18%) 1/11 (9%) | 2/12 (17%) 3/12 (25%) 1/12 (8%) 0 0

The findings of these studies suggest that patients with higher-level injuries are almost twice as likely to require mechanical ventilatory assistance as those with lower cervical injuries (below C5). Furthermore, patients with complete injuries are much more likely than those with incomplete lesions to require MV, although this is probably important only with high cervical level of injury. The amount of secretions and serious pulmonary infection (pneumonia) are also strongly associated with the need for MV. These findings reinforce the potential for treatments aimed at improving ventilation, cough, and secretion clearance to reduce the need for MV.

## Mechanical Ventilation Assistance

### Acute Ventilation Management

The studies we found describing management of mechanical ventilatory assistance after acute cervical SCI were cohort or case series design studies that did not have sufficiently consistent and detailed descriptions of patients, management strategies, or clinical measures to permit comparison among different approaches. However, individually these studies provide potentially useful insights.

Patients requiring MV have a high mortality rate. A large retrospective study described the mortality among 435 patients discharged on a ventilator from a Model Systems rehabilitation center (DeVivo and Ivie, 1995). The study identified patients on admission to a Model Systems facility, often within 1 day post-SCI. For the subgroup of patients admitted within 1 day of SCI, survival was much lower (approximately half) than that of entire cohort of mechanically ventilated Model Systems patients (25.4 percent versus 49.7 percent). Thus, among cohorts or series of patients, survival figures may vary considerably based on whether the high mortality in acute post-injury care is taken into account.

This study also provides descriptive data on the distribution of level of injury for patients with SCI on MV (Table 10). Stratifying only the cervical injuries into high and low, the percentages are as follows: C4 or above, 79 percent, C5 and below, 21 percent.

Table 10. Level of Injury Among Persons with SCI Who Require Mechanical Ventilation

Level of Injury | n | %
C1 C2 C3 C4 C5 C6 C7 C8 T1 and below Total | 68 86 79 79 41 32 11 2 37 435 | 15.6 19.8 18.2 18.2 9.4 7.3 2.4 0.5 8.6 100

Carter (1979) and Carter, Donovan, Halstead et al. (1987) (possible overlap with Carter (1993)) reported a case series of 67 patients with high cervical injuries. There were 20 patients with C3-level injuries, all of whom were apneic on admission, although the time since injury for this group was not specified. Over the course of treatment, six patients had a drop in motor level such that they regained spontaneous respiration, with VC ranging from 800 to 2,000 cc; two of them were discharged without the need for ventilatory assistance. Twelve patients required some form of MV at discharge, five of whom used at least part-time EPR.

The authors categorized 47 patients with C4 injuries into two subgroups based on VC at admission above or below 1,000 cc. The 28 patients with VC below 1,000 cc had average VC on admission of 670 cc. During the course of rehabilitation (average of 75 days), the mean improvement in VC for this group was 1,167 cc, and 23 were discharged breathing on their own. Although 23 of the 28 patients with VC less than 1,000 cc on admission were discharged breathing spontaneously, 16 patients required tracheostomy for prolonged mechanical ventilation, and 2 patients died during their rehabilitation stay.

The 19 patients with VC above 1,000 cc had an average VC on admission of 1,550 cc and improved an average of 1,122 cc over an average of a 57-day rehabilitation course. Eight of the 19 patients (42 percent) required tracheostomies. None of the 18 patients who survived required any ventilatory support at the time of discharge. This study also reported that the 1-year mortality had changed dramatically from the 1960s, decreasing from 40 percent for patients treated in the 1963-1969 period to 15 percent in the 1970-1977 interval. This study suggests that VC > 1 L on admission is a favorable prognostic factor for patients with C4 injury.

Patient preferences regarding MV suggest that most would choose to have MV again. Gardner, Theocleous, Watt et al. (1985) surveyed patients with SCI who received MV following acute cervical SCI, and their caregivers. The 37 patients described in this article were also included in the series of 44 patients described in Gardner, Watt, and Krishnan (1986). Most (18 of 21) patients said they would receive MV again if needed, but one wished to have been allowed to die and two were undecided. Most relatives of surviving patients (76 percent) were glad about the decision to use MV, but four of 21 (19 percent) were not. Those four who responded that they were not glad with the decision (to use MV) cited overly burdensome caregiving responsibilities as their reason.

The use of NPPV was described in a series of 14 patients with cervical SCI (Tromans, Mecci, Barrett et al., 1998). The authors used inspiratory positive airway pressure (IPAP) and expiratory positive airway pressure, with a difference of at least 8 cm H_2_O, cycling spontaneously in response to the patient's own respiration. By the use of NPPV, patients were kept on the spinal cord unit, rather than being transferred to the ICU. Of the 14 patients placed on NPPV, six (43 percent) required intubation for MV within 2 days. The mean VC for these six patients was 583 cc. Eight patients continued on NPPV for an average of 8 days before weaning; their mean VC immediately before commencing NPPV was 875 cc (range 500 to 1,700 cc); however, the difference was not statistically significant (0.05 < p < 0.10). The lack of a clear description of the indication for beginning prophylactic NPPV and the lack of a comparison group randomized to no ventilatory support makes it difficult to evaluate the effectiveness of NPPV in alleviating the need for invasive MV in SCI.

#### Continuous Positive Airway Pressure

Harvey and Ellis (1996) describe the acute effects of continuous positive airway pressure (CPAP) on pulmonary function, in particular, closing volume and functional residual capacity (FRC) in 10 patients with tetraplegia with levels of injury C4 to C8. They found that 30 minutes of CPAP at 5 cm H_2_O and 10 cm H_2_O increased FRC; however, within the first minute after removal of CPAP, FRC returned to baseline values.

### Weaning Techniques

We identified 10 studies describing experience with weaning patients with traumatic tetraplegia from MV. The reports varied in terms of the techniques used, the uniformity of techniques or protocols, and the degree of detail provided about the technique. Some reports described a general strategy for weaning, but not detailed protocols. Others described the techniques applied to individual patients, but neither an overall strategy nor detailed criteria for their use.

One report confined itself to assessing the use of electromyography of the diaphragm as a predictor of eventual recovery of respiratory function (Lesoin, Delandsheer, Lozes et al., 1983) among 10 patients on MV. All patients were described as having complete injuries: six had injuries at the C4-C5 levels, and the rest at C6 or below. Electromyographic (EMG) activity was detected in three patients, all of whom eventually recovered respiratory function; however, none of the seven patients in whom electromyographic activity was not detected regained respiratory function. Although the authors of this letter did not statistically analyze these data, the association between EMG activity and recovery of respiratory function is highly statistically significant despite the small sample size (Fisher's exact test, p = 0.0083).

Only two studies provided data comparing two or more weaning techniques (Peterson, Charlifue, Gerhart et al., 1994; Peterson, Barbalata, Brooks et al., 1999) Both studies were retrospective. Peterson, Charlifue, Gerhart et al. (1994), a study which is also described briefly in Peterson, Brooks, Mellick et al. (1977), described the results of 62 separate weaning attempts in patients with C3-C4 level of injuries using either intermittent mandatory ventilation (IMV; 26 attempts) or progressive ventilatory-free breathing (PVFB; 34 attempts). Seventeen patients underwent PVFB weaning attempts after failing IMV. Although the study was not randomized, and a large proportion of patients went sequentially from one method to another, the populations were nearly identical in terms of level of injury, all being C3 or C4. The completeness of injury was not described. The study found that PVFB succeeded significantly more often than did IMV (p = 0.02). The success rates for the two techniques were generally similar during the first 6 weeks (31 percent versus 32 percent). After 8 weeks, further IMV was not successful, but PVFB was successful in weaning several patients. The fact that 17 patients who failed weaning on IMV were then tried on PVFB (and included in the PVFB data) makes the finding of a higher success rate for PVFB more robust.

In a separate report, Peterson, Barbalata, Brooks et al. (1999) described patients with C3 or C4 level of injury who were ventilated and weaned using PVFB. (This was an expanded series including 13 additional patients reported very briefly in Peterson, Brooks, Mellick et al. [1997].) The 1999 study compared patients who were ventilated with a high tidal volume (> 20 mL/kg) versus a low tidal volume (< 20 mL/kg); both groups were ventilated in assist/control mode. Actual tidal volumes ranged from 20.03 to 32.2 mL/kg in the high-volume group and from 11. 6 to 19.4 mL/kg in the low-volume group. The larger tidal volume group weaned more quickly than the low tidal volume group (p = 0.02). The high-volume group also had fewer patients with atelectasis during weaning (3/19 versus 12/23; p = 0.01). The incidence of pneumonia was similar between groups (1/19 versus 3/23; p = 0.39), and there was no significant difference in the need for chest tube placement (1/19 versus 0/23; p = 0.27).

The remaining studies offered no comparisons between different techniques, but may be useful to describe the variety of ventilation and weaning practices and success rates (Table 11). Comparing the success rates among studies is complicated by differences in the distribution of level of injury among the study populations. For example, the study with the population with the highest levels of injury (Splaingard, Frates, Harrison et al., 1983) reported the lowest success rate, whereas the population with the lowest levels of injury (Tromans, Mecci, Barrett et al., 1998) reported one of the highest success rates.

Table 11. Studies of Weaning from Mechanical Ventilation ^a^

Study | N | LOI | Success | Partial | Failure | Duration | Method
Bach (1991) | 34 | C4 or above | 29% (10) | - | 71% (24) | - | PVFB/NIV
Gardner, Watt, and Krishnan (1986) | 44 | 55% C4 or above | 50% (22) | 2% (1) | 39% (17) | - | -
Lamid, Ragalie, and Welter (1985) | 13 | 46% C3-C4 | 100% (13) | - | - | - | -
Peterson, Barbalata, Brooks et al. (1999) | 23 19 | C3-C4 C3-C4 | 100% 100% | - - | - - | 38 days 59 days | PVFB/High vol A/C PVFB/Low vol A/C
Peterson, Charlifue, Gerhart et al. (1994) | 26 34 | C3-C4 C3-C4 | 35% (9) 68% (23) | 19% (5) 18% (6) | 46% (12) 15% (5) | - | SIMV PVFB
Sortor (1992) | 22 | 86% C3-C4 | - | 18% (4) | 77% (17) | - | -
Splaingard, Frates, Harrison et al. (1983) | 17 | 47% C3-C4 53% C2 or above | 24% (4) | 18% (3) | 59% (10) | - | Not described
Tromans, Mecci, Barrett et al. (1998) | 12 | 50% C4 45% C5 or below | 83% (10) | - | 17% (2) | 38 days | NIV (BiPAP^®^)
Viroslav, Rosenblatt, and Tomazevic (1996) | 76 | Not described | 26% (20) | 30% (23) | 43% (33) | - | NIV

a A/C = assist-control; LOI = level of injury; NIV = noninvasive ventilation; NS = not significant; PVFB = progressive ventilator-free breathing; SIMV = synchronized intermittent mandatory ventilation.

### Chronic Ventilation Management

The prognosis for patients on MV who survive the initial period of high risk is good. DeVivo and Ivie (1995) described survival in a large cohort of persons with SCI who were dependent on MV at the time of death or discharge from rehabilitation from Model Systems institutions. Among those patients surviving to 1 year, the 15-year survival rate was 61. 4 percent. There was a marked improvement in survival over the last three decades, with persons injured since 1986 having 91 percent lower mortality than persons injured between 1973 and 1979. The single most frequent cause of death in these patients was pneumonia, which accounted for 27.3 percent of deaths of known cause; another 12.3 percent of deaths were attributed to "symptoms and ill-defined conditions" that were always respiratory in nature; "other specific respiratory causes" (not including pulmonary embolism) was the fifth most frequent cause of death, accounting for 6.2 percent of deaths. Altogether, respiratory conditions accounted for 48.9 percent of deaths among ventilator-dependent persons with SCI.

It is hypothesized that chronic ventilator dependence may have significant psychosocial effects for patients with SCI. Bach and Tilton (1994) compared overall life satisfaction, general affect (well-being), and level of distress over ventilator dependence versus distress over loss of extremity function between two groups of patients with complete traumatic tetraplegia (level of injuries not specified) -- 42 on chronic ventilatory assistance and 45 autonomously breathing. The ventilator-assisted patients required a mean of 17.6 hours/day of ventilatory support and had been on ventilation for an average of 9.7 years. The autonomously breathing subjects averaged 8.9 years since injury. The investigators also surveyed a larger group of healthcare professionals (n = 273). Long-term quality of life and well-being was found to be similar in ventilator-dependent and autonomously breathing patients with SCI and was correlated with the degree of family and social interaction. Ratings of quality of life and well-being given by healthcare providers responding as if they were ventilator-assisted were lower than those given by patients with SCI. Ventilatory-assisted subjects rated their distress over their loss of breathing autonomy lower than the autonomously breathing SCI subjects predicted they would. This study suggests that chronic ventilatory support does not result in important decrements in quality of life as is often assumed by non-disabled individuals.

#### Chronic NPPV

In cervical SCI, NPPV has been described as a technique for temporary support of acute ventilatory insufficiency to avoid intubation (Tromans, Mecci, Barrett et al., 1998), a means to facilitate weaning from invasive ventilation (Tromans, Mecci, Barrett et al., 1998; Bach, 1991; Bach, Alba, and Saporito, 1993) and as a means of providing long-term ventilatory support (Bach, Rajaraman, Ballanger et al., 1998).

One potential advantage of NPPV over tracheostomy positive pressure ventilation (TPPV) may be that it does not bypass the body's mechanisms for filtering inspired air in the oro- and nasopharynx. NPPV has been associated with a lower risk of respiratory tract infection, particularly pneumonia, than TPPV in acute-care hospitals during short-term use. Whether this is true for persons with cervical SCI using the techniques for home ventilation was tested by Bach, Rajaraman, Ballanger et al. (1998). Among 52 persons with SCI on home ventilation, the incidence of pneumonia was lower after transition to part-time or full-time noninvasive ventilation at home than while on PPV through endo- or nasotracheal tube in hospital (p < 0.05). Patients who used tracheostomy PPV at home had no such decrease in incidence of pneumonia. The hospitalization rate for home-managed patients was lower for patients on part-time or full-time noninvasive ventilation compared with those on TPPV (p < 0.05). This study suggests that noninvasive ventilation may reduce the risk of pneumonia compared with tracheostomy interfaces for patients requiring chronic ventilatory support.

Long-term health outcomes associated with CPAP have rarely been described in persons with tetraplegia, with some information reported on suspected nocturnal hypoxemia. Gothe and Maximin described experience with 14 patients with abnormal nocturnal oxygen saturation. Of six patients maintained on CPAP treatment for up to 5 years, all but one had died. The mortality rate was similarly high among the seven who had not been treated with CPAP. The study, reported as a letter, had incomplete followup and was too small to yield meaningful estimates of mortality; however, it does emphasize that nocturnal oxygen desaturation is associated with high mortality.

#### Diaphragm Pacing

We identified five separate case series describing data on the effectiveness of EPR for chronic ventilation assistance. In Carter (1993), which may overlap with Carter (1980) and Carter, Donovan, Halstead et al. (1987), this retrospective series compared survival among persons with high-cervical SCI discharged home on mechanical ventilation (n = 19) with those discharged with EPR (n = 23). Phrenic nerve stimulators were implanted an average of 14.6 months after SCI. Assuming four patients lost to followup had actually died, total survival rate after SCI (from contemporary patients) was greater for patients on EPR than for those on IPV. However, these differences were not statistically significant, and, excluding the four patients lost to followup, would yield nearly identical survival rates for the two groups.

The application of EPR from the time of implantation was studied in a small series of 15 ventilator-dependent patients with high-cervical SCI (Fodstad, 1989). After implantation, phrenic nerve pacing began on day 10, with hourly pacing for 3 minutes each hour. These periods of pacing were gradually increased over 2 weeks to 2 months. After a followup of from 2 to 96 months (mean 45 months), five of 15 (33 percent) had ceased EPR pacing and were using no MV support; all of these patients had C3-C5 level of injury. Four (27 percent) used EPR pacing full time with no MV support, and six (40 percent) used EPR during the day and MV support at night.

Both of these studies described prognoses of patients who had successfully achieved ventilation via EPR, but they did not describe in how many patients EPR was attempted and failed. According to three other studies, EPR does not succeed between 13 percent and 38 percent of the time (Table 12) (Glenn, Holcomb, Shaw et al., 1976; Miller, Farmer, Stuart et al., 1990; Weese-Mayer, Silvestri, Kenny et al., 1996). The more recent studies appear to have higher success rates than do earlier studies of EPR shown in Table 13.

Table 12. Success Rates and Mortality of Patients on Chronic EPR^a^

Study | Number of Subjects | EPR Use at Followup | | | | Mortality | Followup, Mean (mo.)
Study | Number of Subjects | Off all MV | Full-time | Part-time | Failed
Carter (1993) | 23 | - | - | - | - | 39% (9) | 88.7
Fodstad (1989) | 15 | 33% (5) | 27% (4) | 40% (6) | - | 0% (0) | 45
Glenn, Holcomb, Shaw et al. (1976) | 37 | 0 | 35% (13) | 27% (10) | 38% (14) | 27% (10) | 26
Miller, Farmer, Stuart et al. (1990) | 23 | 0 | 35% (8) | 52% (12) | 13% (3) | 9% (2) | 12
Weese-Mayer, Silvestri, Kenny et al. (1996) | 29 | 0 | - | 86% (25) | 14% (4) | 3% (1) | 26

a EPR = electrophrenic respiration; MV = mechanical ventilation.

Table 13. Complications of EPR^a^

Study | Number of Subjects | Receiver Failure | Electrode Failure | Local Infection | Phrenic Nerve Trauma
Glenn, Holcomb, Shaw et al. (1976) | 37 | "common" | "uncommon" | 14% (5) | 30% (11)
Weese-Mayer, Silvestri, Kenny et al. (1996) | 29 | 10% (3) | 7% (2) | 0% (0) | 10% (3)
Fodstadt (1989) | 15 | "common" | - | - | -
Miller, Farmer, Stuart et al. (1990) | 23 | 13% (3) | - | - | -

a EPR = electrophrenic respiration.

The incidence of complications associated with EPR is described in one of these studies (Weese-Mayer, Silvestri, Kenny et al., 1996). Complications over an average of 2.2 years included equipment-related and nonequipment-related complications. Equipment-related complications included mechanical trauma to the phrenic nerves in 3/29 patients (10 percent) and flutter of the diaphragm in one (3 percent). No patients in this series had infection. Nonequipment-related complications included electrode failures in two (7 percent), receiver failures in three (10 percent), and nonfunctioning electrode combinations in nine episodes in five patients (17 percent). Altogether, 25 patients were successfully paced in this study, but only 15 (52 percent) were successfully paced and had no complications.

#### Pneumobelt

Miller, Thomas, and Wilmot (1988) described their experience in the use of the pneumobelt among patients with cervical SCI. Twenty-one patients were selected to try to use the pneumobelt based on their ability to sit up at 90 degrees and breathe room air. Seventy-one percent of the patients had C3- or higher-level injuries. The patients were an average of 3 to 6 months post-injury. During inpatient rehabilitation, most patients (12/21 [57 percent]) were able to use the pneumobelt for 4 or more hours per day, and another eight patients used it for an average of between 2 and 4 hours daily. One patient complained of abdominal discomfort and was unable to tolerate the technique. The authors gathered limited followup data on the patients who had been discharged (n = 13). Eleven of the 13 (85 percent) were still using a pneumobelt at the time of discharge. Ten respondents to a post-discharge survey all reported a "high level of satisfaction" with the device. The pneumobelt has also been demonstrated to be feasible in a regimen of 24-hour noninvasive ventilatory support in a large series of patients with neuromuscular diseases (Bach and Alba, 1991).

## Nonmechanical Ventilation Assistance

Empirical studies of the effects of a variety of physical interventions on pulmonary function in patients with cervical SCI demonstrate effects of respiratory muscle conditioning; GPB; and changes in head, neck, and body position or posture.

### Respiratory Muscle Conditioning

The VC of patients with cervical SCI is reduced, and the severity of this reduction varies with several factors, the most important being the level of injury. Supine VC among patients with low-cervical injuries who are able to breathe on their own was reduced to about half of predicted normal values.

Several training techniques may be used to improve respiratory function in persons with tetraplegia. Exercise can strengthen and improve endurance of the diaphragm and accessory respiratory muscles (Gross, Ladd, Riley et al., 1980). Stretching may improve chest wall compliance. A variety of active exercises are used, including inspiratory resistive muscle training, abdominal weights training, GPB, and incentive spirometry. Other maneuvers include using a manual resuscitator or volume ventilator to stretch the lungs and chest wall. Studies of respiratory muscle exercise in patients with tetraplegia are described in Table 14.

Table 14. Respiratory Muscle Exercise in Patients with Tetraplegia^a^

Study | LOI | Design | Baseline VC | Interventions | Findings
Lane (1982) | NS | Prosp. series | NS | Abdominal weight training | Improved FVC before to after training
Derrickson, Ciesla, Simpson et al. (1992) | C4-C7 Acute | RCT | 1.3 L | Inspiratory resistance training versus abdominal weight training | Both groups improved in all spirometric parameters; no difference between active and control
Huldtgren, Fugl-Meyer, Jonasson et al. (1980) | C4-C8 Chronic | Prosp. series | 42% ppv | Insufflation and inspiratory resistance training | Improvement in TLC, VC, ERV, P_e_max, P_i_max
Walker and Cooney (1987) | C4-C8 Chronic | Prosp. series | 2.6 L | Incentive spirometry and arm ergometer exercise | 25% improvement in VC 70% improvement in max VE
Loveridge, Badour, and Dubo (1989) | C6-C7 Chronic | RCT | 68% ppv | Inspiratory resistance training versus control | Both groups improved in all spirometric parameters; no difference between active and control
Cheshire and Flack (1978) | C4 MV C4-C6 acute C5-C6 chronic | Prosp. series | 0.37 L 1. 63 L 1. 3 L | Incentive spirometry | Improvement in FVC
  MV group | 566%
  No-MV acute | 84%
  No- MV chronic | 74%
DiPasquale (1986) | C1-C4 | Case series | NS | Deep breathing exercises and glossopharyngeal breathing along with education | Average improvement in VC of 0.5 L per patient

a ERV = expiratory reserve volume; FVC = forced vital capacity; L = liters; LOI = level of injury; MV = mechanical ventilation; NS = not significant; ppv = percent predicted value;P_e_max = maximum expiratory pressure;P_i_max = maximum inspiratory pressure; prosp. = prospective; RCT = randomized controlled trial; TLC = total lung capacity; VE = expired unit per volume time.

In a retrospective study, Lane (1982) demonstrated statistically significant increases in FVC among 16 patients with tetraplegia who received abdominal weight training three times per week for 6 weeks, compared with 15 patients who had routine physical therapy management. In that study, patients with C4 level of injury made slower improvement in FVC than did patients with lower-level injuries (C5).

Derrickson, Ciesla, Simpson et al. (1992) conducted a randomized controlled trial among patients with recent low-cervical SCI comparing two types of exercise: inspiratory resistive muscle training versus abdominal weights. All patients were breathing on their own, although some had only just been weaned from MV. Baseline spirometric values revealed a mean FVC of 1.3 L. Forty-five percent of patients had a C4-C5-level injury, while 18 percent had C6- and 36 percent had C7-level injuries. Patients in both groups received two 15-minute training sessions per day, 5 days per week, for 7 weeks. All patients improved in all spirometric indices, including FVC, maximal voluntary ventilation (MVV), peak expiratory flow rate (PEFR), maximum inspiratory pressure (P_i_max), and inspiratory capacity (IC). However, no differences were observed between the two exercise conditions; similar improvements in pulmonary function measures were observed for both types of breathing exercise.

Huldtgren, Fugl-Meyer, Jonasson et al. (1980) reported the results of an uncontrolled prospective trial of a respiratory training program that included insufflation and resistance training among 12 patients with tetraplegia (level of injury C4 and below). All patients were breathing on their own. Insufflation of air into the lungs using a manually operated pump was performed 10 times daily in supine patients with abdominal binders. The insufflated volume was increased every other day until predicted total lung capacity (TLC) was achieved. Resistance training included forced expiration and inspiration against resistance starting at spontaneous TLC, and in separate attempts starting at a higher lung volume following insufflation (insufflated TLC). After 6 weeks of training, patients showed significant improvement in VC, expiratory reserve volume (ERV), P_i_max, and maximum expiratory pressure (P_e_max). Followup of 11 patients at 1 year and five patients at 5 years suggests that the lung volumes remained improved, although improvements in static respiratory pressures were not maintained.

Walker and Cooney (1987) prospectively studied the effect of incentive spirometry and arm ergometer exercise in 15 patients with chronic low-cervical SCI. The mean VC at the start of the trial was 2.6 L. By the end of the training program, the VC had increased by 25 percent, or 0.66 L, and expiratory volume had increased by 70 percent.

Loveridge, Badour, and Dubo (1989) conducted a randomized controlled trial comparing inspiratory resistive muscle training with control among 12 patients with chronic C6-C7-level injuries. The training, described as ventilatory muscle endurance training, consisted of using an inspiratory resistor twice daily for 15 minutes, 5 days per week, for 8 weeks. The resistance was equivalent to 85 percent of sustained inspiratory mouth pressure (SIP), and was increased as SIP increased. Both the exercise and control groups showed improvement in maximum inspiratory mouth pressure and SIP, and although improvements were somewhat greater in the training group, they were not statistically significantly greater than in the control group.

Incentive spirometry may be used to improve respiratory muscle function in patients on ventilatory support in preparation for weaning, or in autonomously breathing patients. Cheshire and Flack (1978) described the use of an incentive spirometry program involving the Spirocare Incentive Breathing Exerciser, a spirometer with flashing colored lights rather than numbers to more clearly indicate success to the patient. Twelve patients in the study included five on MV; five with recent injury, but who did not require MV; and two with old SCI injuries who were recovering from an acute respiratory illness. Patients in all groups improved FVC, although no control group was assessed.

Another series described the use of a multidisciplinary intervention of respiratory muscle exercise and grouped educational sessions among 56 patients with high-cervical SCI, nearly all of whom were ventilator dependent (DiPasquale, 1986). Both respiratory (GPB) and nonrespiratory (head and neck motion and passive range of motion to upper extremities) exercises were included. The program resulted in an average 0.5 L improvement in VC, although neither baseline VC nor time since injury was described.

### Glossopharyngeal Breathing

Glossopharyngeal breathing (GPB) is a technique in which a patient uses the muscles of the mouth, pharynx, and larynx to add to inspiration by pushing (gulping) boluses of air past the glottis. The glottis closes after each gulp. It requires training, but can be used autonomously by patients to augment VC to provide for improved cough or to allow prolonged ventilator-free time even in patients with minimal spontaneous VC.

Montero, Feldman, and Montero (1967) assessed the effect of training in GPB among 14 patients with low-cervical SCI. Instruction was given for one-half to 1 hour three times weekly until each patient could increase his VC by 0.7 to 1 L with 10 to 20 GPB "gulps." The patient practiced unsupervised for 10 minutes two to three times daily. Pulmonary function tests after training showed improvements in mean VC from 35 percent predicted normal to 65 percent predicted normal. Similar improvements were seen in peak expiratory flow (PEF), MVV, and breath-holding time. Furthermore, the authors observed that GPB allowed improvements in audibility of patients' voices, such that they could call out more loudly than they had been able to before receiving training.

### Posture

In normal persons, the VC is similar when in supine, seated, or standing positions. However, in persons with SCI, changing position from supine to sitting or tilting at various angles results in larger changes in spirometric parameters (Table 15). The effect was first demonstrated by Fugl-Meyer (1971), who described changes in VC with sitting position, supine position, and tilted at various elevations from supine. Similar results have been described in several subsequent studies. VC diminished with increasing head-up tilting from supine position. The reduction in VC associated with a change in position from supine to sitting is both statistically significant and clinically important.

Table 15. Effects of Body Position on Ventilatory Function in Patients with Tetraplegia^a^

Study | Level of Injury | Mean VC in Supine Position | Effect of Changing from Supine to Sitting Position on VC | P-value
Fugl-Meyer (1971) | 4% C4 96% C5-C8 | 42% predicted | Reduced 28% | p < 0.001
Forner, Llombart, and Valledor (1977) | 25% C4 or C5 75% C6 or below | 50% predicted (sitting) | Reduced 11% | p < 0.05
Chen, Lien, and Wu (1990) | C4-C8 | 57.1% predicted | Reduced 11% to 13% predicted | p < 0.05
Estenne and De Troyer (1987) | 21% C4-C5 or C5 50% C5-6 or C6 29% C6-C7 or C7 | 48.4% predicted | Reduced 16% of seated values or 0.41 L | -
Maeda, Baydur, Waters et al. (1990) | 40% C5 50% C6 or below | 65.3% predicted | Reduced 8% predicted | p = 0.015

a VC = vital capacity.

Estenne and De Troyer (1987) replicated the effect of changes in position among 14 persons with chronic cervical SCI. In addition, they tested whether the use of leg cuffs or abdominal binding could reduce the postural effects on VC. Inflating blood pressure cuffs at the base of a subject's legs (up to diastolic blood pressure) before he assumed a seated position had little effect on residual volume (RV) or VC. Abdominal binding using elastic straps was fitted while subjects were supine and at end expiration. Abdominal binding eliminated the increase in RV that occurred when subjects assumed a seated position.

This study suggested that the mechanism of the postural dependence of VC in persons with tetraplegia is a reduction in ERV rather than mechanical advantage of the diaphragm, as had been previously supposed. This study suggests that the effect of gravity (and posture) on the abdominal contents and diaphragm, and hence on VC, can be partially overcome through the use of abdominal binding.

Several more-recent smaller studies have addressed further questions regarding positioning. Amodie-Storey, Nash, Roussell et al. (1996) assessed the head position of 15 persons with cervical SCI, classifying each subject in terms of habitual head posture: forward and not forward. Forward orthostatic position of the head was defined as a more than 6-cm forward displacement of the midcervical spine relative to the thoracic spine when seated. By using rolled towels, investigators were able to alter the habitual posture, so that the three subjects with not-forward head posture were positioned to be forward, and the 12 who were habitually forward were placed in the not-forward position. A variety of spirometric indices were measured, with each subject in his habitual posture and in the experimental altered posture. For the 12 subjects with habitual forward posture, FVC and MVV were significantly lower in the altered than in the habitual posture, with a mean reduction of about 8.5 percent in FVC (p < 0.05) and 14.5 percent in MVV (p < 0.05). Among the three subjects with the not-forward habitual posture, slight reductions in FVC and MVV were not statistically significant. No significant changes were observed for forced inspiratory vital capacity (FIVC) or forced expiratory flow between 25 and 75 percent of the exhaled volume (FEF_25-75_) in either group. These findings suggest that altering the orthostatic head position may result in reduction of pulmonary function.

Halo vests are often used to stabilize the cervical spine following acute SCI. A previous retrospective study found that the halo vest restricted the VC by 8 percent in both quadriplegic and neurologically intact patients (Lind, Bake, Lundqvist et al., 1987). Maeda, Baydur, Waters et al. (1990) prospectively investigated the effects of body position and halo vest on VC in patients with tetraplegia compared with neurologically intact patients. Changes in position from supine to sitting resulted in similar decreases in VC with or without halo vest. The application of the halo vest itself reduced the VC by 6 percent predicted in the supine position (p = 0.01) and by 2.5 percent predicted in the sitting position (p = NS). A control group of neurologically intact subjects showed no decrement in VC from supine to seated, but did show a slightly greater percentage decline in VC with application of the halo vest. Because their pulmonary function was normal, this decrement was not clinically important.

## Clinical Monitoring and Diagnostic Procedures

Efficacy data from the studies reviewed in this section of the report are summarized in Evidence Table 2.

### Pulmonary Function Measures

Ventilatory function is often assessed frequently among patients with acute cervical SCI, typically every 8 hours. Studies that document improvement over time or with respiratory muscle conditions suggest that serial testing may be indicated, although we found no studies that help to determine the optimal timing or frequency of such assessment. Several studies are relevant to how such assessments should be performed. Studies of the effect of posture and positioning on PFTs (discussed in the preceding Posture section) indicate that spirometric tests in the usual seated position give a systematically lower value for FVC when compared to the supine position. Choice of position for testing should depend on patients' functional position.

To meet American Thoracic Society (ATS) criteria for acceptability and reproducibility of FVC and forced expiratory volume in 1 second (FEV_1_) measures, patients must obtain at least three acceptable efforts, which require an exhalation time of at least 6 seconds, no nasal or mouth leaks, cough or other problems, and maximal effort as judged by the technician. However, patients with cervical SCI often fail to meet the requirements for acceptability or reproducibility. They have a relatively long transition time from forceful inhalation to forceful exhalation, which causes difficulty determining the starting time for calculating the FEV_1_. The extrapolation of the starting time leads to an estimate of the volume of air expired that was not measured -- the extrapolated back expiratory volume (EBEV). To be acceptable, the EBEV can be no more than 5 percent of FVC or 100 cc. Ashba, Garshick Tun et al. (1993) described the proportion of patients who could perform acceptable and reproducible spirometry according to the ATS definition and two less-stringent criteria. One less-stringent criteria required two, rather than three, acceptable efforts and allowed a larger EBEV if effort appeared to be maximal. The other modification included the above modifications and also allowed exhalation times of less than 6 seconds so long as a plateau of at least 0.5 seconds had been reached. Two-thirds of subjects had a least two acceptable efforts according to the standard ATS criteria, but 11 of 12 (92 percent of subjects) had two or more acceptable efforts with either modification. Similarly, the modified criteria increased the reproducibility from 58 percent to 83 percent for FVC and from 50 percent to 75 percent for FEV_1_.

The neurological examination for limb muscle strength and tone may be relevant to the assessment of pulmonary function. Roth, Lu, Primack et al. (1997) correlated neurological exam (muscle strength and tone) with PFTs in 44 patients with cervical SCI at the C4 level or lower at an average of 77 days after injury. Muscle tone was measured using the Ashworth scale, which rates the severity of limb spasticity (Ashworth, 1964). The 52 patients described in this article are the same as those described in Roth, Nussbaum, Berkowitz et al. (1995). The muscle strength was measured directly in the limbs. The authors found that the level of injury was significantly correlated with negative inspiratory pressure and estimated reserve volume, but not with most other PFT measures, primarily measures of expiration. Only negative inspiratory pressure was significantly correlated with muscle-tone ratings. The authors concluded that muscle strength may be a more important factor than muscle tone in determining pulmonary function in persons with SCI, and that both strength and tone are closely related to negative inspiratory pressure. However, the narrow spectrum of level of injuries, with all but a few patients in the range from C4 to C7, may have diminished their ability to demonstrate differences.

### Radiography

Chest roentgenography often demonstrates pulmonary lesions in patients with tetraplegia. Available studies do not clarify the significance of these lesions. A retrospective case series reported by Scher (1982) found that 28 percent of all patients (14 of 50) had chest lesions visible on chest roentgenography. The chest X-rays were taken during a period of stable symptoms and at least 12 weeks after SCI. Patients with neurologically complete lesions had a higher rate of chest roentgenogram (CXR) abnormality (40 percent; 12 of 30) than those with incomplete lesions (10 percent; two of 20). The age and significance of these lesions were not specified.

Another retrospective study described pulmonary injuries that had been undetected in the initial assessment of patients with acute SCI. Ryan, Klein, and Bongard (1993) conducted a chart review on 13 patients with cervical SCI in order to identify those who had injuries overlooked at admission. Six of the 13 patients had injuries that were overlooked; three of these were pulmonary (two pneumothoraces, one paralyzed hemidiaphragm). This study did not describe in detail the sort of clinical assessment that did lead to diagnosis of these conditions, but the high prevalence of pulmonary complications in tetraplegia suggests that CXR in the post-acute period may be warranted.

Two further studies describe the accuracy of roentgenographic procedures (Bain, Bodley, Jamous et al., 1995; Hsu, Dreisbach, Charlifue et al., 1987). Bain, Bodley, Jamous et al. (1995) described the agreement between CXR and chest computed tomography (CT) among 60 patients with SCI who had both procedures. Supine CXR was assessed blind to CT findings, and parenchymal abnormalities were identified. Effusions were classified as small, medium, or large, according to stated criteria. CT results were correlated with the CXR. Absolute agreement occurred in 20 percent (12 of 60). CXR underestimated the changes demonstrated on CT (either failed to diagnose it or rated its size differently by more than 1 degree) in 58 percent (35 of 60). In 22 percent (12 of 60), CXR overestimated the changes demonstrated on CT. This study points out that pleural effusions are frequently missed by supine CXR. The study shows pleural effusions are common among persons with SCI even when CXR is normal.

Glottic and subglottic tracheal stenosis is diagnosed and treated by endoscopy, but noninvasive tests such as tomography and CTs could be used to diagnose it and grade its severity. In a retrospective case series of 47 patients with SCI, Hsu, Dreisbach, Charlifue et al. (1987) compared tomography and CT scan for effectiveness in grading the severity of stenosis, comparing both against a reference standard of endoscopy. The severity of stenosis was graded as mild (< 20 percent stenosis), moderate (20 to 49 percent stenosis), severe (50 to 79 percent stenosis), or obstruction (80 percent or higher stenosis). Of the 47 patients, 10 had only glottic stenosis, 19 had only tracheal stenosis, and 18 had both glottic and tracheal stenosis. In diagnosing glottic stenosis, tomography agreed with endoscopy in one-third of cases (nine of 27) and was within one grade of severity in another half of cases. CT scan showed greater agreement with endoscopy, with exact agreement in 69 percent and an additional 25 percent within one severity grade. For grading the severity of tracheal stenosis, tomography agreed with endoscopy in 67 percent of cases and agreed within one severity grade in an additional 25 percent. CT agreed with endoscopy in 73 percent exactly, and another 18 percent within one severity grade. Thus, tomography had better agreement with endoscopy for tracheal than glottic stenosis. CT was more accurate than tomography for diagnosing glottic stenosis, but similarly accurate for grading the severity of tracheal stenosis.

## Oximetry

Cahan, Gothe, Decker et al. (1993) studied the occurrence of nocturnal hypoxia in a group of persons with tetraplegia who were an average of 14 years post-injury and who had lesion levels of C4 or below. None of the clinical data considered -- including level of injury, age, duration since injury, medications, history of snoring, daytime drowsiness, or acute respiratory illness -- could distinguish between the six persons with nocturnal cyclical desaturation of more than 4 percent in SaO_2_ (arterial oxygen saturation) and the 10 persons with normal SaO_2_ values while awake and asleep. Even the combination of snoring and daytime drowsiness, often indications for nocturnal polysomnography in non-SCI persons, did not distinguish hypoxic from normal subjects. This study suggests that clinical history may not be a reliable indicator of the risk for sleep-disordered breathing among persons with cervical SCI.

## Swallowing Study

Swallowing disorders can predispose a person with SCI to aspiration, increasing the risk of airway obstruction, atelectasis, pneumonitis, and pneumonia. The prevalence of swallowing disorders in persons with cervical SCI was described in a recently published study of a bedside swallowing evaluation in 187 patients with acute traumatic spinal cord injury admitted to a rehabilitation hospital (Kirshblum, Johnston, Brown et al., 1999). The bedside evaluation consisted of a test of oral-motor strength, range of motion of the tongue and lips, ability to swallow on command, a dry swallow, trial swallow with solids and liquids, and/or a swallow with adjusting of the position of the head as tolerated. Forty-two (22.5 percent) had signs or symptoms detected on bedside evaluation that were suggestive of dysphagia (delay in initiation of the swallow, wet voice quality, or frank coughing). These patients underwent a videofluoroscopic swallowing study (VFSS). VFSS was considered positive if it demonstrated poor pharyngeal stripping action, sluggish or inefficient opening of the cricopharyngeus, excessive pooling in the piriform sinus, delayed laryngeal elevation, or frank penetration or aspiration. VFSS was positive in 73.8 percent (31 of 42). Among the 42 patients with a positive bedside evaluation, patients with dysphagia by VFSS could be distinguished from those without dysphasia by VFSS with three independent predictors: history of spinal surgery via anterior cervical approach (p < 0.016), tracheostomy with mechanical ventilation (p < 0.01), and older age (p<0.028). Higher level of injury and increased time between injury and rehabilitation admission slightly increased the likelihood of dysphagia. Tracheostomy at admission was the strongest single predictor of dysphagia. Patients with both tracheostomy and anterior surgical approach were highly likely to demonstrate dysphagia (48%). However, the authors caution that none of the predictors is strong enough to obviate the need for testing.

## Drug Therapies

Efficacy data from the studies reviewed in this section are summarized in Evidence Table 3.

### Bronchodilators

It has been suggested that bronchoconstriction is an under-recognized cause of feelings of breathlessness reported by a majority of patients with tetraplegia (Spungen, Grimm, Lesser et al., 1997). Cervical spinal cord transection interrupts the sympathetic nerve supply to the lungs (T1 to T6), but not the parasympathetic innervation, suggesting that unopposed cholinergic tone, which causes hypotension and bradycardia, may also cause bronchial smooth muscle constriction and airway obstruction. Such bronchoconstriction would be potentially treatable with bronchodilating drugs. Perhaps because the restrictive ventilatory impairment among patients with tetraplegia is so severe, less attention has been given to bronchoconstriction and the potential benefit of its treatment. However, we identified a series of studies by the same group of investigators that examines the effects of drug treatments (metaproterenol sulfate, ipratropium bromide, baclofen, oxybutynin chloride) on airway reactivity in patients with SCI. We found no studies of theophylline or other methylxanthines in this population.

Spungen, Dicpinigaitis, Almenoff et al. (1993) and Almenoff, Alexander, Spungen et al. (1995) document that among persons with tetraplegia without acute pulmonary symptoms, nearly half "respond" to inhaled bronchodilators with metaproterenol sulfate (Spungen, Dicpinigaitis, Almenoff et al., 1993) or ipratropium bromide (Almenoff, Alexander, Spungen et al., 1995). Subjects in these studies were all patients with tetraplegia who were able to breathe on their own. Patients with a history of asthma or allergies were excluded. In one study, 28 percent of subjects had chronic dyspnea at rest, but none had evidence of respiratory tract infections or other acute pulmonary symptoms (Almenoff, Alexander, Spungen et al., 1995).

Forty-one percent of patients treated with metaproterenol sulfate (0.6 percent) and 48 percent of patients treated with ipratropium bromide (four puffs inhaled via a spacer device) showed at least 12 percent improvement in FEV_1_ from pre- to post-bronchodilator. The mean improvement in FEV_1_ for responders was about 16 percent, whereas non-responders had a mean change of less than 1 percent. This evidence was observed in similar proportions of smoking and non-smoking patients; it was also seen in similar proportions of patients who either did or did not feel dyspneic.

Given this evidence of airway obstruction in a large proportion of patients with tetraplegia, five additional studies were designed using an experimental model of pharmacologically induced bronchoconstriction. The investigators administered increasing doses of methacholine or histamine to induce sufficient bronchoconstriction to reduce the FEV_1_ by 20 percent (PC_20_) to measure whether acute (metaproterenol sulfate, ipratropium bromide) and chronic (baclofen, oxybutynin chloride) drug treatments could modify this bronchoconstriction. Baclofen and oxybutynin chloride are GABA-agonists often used to treat spasticity in persons with SCI and have also been shown to inhibit bronchial hyperreactivity, presumably through gamma-aminobutyric acid receptors in the lung.

The first of these challenge studies compared the bronchial response to provocation with methacholine in six patients on chronic baclofen treatment with an eight-patient control group who had not taken baclofen (Dicpinigaitis, Spungen, Bauman et al., 1994). The mean concentration of methacholine required to induce bronchoconstriction was significantly higher for the chronic baclofen group than the non-baclofen group. However, this study could not determine whether the action of baclofen was related to its anticholinergic effect or to a direct effect on airway smooth muscle.

A subsequent study again compared patients who took baclofen chronically to those who did not, but investigators used histamine to experimentally provoke bronchoconstriction (Grimm, DeLuca, Lesser et al., 1997). In this study, there was no difference in PC_20_ between the baclofen-treated and nonbaclofen-treated patients. Because bronchoconstriction was induced by histamine in both baclofen and nonbaclofen-treated patients, the authors concluded that baclofen was not causing a generalized bronchial smooth muscle relaxation, but exerting a bronchodilator response through its anticholinergic activity. Thus the authors questioned their hypothesis of bronchoconstriction due to unopposed cholinergic tone, in favor of a nonspecific airway hyperresponsiveness, such as that seen in asthma. Presumably this would occur through chronic bronchial inflammation leading to thickening of epithelial, smooth muscle, and adventitial layers.

Subsequently, the same group compared patients who took oxybutynin chloride (Ditropan^®^) chronically with those who did not and measured experimentally provoked bronchoconstriction response to both methacholine and histamine (Singas, Grimm, Almenoff et al., 1999). Oxybutynin is widely used to treat urinary tract and gastrointestinal spasmodic disorders through its local anesthetic and moderate anticholinergic properties.

Just as in the baclofen studies described above, the oxybutynin-treated patients had much less response to methacholine than did the control patients, whereas both groups responded similarly to histamine. The authors concluded that like baclofen, oxybutynin acts primarily through anticholinergic pathways rather than by causing generalized airway smooth muscle relaxation. Two other studies investigated the potential therapeutic role for acute bronchodilating drugs ipratropium (Fein, Grimm, Lesser et al., 1998) and metaproterenol sulfate (DeLuca, Grimm, Lesser et al., 1999). Fifteen patients with tetraplegia were tested for histamine induced-bronchoconstriction before and after pretreatment with inhaled ipratropium bromide via metered dose inhaler with spacer device. Eighty percent of patients had a significant response to histamine (defined as PC_20_< 8 mg/mL), and this was unchanged with ipratropium pretreatment. In contrast, in a separate study of 25 subjects with tetraplegia, all of whom had previously demonstrated airway hyperreactivity to methacholine or histamine, metaproterenol sulfate pretreatment showed a different effect on airway hyperreactivity (Fein, Grimm, Lesser et al., 1998). When subjects were pretreated with metaproterenol, the methacholine- and histamine-induced bronchoconstriction was reduced significantly, with a reduction in the geometric mean PC_20_ of approximately 20 percent.

Thus, metaproterenol, but not ipratropium, can reduce airway hyperreactivity related to either cholinergic activity or non-specific causes. These studies suggest a potential therapeutic benefit from long-term prophylactic therapy with inhaled beta-agonists to reduce symptoms of breathlessness associated with airway reactivity in patients with tetraplegic. However, none of these studies evaluated the long-term efficacy of this or other drug treatments on symptoms, pulmonary function, or on the incidence of pulmonary complications.

### Vaccinations

Empirical studies relating to the effectiveness of the vaccinations for respiratory infections in tetraplegic patients is limited to two studies describing the antibody response to 23-valent pneumococcal polysaccharide vaccine in populations with SCI (Darouiche, Groover, Rowland et al., 1993; Waites, Canupp, Edwards et al., 1998). We found no studies of the effectiveness of influenza vaccines in this population. Darouiche, Groover, Rowland et al (1993) studied 40 patients with SCI, about half within 1 year of injury and about half with tetraplegia, who were administered the pneumococcal vaccine. The antibody response was compared with that of 40 age-matched, able-bodied controls. Measured at 4 to 6 weeks post-vaccination, the immune responses to five pneumococcal polysaccharides (3, 4, 6A, 8, and 23) were no different between the SCI and control groups. The overall response rates were 78 percent for patients with SCI and 84 percent for controls; these rates are not statistically significantly different. Furthermore, among patients with SCI the antibody response was not affected by age, time since injury, or level of injury. Adverse reactions to vaccination were as expected; approximately one-third of all subjects had transient mild pain or erythema at the site of vaccine injection.

Subsequently, a randomized controlled trial described antibody response to pneumococcal vaccine among 87 patients with SCI (Waites, Canupp, Edwards et al., 1998). The study included patients with acute injury who were randomized, stratified by level of injury, to receive vaccine or placebo 16 to 18 days post-injury. Separately randomized were patients with older injuries who received the vaccine 4 to 6 months after injury. Ninety-five percent of patients receiving the vaccine, compared with 35 percent of the placebo group, developed an immune response at 2 months to at least one serotype of the five tested:3, 4, 14, 19F, and 23F (p < 0.01). At 12 months, 93 percent of vaccine patients maintained a two-fold increase in antibody concentration to one or more serotypes. The timing of vaccination (16 to 18 days versus 4 to 6 months) did not influence mean antibody concentrations.

These studies show that patients with SCI demonstrate a good antibody response to pneumococcal vaccine regardless of whether it is administered soon after injury or later. However, because of differences in pulmonary pathophysiology in patients with SCI, it is uncertain whether the antibody response would be effective in decreasing the incidence of pneumococcal pneumonia or consequences of pneumonia, such as mortality.

### Other Treatments

Other potentially therapeutic drug treatments have been tested for salutary effects on ventilatory muscle function: hyperbaric oxygen, anabolic steroids, and 4-aminopyridine. We identified a single trial of the effect of hyperbaric oxygen (HBO) on VC among patients with tetraplegia (Hart, Strauss, and Riker, 1984). Patients, described as "fully rehabilitated" and "in the chronic phase of their injury," were an average of 16 months (range 4 to 84) post-injury. Subjects were treated with hyperbaric oxygen at 2 Alimentary Toxic Aleukia for 2 hours daily for 21 consecutive days. At baseline, mean VC was 2.38 L, or 47 percent predicted normal; post-HBO VC was 2.6 L, or 51 percent predicted normal. The pre- to post-treatment values were not statistically significantly different. A secondary analysis rated each patient's change in VC as improved, no change, or decreased, but did not account for test-retest reliability by stating a threshold for what is a clinically important change. In a secondary analysis, investigators reported the number of patients who improved by at least more than 10 percent of their baseline value; however, according to the ATS guideline for spirometry, for measures separated by weeks, this does not exceed the test-retest variability (ATS, 1991). The investigators reported that 10/22 patients had at least 10 percent improvement in VC. The lack of a control group, coupled with a threshold for improvement that falls below the discriminatory ability of serial VC measurement, sheds important doubt on the authors' conclusions that HBO leads to an increase in VC.

Anabolic steroids have been used to increase muscle mass and improve muscle performance in a variety of clinical situations. Limited evidence is available on their effect on pulmonary function in SCI. In a small (n = 10) uncontrolled case series, Spungen, Grimm, Strakhan et al. (1999) studied the oral anabolic steroid oxandrolone. The drug was associated with an average 2 percent weight gain (1.4 ± 1.5 kg) (p = 0.01) after 1 month. Spirometric measures also improved significantly, with FVC increasing from a baseline of 2.8 L to 3 L at 1 month (p < 0.005). Improvement was noted on other spirometric measures, including both inspiratory (FIVC and forced inspiratory volume in 1 second [FIV_1_]) and expiratory (FVC, FEV_1_, FEF _25-75_, and PEF) measures. The improvement in spirometric measures was associated with an improvement in subjective symptoms of resting dyspnea (p < 0.05). The study found slight increases in serum liver function and lipoprotein tests that did not exceed normal values. No other adverse events were mentioned in the report; however, the study was not designed to detect long-term complications.

The drug 4-aminopyridine is a potassium channel blocker that can enhance nerve conduction in demyelinated neurons. Several reports suggest that it can enhance motor or sensory function in persons with SCI. We found one study that assessed whether a single dose improved pulmonary function in persons with SCI. In Segal and Brunnemann (1997), 11 subjects with cervical-level injuries were treated with an oral dose of 10 mg of 4-AP. Baseline spirometric measures were compared with repeat spirometry performed at 4, 6, 8, 10, 12, and 24 hours. Accounting for the repeated measures taken, the analysis showed that there were statistically significant improvements in each measure from baseline to each patient's maximum measure. Furthermore, the magnitude of these changes exceeded ATS guidelines for clinically significant effects. This study is limited by its single-dose design; the effectiveness over time with continued therapy was not demonstrated in this study.

## Secretion Management

We identified studies of the efficacy of a variety of methods of rotating beds, assisted cough, and multimodal respiratory therapy interventions to manage secretions and atelectasis. Most of the studies used physiological outcomes such as spirometry. Efficacy data for the studies reviewed in this section of the report are summarized in Evidence Table 4. We found no studies ofmucolytic agents (e.g., acetylcysteine [Mucomyst ^®^], dornase alfa [Pulmozyme^®^]) in persons with SCI. Clinically, one of the most commonly used techniques for secretion clearance involves positive pressure ventilation with air stacking or mechanical insufflation-exsufflation. It is described as part of the care of patients with traumatic tetraplegia in several series (Bach, 1991; Bach and Alba, 1990a; Bach, Rajaraman, Ballanger et al., 1998); however, no quantitative data are available regarding its efficacy. Anecdotally, patients with tracheostomy tubes prefer it to airway suctioning because it is much less uncomfortable than suctioning and clears both right and left main bronchi (Bach, 1996).

### Rotating Beds

We identified three studies of rotating beds conducted among patients with cervical SCI. One was a case series with no comparison group (Green, Green, and Klose, 1980), and two compared patients treated on a rotating bed with a historical cohort of similar patients at the same institution before the rotating bed was used (Borkowski, 1989; Lemons and Wagner, 1994). Green, Green, and Klose (1980) reported the incidence of cardiopulmonary complications among a series of 105 patients with SCI (90 percent with tetraplegia) who were treated with a Roto-Rest bed. Seven of 95 patients with cervical SCI had complications, which, the authors report, is a lower rate than that reported in previous series. In calculating this figure, pulmonary emboli were counted among the various cardiopulmonary complications, which were not detailed. The authors concluded that rotating beds reduced cardiopulmonary complications and suggested that the main effect was on reducing venous stasis.

Borkowski (1989) studied the effectiveness of a kinetic treatment table (KTT) compared with a wedge turning device (WTD) for reducing pulmonary complications in an ICU. A historical cohort of 11 patients with SCI who were treated with WTD was compared with a nonconcurrent series of 11 patients treated with the newer KTT. Fifty-nine percent of all patients had cervical injuries, and these were evenly divided between groups. KTT was associated with a lower incidence of pulmonary infection (p < 0.05) and less time on MV (p < 0.05). The rate of endotracheal intubation and tracheostomy were also lower for KTT-treated versus WTD-treated patients, although not significantly so. There were no significant differences in length of ICU stay or hospitalization.

Lemons and Wagner (1994) compared outcomes among 63 patients with cervical SCI after the use of chest physical therapy and rotating beds was added to the standardized respiratory therapy protocol followed at their institution. Most of the patients (63 percent) had C4-C5 level injuries; 37 percent had C6-T1 level injuries. Thirty-nine of the 63 patients developed respiratory complications and 31 required MV. Slight differences favored the later cohort (treated with rotating bed and chest physiotherapy) in incidence of pneumonia (p = 0.043) and length of ICU stay (p = 0.032). However, there were no significant differences in the incidence or duration of respiratory insufficiency (p > 0.5).

In summary, two studies with historical controls suggest that use of rotating beds may decrease the risk of pneumonia and length of ICU stay. Whether this effect is obtained through improved mobilization and clearance of secretions or by reduction of atelectasis is uncertain.

### Assisted Cough

Among patients with SCI, the ability to cough is impaired. The most important cause of impaired cough is the paralysis of the abdominal muscles. In neurologically intact subjects, the peak air flow during volitional cough is between 300 and 700 L/min; in contrast, peak air flow in tetraplegia has been estimated at 220 L/min (Braun, Giovannoni, and O'Connor, 1984). However, this average value is widely variable between subjects and also varies with level of injury (Wang, Jaeger, Yarkony et al., 1997). Several approaches have been used to assist cough, including manual pressure applied to the abdomen (timed with a patient's cough effort), positive pressure insufflation, and electrical stimulation of the abdominal muscles. Each of these methods requires the active intervention of a caregiver; each also requires coordination with the patient's control of opening and closing the upper airway. In case reports, assisted cough has been associated with dislocation and embolization of vena caval filters and is likely contraindicated in this situation.

We review three Level V studies comparing various methods of assisting cough (Table 16). Each study was prospective, studying patients before and after various techniques for cough assistance. Each clearly defined the outcome measures and criteria and described the cough-assistance techniques sufficiently that such techniques could be reproduced by others. None followed patients to measure health outcomes associated with prolonged use of different techniques. Each study involved mostly patients with lower cervical level of injuries who were breathing on their own, but one to two patients in two studies had C4-level injury (Jaeger, Turba, Yarkony et al., 1993; Lin, Lai, Wu et al., 1998). None described the selection criteria.

Table 16. Effect of Assisted Cough on Peak Flow^a^

Study | N | Level of Injury | Unassisted Cough Peak Flow (L/min) | Method of Assisted Cough | Percent Improvement in Peak Flow Compared with Unassisted Cough
Jaeger, Turba, Yarkony et al. (1993) | 24 | C4-C7 | 203±52 | Manual Electrical/no corset | 15% (p < 0.05) 8% (p < 0.05)
Lin, Lai, Wu et al. (1998) | 12 | C4-C8 | 271± 15 | Corset Electrical/corset | 2% (p = NS) 18% (p < 0.01)
Kirby, Barnerias, and Siebens (1966) | 10 | C5, C6 | 234 | Corset Manual OPP OPP/corset Manual/OPP/corset | 7% 33% 37% 45% 78%

a NS = not significant; L = liters; OPP = oral positive pressure insufflation.

The unassisted cough peak flow ranged from 203 to 271 L/min, a response well below that of unimpaired individuals, but one that would be expected for persons with tetraplegia with lower-cervical injuries. The use of a corset, or abdominal binder, showed negligible improvement in peak flow (2 percent and 7 percent) in two studies (Kirby, Barnerias, and Siebens, 1966; Lin, Lai, Wu et al., 1998). Manual assistance demonstrated larger improvements (15 percent and 33 percent) that were statistically significant in one study (Jaeger, Turba, Yarkony et al., 1993). Electrical stimulation resulted in statistically significant improvement in peak flow during cough in two studies, one in which subjects used a corset (Lin, Lai, Wu et al., 1998), and one in which they did not (Jaeger, Turba, Yarkony et al., 1993). The use of electrical stimulation was limited in one study by two factors: inability of patients to tolerate electrical stimulation (21 percent, 5/24) and inability of patients to obtain sufficiently strong muscle contractions from electrical stimulation (21 percent, 5/24) (Jaeger, Turba, Yarkony et al., 1993). In one study, oral positive pressure insufflation showed large improvements in peak flow with or without a corset; when combined with manual assistance and corset, oral positive pressure improved peak flow to near normal range (Kirby, Barnerias, and Siebens, 1966).

### Multimodal Pulmonary Therapy

Two studies described the use of a "vigorous" respiratory therapy intervention to prevent or reverse secretion retention and atelectasis. One was a retrospective case series (Sugarman, 1985) and the other a historical cohort comparison (McMichan, Michel, and Westbrook, 1980).

In one series of 128 consecutive SCI admissions, atelectasis based on chest radiograph developed in six patients (Sugarman, 1985). Once atelectasis was identified, the six patients (also included in the series described in Sugarman, Brown, and Musher (1982) were treated with a "vigorous" pulmonary therapy. The vigorous pulmonary therapy included doubling the frequency of routine suctioning, assisted coughing, deep breathing, and incentive spirometry. It also included special attempts to suction the left main bronchus and bronchoscopy as needed. The vigorous pulmonary therapy succeeded in returning the chest radiograph to normal within 24 hours after therapy was initiated in all six patients. In addition, four had improvement in tidal volume and FVC; four had improvement in dyspnea. During subsequent hospital course, three of six had a total of seven recurrent episodes of atelectasis.

McMichan, Michel, and Westbrook (1980) described patients in a prospective series after the institution of a respiratory care protocol to prevent, treat, and assess secretion retention. This series demonstrated lower mortality, atelectasis, need for MV, and tracheostomy than did a retrospective series conducted at the same institution before the protocol had been instituted."Usual care" in the historical series consisted of changing the patient's position every 2 hours, and deep breathing exercises, incentive spirometry, chest percussion, and assisted coughing every 4 hours. The prospective series had a more aggressive regimen, which comprised IPPB, aerosolized bronchodilator treatment, and bronchial lavage in addition to the usual care described above. The difference in mortality was large (0 percent versus 41 percent), although the differences in intermediate outcomes were less impressive. Pulmonary complications of secretion retention and atelectasis favored the aggressive care (four versus 12 cases); need for MV was lower for the aggressive care group (three versus nine cases), and need for tracheostomy was lower for the aggressive care group (two versus six cases). The lack of contemporaneous controls limits one's ability to conclude that all these differences stem from the addition of IPPB, aerosolized bronchodilator treatment, and bronchial lavage. Nevertheless, this study is the only one to link the respiratory care interventions to improvements in health outcomes, as opposed to spirometric parameters.

## Airway Management

Efficacy data for the studies reviewed in this section of the report are summarized in Evidence Table 5.

Management of ventilatory support requires a functional airway. The requirements of an airway change over time. Endotracheal intubation is expedient and is sufficient to establish an airway in acute ventilatory failure or for short-term MV. However, if ventilatory support is needed beyond a few weeks, then a more secure permanent airway, such as a tracheostomy, is often given. Positive pressure ventilation is given through a tracheostomy with an inflated cuff.

The technique for endotracheal intubation is modified when cervical spine injury is known or suspected. Meschino, Devitt, Koch et al. (1992) described the consequences of intubation among 165 patients with cervical spinal fracture with or without cord injury. Intubation was performed on conscious non-sedated patients using a variety of techniques, including oral or nasal intubation with fiberoptic bronchoscopy (46 percent), blind nasotracheal intubation (32 percent), or oral intubation with direct laryngoscopy (22 percent). Neurological deterioration occurred in four of 165 patients (2 percent) who were intubated and in the same proportion of patients managed without intubation (7/289, 2 percent). Investigators reported no cases of gastric aspiration. Most patients were intubated in preparation for surgery and anesthesia (62 percent), and a minority was intubated for respiratory failure (27 percent), airway protection (8 percent), and tracheobronchial toilet (3 percent).

As treatment goals shift from management of acute medical and surgical problems to rehabilitation, the patient's ability to speak is considered in selecting an airway. To enable a patient to speak, the cuff of a tracheostomy tube must be deflated or a cuffless or fenestrated tracheostomy tube must be used. This transition may be performed during ventilatory weaning.

Tracheostomy complications include infection, granulation formation, and mucous accumulation, which can lead to bronchial mucous plugging, atelectasis, pneumonia, and difficulty swallowing. Using cuffed fenestrated tracheostomy tubes exacerbates granulation formation. Other complications of TPPV with cuff inflation include hemorrhage, hemoptysis, pneumothorax, subcutaneous emphysema, tracheomalacia, tracheoesophageal fistula, impingement and erosion of the subclavian artery, and tracheal stenosis.

Patients with tracheostomy PPV sometimes do not tolerate deflation of the tracheostomy cuffs. Leaking around a deflated cuff reduces the efficiency of ventilation. A variable leak may result in either hypoventilation (hypercapnea) or hyperventilation (hypocapnea). Many patients can learn to control this variable insufflation leak while awake; however, when asleep, increased leakage may occur, leading to insufficient ventilation. Excessive leak can be compensated for by increasing delivered volumes to produce the same airway pressures as with the cuff inflated. Cuffs are also often kept inflated in an effort to reduce the risk of aspiration of gastric contents and upper airway secretions.

Many people with neuromuscular disease who are ventilator dependent will chronically hyperventilate (with resulting hypocapnea) unrelated to any variable air leak. Watt and Devine (1995) and Watt and Fraser (1994) tested whether adding dead space of 3 mL/kg could reduce hypocapnia that occurred as a result of the variable leak around a cuffless tracheostomy tube. Investigators described a series of 12 patients with high tetraplegia on chronic tracheostomy PPV who were switched from cuffed to cuffless tube. Addition of dead space increased pCO_2_ to near-normal levels, reducing hypocapnia during waking and sleeping periods (p < 0.05).

Bach and Alba (1990a) (1990b) reported daytime and overnight oximetry in patients with tetraplegia who were converted to cuffless tracheostomy or who had their cuffs deflated. Investigators used the following procedures: cuffs were deflated for short but increasingly longer periods during the day; volume was adjusted so that ventilatory pressures and blood gases during deflated/cuffless periods were equivalent to those during inflated cuff periods; delivered volumes were adjusted if necessary to compensate for insufflation leak; supplemental oxygen was used if necessary to maintain PO_2_levels; continuous monitoring of finger pulse SaO_2_ and end-tidal pCO_2_ was performed; arterial blood gases (ABGs) were measured; patients were trained to use leak across vocal cords to aid in speech; smaller tracheostomy tubes were inserted if patients needed them for effective speech; once patients could tolerate deflated cuffs during day, they were converted to using such cuffs overnight. Full cuff deflation/removal usually took 1 to 2 weeks. Of 10 patients with SCI, daytime SaO_2_ was within normal limits. SaO_2_ was at least 90 percent at all times in eight of 10 patients; in two patients, SaO_2_ was less than 90 percent for 2 percent and 3 percent of the time, respectively. One of the 10 patients was completely weaned from MV, four became ventilator-free during daytime but not overnight, three could tolerate between 20 minutes and 1 hour off ventilator, and two could tolerate 20 minutes or less. The authors concluded that patients with adequate pulmonary compliance are candidates for conversion to cuffless tracheostomy tube even if they have little or no autonomous respiration.

Bellamy, Pitts, and Stauffer (1973) reported the incidence of pulmonary complications overall, the need for tracheostomy, and pulmonary complications following tracheostomy in their case series of 54 patients with SCI. Most of the tracheostomies were performed within 3 days of injury (28/32 cases, 87 percent). Complications directly related to the tracheostomy included one patient who had minor bleeding and one who was found to have tracheal stenosis following removal of the tracheostomy tube.

A larger series of 46 patients with tracheostomy performed for cervical SCI was reported by Biering-Sørensen and Biering-Sørensen (1992). They found a low incidence of tracheal stenosis (2 percent) over a median 10.4-year followup. Early complications (bleeding from stoma, pneumothorax, and pneumomediastinum) were each reported in three of 46 patients (7 percent).