# Methodology

This section describes the basic methodology used to develop the evidence report beginning with the topic assessment and refinement through the literature search, screening, and data abstraction process. Included are the literature search strategies, literature sources, screening criteria, and quality control procedures.

## Topic Assessment and Refinement

The key questions in the original Request for Task Order Proposals for this evidence report were very broad. After Duke's initial proposal was submitted, these questions were discussed in a conference call that included the Duke research team, AHRQ staff, and members of the Consortium for Spinal Cord Medicine (which nominated the topic). The Consortium proposed a refined list of topics that more closely represented their information needs. These issues were the focus of a revised proposal that was subsequently approved by AHRQ:

1. Management of the acutely injured patient to prevent respiratory failure, with emphasis on secretion control, atelectasis, aspiration, and pneumonia
2. Selection of criteria for determining placement on a ventilator
3. Identification of optimal ventilator parameters to preserve lung compliance and prevent atelectasis
4. Establishment of criteria for weaning the SCI patient from MV
5. For patients with chronic SCI who breathe on their own, determination of the key medical and therapeutic measures to prevent recurrence of respiratory failure, including prevention/management of late respiratory failure
6. Proper management of tracheostomy to allow speech
7. Complications of intubation and tracheostomy and how to prevent them
8. Indications and timing for bronchoscopy
9. Optimal use of medications and prophylactic respiratory therapy modalities, including IPPB, assisted cough, postural drainage, bronchodilators, humidification, spirometry, vital capacity (VC) assessment, etc.
10. Establishment of parameters for phrenic nerve stimulation
11. Ventilator management in the context of rehabilitation, including balancing weaning, speech, swallowing, and mobility
12. Essential equipment and optimal methods for accommodating persons on a ventilator in the home.

A national advisory panel of technical experts was convened to work with the Duke research team. The eight-member panel was composed of pulmonologists, rehabilitation specialists, a respiratory therapist, a patient care representative (who specializes in SCI), and the Consortium's representative. Peter Almenoff, MD, VA Medical Center, Kansas City, MO Fred Cowell, Paralyzed Veterans of America, Washington, DC J. Douglas Hussey, MBA, RRT, VA Puget Sound Health Care System, Seattle, WA Steven C. Kirshblum, MD, Kessler Rehabilitation Institute, West Orange, NJ Kenneth C. Parsons, MD, The Institute for Rehabilitation and Research, Houston, TX, and the Consortium for Spinal Cord Medicine, Washington, DC Peter Peterson, MD, Craig Hospital, Denver, CO Ann Marie Smith, PhD, RN, CRRN, CANP, Ohio State University Medical Center, Columbus, OH Andrew D. Zadoff, MD, Shepherd Center, Atlanta, GA

Prior to the first meeting of the advisory panel via conference call, the panel received a document that, in a summary fashion, assessed the incidence and prevalence of pulmonary disease following SCI; described the characteristics and size of the affected population; identified the most affected practice settings and providers; assessed the burden of illness; and investigated the extent to which there is variation in practice associated with the prevention, diagnosis, treatment, or management of pulmonary disease following SCI.

The panel was also presented with the 12 key questions specified in the task order, grouped into four major topic areas: acute management (item 1 on list above); ventilator management (items 2, 3, 4, 10, 11, and 12); tracheostomy (items 6, 7, and 8); and prevention of late respiratory failure (items 5 and 9). From these four topic areas, Duke proposed to address two questions related to ventilator management and prevention of late respiratory failure, specifically the following:

1. For persons with traumatic high cervical SCI who are at high risk of respiratory failure or require ventilator support, what are the best practices regarding ventilator management? Specifically,
  a. What characteristics predict need for initiation of mechanical ventilation?
  b. What characteristics predict success in weaning from mechanical ventilation?
  c. What ventilator management techniques improve the ability to wean from MV?
  d. What are safe and effective techniques for intubation and airway management?
  e. What are ventilator management techniques that can preserve lung compliance, prevent atelectasis, reduce the risk of complications?
2. For persons with traumatic cervical SCI who breathe on their own, what interventions -- including medications (bronchodilators, mucolytics) and prophylactic respiratory therapy NPPV, assisted cough, postural drainage, humidification, spirometry, VC assessment)--are effective to reduce the risk of late respiratory failure?

Ventilator management issues were limited to patients with cervical SCI because this population either requires ventilatory support or is at high risk of respiratory failure. All acute management issues would have exceeded available time and budget; thus, those aspects of acute management that were most closely linked to ventilator use were included, such as decisionmaking about initiation of mechanical ventilation and intubation techniques. The long-term ventilator management literature appeared to be of moderate size and consisted mainly of case series with a few cohort studies. Almost no randomized controlled trials were available, but some studies used concurrent or historical controls as comparison groups.

There was an additional body of literature considered. These were studies using small cohorts to examine individual self-contained issues such as optimal ventilator design. Outcome variables in these studies were often proximal, e.g., laboratory parameters rather than clinical outcomes that are of ultimate interest.

Prevention of late respiratory failure is a main goal of therapy for patients with cervical SCI who breathe on their own. Longitudinal data on rate of late ventilatory failure was sought by level of injury. While there are a wide range of techniques listed in the questions above, the literature describing clinical effectiveness is small. Although populations with respiratory muscle weakness (of other etiologies, such as Guillain-Barr? syndrome) may be similar in risk for late respiratory failure, they differ sufficiently in pathophysiology that we excluded these populations.

The advisory panel recommended no significant changes to the proposed focus.

## Literature Search and Selection

The comprehensive review of the literature, from identification of databases through abstraction of individual articles into evidence tables, was a multistep, sequential process.

### Literature Sources

The primary sources of literature were four of the most widely used computerized bibliographic databases: MEDLINE (1966-Feb 2000) (MEDLINE [database online]), HealthSTAR (1975-Feb 2000) (HealthSTAR [database online]), Cumulative Index to Nursing & Allied Health Literature (CINAHL) (1983-Feb 2000) (CINAHL [database online]) and EMBASE (1980-Feb 2000) (EMBASE [database online]). These searches were supplemented by secondary searches, including e-mail subscriptions for announcements of newly published journals and thorough searching of reference lists in all included articles and review articles. In addition, the Cochrane Controlled Trials Register and Cochrane Database of Systematic Reviews were searched, but did not yield useful literature.

### Search Strategy

The search strategies were initially developed using the National Library of Medicine Medical Subject Heading (MeSH) key word nomenclature developed for MEDLINE. The same search strategy was used for HealthSTAR and CINAHL. A Duke University Medical Center librarian checked our basic strategies and assisted with their translation to the key word structure used by EMBASE. Each online search began with the first year of the database (specified in the preceding Literature Sources section).

The search strategies combined an SCI concept (implemented using MeSH terms spinal cord injuries, paraplegia, and quadriplegia [exploded] and text words for tetraplegia, quadriplegia, and paraplegia) with a pulmonary disease concept. The search was limited to articles pertaining to humans and published in the English language. The exact texts of the strategies are provided in Appendix A.

### Screening Criteria

Inclusion and exclusion criteria were developed for the literature searches so that the yield of articles would be appropriately focused.

Empirical studies or review articles were included after screening by the following criteria:

- The study population must include traumatic cervical SCI.
- All studies relating to the research questions described above were included.
- Outcomes were included if they were health outcomes, health services utilization or economic outcomes, or physiological measures related to respiratory status.
- The study design included controlled trials, prospective trials with historical controls, prospective or retrospective cohort studies, and medium- to large-sized case series.

The criteria used to exclude articles:

- Article was not original research (relevant reviews were included only if they focused on management of traumatic cervical SCI or on pulmonary disease in other SCI or neurological diseases).
- Article did not address traumatic cervical SCI.
- Focus of the article was not pulmonary disease.
- Article focus was a pediatric population (all subjects or mean age < 18 years).
- The study design was a single case report.
- The study design was a small case series with fewer than 20 subjects.
- The pulmonary condition was thromboembolism or pulmonary embolism.
- The article was a review.
- Other articles that did not meet the inclusion criteria.

The inclusion and exclusion criteria related to small case series were initially defined with a threshold of less than 20 subjects. The advisory panel recommended this threshold, with the proviso that if there were relatively few randomized controlled trials (as was the case), then the threshold should be lowered to 10 subjects. Appendix A provides a list of the articles that were excluded because they were small case series with fewer than 10 subjects. Exclusion criteria for review articles and "other" articles were added at the full-text screening stage. The screening form is provided in Appendix A.

### Screening Results

Our literature search yielded 1,888 English language articles. The abstract of each article in the database was reviewed against inclusion/exclusion criteria by four investigators, Drs. Joseph Govert, David Matchar, Douglas McCrory, and Gregory Samsa. Each abstract was reviewed by teams of two of these investigators. Abstracts were available for more than three-fourths of the citations; however, when no abstract was available, the title, source, and MeSH words were reviewed. At this stage, an article was included if requested by one member of the review team.

Each abstract in the first set to be reviewed (n = 340) was reviewed by all four investigators, and a kappa statistic was calculated to determine the strength of the agreement to include or exclude articles and the reason for exclusion. One review team had good agreement (kappa = 0.590; confidence bounds = 0.447 to 0.733); their disagreements were largely on the inclusion of small case series, which were easily resolved. The other team had poor agreement (kappa = 0.185; confidence bounds = 0.050 to 0.319) resulting from misinterpretation of the selection criteria. After clarifying the criteria, another kappa statistic was calculated for this team on a subsequent set of 329 abstract screening decisions, and the result was a much improved kappa score of 0.402, with confidence bounds of 0.204 to 0.600. Because agreement was still only fair, articles were retained if selected by either reviewer.

At the full-text screening stage, each article was independently reviewed by two investigators who forwarded their decisions to the project manager for recording and comparison. If indicated, they were asked to reconcile differences of opinion. Overall, the teams disagreed on about 15 to 20 percent of their decisions, and all were reconciled for total agreement on all articles. In the event the two investigators could not agree, Dr. Douglas McCrory, the principal investigator, would be the arbiter; however, the need for arbitration did not arise.

The records in the bibliographic database were coded at each screening stage. Results are shown in Tables 3 and 4 at the end of this chapter.

Table 3. Number of Records Identified in Literature Search by Database

Database | Number of Records | Percent of Total (%)
MEDLINE | 1,365 | 72.3
EMBASE | 488 | 25.9
CINAHL ^a^ | 4 | 0.2
None (from reference lists or newly published journals) | 31 | 1.6
Total | 1,888 | 100

a CINAHL = Cumulative Index to Nursing & Allied Health Literature.

Table 4. Results of Abstract and Full-Text Article Reviews

Description | No. | Percent (%)
Abstracts
Number of abstracts reviewed ^a^ | 1,888 | -
Number included | 502 | 26.6
Number excluded | 1,386 | 73.4
Reasons for exclusion ^b^
1-Not original research | 19 | 1.4
2-Not spinal cord injury | 688 | 49.6
3-Not pulmonary disease | 457 | 33.0
4-Pediatric population | 48 | 3.5
5-Single case report | 64 | 4.6
6-Small case series (N < 10) | 57 | 4.1
7-Thromboembolism/pulmonary embolism | 53 | 3.8
Full-Text Articles
Number of full-text articles reviewed | 502 | -
Number of relevant articles | 157 | 31.1
Number of articles included in evidence tables, i.e., efficacy articles | 81 ^c^ | 16.0
Number excluded | 345 | 68.9
Reasons for exclusion ^b^
1-Not original research | 36 | 10.4
2-Not spinal cord injury | 37 | 10.7
3-Not pulmonary disease | 74 | 21.4
4-Pediatric population | 12 | 3.5
5-Single case report | 50 | 14.5
6-Small case series (N < 10) | 66 | 19.1
7-Thromboembolism/pulmonary embolism | 1 | 0.3
8-Review article | 65 | 18.8
9-Other (no quantitative data or no separate results reported) | 4 | 1.2

a Some records did not contain abstracts.

b Only one reason for exclusion is listed for each article. The reasons for exclusion were applied in sequence, so that an article excluded for reason #4 might also fail reasons #5-7 but can be assumed not to have failed for reasons #1-3.

c Of the 81 articles, 27 were included after the inclusion criteria were changed to admit case series with between 10 and 20 subjects.

### Data Abstraction

The template of the data abstraction form is in Appendix A. The data were abstracted directly from the article into the evidence table format. Dr. McCrory was responsible for checking all data abstracted by a non-clinician abstractor and for summarizing articles on pathophysiology. Dr. Samsa summarized all articles on epidemiology and health services utilization.

All relevant outcomes reported in each included study were listed in the evidence tables; however, study results were summarized only for those outcomes selected by Dr. McCrory on an article-by-article basis. Table 5 lists outcomes represented in the included studies and the number of studies reporting them (see Appendix B for citations of studies by type of outcome).

Table 5. Number of Studies Reporting Various Outcome Measures^a^

Type of Outcome ^b^ | No. (%) Studies in Ev. Tables Reporting These Outcomes
Health State
Mortality (no. of pts who died, cause of death, etc.) | 30 (38)
Nonfatal complications (adverse events, pneumonia, atelectasis, stenosis, etc.) | 27 (34)
Quality of life | 4 (5)
Health Services
MV (no. of pts ventilated, need for MV, etc.) | 14 (18)
Weaning (no. of pts successfully weaned, amt. of time to achieve weaning) | 13 (16)
Tracheostomies | 10 (12)
Electrophrenic or diaphragmatic pacing | 9 (11)
Hospitalization (duration of, no. of hospitalizations) | 9 (11)
Discharge status (no. of pts discharged to home, etc.) | 7 (9)
Spirometry
VC or FVC | 35 (44)
FEV or FEV_1_ | 15 (19)
PEF and/or PEFR | 8 (10)
TLC | 7 (9)
Other
PC_20_ | 5 (6)
Antibodies (mean antibody concentrations - pneumonia vaccination) | 2 (2)

a Ev. = evidence; FEV = forced expiratory volume; FEV_1_ = forced expiratory volume in 1 second; FVC = forced vital capacity; PC_20_ = provocative concentration of methacholine or histamine that causes a 20% decrease in FEV_1_; PEF = peak expiratory flow; PEFR = peak expiratory flow rate; pts = patients; MV = mechanical ventilation; TLC = total lung capacity; VC = vital capacity.

b Identity of studies reporting each outcome is listed in Appendix B.

### Grading of Articles

For grading internal validity, the investigators employed the hierarchy (Table 6) published by the Consortium for Spinal Cord Medicine in their clinical practice guidelines on Outcomes Following Traumatic Spinal Cord Injury (1999), based on the work of Sackett (1989) and the USPSTF (1996).

Table 6. Internal Validity Scale^a^

Level | Description
I | Large randomized trials with clear-cut results (and low risk of error)
II | Small randomized trials with uncertain results (and moderate to high risk of error)
III | Nonrandomized trials with concurrent or contemporaneous controls
IV | Nonrandomized trials with historical controls
V | Case series with no controls

a Sources: Sackett, DL. Rules of evidence and clinical recommendations on the use of antithrombotic agents. Chest 1989;95(2 Suppl):2S-4S; and the U. S. Preventive Health Services Task Force. Guide to clinical preventive services. 2nd ed. Baltimore: Williams & Wilkins; 1996. Used with permission.

Each study was also evaluated for factors affecting external validity using the criteria given in Table 7. The investigators proposed, and the advisory panel agreed, not to aggregate these items into an overall quality score, but to consider them individually.

Table 7. External Validity Criteria

- Were the criteria for selection of patients described?; - Were patients included in the study adequately characterized with regard to level and completeness of SCI?; - Were criteria for outcomes clearly defined (e.g., timing, measurement, reliability)?; - Was the clinical care of patients adequately described to be able to reproduce?; - Were results given reported according to level of injury (minimum high cervical [C4 or above] versus low cervical [below C4]) or ventilation status (independently breathing versus ventilator dependent)?

## Quality Control Procedures

We employed quality-monitoring checks at every phase of the literature search, review, and data abstraction process to reduce bias, enhance consistency, and to check accuracy of study review:

- Advisory panel review of the literature search strategy
- Medical librarian review of the literature search strategy
- Check on completeness of the literature search results by solicitation of key citations from the advisory panel
- Check on completeness of the literature search results through reference list checks by the article reviewers
- Kappa statistics to demonstrate strength of agreement among and between reviewers
- Corrective action to increase strength of agreement of one review team, which includedanother kappa test
- Reconciliation of all differences of opinion by reviewers on all full-text articles
- Agreement of two reviewers for all eligible studies
- Training and oversight of abstractor by a clinician-investigator
- Solicitation of advice at key decision points from study consultants, Dr. Byron Hamilton and Dr. Michael DeVivo
- Solicitation of advice at key decision points from the advisory panel of technical experts
- Review of the draft evidence report by a peer review panel of 14 experts representing key clinical constituencies and major use organizations approved by AHRQ.