# Introduction

## Purpose and Scope of Report

This report assesses the evidence currently available on the prevention and treatment of pulmonary disease following traumatic cervical spinal cord injury (SCI). Injuries at this level of the spinal cord, depending on the completeness of the lesion (described in Figures 1a and 1b), can lead to tetraplegia, loss of sensory function, and paralysis of the respiratory muscles. Patients with paralyzed inspiratory muscles (principally the diaphragm) may not be able to breathe on their own and often must be placed on mechanical ventilators; patients with weak or paralyzed expiratory muscles (principally the abdominal and intercostal muscles) may have impaired ability to cough and clear mucoid secretions. The accumulation of retained secretions can lead to atelectasis and pneumonia.

Figure 2. Standard Neurological Classification of Spinal Cord Injury: Asia Impairment Scale

Reprinted with permission from The American Spinal Injury Association. Chicago: International standards for neurological and functional classification of spinal cord injury; 1996.

Figure 1. Standard Neurological Classification of Spinal Cord Injury

Reprinted with permission from The American Spinal Injury Association. Chicago: International standards for neurological and functional classification of spinal cord injury; 1996.

This report focuses on empirical studies relating to two research questions about (1) management of ventilatory insufficiency in acute and chronic phases, including weaning from mechanical ventilation (MV), management of secretions, atelectasis, and pulmonary infection, and (2) the prevention of late respiratory failure in patients with traumatic cervical SCI. Excluded from consideration were nonpulmonary complications of SCI and venous thromboembolism/pulmonary embolus. The report does not cover patients with SCIs occurring below the cervical level or respiratory muscle weakness caused by neuromuscular or other spinal cord diseases such as Guillain-Barré syndrome and polio.

The report describes the methodology used to search for, screen, abstract, and assess the quality of published research. It also provides the results of our analysis, conclusions, and recommendations for future research. The evidence is summarized in evidence table format in a later section of this report.

## Incidence and Prevalence

There have not been any studies of the overall incidence of SCI in the United States during the past decade. Recent reports from state-based SCI registries provide an estimate of the incidence of SCI in the United States at approximately 10,000 new cases each year (Acton, Farley, Freni et al., 1993; Price, Makintubee, Herndon et al., 1994; Thurman, Burnett, Jeppson et al., 1994; Woodruff and Baron, 1994), or 32 to 35 persons per million.

The prevalence of SCI is estimated at around 200,000 persons in the United States (DeVivo, Fine, Maetz et al., 1980; Harvey, Rothschild, Asmann et al., 1990; Lasfargues, Custis, Morrone et al., 1995). Causes of SCI include motor vehicle crashes in 43 percent, followed by acts of violence in 19 percent; falls in 18.8 percent; sports in 11.1 percent; and all other causes, 8.1 percent (Nobunaga, Go, and Karunas, 1999). Most persons with SCI are injured in their late teens or twenties, and men are about four times more likely to be injured than women (DeVivo, Rutt, Black et al., 1992). However, because persons with SCI are surviving longer, the average age is increasing. As persons with SCI age, so does the prevalence of co-morbid medical diseases, including pulmonary diseases. Overall, about half are cervical injuries, with the remaining half divided among thoracic, lumbar, or sacral injuries. The most frequent injury level is C5, followed by C4, C6, T12, and L1 (De Vivo, Richards, Stover et al., 1991) About half of injuries are neurologically complete (53.8 percent); incomplete injuries are divided between motor functional (27.2 percent) and motor non-functional sensory sparing (19 percent) (DeVivo, Krause, and Lammertse, 1999).

## Natural History

Although survival after SCI is improving, mortality rates remain considerably higher than for the population as a whole. Respiratory complications contribute to this excess mortality. Several studies document the importance of respiratory complications as causes of death (DeVivo, Black, and Stover, 1993; DeVivo, Krause, and Lammertse, 1999). It should be noted that all of these studies deal with the relative proportion of deaths that are due to respiratory causes. Importantly, if the mortality rate from respiratory causes decreases over time, but at the same rate that the mortality rate for other causes decreases, then no change will be observed in the relative proportion of deaths due to respiratory causes over time. Similarly, if the mortality rate from respiratory causes decreases over time, but the mortality rate from other causes decreases more quickly, then the proportion of patients with deaths due to respiratory causes will actually increase. This phenomenon was, in fact, observed by Frankel, Coll, Charlifue et al. (1998). Thus, analyses of cause of death are appropriate for establishing the importance of respiratory causes of mortality, but not for establishing the absolute impact of reducing mortality due to respiratory causes.

That said, 50 years ago the most common cause of death among patients with SCI was urinary tract infections. For the last 30 years or so, respiratory failure is the most common cause of death for patients with cervical injuries (particularly high-cervical injuries) during the acute phase of hospitalization, and one of the three most common causes of death subsequently. The most comprehensive data come from the US Department of Education, National Institute on Disability and Rehabilitation Research (NIDRR) Model Spinal Cord Injury Care Systems, also known as "Model Systems," which estimates the mortality from respiratory causes at 30 percent during acute hospitalization and 20 percent subsequently. In particular, from a large cohort of persons treated within an SCI Model Systems facility within 1 year of injury from 1973 to 1984, 226 patients with incomplete tetraplegia died; for the primary cause of death 20 patients had diseases of pulmonary circulation, 35 had pneumonia and influenza, and six had other respiratory causes (i.e., total 61/226 = 27 percent). In patients with complete tetraplegia, pulmonary complications were the primary cause of death in 132 of the 382 deaths (35 percent): 19 died from diseases of the pulmonary system; 93 from pneumonia and influenza, and 20 from other respiratory diseases. During extended followup, pneumonia was the leading cause of death for each age group and all time periods, but was much less common for patients with incomplete injuries (DeVivo, Black, and Stover, 1993). The findings of a more recent report from the SCI Model Systems, with followup extending through 1998, show similar trends in respiratory diseases (DeVivo, Krause, and Lammertse, 1999).

The literature also contains a number of small- to moderate-sized case series describing cause of death among patients with SCI, and although definitions and methodology differ across studies, the conclusion that a significant number of deaths among patients with cervical injuries are due to respiratory causes is consistent throughout. Some representative results among studies having at least 20 deaths are presented in Table 1. Some of the very early studies illustrate the contribution of urinary tract complications in preceding respiratory complications as a possible cause of death.

Table 1. Respiratory Causes of Death: Small- to Moderate-Sized Case Series

Study | Population | Definition of pulmonary complications | Time after Injury | | | | | | | | | Comments
Study | Population | Definition of pulmonary complications | Completeness of Injury ^a^ | | | Early Phase ^a^ | | | Late Phase ^a^ | | | Comments
Study | Population | Definition of pulmonary complications | IQ | CQ | AQ | IQ | CQ | AQ | IQs | CQ | AQ | Comments
Nyquist, Bors, 1967 | Long Beach SCI Center | Pulmonary complications | | | | | | | 3/32 (9%) | 10/38 (26%) | | One death at 45 days; all others at least 10 months post-injury
Silver, Gibbon, 1968 | Liverpool SCI Center | Chest complications, pneumonia, respiratory failure | | | | 8/9 (89%) | 14/17 (82%) | | | | | Early = first 3 months post-injury
Wilcox, Stauffer, 1972 | California SCI Center | Pneumonia | | | | | | | | | 10/32 (31%) | Includes three deaths within first year
Geisler, Jousse, Wynne-Jones et al., 1983 | Toronto SCI Center | Respiratory causes | | | | | | | 6/48 (13%) | 11/33 (33%) | | All at least 1 year post-injury
Minaire, Demolin, Bourret et al., 1983 | French SCI Center | Acute respiratory insufficiency (often caused by bronchitis and/or airway obstruction) | | | 20/21 (95%) | | | | | | | Most deaths within 1 year post-injury
Chen, Lien, 1985 | Taiwan general hospitals | Respiratory failure | | | | | 18/22 (87%) | | | | | Initial hospitalization
Reines, Harris, 1987 | South Carolina neuro-surgical ICU | Pulmonary complications, primarily pneumonia | | | | | | 14/22 (64%) | | | | Initial hospitalization, includes six deaths among patients with paraplegia
Kiwerski, 1992 | Polish SCI center | Primarily pneumonia | | | | | | 66/82 (80%) | | | | Patients with C1-C5 injuries
Kiwerski, 1993 | Polish SCI Center | Primarily pneumonia | | | | | 21/37 (57%) | 157/206 (76%) | | | | Initial hospitalization
Hartkopp. Bronnum-Hansen, Seidenschnur et al., 1997 | Danish SCI Center | Lung disease and pneumonia | | | 51/67 (76%) | | | | | | | Long-term followup, including early deaths

a IQ = incomplete quads; CQ = complete quads; AQ = all quads.

## Respiratory Complications

The rate of respiratory complications is a particularly important parameter for benchmarking, estimation of public health burden, and cost-effectiveness analysis. Even among patients with cervical injuries, these complication rates differ by injury level and completeness, with patients having higher level of injury (LOI) and complete injuries being at highest risk. Accordingly, rates reported in the literature will differ according to population composition. In addition, rates will vary according to the definition of respiratory complications, and also according to the time from injury to the beginning of followup. In particular, the rate of respiratory complications is highest in the period immediately following SCI (Branscomb, Stover, DeVivo et al., 1984); thus, cohorts that include significant numbers of patients presenting some time after injury will have lower complication rates than those that begin to follow up patients soon after injury. Despite the above sources of heterogeneity, the literature consistently reports respiratory complications to be a very serious problem after SCI.

To quantify the above, various analyses by the SCI Model Systems give the complication rates during the initial hospitalization (acute care and rehabilitation) to be at least 20 percent for pneumonia and 20 percent for atelectasis (Kendall, Lafuente, and Hosie, 1997), these being the most common pulmonary complications (Branscomb, Stover, DeVivo et al., 1984). A subsequent report by Waters (Waters, Meyer, Adkins et al., 1999) is consistent with the above.

Using more extensive followup of patients admitted to one of five Model System facilities from 1985 to 1990 within 48 hours of injury, Jackson and Groomes (1994) give the proportion of patients experiencing at least one respiratory complication to be 84 percent for patients with LOI C1-C4, in comparison with 60 percent for patients with LOI C5-C8.

Fishburn, Marino, and Ditunno (1990) followed 30 patients admitted to a single facility, finding 14/19 patients (74 percent) with LOI C1-C4 developing atelectasis and/or pneumonia, in comparison with 3/11 patients (27 percent) with LOI C5-C7 (Fishburn, Marino, and Ditunno, 1990).

Reines and Harris (1987) followed 33 patients with injuries at LOI C1-C4, and found seven (21 percent) episodes of atelectasis, five (15 percent) episodes of pneumonia, and two (6 percent) episodes of aspiration. For 62 patients with injuries at LOI C5-C7, they found 11 (18 percent) episodes of atelectasis, six (10 percent) episodes of pneumonia, two (3 percent) episodes of edema, and three (5 percent) episodes of aspiration (Reines and Harris, 1987). Silver, Morris, and Otfinowski (1980) followed 51 patients with traumatic cervical SCI admitted to a British SCI center from 1971 to 1973; 15/51 (29 percent) developed pneumonia.

To our knowledge, Chen, Apple, and Hudson (1999) are the only investigators to present respiratory complications occurring in the initial episode of rehabilitation separately from those occurring in the initial acute hospitalization. Combining atelectasis and pneumonia, they estimated the rate of respiratory complications during the initial episode of rehabilitation at 13 percent.

Respiratory complications during the initial hospitalization (acute hospitalization and rehabilitation) are associated with increased likelihood of requiring MV, this in turn being associated with lower functional status (Fuhrer, Carter, Donovan et al., 1987), greater probability of nursing home placement, greater medical costs, and potential decrements in survival (DeVivo and Ivie, 1995). Although all of these outcomes are associated with level of injury, the association with respiratory complications holds even after controlling for level of injury.

More specifically, using a cohort of over 16,000 SCI Model Systems patients from 1973 to 1996, DeVivo (1999) found that approximately 16 percent of ventilator-dependent patients with tracheostomy were discharged to nursing homes, in comparison with 4 percent of patients who were able to breathe independently. Approximately 9 percent of patients with LOI C1-C4 were discharged on a ventilator, in comparison with 5 percent of those with LOI C5-C8. Approximately 35 percent of patients with traumatic cervical SCI require a ventilator at some point during the initial hospitalization (Kendall, Lafuente, and Hosie, 1997).

As the person with cervical SCI enters the late phase (months to years after injury), he or she has a continued risk of pulmonary complications. An elevated risk for atelectasis and pneumonia persists. For persons who breathe on their own, there is a risk of late-onset ventilatory failure (Bach, 1993). Several factors can contribute to late ventilatory failure, including late neurologic deterioration, lung disease, and restrictive ventilatory impairments. Late neurologic deterioration can occur from syringomyelia, for example. Recurrent episodes of atelectasis and pneumonia may lead to chronic lung disease. Restrictive ventilatory impairment may result from kyphoscoliosis or obesity.

The most comprehensive data on annual rates of respiratory complications are provided by McKinley, Jackson, Cardenas et al. (1999), using routine annual evaluations of SCI Model Systems patients. For patients with incomplete injuries, the probability of experiencing at least one episode of pneumonia and/or atelectasis during the preceding year was 3.1, 3.8, 3.3, 2.2, 1.8, and 0.0 percent for 1, 2, 5, 10, 15, and 20 years post-injury, respectively. For patients with complete injuries, these figures were 9.9, 9.8, 6.4, 4.9, 4.1, and 3.7 percent. This gradual decrease in rates may be the result of differential survival, as those patients who suffer respiratory complications are at a higher risk for death.

In an analysis of data from an independent living facility, Meyers, Bisbee, and Winter (1999) found the annual rate of respiratory infections (e.g., including influenza and pneumonia, but not colds) to be in the range of 18 to 25 percent for persons with SCI. The higher rates found in this study were likely inflated by self report and inclusion of less serious infections.

## Burden of Illness

Acute cervical SCI is a devastating injury that completely changes a patient's way of life. Hospitalization for acute care is usually prolonged and followed by a lengthy period of rehabilitation and readjustment. The burdens include enormous costs for acute medical care, rehabilitation, medications and supplies, modification to home and vehicles, and personal assistance.

SCI is a very expensive condition to treat. The Agency for Healthcare Research and Quality (AHRQ) reports an average hospital charge incurred (not including professional fees, rehabilitation, or rehospitalization) of $56,800 per patient per hospitalization in 1996 (AHRQ, 1999). Other estimates of the cost of initial hospitalization for acute SCI are even higher, ranging from $87,238 in persons with paraplegia to $156,790 in persons with tetraplegia, also in 1996 dollars (Berkowitz, O'Leary, Druse et al., 1998). Post-injury rehabilitation costs are also burdensome, averaging $139,180 for tetraplegic patients (Berkowitz, O'Leary, Druse et al., 1998).

There have been few studies of the economic impact of respiratory complications among patients with SCI. Based upon a small sample of only eight patients, Johnson, Brooks, and Whiteneck (Johnson, Brooks, and Whiteneck, 1996) found the mean increase in acute care costs attributable to a respiratory complication to be $13,000. However, this is likely to be an underestimate, as only one-third of the excess costs in the data set could be attributed to a specific complication. In a small case series, Tator, Duncan, Edmunds et al. (1993) found that respiratory complications increased the mean length of stay by 27 days. In another small case series, Branscomb, Stover, DeVivo et al. (1984) found the mean duration of complications to be 20 days for patients with high-level quadriplegia and 14 days for patients with low-level quadriplegia. Thus, the economic data, although sparse, are fairly consistent.

Considering patients with high-level tetraplegia, Fuhrer, Carter, Donovan et al. (1987) compared 14 patients who were ventilator-dependent on their initial discharge with 143 patients who were not. At 1 year post-injury, 89 percent of ventilator-independent patients (primarily complete injuries at C4) were living at home, in comparison with 79 percent of those requiring a ventilator to breathe (primarily complete injuries at C1 to C4). Current lower reimbursement for in-home caregiving suggests these percentages may be higher now. The ventilator-dependent group required a greater number of hours of caregiver time per week as well (Fuhrer, Carter, Donovan et al., 1987).

## Disease Biology

Breathing involves two distinct phases, inspiration and expiration. Inspiration is an active process. Expiration is almost entirely passive at normal tidal volumes, though in heavy breathing there is an additional active component. In inspiration, the diaphragm, scalenes, and the intercostal muscles contribute significantly to tidal volume, with the diaphragm being the most important. Several other muscles play an auxiliary, or accessory, role in inspiration, including the trapezius, levator scapulae, pectoralis, serratus anterior, costal levators, and others. In expiration, the intercostals and oblique abdominals play an active role.

In cervical SCI, some or all of the muscles responsible for breathing are affected. Lower-cervical injuries will affect the scalenes (innervated by cord levels C4 to C7), the intercostals (T1 to T11), the oblique abdominals (T6 to L1), and the rectus abdominus. High-cervical cord injuries affect the diaphragm (innervated by C3, C4, and C5), as well as all of the previously mentioned muscle groups.

Without active chest wall expansion during inspiration from intercostal muscles, the breathing efforts of patients with tetraplegia are inefficient, and the chest wall contracts in a paradoxical movement. Pulmonary function tests (PFTs) show low forced vital capacity (FVC) (Forner, 1980) and reduced lung and chest wall compliance. After the acute period following SCI, pulmonary function shows improvement over time in most patients. However, currently available data fail to show an association between the rate or amount of improvement and PFTs, neurologic examination, or muscle function evaluations in the early phases of recovery (Axen, Pineda, Shunfenthal et al., 1985). The mechanism through which improvement in vital capacity occurs without improvement in neurological function is believed to be the spasticity that develops in the intercostal and abdominal musculature, which stabilizes the rib cage, thus allowing for more biomechanically effective diaphragmatic action.

Patients with complete lesions above C4 require mechanical ventilatory support in the acute phase. Those with complete lesions below C4 can, after the acute phase, and barring pulmonary complications, breathe independently. Those patients with complete injury at the C4 levels (and sometimes at the C3 level) represent particular challenges, as they have the potential to breathe on their own, but have little reserve. Any pulmonary compromise due to secretions or atelectasis or infection thus can result in ventilatory insufficiency and the need for MV. Injuries at C6 level and below do not usually require ventilatory support unless other pulmonary complications or injuries exist. Among patients with incomplete lesions, the LOI is not so clearly associated with the need for mechanical ventilatory support, and even patients with C2 or C3 LOI sometimes do not require MV.

Paralysis of the abdominal muscles (T6 to T12) results in the inability to cough effectively. Poor ventilation and poor cough can lead to retained secretions, mucous plugging, and atelectasis. Atelectasis allows bacterial overgrowth and ultimately pneumonia. Furthermore, cervical lesions lead to a loss of sympathetic nervous system innervation, causing a parasympathetic imbalance that, in the lung, leads to bronchoconstriction and increased mucous secretion. The increased mucous secretions compound the problem of impaired clearance.

## Pertinent Clinical Features

We have organized this section, which provides background on the myriad clinical problems encountered in the care of a patient with cervical SCI, according to an outline of the most salient issues during the sequence of care following an acute injury (Table 2). Immediate management in the minutes to hours following high-cervical injury often involves recognizing acute ventilatory failure, securing an airway and providing mechanical ventilatory support, and preventing aspiration of airway and oral secretions and gastric contents. In the first several days following injury, these same pulmonary issues remain prominent, in addition to other injuries and medical problems that often accompany SCI. Prevention of thromboembolism and pulmonary embolus must also be addressed. In the weeks that follow, attention turns to rehabilitation issues such as securing a permanent artificial airway while permitting speech, and initiation of weaning. The setting of care usually changes as patients progress through these phases. Long-term management, particularly for patients with high-cervical injuries, centers on the inability of the patient with SCI to adequately clear pulmonary secretions and on prevention of pneumonia and related complications. Prevention of pulmonary complications becomes increasingly difficult over time as patients age, amass scar tissue, and otherwise lose lung capacity.

Table 2. Model of Care for Spinal Cord Injury^a^

Time Period | Setting | Interventions
Time Period | Setting | Ventilation/Airway | | | Speech
Minutes to hours | Emergency care | Intubation | NG tube | Suction, bronchodilators | -
Hours to days | Acute care hospital, neurology ICU | - | - | - | -
Days to weeks | - | Tracheostomy, complication | G tube | Physical therapy, bronchoscopy, IPV, mechanical insufflation-exsufflation | Cuff deflation
Weeks to months | Rehabilitation facility | Weaning, NPPV | - | Mucolytic Rx, IPV, mechanical insufflation-exsufflation | -
Months to years | Home, outpatient care, rehabilitation or SCI facility | Chronic ventilatory management Diaphragm pacing (tracheostomycomplication) Predictors of late respiratory failure | - | - | -

a G = gastric; ICU = intensive care unit; NG = nasogastric; NPPV = noninvasive positive pressure ventilation; SCI = spinal cord injury.

In the following sections, each of the most important pulmonary management issues are addressed: acute ventilatory insufficiency, weaning, and chronic ventilation support.

## Acute Ventilatory Insufficiency

Signs and symptoms associated with acute ventilatory failure include tachypnea, dyspnea, and drowsiness or declining mental alertness. These symptoms may develop in acutely injured patients due to progression of neurologic injury, fatigue of respiratory muscles, or pulmonary complications such as atelectasis or pneumonia. Arterial blood gas, pulmonary function tests, pulse oximetry, and end-tidal CO_2_ monitoring may be helpful in confirming the diagnosis of acute ventilatory failure.

Therapeutic interventions for acute ventilatory failure include mechanical ventilatory support, which provides MV by means of endotracheal or nasotracheal intubation, tracheostomy, face or nasal masks, or mouthpiece and mouthpiece with lipseal retention. Less-intensive ventilatory support can be accomplished through continuous positive airway pressure (CPAP), bilevel positive airway pressure, or glossopharyngeal breathing (GPB). Oxygen supplementation may be helpful in patients with underlying lung disease, but its use should be carefully monitored, as it may mask signs and symptoms of carbon dioxide retention.

## Weaning

Weaning from MV consists of maneuvers intended to allow the patient to become independent of ventilator support. Weaning may be accomplished in several ways: (1) keeping the patient on limited ventilator support, but changing the ventilator function to reduce the assistance provided; (2) removing the patient from ventilator support for limited periods of time that are progressively increased; or (3) providing an alternative means of ventilatory support, for example, intermittent abdominal pressure respiration, GPB, or electrophrenic respiration (EPR).

Reduced ventilator support is most often accomplished through synchronized intermittent mandatory ventilation (SIMV) mode, which allows the patients to take breaths through the ventilation system between positive pressure ventilator breaths, which are triggered only if the respiratory rate or minute ventilation volume do not reach minimum pre-set values. In weaning, these minimum values are gradually decreased. This is the weaning method used most commonly in a wide variety of medical and post-surgical conditions. Alternatively, pressure support ventilation provides positive pressure during patient-initiated respiration. In weaning, the amount of pressure delivered during inspiration is gradually reduced. SIMV and pressure support ventilation are convenient in that they use existing equipment and staff; however, they offer neither a sustained period of respiratory muscle conditioning nor rest.

Removal of ventilator support for limited periods of time is often accomplished by using a T-piece, with one end open to atmospheric pressure. Patients may be placed on a T-piece for brief periods of time at first, with the duration of ventilator-free periods progressively increased as the patient's independent respiratory capability improves. Non-invasive ventilation with a mouthpiece, allowing the patient to take ventilator-assisted breaths as needed, has been described as an alternative to the more standard SIMV or T-piece weaning techniques (Bach, 1991; Bach and Alba, 1990a; Bach and Saporito, 1996).

Patients with tetraplegia with lower-cervical LOI (C5 or below) are easier to wean than those with higher-level injuries. Those with C2-level complete injuries are not candidates for weaning because they can be expected to have no intact diaphragmatic function. However, patients with incomplete C2 or below lesions or complete C3 or below lesions might be successfully weaned. The decision of when to begin attempts at weaning is individualized. Some studies articulate criteria used. Most such criteria insist on the absence of cardiopulmonary problems and acute infections, as well as minimal values for spirometric indices. Several studies gave threshold values for VC before weaning should be attempted. These values varied from a VC of at least 300 mL (Gardner, Watt, and Krishnan, 1986), more than 10 mL/kg body weight (Lamid, Ragalie, and Welter, 1985), or as little as 100 mL (Peterson, Brooks, Mellick et al., 1997).

## Chronic Ventilatory Support

Patients with cervical SCI who are unable to wean from ventilatory support need some form of chronic mechanical ventilatory assistance. During the acute phase, invasive MV is most often accomplished using an endotracheal tube. However, this interface is not appropriate for chronic ventilation; the endotracheal tube is not easily replaced if dislodged and can cause tracheal stenosis and other local effects. Thus, if prolonged MV is required, the usual approach to securing the airway involves a tracheostomy. However, a tracheostomy tube interferes with speech. Other options for management of chronic ventilatory failure include use of noninvasive positive pressure ventilation (NPPV), intermittent abdominal pressure respiration, EPR, and respiratory muscle conditioning (with eventual weaning).

### Tracheostomy Positive Pressure Ventilation

Tracheostomy positive pressure ventilation (PPV) is the usual next step for patients on endotracheal tube PPV who cannot be weaned from ventilatory support within a few weeks. In order to permit speech, modifications need to be made to permit air leakage around the tracheostomy tube. This has been described in several ways: the use of cuffless tracheostomy tubes or in-line one-way speech valves (Passy-Muir valves), which permit leakage around the tube (between the tube and the tracheal wall), or fenestrated tubes, which permit air to escape through holes in the cephalad portion of the tracheostomy tube. With both of these techniques, the leakage requires increased volumes of air to be delivered by the ventilator and often results in hypocapnia.

### Chronic Noninvasive Ventilation

Chronic noninvasive ventilation (NIV) has been described as a means of providing chronic ventilatory support in patients with cervical SCI by assisting ventilation without using an endotracheal tube to establish an airway. There are two types: negative and positive pressure ventilation. Noninvasive negative pressure ventilation (NNPV) uses devices (total body chambers [iron lungs], or chest wraps) that surround the patient's thorax and enable lung expansion by applying negative (subatmospheric) extra-thoracic pressure during inspiration. However, iron lungs are confining to patients, restrict healthcare providers' access to patients, and require a great deal of space. The simpler chest wraps are also cumbersome to use and difficult to operate properly. Because of these difficulties, NNPV has been replaced by NPPV for nearly all cases (Bach, 1996).

NPPV delivers positive airway pressure from a ventilator through an interface into the patient's upper airway and lungs during inspiration. Interfaces are nasal-only or nasal/facial mask types and include nasal mask, nasal pillows, nasal-oral device, full face mask, or mouthpiece. Both interfaces will leak (nasal interfaces leak through the mouth; facial masks leak around the mask at the skin), and the NPPV system must be designed to accommodate this leak. A number of ventilator modes have been used to provide NPPV. Volume-cycled modes deliver a set flow and volume, whereas pressure-targeted modes deliver a set pressure with each breath. Positive end expiratory pressure (PEEP), supplemental oxygen, and backup mandatory breath rates can be provided as clinically indicated. Although conventional intensive care unit (ICU) ventilators can be adjusted to provide support through a mask interface, there are other options, including portable volume ventilators and BiPAP^®^. Portable volume ventilators with an oral interface allow intermittent positive pressure ventilation and allow patients to "stack" consecutively delivered breaths held with the glottis closed to be able to cough effectively. In addition, several simple pressure-targeted systems specifically designed for mask applications (e.g., BiPap^®^) are clinically available. For NPPV to be most effective, patients must be able to cooperate and coordinate their breathing with the ventilator. If not, breathing is actually hampered, not augmented. Usually a respiratory therapist or a nurse trained in NPPV techniques is required to monitor patients for ventilator-breathing synchrony and to make sure the equipment is functioning properly. That professional will also follow the patient for signs of physical improvement or deterioration. This monitoring is best performed in either an ICU or in another specialized ventilatory/respiratory care unit.

### Electrophrenic Respiration

EPR, or phrenic nerve pacing, is an artificial respiration technique in which electrodes surgically implanted around the phrenic nerves or diaphragm are stimulated to induce cyclical diaphragmatic contraction and, hence, ventilation of the lungs. The use of phrenic nerve pacing in a tetraplegic patient with chronic ventilator dependency was first described in 1972 (Glenn, Holcomb, McLaughlin et al., 1972). The pulse generator is surgically implanted and may be controlled by an external radiofrequency transmitter pacemaker. Various techniques and routes of phrenic nerve and diaphragm stimulation and a variety of pacemaker technologies have been reported.

EPR has the potential advantage of being more portable and of providing better speech and perhaps a more normal airway physiology than positive pressure ventilator techniques provide. However, not every SCI patient with chronic respiratory failure is a suitable candidate for this procedure. It generally requires an intact and viable phrenic nerve (although intercostal nerve grafts have been used), and response of the diaphragm to electrical stimulation on pre- or intra-operative testing. For the phrenic nerve to remain viable, the cell bodies and nerve axons originating in segments C3, C4, and C5 of the spinal cord must be intact. The use of EPR is further limited by diaphragm fatigue and deconditioning occurring between the onset of trauma and electrophrenic implant. EPR is frequently used unilaterally, thereby causing paradoxic motion of the contralateral diaphragm (Pedulluft breathing). EPR also does not allow the pressure increases that, with glottic closure, are needed to cough and can contribute to obstructive sleep apnea, necessitating that tracheostomies be kept.

### Intermittent Abdominal Pressure Respirator

The intermittent abdominal pressure respirator, also known as an exsufflation belt (or pneumobelt), assists in expiration rather than inspiration. It is a corset-type device that is placed around the abdomen and usually used only when the patient is awake and in an upright position. An inflatable bladder within the corset fills, thus compressing the abdominal wall, causing the diaphragm to rise, and producing active expiration. When the bladder deflates, passive inspiration results as the abdominal contents and diaphragm return to their regular position by gravity. Like NPPV, the intermittent abdominal pressure respirator allows for ventilation without a tracheostomy.

## Late Ventilatory Failure

Ventilatory failure also may occur late in the course of SCI in patients who have been breathing on their own for years, and is associated with acute changes in respiratory demands (e.g., pneumonia) or with progressive decline in pulmonary or neurologic function. Signs and symptoms associated with indolent ventilatory failure include tachypnea, dyspnea, daytime drowsiness, fluctuating mental alertness, unexplained erythrocytosis, and increased positional influences on breathing.

### Secretion Clearance

All patients with SCI have an impaired ability to clear secretions. Retained secretions may plug bronchi and lead to atelectasisand eventually to pneumonia. Because patients with SCI have decreased sensation of respiratory distress, the only signs and symptoms of impending respiratory failure from mucous plugging may be anxiety and increased respiratory rate. Failure to respond quickly to major mucous-plugging events may lead to respiratory arrest and death. Fever and purulent sputum may mark progression to pneumonia. Chest roentgenography is used to diagnose atelectasis or pneumonia, swallowing studies may identify potential for aspiration, and fluoroscopy or ultrasound can identify diaphragm paralysis.

Treatment methods include postural drainage and chest percussion, active suction, assisted cough, and rotating beds. In addition, intermittent positive pressure breathing (IPPB) with breath stacking or mechanical insufflation-exsufflation with concomitant abdominal thrusts and intrapulmonary percussive ventilation can be used to promote secretion clearance. Bronchodilating and mucolytic drugs may improve ventilation and reduce secretions. Fiberoptic bronchoscopy is also used to remove recalcitrant mucous plugs.

Postural drainage (positioning the patient so drainage occurs by gravity) is often assisted by chest physiotherapy or clapping hands on a patient's chest and back to loosen secretions in the bronchi. Several approaches have been used to assist cough, including manual pressure applied to the abdomen (timed with a patient's cough effort), positive pressure insufflation, mechanical insufflation-exsufflation (coughalator), and electrical stimulation of the abdominal muscles. Each of these methods requires the active intervention of a caregiver; each also requires coordination with the patient's control of opening and closing the upper airway. Rotating beds place a patient in a continuous turning motion in which he or she is turned equally from side to side. The potential benefits of mobilizing patients with SCI in this way may include reducing dermatological, cardiovascular, and other complications; it may also reduce pulmonary complications by improving secretion clearance and reducing atelectasis. Continuous turning is associated with continuous postural drainage. In addition, vibration, which is available on some rotating beds, may also encourage movement of mucus out of the lungs. The use of rotating beds has been associated with reduced rate of pulmonary complications in patients with SCI in general (Brackett and Condon, 1984).

## Target Populations

We focused on patients with acute traumatic cervical SCI, regardless of the degree of completeness of injury. We are interested in treatment in the days to months following acute injury and also the long-term followup over years.

We expected that among studies of patients requiring ventilatory support, and for certain techniques such as diaphragmatic pacing, the majority of patients using these technologies would have high-cervical SCI. However, patients with low-cervical injury or incomplete injury are also at high risk of late respiratory failure and are a relevant population to study for the effectiveness of interventions to prevent this outcome.

We did not consider persons with thoracic and lumbar SCI among the target population because with intact diaphragm function, the respiratory problems are generally less severe and less common than those in persons with cervical SCI. Furthermore, because of this physiological difference, data on persons with thoracolumbar SCI would not be relevant to persons with cervical SCI.

We did not include children as part of the target population for two reasons: (1) empirical evidence in the literature is almost nonexistent, and (2) there are probably differences in the management of their care, e.g., noninvasive ventilation may be more difficult in children than in adults.

## Target Practice Settings

The treatment of pulmonary complications in patients with cervical SCI may begin with the acute injury and extend throughout a patient's lifetime (Table 2), and the specific problems addressed are different at different times post-injury. We focused on the care of acuteSCI during the period of days to months after SCI that typically takes place in a rehabilitation facility, long-term care facility, or outpatient setting. Rehabilitation facilities should be able to provide invasive and noninvasive MV therapy, respiratory therapy, physical therapy, tracheostomy care, and speech therapy. Although some treatments (such as MV) can be more difficult in the outpatient setting, many of the interventions considered in this document are relevant to outpatients, thus we consider outpatient settings as well.

Initial management of acute injury may begin at the site of injury by emergency caregivers and can continue in emergency departments or trauma centers. Issues such as airway management (intubation technique) are relevant in this time frame. This settingwas not included in the scope of this report.

## Target Audience

The principal audience of our report is healthcare providers likely to care for persons with acute SCI or chronic SCI. We expect that this will include primary care, pulmonary, physical medicine, and rehabilitation physicians; respiratory therapy and nursing professionals; and members of rehabilitation teams including physical therapy, occupational therapy, speech therapy, and social workers.