# Appendix C. Acronyms and Abbreviations

ABG: arterial blood gas

ATS: American Thoracic Society

AHRQ: Agency for Healthcare Research and Quality

BiPAP®: bi-level positive airway pressure

CINAHL: Cumulative Index to Nursing & Allied Health Literature

CPAP: continuous positive airway pressure

CT: computed tomography

CXR: chest roentgenogram

EBEV: extrapolated back expiratory volume

EMG: electromyography

EPR: electrophrenic respiration

ERV: expiratory reserve volume

FEF25-75: forced expiratory flow between 25 and 75 percent of the exhaled volume

FEV: forced expiratory volume

FEV1: forced expiratory volume in 1 second

FIVC: forced inspiratory vital capacity

FIV1: forced inspiratory volume in 1 second

FRC: functional residual capacity

FVC: forced vital capacity

GPB: glossopharyngeal breathing

HBO: hyperbaric oxygen

IC: inspiratory capacity

ICU: intensive care unit

IMV: intermittent mandatory ventilation

IPAP: inspiratory positive airway pressure

IPPB: intermittent positive pressure breathing

KTT: kinetic treatment table

L: liter

LOI: level of injury

MeSH: Medical Subject Heading

MV: mechanical ventilation

MVV: maximal voluntary ventilation

NIDRR: National Institute on Disability and Rehabilitation Research

NIV: non-invasive ventilation

NNPV: non-invasive negative pressure ventilation

NPPV: non-invasive positive pressure ventilation

PC20: provocative concentration that causes a 20 percent decrease in FEV1

PEEP: positive end expiratory pressure

PEF: peak expiratory flow

PEFR: peak expiratory flow rate

PFT: pulmonary function test

Pemax: maximum expiratory pressure

Pimax: maximum inspiratory pressure

PPV: positive pressure ventilation

PVFB: progressive ventilatory-free breathing

RCT: randomized controlled trial

RV: residual volume

SaO2: arterial oxygen saturation

SCI: spinal cord injury

SIMV: synchronized intermittent mandatory ventilation

SIP: sustained inspiratory pressure

TLC: total lung capacity

TPPV: tracheostomy positive pressure ventilation

VC: vital capacity

VFSS: videofluoroscopic swallowing study

WTD: wedge turning device