# APPENDIX B. Studies Corresponding to Representative Outcomes in Table 5 ^1^ 1 FEV = forced expiratory volume in 1 second; FVC = forced vital capacity; PC_20_ = provocative concentration of methacholine or histamine that causes a 20% decrease in FEV; PEF = peak expiratory flow; PEFR = peak expiratory flow rate; pt = patient; MV = mechanical ventilation; TLC = total lung capacity; VC = vital capacity

Health State

Mortality (n = 30)

(Bach and Alba, 1990b)

Bach, 1991

Bach, Alba, and Saporito, 1993

Bellamy, Pitts, and Stauffer, 1973

Biering-Sorensen and Biering-Sorensen, 1992

Borkowski, 1989

Carter, 1979

Carter, 1993

Carter, Donovan, Halstead et al., 1987

Claxton, Wong, Chung et al., 1998

DeVivo and Ivie, 1995

Fodstad, 1989

Gardner, Theocleous, Watt et al., 1985

Gardner, Watt, and Krishnan, 1986

Glenn, Holcomb, Shaw et al., 1976

Gothe, Maximin, Sajkov et al., 1999

Green, Green, and Klose, 1980

Lamid, Ragalie, and Welter, 1985

Lemons and Wagner, 1994

McMichan, Michel, and Westbrook, 1980

Miller, Farmer, Stuart et al., 1990

Miller, Thomas, and Wilmot, 1988

Myllynen, Kivioja, Rokkanen et al., 1989

Ryan, Klein, and Bongard, 1993

Scher, 1982

Sortor, 1992

Splaingard, Frates, Harrison et al., 1983

Sugarman, 1985

Viroslav, Rosenblatt, and Tomazevic, 1996

Weese-Mayer, Silvestri, Kenny et al., 1996

Non-fatal Complications (n = 27)

Bach and Alba, 1990b

Bach, 1991

Bach, Alba, and Saporito, 1993

Bach, Rajaraman, Ballanger et al., 1998

Bellamy, Pitts, and Stauffer, 1973

Biering-Sorensen and Biering-Sorensen, 1992

Borkowski, 1989

Branscomb, Stover, DeVivo et al., 1984

Claxton, Wong, Chung et al., 1998

Darouiche, Groover, Rowland et al., 1993

Gardner, Watt, and Krishnan, 1986

Glenn, Holcomb, Shaw et al., 1976

Green, Green, and Klose, 1980

Hart, Strauss, and Riker, 1984

Hsu, Dreisbach, Charlifue et al., 1987

Lamid, Ragalie, and Welter, 1985

Lemons and Wagner, 1994

McMichan, Michel, and Westbrook, 1980

Meschino, Devitt, Koch et al., 1992

Miller, Farmer, Stuart et al., 1990

Myllynen, Kivioja, Rokkanen et al., 1989

Peterson, Barbalata, Brooks et al., 1999

Scher, 1982

Sugarman, 1985

Waites, Canupp, Edwards et al., 1998

Wang, Jaeger, Yarkony et al., 1997

Weese-Mayer, Silvestri, Kenny et al., 1996

Quality of Life (n = 4)

Bach and Tilton, 1994

Gardner, Theocleous, Watt et al., 1985

Lamid, Ragalie, and Welter, 1985

Miller, Thomas, and Wilmot, 1988

Health Services

Mechanical Ventilation (n = 14)

Bach and Tilton, 1994

Borkowski, 1989

Carter, 1979

Carter, 1993

Claxton, Wong, Chung et al., 1998

Fodstad, 1989

Gardner, Theocleous, Watt et al., 1985

Gardner, Watt, and Krishnan, 1986

Lemons and Wagner, 1994

McMichan, Michel, and Westbrook, 1980

Miller, Farmer, Stuart et al., 1990

Myllynen, Kivioja, Rokkanen et al., 1989

Tromans, Mecci, Barrett et al., 1998

Viroslav, Rosenblatt, and Tomazevic, 1996

Weaning (n = 13)

Bach and Alba, 1990a

Bach, 1991

Bach, Alba, and Saporito, 1993

Carter, 1979

Gardner, Watt, and Krishnan, 1986

Lamid, Ragalie, and Welter, 1985

Miller, Farmer, Stuart et al., 1990

Peterson, Barbalata, Brooks et al., 1999

Peterson, Charlifue, Gerhart et al., 1994

Sortor, 1992

Splaingard, Frates, Harrison et al., 1983

Tromans, Mecci, Barrett et al., 1998

Viroslav, Rosenblatt, and Tomazevic, 1996

Tracheostomies (n = 10)

Bach, 1991

Bach, Alba, and Saporito, 1993

Bellamy, Pitts, and Stauffer, 1973

Biering-Sorensen and Biering-Sorensen, 1992

Borkowski, 1989

Carter, 1979

Lamid, Ragalie, and Welter, 1985

McMichan, Michel, and Westbrook, 1980

Sortor, 1992

Viroslav, Rosenblatt, and Tomazevic, 1996

Hsu, Dresibach, Charlifue et al., 1987

Electrophrenic or Diaph. Pacing (n = 9)

Carter, 1979

Carter, 1993

Carter, Donovan, Halstead et al., 1987

Fodstad, 1989

Gardner, Watt, and Krishnan, 1986

Glenn, Holcomb, Shaw et al., 1976

Jaeger, Turba, Yarkony et al., 1993

Miller, Farmer, Stuart et al., 1990

Weese-Mayer, Silvestri, Kenny et al., 1996

Hospitalization (n = 9)

Bach and Alba, 1990b

Bach, 1991

Bach, Rajaraman, Ballanger et al., 1998

Borkowski, 1989

Claxton, Wong, Chung et al., 1998

Gardner, Theocleous, Watt et al., 1985

Gardner, Watt, and Krishnan, 1986

Lemons and Wagner, 1994

Ryan, Klein, and Bongard, 1993

Discharge Status (n = 7)

Carter, 1979

Carter, 1993

Gardner, Theocleous, Watt et al., 1985

Gardner, Watt, and Krishnan, 1986

Lamid, Ragalie, and Welter, 1985

Sortor, 1992

Splaingard, Frates, Harrison et al., 1983

Spirometry

VC or FVC (n = 35)

Almenoff, Alexander, Spungen et al., 1995

Amodie-Storey, Nash, Roussell et al., 1996

Ashba, Garshick, Tun et al., 1993

Axen, Pineda, Shunfenthal et al., 1985

Bach and Alba, 1990a

Bach and Alba, 1990b

Bach, 1991

Bach, Alba, and Saporito, 1993

Carter, 1979

Chen, Lien, and Wu, 1990

Cheshire and Flack, 1978

Claxton, Wong, Chung et al., 1998

Derrickson, Ciesla, Simpson et al., 1992

Dicpinigaitis, Spungen, Bauman et al., 1994

DiPasquale, 1986

Estenne and De Troyer, 1987

Fein, Grimm, Lesser et al., 1998

Forner, 1980

Forner, Llombart, and Valledor, 1977

Fugl-Meyer, 1971

Grimm, DeLuca, Lesser et al., 1997

Hart, Strauss, and Riker, 1984

Huldtgren, Fugl-Meyer, Jonasson et al., 1980

Loveridge, Badour, and Dubo, 1989

Maeda, Baydur, Waters et al., 1990

McMichan, Michel, and Westbrook, 1980

Montero, Feldman, and Montero, 1967

Peterson, Barbalata, Brooks et al., 1999

Roth, Lu, Primack et al., 1997

Segal and Brunnemann, 1997

Spungen, Dicpinigaitis, Almenoff et al., 1993

Spungen, Grimm, Strakhan et al., 1999

Sugarman, 1985

Tromans, Mecci, Barrett et al., 1998

Walker and Cooney, 1987

FEV or FEV_1_ (n = 15)

Almenoff, Alexander, Spungen et al., 1995

Ashba, Garshick, Tun et al., 1993

Chen, Lien, and Wu, 1990

DeLuca, Grimm, Lesser et al., 1999

Dicpinigaitis, Spungen, Bauman et al., 1994

Fein, Grimm, Lesser et al., 1998

Forner, 1980

Fugl-Meyer, 1971

Grimm, DeLuca, Lesser et al., 1997

McMichan, Michel, and Westbrook, 1980

Roth, Lu, Primack et al., 1997

Segal and Brunnemann, 1997

Singas, Grimm, Almenoff et al., 1999

Spungen, Dicpinigaitis, Almenoff et al., 1993

Spungen, Grimm, Strakhan et al., 1999

PEF and/or PEFR (n = 8)

Derrickson, Ciesla, Simpson et al., 1992

Forner, 1980

Forner, Llombart, and Valledor, 1977

Fugl-Meyer, 1971

Jaeger, Turba, Yarkony et al., 1993

Lin, Lai, Wu et al., 1998

Spungen, Grimm, Strakhan et al., 1999

Wang, Jaeger, Yarkony et al., 1997

TLC (n = 7)

Estenne and De Troyer, 1987

Forner, 1980

Fugl-Meyer, 1971

Huldtgren, Fugl-Meyer, Jonasson et al., 1980

Loveridge, Badour, and Dubo, 1989

McMichan, Michel, and Westbrook, 1980

Roth, Lu, Primack et al., 1997

Other PC_20_ (n = 2)

DeLuca, Grimm, Lesser et al., 1999

Dicpinigaitis, Spungen, Bauman et al., 1994

Fein, Grimm, Lesser et al., 1998

Grimm, DeLuca, Lesser et al., 1997

Singas, Grimm, Almenoff et al., 1999

Antibodies (n = 2)

Darouiche, Groover, Rowland et al., 1993

Waites, Canupp, Edwards et al., 1998