# Appendix A. Excluded Small Case Series, Search Strategies, Screening Form, and Data Abstraction Template

Excluded Small Case Series With Fewer Than 10 Subjects

1. Abelson H, Brewer K. Inspiratory muscle training in the mechanically ventilated patient. Physiother Can 1987;39(5):305-7.
2. Al-Kaisy AA, Kent AP, Watt JWH. Maintaining ventilation through the Montgomery t-tube. Can J Anaesthesia 1997;44(3):340.
3. Ali J, Qi W. Pulmonary function and posture in traumatic quadriplegia. J Trauma 1995;39(2):334-7.
4. Armitage JM, Pyne A, Williams SJ, et al. Respiratory problems of air travel in patients with spinal cord injuries. BMJ 1990;300(6738):1498-9.
5. Bach JR. Inappropriate weaning and late onset ventilatory failure of individuals with traumatic spinal cord injury. Paraplegia 1993;31(7):430-8.
6. Bach JR. Mechanical insufflation-exsufflation. Comparison of peak expiratory flows with manually assisted and unassisted coughing techniques. Chest 1993;104(5):1553-62.
7. Bach JR, McDermott IG. Strapless oral-nasal interface for positive-pressure ventilation. Arch Phys Med Rehab 1990;71(11):910-3.
8. Baer GA, Talonen PP, Shneerson JM, et al. Phrenic nerve stimulation for central ventilatory failure with bipolar and four-pole electrode systems. Pacing Clin Electrophysiol 1990;13(8):1061-72.
9. Bake B, Fugl-Meyer AR, Grimby G. Breathing patterns and regional ventilation distribution in tetraplegic patients and in normal subjects. Clin Sci 1972;42(2):117-28.
10. Banzett RB, Lansing RW, Reid MB, et al. 'Air hunger' arising from increased pCO_2_ in mechanically ventilated quadriplegics. Respir Physiol 1989;76(1):53-67.
11. Biering-Sorensen M, Norup PW, Jacobsen E, et al. Treatment of sleep apnoea in spinal cord injured patients. Paraplegia 1995;33(5):271-3.
12. Chawla JC. Rehabilitation of spinal cord injured patients on long term ventilation. Paraplegia 1993;31(2):88-92.
13. Danon J, Druz WS, Goldberg NB, et al. Function of the isolated paced diaphragm and the cervical accessory muscles in C1 quadriplegics. Am Rev Respir Dis 1979;119(6):909-19.
14. Davenport LF. Inhalation therapy in quadriplegic patients. Proc Annu Clin Spinal Cord Inj Conf 1964;13:45-7.
15. De Boeck H, Vincken W, Cham B, et al. Diaphragmatic pacing in the treatment of chronic respiratory insufficiency of quadriplegic patients. Acta Chir Belg 1989;89(5):276-80.
16. Dee PM, Suratt PM, Bray ST, et al. Mucous plugging simulating pulmonary embolism in patients with quadriplegia. Chest 1984;85(3):363-6.
17. Devine A, Watt JW. Anaesthesia and diaphragmatic pacing in patients with tetraplegia. A review of peri-operative management in patients over a 10-year period. Eur J Anaesthesiol 1996;13(6):553-61.
18. Dicpinigaitis PV, Spungen AM, Bauman WA, et al. Bronchial hyperresponsiveness after cervical spinal cord injury. Chest 1994;105(4):1073-6.
19. DiMarco AF, Supinski GS, Petro JA, et al. Evaluation of intercostal pacing to provide artificial ventilation in quadriplegics. Am J Respir Crit Care Med 1994;150(4):934-40.
20. Elefteriades JA, Hogan JF, Handler A, et al. Long-term follow-up of bilateral pacing of the diaphragm in quadriplegia [letter]. N Engl J Med 1992;326(21):1433-4.
21. Epstein SW, Vanderlinden RG, Man SF, et al. Lung function in diaphragm pacing. Can Med Assoc J 1979;120(11):1360-8.
22. Esclarin A, Bravo P, Arroyo O, et al. Tracheostomy ventilation versus diaphragmatic pacemaker ventilation in high spinal cord injury. Paraplegia 1994;32(10):687-93.
23. Estenne M, De Troyer A. Cough in tetraplegic subjects: an active process. Ann Intern Med 1990;112(1):22-8.
24. Estenne M, Gorini M. Action of the diaphragm during cough in tetraplegic subjects. J Appl Physiol 1992;72(3):1074-80.
25. Estenne M, Knoop C, Vanvaerenbergh J, et al. The effect of pectoralis muscle training in tetraplegic subjects. Am Rev Respir Dis 1989;139(5):1218-22.
26. Fairshter RD, Vaziri ND, Gordon S. Frequency and spectrum of pulmonary diseases in patients with chronic renal failure associated with spinal cord injury. Respiration 1983;44(1):58-62.
27. Forner Valero JV. Postural variations of the capacity in tetraplegics. Paraplegia 1970;8(3):176.
28. Frankel HL. Tracheal stenosis following tracheostomy. Paraplegia 1970;8(3):172-6.
29. Frankel HL, Guz A, Noble M. Respiratory sensations in patients with cervical cord transection. Paraplegia 1971;9(3):132-6.
30. Frankel HL, Mathias CJ, Spalding JM. Mechanisms of reflex cardiac arrest in tetraplegic patients. Lancet 1975;2(7946):1183-5.
31. Frates RC Jr, Splaingard ML, Smith EO, et al. Outcome of home mechanical ventilation in children. J Pediatr 1985;106(5):850-6.
32. Fugl-Meyer AR. A model for treatment of impaired ventilatory function in tetraplegic patients. Scand J Rehabil Med 1971;3(4):168-77.
33. Garner SH, Bloch RF, Sutton JR. Heart rate response to facial immersion and apnea in quadriplegia. Arch Phys Med Rehabil 1985;66(11):763-7.
34. Garrido-Garcia H, Martin-Escribano P, Palomera-Frade J, et al. Transdiaphragmatic pressure in quadriplegic individuals ventilated by diaphragmatic pacemaker. Thorax 1996;51(4):420-3.
35. Gilgoff IS, Peng RC, Keens TG. Hypoventilation and apnea in children during mechanically assisted ventilation. Chest 1992;101(6):1500-6.
36. Glass CA. The impact of home based ventilator dependence on family life. Paraplegia 1993;31(2):93-101.
37. Glenn WW, Hogan JF, Loke JS, et al. Ventilatory support by pacing of the conditioned diaphragm in quadriplegia. N Engl J Med 1984;310(18):1150-5.
38. Glenn WW, Holcomb WG, Hogan J, et al. Diaphragm pacing by radiofrequency transmission in the treatment of chronic ventilatory insufficiency. Present status. J Thorac Cardiovasc Surg 1973;66(4):505-20.
39. Glenn WW, Phelps M, Gersten LM. Diaphragm pacing in the management of central alveolar hypoventilation. pp. 333-45. In: Guilleminault C, Dement WC, Ed. Sleep Apnea Syndromes. New York, Liss, 1978.
40. Gupta A, McClelland MR, Evans A, et al. Minitracheotomy in the early respiratory management of patients with spinal injuries. Paraplegia 1989;27(4):269-77.
41. Hammon WE, Martin RJ. Chest physical therapy for acute atelectasis. A report on its effectiveness. Phys Ther 1981;61(2):217-20.
42. Hjeltnes N. Cardiorespiratory capacity in tetra- and paraplegia shortly after injury. Scand J Rehabil Med 1986;18(2):65-70.
43. Ivatury R, Siegel JH, Stahl WM, et al. Percutaneous tracheostomy after trauma and critical illness. J Trauma-Inj Infect Crit Care 1992;32(2):133-40.
44. Jordan SA, Wellborn WR 3d, Kovnick J, et al. Understanding and treating motivation difficulties in ventilator-dependent SCI patients. Paraplegia 1991;29(7):431-42.
45. Kokkola K, Moller K, Lehtonen T. Pulmonary function in tetraplegic and paraplegic patients. Ann Clin Res 1975;7(2):76-9.
46. Lerman RM, Weiss MS. Progressive resistive exercise in weaning high quadriplegics from the ventilator. Paraplegia 1987;25(2):130-5.
47. Levine SP, Koester DJ, Kett RL. Independently activated talking tracheostomy systems for quadriplegic patients. Arch Phys Med Rehab 1987;68(9):571-3.
48. Linder SH. Functional electrical stimulation to enhance cough in quadriplegia. Chest 1993;103(1):166-9.
49. Mayr W, Bijak M, Girsch W, et al. Multichannel stimulation of phrenic nerves by epineural electrodes. Clinical experience and future developments. ASAIO J 1993;39(3): M729-35.
50. McCool FD, Pichurko BM, Slutsky AS, et al. Changes in lung volume and rib cage configuration with abdominal binding in quadriplegia. J Appl Physiol 1986;60(4):1198-202.
51. McKinley AC, Auchincloss JH Jr, Gilbert R, et al. Pulmonary function, ventilatory control, and respiratory complications in quadriplegic subjects. Am Rev Respir Dis 1969;100(4):526-32.
52. Mugica J, Dejean D, Smits K, et al. Direct diaphragm stimulation. Pacing Clin Electrophysiol 1987;10(1 Pt 2):252-6.
53. Oakes DD, Wilmot CB, Halverson D, et al. Neurogenic respiratory failure: a 5-year experience using implantable phrenic nerve stimulators. Ann Thorac Surg 1980;30(2):118-21.
54. Oku Y, Kurusu M, Hara Y, et al. Ventilatory responses and subjective sensations during arm exercise and hypercapnia in patients with lower-cervical and upper-thoracic spinal cord injuries. Intern Med 1997;36(11):776-80.
55. Opaskar Hincman H, Ramakrishnan Bhaskar K DeFeudis O'Sullivan D, Brown R, et al. Lipids in airway mucus of acute quadriplegic patients. Experimental Lung Research 1990;16(4):369-85.
56. Peterson WP, Whiteneck GG, Gerhart KA. Chest tubes, lung entrapment, and failure to wean from the ventilator. Report of three patients with quadriplegia. Chest 1994;105(4):1292-4.
57. Segal JL, Brunnemann SR, Gordon SK, et al. The absolute bioavailability of oral theophylline in patients with spinal cord injury. Pharmacotherapy 1986;6(1):26-9.
58. Shwiry B, Joseph S, Sullivan CA, et al. A method of intubation for cervical spine injured patients. AANA J 1983;51(4):403-5.
59. Silver JR, Abdel-Halim RE. Chest movements and electromyography of the intercostal muscles in tetraplegic patients. Paraplegia 1971;9(3):123-31.
60. Silver JR, Moulton A. The physiological and pathological sequelae of paralysis of the intercostal and abdominal muscles in tetraplegic patients. Paraplegia 1969;7(2):131-41.
61. Singas E, Lesser M, Spungen AM, et al. Airway hyperresponsiveness to methacholine in subjects with spinal cord injury. Chest 1996;110(4):911-5.
62. Thoma H, Gerner H, Holle J, et al. The phrenic pacemaker. Substitution of paralyzed functions in tetraplegia. ASAIO Trans 1987;33(3):472-9.
63. Tran NV, Vernick J, Cotler JM, et al. Lateral tracheostomy in patients with cervical spinal cord injury. British Journal of Surgery 1995;82(3):412-3.
64. Vanderlinden RG, Epstein SW, Hyland RH, et al. Management of chronic ventilatory insufficiency with electrical diaphragm pacing. Can J Neurol Sci 1988;15(1):63-7.
65. Vergith TS. Mechanism of active expiration in tetraplegic subjects [letter]. N Engl J Med 1986;315(19):1233.
66. Zupan A, Savrin R, Erjavec T, et al. Effects of respiratory muscle training and electrical stimulation of abdominal muscles on respiratory capabilities in tetraplegic patients. Spinal Cord 1997;35(8):540-5.

## Search Strategies

MEDLINE: Search 1
1. exp spinal cord injuries/; 2. exp paraplegia/; 3. quadriplegia/; 4. tetraplegi$.tw.; 5. quadriplegi$.tw.; 6. paraplegi$.tw.; 7. or/1-6; 8. exp respiratory insufficiency/; 9. exp respiration, artificial/; 10. intubation, intratracheal/; 11. tracheostomy/; 12. speech/; 13. respiratory therapy/; 14. postural drainage/; 15. respiratory tract diseases/; 16. weaning.tw.; 17. or/8-16; 18. 7 and 17; 19. limit 18 to human; 20. limit 19 to english language

MEDLINE: Search 2
1. exp spinal cord injuries/; 2. exp paraplegia/; 3. quadriplegia/; 4. tetraplegi$.tw.; 5. quadriplegi$.tw.; 6. paraplegi$.tw.; 7. or/1-6; 8. exp respiratory insufficiency/; 9. exp respiration, artificial/; 10. intubation, intratracheal/; 11. tracheostomy/; 12. speech/; 13. respiratory therapy/; 14. postural drainage/; 15. respiratory tract diseases/; 16. weaning.tw.; 17. or/8-16; 18. limit 17 to human; 19. limit 18 to english language; 20. 7 and 19; 21. limit 20 to abstracts; 22. exp otorhinolaryngologic diseases/; 23. 7 and 22; 24. limit 23 to human; 25. limit 24 to english language; 26. limit 25 to abstracts; 27. 26 not 21; 28. exp respiration disorders/; 29. 7 and 28; 30. limit 29 to human; 31. limit 30 to english language; 32. limit 31 to abstracts; 33. 32 not 21; 34. exp respiratory function tests/; 35. 7 and 34; 36. limit 35 to human; 37. limit 36 to english language; 38. limit 37 to abstracts; 39. 38 not 21; 40. exp respiratory tract diseases/; 41. 7 and 40; 42. limit 41 to human; 43. limit 42 to english language; 44. limit 43 to abstracts; 45. 44 not 21; 46. breathing exercises/; 47. 7 and 46; 48. limit 47 to human; 49. limit 48 to english language; 50. limit 49 to abstracts; 51. 50 not 21; 52. smoking/; 53. 7 and 52; 54. limit 53 to human; 55. limit 54 to english language; 56. limit 55 to abstracts; 57. 56 not 21; 58. exp bronchodilator agents/; 59. 7 and 58; 60. limit 59 to human; 61. limit 60 to english language; 62. limit 61 to abstracts; 63. exp respiratory physiology/; 64. 7 and 63; 65. limit 64 to human; 66. limit 65 to english language; 67. limit 66 to abstracts; 68. 67 not 21; 69. 68 not 39; 70. exp diagnostic techniques, respiratory system/; 71. 7 and 70; 72. limit 71 to human; 73. limit 72 to english language; 74. limit 73 to abstracts; 75. 74 not 21; 76. 75 not 39; 77. 45 not 33; 78. 33 or 27 or 39 or 77 or 51 or 57 or 62 or 69

EMBASE Search
001 | exp spinal cord injury/
002 | paraplegia/
003 | quadriplegia/
004 | spastic paraplegia/
005 | tetrapleg$.tw.
006 | 1 or 2 or 3 or 4 or 5/
007 | exp respiratory tract disease/
008 | ventilator/
009 | exp assisted ventilation/
0010 | tracheostomy/
0011 | postural drainage/
0012 | 7 or 8 or 9 or 10 or 11/
0013 | 6 and 12/
0014 | l/13 lg=en/
0015 | l/14 hu=y/
0016 | 15/

## Screening Form

(2-sided form - see next page) Treatment of Pulmonary Disease following Spinal Cord Injury Screening Decisions: Full-Text Articles

Reviewer: | _____________________
Record # | _____________________
First Author: | _____________________

If decision is to EXCLUDE, check first reason that applies below:

_______1-NoOrig: not original research (or relevant review)

_______2-NoSCI: not traumatic cervical SCI

_______3-NoPulm: not related to pulmonary disease

_______4-Ped: pediatric population (all subjects or mean age <18)

_______5-CR: single case report

_______6-SmCS: small case series (n<20) (if this is the only reason for exclusion, then please categorize article by completing reverse side) Size of case series N=______

_______7-TE-PE: thromboembolism/pulmonary embolism

Check here _________ if decision is to INCLUDE and complete reverse side.

Check here _________ if article is a RELEVANT REVIEW ARTICLE (i.e., not original research) and complete reverse side

COMPLICATION (indicate 1 or more) ~ Ventilatory failure ~ Acute ventilatory failure ~ Inability to wean ~ Chronic ventilator dependence ~ Late ventilatory failure ~ Aspiration ~ Atelectasis or lobar collapse ~ Impaired cough, secretion clearance ~ Impaired lung compliance ~ Impaired speech ~ Infect'n (Pneumonia/tracheobronchitis) ~ Pleural effusion ~ Pneumothorax ~ Sleep apnea/nocturnal oxygen desat ~ Tracheal or laryngeal stenosis ~ Other________________________________ SCI TIME COURSE (indicate 1 best) ~ Emergency care min-hrs Stage 0 ~ Medical stab days Stage 1-2 ~ Inpatient rehab weeks-mos Stage 2-3 ~ Community integr mos Stage 4 ~ Long-term f/u years TYPE OF DATA ~ Epidemiology of pulmonary dz in SCI Incidence/prevalence Risk factors Natural history ~ Health services utilization Utilization Costs of care ~ Clinical assessment/measurement ~ Physiological data ~ Efficacy And/Or Harms Of Intervention (indicate intervention class [in italics] below) Airway management Intubation Tracheostomy Trach care Cuff deflation protocol Other ________________ Secretion management Suction and/or bagging, Intermittent NPPV Elevating head/sitting up/postural Assisted cough, manual, electrical Nebulized saline or humidification Passive drainage/Position and turn Roto Rest beds Other ________________ Ventilation management Wean protocol Air-shift maneuvers Glossopharyngeal breathing Deep breathing exercises (inflation hold or incentive spirometer) Diaphragmatic strengthening exercise (wts vs resisted inspiration) Phrenic nerve pacing or FES Manual pectoral-chest stretch ex Noninvasive ventilation (body ventilators, NPPV, BiPAP) Pneumobelt, Abdominal corset Invasive vent (ET or trach) Large volume (>2500cc, pressure control or stacked breaths) Rocking bed (vent assist device) Other ________________ Drug therapy Accolate Antibiotics Bronchodilators Cromolyn, inhaled Guaifenesin Mucolytics Mucomyst Steroids Vaccinations Other ________________ Clinical monitoring and diagnostic tests ABG monitoring Auscultation/Physical exam Chest x-ray (surveillance) Monitor sputum characteristics Monitor temp and RR Oximetry monitoring (day, night) Respiratory function tests Semi-annual evaluation Other ________________ Therapeutic medical/surgical procedures Bronchoscopy Pulmonary medicine consults Other ________________ Patient education and counselling Discourage smoking Other ________________ Diet Milk free diet Other ________________ Other ________________________

## Data Abstraction Form (Template)

Study | Design and Quality | Patient Population | Study Protocol/Interventions | Results/Outcomes
Study | Design: Quality: Internal validity External validity | N = Neurol. status Time since injury: Level of injury: Completeness of injury: (C, I) [for "incomplete," give Frankel, ASIA rating, etc., if provided] Pulmonary status: Age: Sex: Race: