# Appendixes

Appendix A. Excluded Small Case Series, Search Strategies, Screening Form, and Data Abstraction Template

APPENDIX B. Studies Corresponding to Representative Outcomes in Table 5

Appendix C. Acronyms and Abbreviations