# Supplemental Analyses

## Meta-Analyses

Data used for meta-analyses and the results are presented in this chapter (Tables 53 to 64; Figures 921 to 22). The methodologies for performing meta-analyses were described in Chapter 2. Meta-analyses were performed for technologies where there are an adequate number of studies.

Table 53. Meta-analysis of diagnostic performance of prehospital 12-lead ECG for ACI

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Kudenchuk 1998 | 740/873 | 56/1358 | 0.46 | 0.43-0.48 | 0.96 | 0.95-0.97 | 48.1050
Bertini 1991 | 298/16 | 19/272 | 0.95 | 0.92-0.97 | 0.93 | 0.90-0.96 | 8.6049
Aufderheide 1992b | 102/137 | 26/174 | 0.43 | 0.36-0.49 | 0.87 | 0.81-0.91 | 16.6691
Aufderheide 1990 | 55/6 | 42/48 | 0.90 | 0.79-0.96 | 0.53 | 0.43-0.64 | 4.8193
Dalzell 1991 | 63/18 | 1/7 | 0.78 | 0.67-0.86 | 0.88 | 0.47-0.99 | 1.2950
Total (range) | 2,308 | 2,003 | 0.43-0.95 | | 0.53-0.96
| | REM pooled | 0.76 | 0.54-0.89 | 0.88 | 0.67-0.96
| | Odds ratio | 23.3 | (6.3-85.4)

Note: The following acronyms are used in the tables: TP-true positive; FN-false negative; FP-false positive; TN-true negative; Sens-sensitivity; CI-confidence interval; Spec-specificity; Var-variance.

Table 54. Meta-analysis of diagnostic performance of prehospital 12-lead ECG for AMI

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Kudenchuk 1998 | 259/132 | 41/757 | 0.66 | 0.61-0.71 | 0.95 | 0.93-0.96 | 27.3566
Bertini 1991 | 120/37 | 29/419 | 0.76 | 0.69-0.83 | 0.94 | 0.91-0.96 | 14.1654
Aufderheide 1992b | 38/53 | 1/347 | 0.42 | 0.32-0.53 | 1.00 | 0.98-1.00 | 1.8216
Aufderheide 1990 | 13/11 | 1/126 | 0.54 | 0.33-0.74 | 0.99 | 0.95-1.00 | 1.4857
Foster 1994 | 17/4 | 0/134 | 0.81 | 0.58-0.94 | 1.00 | 0.97-1.00 | 0.7796
Millar-Craig 1997 | 71/1 | 53/37 | 0.99 | 0.92-1.00 | 0.41 | 0.31-0.52 | 1.7657
Dalzell 1991 | 37/11 | 1/45 | 0.77 | 0.62-0.87 | 0.98 | 0.87-1.00 | 1.5504
Arntz 1992 | 268/149 | 4/805 | 0.64 | 0.59-0.69 | 1.00 | 0.99-1.00 | 4.7192
Total (range) | 1,221 | 2,800 | 0.42-0.99 | | 0.41-1.00
| | REM pooled | 0.68 | 0.59-0.76 | 0.97 | 0.90-0.99
| | Odds ratio | 104 (48-224)

Table 55. Meta-analysis of diagnostic performance of single CK at presentation to diagnose AMI (ED studies)

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Thomson 1995 | 29/40 | 22/292 | 0.42 | 0.30-0.54 | 0.93 | 0.89-0.95 | 9.4696
Eisenberg 1979 | 7/6 | 12/55 | 0.54 | 0.26-0.79 | 0.82 | 0.70-0.90 | 2.5997
Mair 1991b | 22/29 | 13/62 | 0.43 | 0.30-0.58 | 0.83 | 0.72-0.90 | 5.9958
Viskin 1987 | 29/47 | 13/163 | 0.38 | 0.27-0.50 | 0.93 | 0.87-0.96 | 7.5275
Lee 1987 | 40/64 | 108/427 | 0.38 | 0.29-0.49 | 0.80 | 0.76-0.83 | 19.3463
Gornall 1996 | 11/29 | 8/50 | 0.28 | 0.15-0.44 | 0.86 | 0.74-0.93 | 3.9595
Hetland 1996 | 3/42 | 6/82 | 0.07 | 0.02-0.19 | 0.93 | 0.85-0.97 | 2.2936
Mair 1991a | 8/15 | 8/65 | 0.35 | 0.17-0.57 | 0.89 | 0.79-0.95 | 3.2347
Roxin 1984 | 22/58 | 10/215 | 0.28 | 0.18-0.39 | 0.96 | 0.92-0.98 | 6.3635
Hedges 1987 | 28/23 | 253/469 | 0.55 | 0.40-0.69 | 0.65 | 0.61-0.68 | 11.9452
Total (range) | 552 | 2,333 | 0.07-0.55 | | 0.65-0.96
| | REM pooled | 0.36 | 0.29-0.44 | 0.88 | 0.80-0.93
| | Odds ratio | 4.0 (2.6-6.2)

Table 56. Meta-analysis of diagnostic performance of single CK-MB at presentation to diagnose AMI (ED studies)

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Montague 1995 | 9/16 | 1/63 | 0.36 | 0.19-0.57 | 0.98 | 0.91-1.00 | 1.4517
Mair 1996 | 23/16 | 7/54 | 0.59 | 0.42-0.74 | 0.89 | 0.77-0.95 | 4.0226
Hetland 1996 | 20/25 | 2/86 | 0.44 | 0.30-0.60 | 0.98 | 0.91-1.00 | 2.2897
Mair 1991b | 29/22 | 6/69 | 0.57 | 0.42-0.70 | 0.92 | 0.83-0.97 | 4.2095
Gornall 1996 | 10/30 | 1/57 | 0.25 | 0.13-0.41 | 0.98 | 0.90-1.00 | 1.5328
Thomson 1995 | 38/30 | 20/287 | 0.56 | 0.43-0.68 | 0.93 | 0.90-0.96 | 9.0902
Hedges 1996 | 38/29 | 35/940 | 0.57 | 0.44-0.69 | 0.96 | 0.95-0.97 | 11.2708
Brogan 1994 | 5/17 | 1/166 | 0.23 | 0.09-0.46 | 0.99 | 0.96-1.00 | 1.3489
Collins 1993 | 42/39 | 3/111 | 0.52 | 0.41-0.63 | 0.97 | 0.92-0.99 | 3.2253
Castaldo 1994 | 13/45 | 2/97 | 0.22 | 0.13-0.36 | 0.98 | 0.92-1.00 | 2.2636
Total (range) | 496 | 2,008 | 0.22-0.59 | | 0.89-0.99
| | REM pooled | 0.44 | 0.35-0.53 | 0.96 | 0.94-0.97
| | Odds ratio | 23 (17-32)

Table 57. Meta-analysis of diagnostic performance of serial CK-MB to diagnose AMI (ED studies)

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Gerhardt 1982 | 206/1 | 9/265 | 1.00 | 0.97-1.00 | 0.97 | 0.94-0.98 | 1.6356
Montague 1995 | 17/8 | 5/59 | 0.68 | 0.47-0.84 | 0.92 | 0.82-0.97 | 2.7814
Gibler 1995 | 12/0 | 17/981 | 1.00 | 0.74-1.00 | 0.98 | 0.97-0.99 | 0.8175
Hedges 1996 | 59/8 | 49/926 | 0.88 | 0.77-0.94 | 0.95 | 0.93-0.96 | 6.6319
Hedges 1992 | 19/9 | 11/222 | 0.68 | 0.48-0.83 | 0.95 | 0.91-0.97 | 4.1059
Brogan 1994 | 9/13 | 1/166 | 0.41 | 0.22-0.63 | 0.99 | 0.96-1.00 | 1.4530
Castaldo 1994 | 36/22 | 5/94 | 0.62 | 0.48-0.74 | 0.95 | 0.88-0.98 | 3.9888
Total (range) | 419 | 2,810 | 0.41-1.00 | | 0.92-0.99
| | REM pooled | 0.80 | 0.61-0.91 | 0.96 | 0.94-0.98
| | Odds ratio | 171 (58-505)

Table 58. Meta-analysis of diagnostic performance of presentation myoglobin to diagnose AMI (ED studies)

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Brogan 1994 | 12/10 | 3/164 | 0.55 | 0.33-0.75 | 0.98 | 0.94-1.00 | 2.3092
Roxin 1984 | 57/23 | 38/187 | 0.71 | 0.60-0.81 | 0.83 | 0.77-0.88 | 11.0202
Gilkeson 1978 | 5/8 | 4/54 | 0.38 | 0.15-0.68 | 0.93 | 0.83-0.98 | 1.9191
Mair 1992 | 23/28 | 7/68 | 0.45 | 0.31-0.60 | 0.91 | 0.81-0.96 | 4.5663
Mair 1996 | 18/21 | 7/55 | 0.46 | 0.30-0.63 | 0.89 | 0.78-0.95 | 4.0690
Hetland 1996 | 23/22 | 5/83 | 0.51 | 0.36-0.66 | 0.94 | 0.87-0.98 | 3.7364
Gornall 1996 | 17/23 | 1/57 | 0.43 | 0.27-0.59 | 0.98 | 0.90-1.00 | 1.5979
Montague 1995 | 16/13 | 17/78 | 0.55 | 0.36-0.73 | 0.82 | 0.73-0.89 | 4.9098
Kennedy 1997 | 8/13 | 3/67 | 0.38 | 0.19-0.61 | 0.96 | 0.87-0.99 | 2.1752
Castaldo 1994 | 22/36 | 0/99 | 0.38 | 0.26-0.52 | 1.00 | 0.96-1.00 | 0.9158
Total (range) | 398 | 997 | 0.38-0.71 | | 0.82-1.00
| | REM pooled | 0.49 | 0.41-0.57 | 0.93 | 0.88-0.96
| | Odds ratio | 13 (7.9-21)

Table 59. Meta-analysis of diagnostic performance of serial myoglobin (2 to 4 hours) to diagnose AMI (ED studies)

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Roxin 1984 | 78/2 | 38/187 | 0.98 | 0.90-1.00 | 0.83 | 0.77-0.88 | 2.6218
Montague 1995 | 25/0 | 15/49 | 1.00 | 0.86-1.00 | 0.77 | 0.64-0.86 | 0.8593
Brogan 1994 | 16/6 | 6/161 | 0.73 | 0.50-0.88 | 0.96 | 0.92-0.99 | 2.7718
Castaldo 1994 | 52/6 | 0/99 | 0.90 | 0.78-0.96 | 1.00 | 0.96-1.00 | 0.8441
Kennedy 1997 | 18/3 | 3/67 | 0.86 | 0.63-0.96 | 0.96 | 0.87-0.99 | 1.7079
Total (range) | 206 | 625 | 0.73-1.00 | | 0.77-1.00
| | REM pooled | 0.90 | 0.78-0.96 | 0.92 | 0.82-0.97
| | Odds ratio | 140 (66-300)

Table 60. Meta-analysis of diagnostic performance of presentation troponin T to diagnose AMI (ED studies)

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Mair 1991 | 13/10 | 3/70 | 0.57 | 0.35-0.76 | 0.96 | 0.88-0.99 | 2.2878
Mair 1996 | 11/28 | 5/57 | 0.28 | 0.16-0.45 | 0.92 | 0.82-0.97 | 3.2498
Hetland 1996 | 24/21 | 12/76 | 0.53 | 0.38-0.68 | 0.86 | 0.77-0.92 | 5.6090
Gust 1998 | 4/12 | 1/51 | 0.25 | 0.08-0.52 | 0.98 | 0.88-1.00 | 1.2144
Hamm 1997 | 24/23 | 55/671 | 0.51 | 0.36-0.66 | 0.92 | 0.90-0.94 | 9.7299
Total (range) | 170 | 1,001 | 0.25-0.57 | | 0.86-0.98
| | REM pooled | 0.44 | 0.32-0.56 | 0.92 | 0.88-0.95
| | Odds ratio | 10 (5.9-18)

Table 61. Meta-analysis of diagnostic performance of rest echocardiography to diagnose ACI (broadened definition of ACI used)

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Kontos 1998 | 15/6 | 22/142 | 0.71 | 0.48-0.88 | 0.87 | 0.80-0.91 | 3.7606
Mohler 1998 | 27/28 | 0/37 | 0.49 | 0.36-0.63 | 1.00 | 0.91-1.00 | 0.8885
Peels 1990 | 22/3 | 4/14 | 0.88 | 0.68-0.97 | 0.78 | 0.52-0.93 | 1.7045
Total (range) | 101 | 219 | 0.49-0.88 | | 0.78-1.00
| | REM pooled | 0.70 | 0.43-0.88 | 0.87 | 0.72-0.94
| | Odds ratio | 20 (9-48)

Table 62. Meta-analysis of diagnostic performance of rest echocardiography to diagnose AMI

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Kontos 1998 | 6/0 | 31/148 | 1.00 | 0.54-1.00 | 0.83 | 0.76-0.88 | 0.7291
Peels 1990 | 12/1 | 14/16 | 0.92 | 0.62-1.00 | 0.53 | 0.35-0.71 | 1.3316
Sabia 1991 | 27/2 | 60/80 | 0.93 | 0.76-0.99 | 0.57 | 0.49-0.65 | 2.4348
Total (range) | 48 | 349 | 0.92-1.00 | | 0.53-0.83
| | REM pooled | 0.93 | 0.81-0.97 | 0.66 | 0.43-0.83
| | Odds ratio | 20 (6.5-62)

Table 63. Meta-analysis of diagnostic performance of sestamibi imaging to diagnose ACI

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Kontos 1997b | 91/23 | 80/338 | 0.80 | 0.71-0.87 | 0.81 | 0.77-0.84 | 14.6350
Stewart 1996 | 6/0 | 28/34 | 1.00 | 0.54-1.00 | 0.55 | 0.42-0.67 | 0.7156
Hilton 1994 | 14/1 | 18/69 | 0.93 | 0.66-1.00 | 0.79 | 0.69-0.87 | 1.4878
Total (range) | 135 | 567 | 0.80-1.00 | | 0.55-0.81
| | REM pooled | 0.81 | 0.74-0.87 | 0.73 | 0.56-0.85
| | Odds ratio | 18 (11-29)

Sestambi scan- broader definition of coronary disease syndrome

Table 64. Meta-analysis of diagnostic performance of sestamibi imaging to diagnose AMI

Study Characteristics and Pooled Results
Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var.
Kontos 1997b | 26/2 | 145/359 | 0.93 | 0.75-0.99 | 0.71 | 0.67-0.75 | 2.5429
Stewart 1996 | 1/0 | 34/33 | 1.00 | 0.03-1.00 | 0.49 | 0.37-0.62 | 0.3269
Hilton 1994 | 12/0 | 20/70 | 1.00 | 0.74-1.00 | 0.78 | 0.68-0.86 | 0.8136
Total (range) | 41 | 661 | 0.93-1.00 | | 0.49-0.78
| | REM pooled | 0.92 | 0.78-0.98 | 0.67 | 0.52-0.79
| | Odds ratio | 26 (6-113)

Figure 15. SROC analysis of serial CK-MB to diagnose AMI (ED, hospital, and CCU studies combined)^ 1 1 Time since presentation to ED of last of serial blood draws, in hours, is labeled; two studies with * time indicates duration of symptoms at last of serial blood draws. (black - ED studies; white - hospitalized studies; grey - CCU studies) ^

Figure 18. SROC analysis of presentation troponin T to diagnose AMI (ED only studies)

Figure 19. SROC analysis of rest echocardiography to diagnose ACI (broadened definition of ACI used - see text)

Figure 20. Studies of rest echocardiography to diagnose AMI^ 1 1 SROC analysis was not performed due to very few data points. ^

Figure 21. SROC analysis of sestamibi perfusion imaging to diagnose ACI

Figure 22. Studies of sestamibi perfusion imaging to diagnose AMI^ 1 1 SROC analysis was not performed due to very few data points. ^

Meta-analysis results of test performance are shown here for prehospital 12-lead ECG, single CK, single and serial CK-MB, myoglobin, troponin T, rest echocardiography, and rest sestamibi.

### Explanations for Summary Receiver Characteristics Analysis Figures

Plotted in each of the SROC graphs are individual studies depicted as ellipses. The x- and y- dimensions of the ellipses are proportional to the square root of the number of patients available to study the specificity and sensitivity, respectively, within the analysis. In some of the figures, the ellipses are labeled with the name and publication year of the study, or the values of a variable (e.g., duration of symptoms in hours for CK enzymes), to provide a reference when the individual studies are mentioned in the discussions about the analyses. In some of the figures, the ellipses may be shaded with more than one density to depict various groupings of the studies. The unweighted SROC curve is displayed only within the range where data are available. The cross (X) represents the random effects average of sensitivity and specificity values of the studies. The x- and y- dimensions of the shaded rectangle represent the 95 percent confidence intervals of the combined specificity and sensitivity, respectively. Additional explanations are provided in the figures as needed.

## Decision and Cost-Effectiveness Analysis

### Introduction

Little information exists to aid ED physicians in the decision as to which test best identifies a patient with ACI among several alternatives or to aid policymakers in the decision as to which tests represent the best value. As some technologies for the diagnosis of ACI are more accurate and also more expensive than others, the tradeoff between cost and effectiveness may give valuable information about decisions on use of specific technologies in the ED.

We developed a decision analytic model to assess outcomes and costs that result from applying different diagnostic strategies to patients presenting to the ED with signs and symptoms suggestive of ACI. The model applies to all adult patients who present to the ED in whom the ED physician suspects UAP or AMI. We evaluated the cost-effectiveness of 17 different strategies and 4 combinations of technologies applied in all ED patients, as well as in a subgroup of low-risk ED patients with possible ACI. The technologies evaluated are those analyzed in this report (see Chapter 3); the combinations of technologies are those that have been reported in the literature.

Assessment of the cost-effectiveness of diagnostic strategies is complex because of the various definitions of effectiveness and the multiple factors that affect it. We attempted to be as inclusive as possible by taking into account both the patient's and payers' perspectives in the overall analysis. For the patient's perspective, we used two definitions of effectiveness: appropriate triage and 30-day survival of patients with ACI. Quality-of-life measures are not included because the model evaluates triage for, and not management of, ACI.

The cost analysis is from the payers' perspective (e.g., health maintenance organizations, commercial insurance companies, and the government). Direct costs associated with the use of the technologies and the triage of ED patients are considered. Indirect costs, such as lost work days, are not included.

The model demonstrates how the diagnostic performance of a technology affects (1) costs, (2) appropriate triage for ACI, and (3) 30-day survival; the model also evaluates the cost-effectiveness and marginal cost-effectiveness of each technology. The cost-effectiveness of a technology is the cost of applying the technology to an ED patient with possible ACI per appropriate triage (hospitalization) for a patient who truly has ACI.

### Methods

#### Overview

The decision analysis applies to the population of ED patients who have signs and symptoms of ACI. The technologies evaluated in the decision analysis are:

1. Serum biomarkers: single and serial CK-MB; single and serial troponin T; troponin I; single and doubling of myoglobin.
2. ECG-based technologies and algorithms: continuous and serial ECG, nonstandard ECG leads, ACI-TIPI, artificial neural network, Goldman chest pain protocol, and stress ECG.
3. Imaging studies: rest and stress echocardiography; rest and stress sestamibi.
4. Combinations of two technologies: single CK-MB and single myoglobin; single CK-MB and serial ECG; single myoglobin and artificial neural network; single troponin T and echocardiography.

The cost-effectiveness of a specific technology is the sum of all the costs incurred by using the technology on a patient presenting to the ED divided by its effectiveness. Effectiveness is defined as either accurate triage for ACI (i.e., hospitalization) or 30-day survival. Although the results of diagnostic testing are rarely used alone to guide triage decisions, the lack of data on how most technologies affect triage of ED patients led us to use diagnostic performance as a proxy for triage accuracy.

Data on diagnostic performance for each technology were obtained from the meta-analyses and pooled results in this report or estimated from values reported in the literature. Sources for cost data included published Medicare reimbursements for patient services and median nationwide physicians fees for technologies. We used published mortality, hospitalization, and prevalence rates from a large study which included all ED patients evaluated for ACI.

Data TreeAge 3.5 software (Williamstown, MA) was used to construct the decision model and perform the cost-effectiveness analyses. Sensitivity analyses on relevant variables were performed to determine the effect of the specific values used and to assess the stability of the results from the base analysis.

Some of the technologies may not apply to all patients, such as patients at high risk for AMI. These patients include those with acute chest pain and significant ST-segment elevation or depression on initial ECG. It is unlikely that such patients would undergo stress ECG or imaging studies. Indeed, the studies that evaluated the diagnostic performance of such technologies explicitly excluded patients with significant ST-segment elevation on initial ECG from study protocols. Furthermore, it is unlikely that stress testing or sestamibi imaging would add significantly to diagnostic decisionmaking in patients with obvious AMI on presenting ECG.

To account for this, we used two models in the decision analysis. The General Population Model, which includes all ED patients, does not include any technologies that could not be applied to all ED patients. Such technologies include all stress testing, sestamibi imaging, continuous and serial ECGs, and technology combinations which use these technologies. We evaluated these technologies in the Subgroup Model which includes ED patients who do not have ST elevation on initial ECG that would preclude them from stress testing and imaging. This population has a lower prevalence of AMI than that of the General Population Model.

The structure, outcomes, and patient dispositions of the two models, the General Population Model and the Subgroup Model, are the same. The models differ in their AMI and ACI prevalences and in the technologies they evaluate. All technologies are evaluated in the Subgroup Model; a subset of technologies is evaluated in the General Population Model. Both models estimate the costs of the outcomes from applying technologies to their respective patient populations.

### Patient Population

The General Population Model applies to all patients who present to the ED with signs and symptoms suggestive of ACI (population category I, described in Chapter 2). The Subgroup Model applies to a subgroup of the General Population Model: lower risk patients who do not have significant ST elevation on initial ECG (population category III).

The values for the prevalence of ACI, 23 percent, and AMI, approximately 8 percent, used in the General Population Model were obtained from the ACI-TIPI trial which evaluated all patients who presented to the ED with possible ACI (Pope, Ruthazer, Beshansky, et al., 1998; Pope, Aufderheide, Ruthazer, et al., 2000). The prevalence of ACI and AMI in the Subgroup Model was estimated by reducing the proportion of AMI patients by the percentage of AMI patients who have significant ST elevation on initial ECG. As approximately 25 percent of AMI patients may have significant ST elevation on initial ECG (Pope, Ruthazer, Beshansky, et al., 1998), we estimated the prevalence of AMI in the Subgroup Model to be 6 percent. The prevalence of UAP remains the same; thus the prevalence of ACI in the Subgroup Model is 21 percent.

### Technology Performance Characteristics

Clinical test results are usually evaluated in the context of the patient's signs and symptoms, physical examination, and the ED physician's suspicion of ACI. Thus, triage decisions by ED physicians incorporate not only test results but clinical assessments as well. Sometimes test results may be ignored because of overwhelming clinical signs and symptoms and/or physicians' intuitions.

However, data on the effect of technologies on ED physicians' triage decisions of patients with possible ACI are very sparse. The ACI-TIPI trial, in which patient triage outcomes with the use of the predictive instrument were compared with triage outcomes without the instrument, is one of the few studies to provide data on the actual impact of a technology on ED patient triage.

As a result, we used the reported sensitivity and specificity of a technology for AMI and ACI as proxies for a test's "clinical impact," i.e., what we considered "triage accuracy." The diagnostic performance of a test may even be thought to represent the technology's optimal performance: how well a technology detects ACI without the added decisionmaking input (correct or incorrect) from an ED physician. The probabilities for appropriate ACI and non-ACI triage for each technology are thus based on the technology's reported diagnostic performance in ED patients, with the notable exception for ACI-TIPI, in which actual patient triage outcomes are available. The diagnostic performance for the four combinations of technologies were obtained from values reported in studies in which the combinations were evaluated.

Assessment of technology diagnostic performance for detection of ACI was determined from studies that applied the technologies to all eligible ED patients. Estimates for technology diagnostic performance for ACI were obtained from the meta-analyses or pooled results found in this report. When data on a technology's diagnostic performance in the ED were not available, values based on reported results in other settings (e.g., admitted ED patients) or on estimates were used.

Evaluation of the diagnostic performance of technologies for AMI is relatively straightforward because the reference standard for AMI in the majority of studies was the WHO criteria (with minor variations). In contrast, data on the diagnostic performance of technologies for the detection of UAP were lacking or particularly difficult to assess because definition and identification of UAP were not reported. In some cases, we used diagnostic performance for the detection of non-AMI "severe" coronary artery disease or the need for revascularization as proxies for unstable angina. Thus, the majority of sensitivity values for UAP are estimates.

Values or estimates for each technology's sensitivity for AMI, UAP and non-ACI (specificity) used in the decision analysis, and the sources from which values or estimates are derived, are shown in Tables 65 to 68.

Table 65. Sensitivity values for serum biomarkers' diagnostic performance used in the decision analysis

Technology | Acute myocardial infarction | | Unstable angina ^1^ | | Nonacute cardiac ischemia
Technology | Base value | Reference | Base value | Reference | Base value | Reference
CK-MB single | 0.44 | Supplemental Analyses: Meta-Analyses | 0.02 | Estimate based on: Hedges, 1987, 1996; Hamm, 1997; Laurino, 1996 | 0.95 | Estimate from Laurino, 1996; Levitt, 1996; Mohler, 1998
CK-MB serial | 0.88 | Supplemental Analyses: Meta-Analyses | 0.05 | Above | 0.95 | Above and Hedges, 1992
Myoglobin initial | 0.5 | Supplemental Analyses: Meta-Analyses | 0.05 | Kennedy, 1997 | 0.9 | Levitt, 1996; Kennedy, 1997; Gilkeson, 1978; Laurino, 1996
Myoglobin doubling | 0.87 | Estimate from pooled analysis (Chapter 3) | 0.2 | Estimate based on troponin data | 0.9 | Estimate based on above
Troponin T initial | 0.53 | Meta-Analysis | 0.2 | Mohler, 1998; Hamm, 1992, 1997 | 0.98 | Mohler, 1998
Troponin T serial | 0.88 | Sayre, 1998; Hamm, 1997 | 0.2 | Mohler, 1998; Hamm, 1997 | 0.98 | Estimate based on Green, 1998; Mohler, 1998
Troponin I | 0.35 | Mair, 1996; Tucker, 1997; Brogan, 1997; Hamm, 1997 | 0.2 | Mair, 1996; Hamm, 1997 | 0.98 | Hamm, 1997; Kontos, 1999b

1 Some values estimated from data on diagnostic performance for detection of coronary artery disease or similar endpoint because of sparse data on diagnostic performance for the detection of UAP specifically.

Table 66. Sensitivity values for imaging studies' diagnostic performance used in the decision analysis

Technology | Acute myocardial ischemia | | Unstable angina | | Nonacute cardiac ischemia
Technology | Base value | Reference | Base value | Reference | Base value | Reference
ECHO rest | 0.93 | Supplemental Analyses: Meta-Analyses | 0.35 | Sasaki, 1986; Mohler, 1998 | 0.66 | Estimate from meta-analysis
ECHO stress | 0.93 | Estimated from Trippi, 1996 | 0.5 | Estimate from Trippi, 1997 | 0.89 | Trippi, 1996
Sestamibi rest | 0.93 | Supplemental Analyses: Meta-Analyses | 0.75 | High estimate based on Hilton, 1994; Kontos, 1999b; Varetto, 1993 | 0.77 | Meta-analysis
Sestamibi stress | 0.99 | Estimate based on Stewart, 1996 | 0.75 | Above | 0.99 | Estimate based on Hilton, 1994; Kontos, 1999b; Varetto, 1993

Table 67. Sensitivity values of diagnostic performance of ECG-based technologies and algorithms used in the decision analysis

Technology | Acute myocardial ischemia | | Unstable angina | | Nonacute cardiac ischemia
Technology | Base value | Reference | Base value | Reference | Base value | Reference
Exercise ECG | 0.99 | Estimate based on Kirk, 1998; Lewis, 1999 | 0.6 | Lewis, 1999; Garber, 1999 | 0.77 | Kirk, 1998; Lewis, 1999; Tsakonis, 1991; Garber, 1999
ACI-TIPI | 0.98 | Selker, 1998 | 0.97 | Selker, 1998 | 0.43 | Selker, 1998
Goldman chest pain protocol | 0.89 | Goldman, 1982, 1988; Poretsky, 1985 | 0 | Not intended for detection of UAP | 0.7 | Estimate based on Goldman, 1982, 1988; Poretsky, 1985
Continuous/serial ECG | 0.4 | Estimate based on: Hedges, 1992; Fesmire, 1998 | 0.2 | Estimate based on Gibler, 1995 | 0.95 | Fesmire, 1998; Gibler, 1995
Nonstandard ECG leads | 0.7 | Estimate based on Justis, 1992; Zalenski, 1993, 1997b | 0.2 | Estimate ^1^ | 0.85 | Estimate based on Justis, 1992; Zalenski, 1993, 1997b
Artificial neural network | 0.95 and 0.5 ^2^ | Baxt, 1991, 1996; Kennedy, 1997 | 0.23 | Kennedy, 1997 | 0.83 | Kennedy, 1997

1 Estimated from data on diagnostic performance for detection of coronary artery disease or similar endpoint because of sparse data on diagnostic performance for the detection of UAP specifically.

2 Two different values used: for General Population Model, sensitivity for AMI is 0.95 (Baxt, 1991, 1996); for Subgroup Model, sensitivity for AMI is 0.5 (Kennedy, 1997).

Table 68. Sensitivity values of combination technologies' diagnostic performance used in the decision analysis

Technology | Acute myocardial infarction | | Unstable angina | | Nonacute cardiac ischemia
Technology | Base value | Reference | Base value | Reference | Base value | Reference
CK-MB (single) & myoglobin (single) | 0.7 | Estimate based on Levitt, 1996; Montague, 1995; Kontos, 1997a, 1999a | 0.3 | Estimate ^1^ | 0.9 | Levitt, 1996
Troponin T (single) & ECHO | 0.99 | Mohler, 1998 | 0.5 | Estimate based on Mohler, 1998 | 0.9 | Estimate based on Mohler, 1998
CK-MB (single) & serial ECG | 0.79 | Hedges, 1992 | 0.5 | Estimate ^1^ | 0.85 | Hedges, 1992
Myoglobin (single) & artificial neural network | 0.8 | Estimate based on Kennedy, 1997 | 0.4 | Estimate based on Kennedy, 1997 | 0.56 | Estimate based on Kennedy, 1997

1 Some values estimated from data on diagnostic performance for detection of coronary artery disease or similar endpoint because of sparse data on diagnostic performance for the detection of UAP specifically.

### Outcomes

The model evaluated cost-effectiveness separately for each of two outcomes: triage accuracy and 30-day survival of patients with ACI. Quality-adjusted life-years were not used, since the focus of the analysis was appropriate triage for ACI and not long-term management of ACI.

Triage accuracy of the technologies for patients with ACI was defined as the number or proportion of patients with ACI appropriately admitted to the hospital from the ED. Admission was considered appropriate and ED discharge was considered inappropriate triage for patients with ACI.

Thirty-day survival was similarly defined: the number of patients with ACI who survived to 30 days. The probability of 30-day survival is calculated from mortality data for patients with ACI admitted to the hospital or discharged from the ED from the large ACI-TIPI trial (Pope, Aufderheide, Ruthazer, et al., 2000).

Appropriate triage and survival of patients with ACI were assigned a utility value of 1. Inappropriate triage and death of patients with ACI were assigned a value of 0. Variable values for the probabilities used in the decision analysis are shown in Table 69.

Table 69. Transition probabilities

Variable | Base value | Reference
Prevalence of ACI | General Model: 23% Subgroup Model: 21% | Maynard, 1996; Pope, 1998
Prevalence of UAP | Both models:15% | Pope, 1998
Prevalence of AMI | General Model: 8.4% Subgroup Model: 6% | Maynard, 1996; Pope, 1998
Subsequent hospitalization rate within 30 days for missed AMI | 72% | Pope, 2000
Subsequent hospitalization rate within 30 days for missed UAP | 42% | Pope, 2000
30-day survival rate for hospitalized patients with AMI | 89% | Pope, 2000
30-day survival rate for hospitalized patients with UAP | 98% | Pope, 2000
30-day survival rate for patients with AMI discharged from the ED | 89% | Pope, 2000
30-day survival rate for patients with UAP discharged from the ED | 96% | Pope, 2000
Percentage of patients with untreated UAP who develop AMI within 30 days | 5% | Estimate based on expert opinion and National Cooperative Study Group. 1981, and Krauss, 1972
Subsequent hospitalization rate for patient without ACI discharged from the ED | 10% | Analysis of ACI-TIPI data
Value of appropriate triage or survival for patients with ACI | 1 | Decision analysis
Value of inappropriate triage or death for patients with ACI | 0 | Decision analysis

1 From the Physicians' Fee Reference, 1999; all values are the median nationwide fees.

2 PFR data not available; cost for test at New England Medical Center, Boston.

3 No separate billing code for nonstandard ECG; cost is that of a standard ECG.

4 This is the cost for an ECG as there is no additional cost for an ECG with the ACI-TIPI prediction output. Unless otherwise noted in the text, the cost for ACI-TIPI is that of an ECG.

### Patient Disposition

The disposition of a patient who enters the ED is determined by the technology applied, the result of the test, the subsequent triage and followup evaluation, and the probabilities associated with survival or death from appropriately or inappropriately triaged ACI. This is detailed in the Description of the Decision Analysis section below. Values for probabilities affecting patient disposition, such as mortality and hospital admission rates, were obtained from the large ACI-TIPI trial or based on expert opinion and are shown in Table 69.

We did not include complications to patients that may arise from use of some of the technologies, such as stress testing, because of the extremely low rate of clinically significant complications and because we used a model to account for the subgroup of patients at higher risk of complications.

The rate of complications from stress testing, for example, is extremely low: As reported in the previous NHAAP report, in a national survey of ECG exercise testing, Stuart and Ellestad (1980) reported fewer than 1 death per 10,000 patients tested and overall morbidity (including clinically significant and insignificant arrhythmias and hypotension, some of which may have occurred regardless of stress testing) of 0.05 percent. None of the studies of stress sestamibi, ECG, or echocardiography stress testing evaluated in this report reported deaths or significant morbidity (complications that altered the care given to a patient).

We also accounted for the likely possibility of higher rates of complications from stress testing in a certain subgroup of patients with obvious ECG signs of ACI, such as T-wave inversion or ST elevation, or patients with severe clinical symptoms. Thus, these patients are only included in the General Population Model which does not include stress testing.

### Costs

All costs used in the model are those that result from applying the technology to an ED patient and are incurred by the payer. The values for costs reflect the reimbursement to the hospital or outpatient clinic for patient services. The costs of the technology and subsequent management of a patient contribute to the total cost for each diagnostic strategy. The costs of subsequent management depend on a patient's disposition (discussed below) and may include costs of admission to the hospital, outpatient followup, return visits to the ED, and death from "missed" AMI or UAP. Costs associated with death of a patient with AMI or UAP inappropriately discharged from the ED range from a minimum of $600 for a return ED visit and resuscitation attempt to $2 million for a malpractice settlement case.

The cost of a technology represents a component of the total cost incurred by using the technology to determine triage for a patient with suspected ACI in the ED. Of note, ACI-TIPI was evaluated at two costs, $0 and $68, because ACI-TIPI may not be incorporated into all ECG machines in an ED. If the initial ECG performed in the ED has the ACI-TIPI printout, then there is no additional cost for the technology (the initial ECG is not included as an extra cost in the decision analysis). If a second ECG is required because the initial ECG does not provide the predictive instrument printout, then the cost for this ECG is considered the cost for ACI-TIPI.

Unless noted otherwise, all analyses were performed using the more conservative cost, the cost for an ECG ($68), for ACI-TIPI. Sensitivity analyses on the cost of ACI-TIPI were also performed and are described below.

Total costs do not include the reimbursement for the initial ED visit unless the patient is discharged from the ED, as the reimbursement for the ED visit for an admitted patient is usually included in the reimbursement for the admission. As the standard of care is to obtain an ECG on all ED patients evaluated for ACI, the cost of an initial ECG was not included in the analysis. Professional fees for administering the tests and ED and outpatient visits are included in total costs. Discounting was unnecessary because of the short time horizon of the analysis.

Reimbursement rates for the technologies are taken from the Physicians' Fee Reference (1999), a compendium of nationwide fees for procedures and interventions charged by physicians and hospitals. We used the median nationwide fee charged for each technology because many payers reimburse only up to the 60^th^ percentile. All costs include the physician report and interpretation. For strategies that used a combination of two technologies, the costs for each technology were added. The costs of the technologies used in the analysis are shown in Table 70.

Table 70. Costs for technologies^1^

Technology and combinations | Costs ($)
CK-MB single | 45
CK-MB serial | 90
Myoglobin at time of ED presentation | 55
Myoglobin doubling | 110
Troponin T at ED presentation | 56 ^2^
Troponin T serial | 112
Continuous/serial ECG | 297
Nonstandard ECG leads | 68 ^3^
ACI-TIPI | 68 ^4^
Goldman criteria | 0
Artificial neural network | 0
Exercise ECG | 296
ECHO rest | 379
ECHO stress | 929 (rest and stressed bundled)
Sestamibi rest | 834
Sestamibi stress | 1,130
Combination: CK-MB and myoglobin | 100
Combination: CK-MB and serial ECG | 342
Combination: Myoglobin and artificial neural network | 55
Combination: Troponin T and ECHO rest | 435

1 From the Physicians' Fee Reference, 1999; all values are the median nationwide fees.

2 PFR data not available; cost for test at New England Medical Center, Boston.

3 No separate billing code for nonstandard ECG; cost is that of a standard ECG.

4 This is the cost for an ECG as there is no additional cost for an ECG with the ACI-TIPI prediction output. Unless otherwise noted in the text, the cost for ACI-TIPI is that of an ECG.

Reimbursement rates for hospital admission were based on the average national payments for the diagnosis-related group (DRG) codes. The reimbursement rate for an ED visit for a patient with suspected ACI was obtained from actual ED patient visits to the New England Medical Center between October 1998 and May 1999. Outpatient visit reimbursements were calculated from median fees for tests performed as part of the outpatient workup and the average national payment for the professional component of the outpatient visit.

The costs and calculations for all total costs for each patient disposition are shown in Table 71.

Table 71. Factors involved in calculating total costs^1^

Patient disposition | Factors involved in total cost calculation | Cost ($)
Patient with ACI appropriately triaged (admitted) | Costs of: technology + admission | Varies
Patient with ACI inappropriately discharged, dies | Costs of: technology + ED visit + return ED visit (resuscitation attempt) + missed ACI ^2^ | Varies
Patient with AMI inappropriately discharged, survives | Cost of: technology + ED visit + subsequent admission or outpatient workup | Varies
Patient with UAP inappropriately discharged, develops AMI, survives | Costs of: technology + ED visit + subsequent hospitalization for AMI | Varies
Patient with UAP, inappropriately discharged, survives | Costs of: technology + ED visit + subsequent outpatient workup or subsequent admission | Varies
Non-ACI patient admitted for ACI treatment | Costs of: technology + 23-hr observation (ruled out for AMI) | Varies
Non-ACI patient discharged from ED | Costs of: technology + ED visit + outpatient workup or subsequent admission | Varies
Non-ACI admission (23-hr observation) | | 2,158
Admission for ACI | Average of an average admission for an uncomplicated AMI ($4,627) and admission for UAP with angiography ($4,155) | 4,400
Initial and return ED visits | Includes all services provided by the ED, including resuscitation attempts if necessary | 600
Outpatient visit | Includes professional fee and cost of exercise ECG | 430
Outpatient visit for patients with negative exercise ECG in ED | Includes professional fee and cost of stress sestamibi scan | 1,260
Outpatient visit for patients with negative stress sestamibi scan in ED | Professional fee only | 130

1 Values for patients' services obtained from average Medicare reimbursements based on DRG codes.

2 Costs associated with a missed ACI death include: cost for malpractice settlement or cost of a trial.

### Methods of Comparison

The diagnostic strategies were ranked by order of overall cost. The strategies that were both more expensive and less effective than another strategy were eliminated by strict dominance. The marginal cost-effectiveness of a strategy, or the additional cost per additional effectiveness, was compared with its less costly alternative among the remaining strategies. The analyses included evaluation of the total costs associated with 30-day survival and appropriate triage for patients with ACI.

### Description of the Decision Analysis

The decision analysis represents the possible dispositions and triage outcomes that may occur for a patient with signs and symptoms of ACI evaluated in the ED. The possible patient dispositions and triage outcomes are shown in Figure 23, which represents the basic decision model used in the analysis. All outcomes and dispositions are those that occur within 30 days of initial evaluation in the ED. All strategies, a total of 21, are evaluated in the Subgroup Model. All biomarkers, algorithms, nonstandard ECGs, ACI-TIPIs, echocardiography, and the combinations of CK-MB-myoglobin, and troponin T-echocardiography are evaluated in the General Population Model.

Figure 23 Decision Tree

Shown is one decison node branch of the tree. Each technology represents a decision node, or option. The branches emanating from a chance node, depicted by a circle, represent the possible outcomes that could occur. The possible outcomes are determined by the probabilities assigned to each branch of a chance node. The number of patients at each of the terminal nodes, from a cohort of 1000 ED patients, is determined by the probabilities of all choices that occurred along the way.

ED D/C: EDdischargeOPD: Out-patient

* Determined by prevalence of AMI and UAP in population of ED patients

The following are the possible patient dispositions that may occur in the decision analysis:

1. A patient with signs and symptoms of ACI is admitted to the ED at which time the ED physician may apply 1 of the 21 diagnostic strategies evaluated in this analysis. This is the only decision point in the tree. All subsequent patient dispositions and outcomes are determined by the prevalence of ACI in the ED population, the triage accuracy of the technology applied, and the probabilities of survival from appropriately or inappropriately triaged UAP and AMI.
2. The probability that a patient has ACI is determined by the prevalence of AMI and UAP.
3. A patient with ACI may either be admitted for management of ACI ("appropriate" triage) or may be sent home from the ED ("inappropriate" triage) based on the results of the diagnostic technology the ED physicians decide to use. A positive test result leads to admission; a negative test result leads to discharge from the ED.
4. A patient with UAP and AMI who is admitted will either survive or die. Although this outcome does not depend on the technology used to detect the ACI, it is included in the model to show the difference in death rates in those with ACI appropriately admitted and those inappropriately discharged from the ED.
5. A patient with AMI who is discharged from the ED may either survive or die. Those who survive will return for either hospital admission or outpatient evaluation within 30 days.
6. A patient with UAP who is discharged from the ED may either survive or die. Those who survive may: (a) develop an AMI and survive or die, or (b) might not develop an AMI. A patient who develops an AMI and survives will subsequently return for hospital admission. A patient who does not develop an AMI (and does not die from UAP) will either return for hospital admission or have an outpatient workup.
7. A patient without ACI may be either admitted for ACI management (because of a false positive test result) or discharged appropriately (true negative test result). Some patients without ACI, however, continue to have symptoms even after appropriate discharge from the ED. A proportion of these patients will continue to seek care and may be admitted later (during the 30-day period) to the hospital for evaluation or will have outpatient followup. All patients without ACI, admitted or discharged from the ED, survive the 30-day period.
8. A patient without ACI who is admitted appropriately for a recognized non-ACI condition is not included in the analyses because of the great uncertainty in modeling the costs and outcomes of this disposition.

The 15 possible patient dispositions are summarized below:

- AMI detected and patient admitted: patient survives.
- AMI detected and patient admitted: patient dies.
- AMI missed: patient dies.
- AMI missed, patient survives: returns for admission.
- AMI missed, patient survives: outpatient workup.
- UAP detected and patient admitted: patient survives.
- UAP detected and patient admitted: patient dies.
- UAP missed: patient dies.
- UAP missed: patient develops AMI and dies.
- UAP missed: patient develops AMI and survives and returns for admission.
- UAP missed: UAP continues and patient returns for admission.
- UAP missed: UAP continues and patient returns for outpatient workup.
- Non-ACI detected: patient discharged from ED and has outpatient workup.
- Non-ACI detected: patient discharged from ED and returns for admission.
- Non-ACI incorrectly diagnosed as ACI: patient admitted for ACI management.

### Model Assumptions

#### Patient Population

- General Population Model: patients have signs and symptoms suggestive of unstable angina or myocardial infarction; no patients are excluded.
- Subgroup Model: same population as General Population Model excluding patients who have ST elevation on initial ECG; this represents a lower risk population.
- Both models include patients who may present without chest pain.
- The model does not apply to patients who are in cardiac arrest or in whom life-saving measures need to be applied.
- Patients who have stable angina are considered not to have ACI; they are included in the non-ACI group.
- All patients are able to undergo any of the technologies evaluated in the decision analysis.

#### Costs

- All patients are given the same treatment in the ED, other than the diagnostic test, so the cost for an ED visit is the same for all patients.
- The cost for hospitalization of a patient with UAP is the same as for a patient with AMI to prevent penalizing appropriate admission for AMI and to provide for the possibility of cardiac angiography for a patient with UAP. This assumption was also based on the similar hospital reimbursements for uncomplicated AMI ($4,627) and UAP with cardiac angiography ($4,155) admission.
- The cost for ACI-TIPI is assumed to be the cost for an ECG ($68) unless otherwise noted (discussed above).
- The cost for death of a patient with AMI or UAP discharged form the ED is the cost of a return ED visit and resuscitation attempt ($600) in the base analysis and increases to the cost of a typical malpractice settlement ($2 million) in the sensitivity analyses.

#### Diagnostic Technologies

- All test results are either positive or negative. A nondiagnostic test is considered negative.
- A positive test result for combination technologies requires that either test be positive.
- A negative test result for combination technologies requires that both tests be negative.
- There are no complications from biomarker, algorithm, ECG-based, or rest-imaging technologies, as no study reported complications from these technologies. There are no complications from the stress technologies (exercise ECG, stress imaging) because these technologies are applied only to the subgroup of ED patients who have AMI excluded on initial ECG and because no studies reported significant complications from these technologies.
- Only patients in the Subgroup Model undergo sestamibi imaging or stress or serial/continuous ECG tests.
- Stress testing may be physiological (exercise), or pharmacological (dobutamine).
- The model does not account for patients who are unable to undergo exercise ECG. ED physicians may choose which of the remaining strategies to apply to these patients.
- All patients who return for an outpatient workup because of a negative test result undergo exercise stress testing for evaluation of their symptoms (expert opinion).
- Patients who have a negative exercise test in the ED and return for outpatient followup undergo sestamibi stress testing.
- Patients who have a negative stress sestamibi scan in the ED and return for outpatient evaluation do not undergo further testing because the negative predictive value of stress sestamibi scan is very high (expert opinion).

#### Effectiveness

- The effectiveness of a technology is determined by the proportion of patients who are given the appropriate triage.
- Appropriate triage is hospital admission for ACI and discharge home or non-ACI treatment for non-ACI patients.
- Appropriate triage for UAP is hospital admission because early therapy during a high-risk period may prevent complications and/or progression to AMI.
- Inappropriate triage is discharge from the ED for ACI patients or admission to the hospital for ACI treatment for non-ACI patients.
- Triage of ED patients is determined by the results of the test.
- Patients who have a positive test result, or a test result that implies a high likelihood of ACI, are admitted to the hospital for ACI treatment. These patients may have either a true positive or a false positive test result.
- Patients who have a negative test result, or a test result that indicates a very low likelihood of ACI, are not admitted to the hospital for ACI treatment. These patients may have either a true negative or a false negative test result.

#### Patient Disposition

- No patients die in the ED during the initial visit.
- Patients with ACI who are admitted are considered to have definitive evaluation for their condition during hospitalization.
- All patients with ACI who are inappropriately discharged from the ED may: (1) be admitted subsequently to the hospital for evaluation, (2) undergo outpatient diagnostic testing, or (3) die.
- Admitted patients who do not have ACI are admitted for a "rule-out MI" protocol (a 23-hour observation hospitalization).
- Patients with non-ACI who are admitted are considered to have a definitive evaluation of their condition and therefore do not return for further followup.
- Patients who do not have ACI and who are admitted for treatment of a non-ACI condition have appropriate triage and no additional costs.

### Results

The results are presented in the following order:

1. Description of costs of technologies and total costs.
2. General Population Model: triage accuracy, results of cost-effectiveness analysis, sensitivity analysis.
3. Subgroup Model: triage accuracy, results of cost-effectiveness analysis, sensitivity analysis.
4. Survival outcome results.
5. Sensitivity analysis on cost of ACI-TIPI.

#### Technology Costs and Total Costs

The cost for a technology makes up a component of the total costs incurred by applying the technology to a population of ED patients. The ratio of total cost associated with a technology to the cost of the technology itself decreases exponentially as the cost of a technology increases (Figure 24). This pattern indicates that the proportion of total costs from using a less costly technology (such as a serum biomarker) is much smaller compared with using a more costly technology (such as an imaging study) in which nearly half the total cost is the cost of the technology itself. The relationship between total costs and the effectiveness of technologies is discussed in detail below.

Figure 24. Cost of technology and ratio of total costs to technology cost

A: ACI-TIPI; AN: artificial neural network; CK: CK-MB, single; CE: continuous/serial ECG; CS: CK-MB, serial; ER: resting ECHO; ES: stress ECHO; ET: exercise ECG; G: Goldman chest pain protocol; I: troponin I; M: Myoglobin initial; MD: Myoglobin doubling; NS: nonstandard ECG; SES: stress sestamibi; SR: resting sestamibi; T: troponin T, initial; TS: troponin T serial; 1: CK-MB and Myoglobin; 2: myoglobin and artificial neural network; 3: CK-MB and serial ECG; 4: troponin T and ECHO.

#### General Population Model

This model estimates the total costs associated with the use of technologies that can be applied to any patient in the ED with signs and symptoms of ACI. The prevalence of ACI in this population is 23 percent; 8 percent of patients have AMI. A test with perfect sensitivity results in appropriate triage of 230 patients with ACI per 1,000 ED patients evaluated for ACI and has an effectiveness value of 0.23.

##### Triage Accuracy

Figure 25 shows the rankings of technologies by percentage of patients with ACI inappropriately discharged from the ED. The biomarkers perform poorly, primarily because of their inability to detect UAP. The range of missed ACI is 83 percent for a single CK-MB value to 56 percent for serial troponin T. Serial testing or combination of biomarkers improves sensitivity. Of the biomarkers, troponin T appears to have the best triage accuracy for ACI. Troponin T and myoglobin perform better than CK-MB, primarily because their estimates for UAP detection are higher than that of CK-MB; however, estimates for detection of UAP are based on few studies (see Sensitivity Analysis, below).

Figure 25. General population model: Technology rankings by percent inappropriate triage (ED discharge) of patients with ACI at ACI prevalence of 23 percent

ANN: Artificial neural network applied in general ED population.

Nonstandard ECG is better than the single biomarkers, but not as effective as serial troponin T or myoglobin doubling. The artificial neural network performs better than any of the biomarkers; however, prospective trials of its actual performance in the general ED population have not been performed. Although the Goldman chest pain protocol has very good sensitivity for AMI, it is not designed to identify patients with UAP; thus, its triage accuracy for patients with both AMI and UAP is much lower than that for patients with AMI. The combination of troponin T-echocardiography, the technology with the best diagnostic performance, leads to appropriate triage of 68 percent of patients with ACI.

If data from clinical impact studies are used, ACI-TIPI has the best triage accuracy: In a large clinical trial, use of ACI-TIPI did not change the 97-percent triage accuracy for patients with ACI of ED physicians (whose decisions may have incorporated the results of various and multiple technologies).

##### Cost-Effectiveness Analysis

The cost-effectiveness of a technology, which represents the total costs associated with the technology divided by its effectiveness (appropriate triage for ACI) reflects the tradeoff between costs and effectiveness. The results of the cost-effectiveness analysis for appropriate triage for patients with ACI are shown in Table 72. As expected, technologies with the best diagnostic accuracy for both AMI and UAP have the highest values for appropriate triage for patients with ACI (see ACI Triage [%] column). Figure 26 shows the number of patients with ACI appropriately triaged and the costs associated with applying a technology to 1,000 ED patients.

Table 72. General population model: Cost-effectiveness of technologies for appropriate triage for patients with ACI

Technology | Cost ^1^ | ACI triage ^2^ | CE ^3^ | Marginal CE ^4^ | No. ACI triage/1,000 ED patients ^5^ | ACI triage(%) ^6^
CPK-MB single | $1,728 | 0.039 | $43,877 | | 39 | 17
Troponin I | $1,754 | 0.058 | $30,016 | $1,358 | 58 | 25
Troponin T initial | $1,769 | 0.073 | $24,129 | $1,049 | 73 | 32
Myoglobin initial | $1,787 | 0.049 | $36,652 | (Dominated) | 49 | 21
CK-MB serial | $1,818 | 0.080 | $22,666 | $7,129 | 80 | 35
Troponin T serial | $1,856 | 0.102 | $18,138 | $1,686 | 102 | 44
Neural network | $1,868 | 0.113 | $16,597 | $1,162 | 113 | 49
Nonstandard ECG | $1,892 | 0.087 | $21,643 | (Dominated) | 87 | 38
Goldman | $1,901 | 0.074 | $25,793 | (Dominated) | 74 | 32
Myoglobin doubling | $1,912 | 0.101 | $18,838 | (Dominated) | 101 | 44
CK-MB & myoglobin | $1,912 | 0.102 | $18,720 | (Dominated) | 102 | 44
Troponin T & ECHO | $2,322 | 0.156 | $14,923 | $10,558 | 156 | 68
ACI-TIPI (at cost $0) | $2,349 | 0.224 | $10,489 | $397 | 224 | 97
ECHO rest | $2,400 | 0.129 | $18,670 | (Dominated) | 129 | 56
ACI-TIPI (at cost $68) | $2,417 | 0.224 | $10,790 | $1,397 | 224 | 97

1 Total cost of applying technology to one ED patient with possible ACI (includes costs of technology, hospitalization, and/or return ED visits and/or outpatient followup).

2 "Effectiveness" value: probability of appropriate triage for ACI for an ED patient at ACI prevalence of 23 percent.

3 Cost-effectiveness ratio: total cost of applying technology to one ED patient with possible ACI divided by probability of appropriate triage for ACI. Calculated values may differ because of rounding.

4 Marginal cost-effectiveness: ratio of difference in costs to difference in effectiveness between two adjacent nondominated strategies.

5 Number of patients with ACI appropriately triaged per 1,000 ED patients.

6 Percent appropriate triage for patients with ACI.

Figure 26. General population model: Cost of applying technology to 1,000 ED patients and number of patients appropriately triaged for ACI at 23 percent prevalence of ACI (reference line)

A: ACI-TIPI at a cost of $0; A68: ACI-TIPI at a cost of $68; AN: artificial neural network applied in general ED population; CK: CK-MB, single; CS: CK-MB, serial; ER: resting ECHO; G: Goldman protocol; I: Troponin I; M: Myoglobin initial; MD: myoglobin doubling; NS: nonstandard ECG; T: troponin T, initial; TS: troponin T serial; 1: CK-MB and myoglobin; 4: troponin T and ECHO.

Technologies that are more effective (greater number of patients with ACI appropriately triaged) tend to have higher total costs, with the exception of ACI-TIPI. The biomarkers are least costly and have the lowest values for appropriate triage. The CE of troponin T-echocardiography is lower than that of the biomarkers because, although it has higher total costs, its better triage accuracy "outweighs" the higher costs.

Based on data using the diagnostic performance of technologies, the combination technology troponin T-echocardiography has the best CE of all technologies in the General Population Model. If results from clinical impact studies are incorporated, ACI-TIPI has the best CE because of its very high triage accuracy and low cost.

The combination of troponin T-echocardiography results in appropriate triage for about 55 more patients with ACI (per 1,000 ED patients) than serial troponin T, myoglobin doubling, or the combination of single CK-MB and single myoglobin. The total per ED patient cost for troponin T-echocardiography is $2,322 compared with about $1,900 for serial or combination biomarkers. Thus, troponin T-echocardiography costs approximately $422 more per ED patient but results in appropriate triage for 55 more patients with ACI (per 1,000 ED patients) compared with serial or combination biomarkers. The incremental CE between troponin T-echocardiography and serial or combination biomarkers is about $7,670: it costs about $7,670 more per additional appropriate triage for a patient with ACI using the combination of troponin T-echocardiography compared with the serial or combination biomarkers.

The next most effective technology is the artificial neural network applied in a general ED population. The per ED patient cost of applying the artificial neural network is $1,868, about $455 less than the combination troponin T and echocardiography; however, 43 fewer patients with ACI (per 1,000 ED patients) are appropriately triaged. The incremental cost-effectiveness between troponin T-echocardiography and the artificial neural network is approximately $10,568. This incremental CE is greater than that between the serial biomarkers and troponin T-echocardiography because the difference in triage accuracy between the artificial neural network and troponin T-echocardiography is smaller than the difference between the serial biomarkers and troponin T-echocardiography. Given the economic ramifications and the effects on the patient of a missed ACI diagnosis, the incremental CE for troponin T-echocardiography is minimal.

Cost-effectiveness rankings of the technologies are shown in Figure 27.

Figure 27. General population model: Total cost of applying technology to 1,000 ED patients per appropriate triage for one patient with ACI at 23 percent prevalence of ACI

Numbers in bars represent the cost-effectiveness ratio.

* Artificial neural network applied in general ED population.

ACI-TIPI: at cost of an ECG ($68); ACI-TIPI $0: ACI-TIPI at cost of $0.

##### Sensitivity Analysis

###### Triage accuracy and cost-effectiveness for AMI only

Because the estimates for technology sensitivity for UAP are based on sparse data, we evaluated the triage accuracy and cost-effectiveness of technologies for appropriate triage for patients with AMI only. Figure 28 shows the triage accuracy rankings of technologies for patients with AMI. There are few but important differences in triage accuracy for AMI: (1) the Goldman chest pain protocol improves significantly, (2) serial CK-MB improves slightly, and (3) the combination of troponin T-echocardiography is slightly more accurate than ACI-TIPI (a difference of one patient with AMI appropriately triaged).

Figure 28. General population model: Technology rankings by percent inappropriate triage (ED discharge) of patients with AMI at AMI prevalence of 8 percent

ANN: Artificial neural network applied in general ED population.

Table 73 shows the cost-effectiveness and marginal cost-effectiveness for the technologies. The combination of troponin T-echocardiography is the most cost-effective, followed by the artificial neural network and serial CK-MB. The incremental CE between the two most cost-effective technologies is much larger than that in the general ACI model: approximately $137,000 per additional appropriately triaged patient with AMI. The incremental CE between troponin T-echocardiography and serial CK-MB, the third most cost-effective strategy, is approximately $56,000 per additional appropriately triaged patient with AMI, less than half that between troponin T-echocardiography and artificial neural network. Troponin T-echocardiography results in nine additional appropriate triages for patients with AMI compared with CK-MB, but only three additional appropriate triages for patients with AMI compared with the neural network.

Table 73. General population model: Cost-effectiveness of technologies for appropriate triage for patients with AMI

Technology | Cost ^1^ | Marginal cost | AMI triage ^2^ | Marginal effectiveness | CE ^3^ | Marginal CE ^4^ | AMI triage (%) ^5^
CK-MB single | $1,728 | | 0.03640 | | $47,423 | | 44
Troponin I | $1,754 | $26 | 0.02900 | 0.0075 | $60,509 | (Dominated) | 35
Troponin T initial | $1,769 | $42 | 0.04390 | 0.0075 | $40,315 | $5,568 | 53
Myoglobin initial | $1,787 | $18 | 0.04140 | 0.0025 | $43,168 | (Dominated) | 50
CK-MB serial | $1,818 | $49 | 0.07290 | 0.0290 | $24,956 | $1,697 | 88
Troponin T serial | $1,856 | $37 | 0.07290 | 0.0000 | $25,467 | (Dominated) | 88
Neural network | $1,869 | $50 | 0.07870 | 0.0058 | $23,754 | $8,641 | 95
Nonstandard ECG | $1,892 | $23 | 0.05800 | 0.0207 | $32,636 | (Dominated) | 70
Goldman | $1,903 | $34 | 0.07370 | 0.0050 | $25,823 | (Dominated) | 89
Myoglobin doubling | $1,912 | $43 | 0.07200 | 0.0066 | $26,536 | (Dominated) | 87
CK-MB & myoglobin | $1,912 | $43 | 0.05800 | 0.0207 | $32,982 | (Dominated) | 70
Troponin T & ECHO | $2,322 | $454 | 0.08200 | 0.0033 | $28,326 | $136,925 | 99
ECHO rest | $2,402 | $80 | 0.07700 | 0.0050 | $31,198 | (Dominated) | 93
ACI-TIPI | $2,417 | $95 | 0.08110 | 0.0008 | $29,782 | (Dominated) | 98

1 Total cost of applying technology to one ED patient with possible ACI (includes costs of technology, hospital admission, and/or return ED visits and/or outpatient followup).

2 "Effectiveness" value: the probability of appropriate triage for AMI for an ED patient at AMI prevalence of 8 percent.

3 Cost-effectiveness ratio: total cost of applying technology to an ED patient with possible ACI divided by the probability of appropriate triage for a patient with AMI. Calculated values may be different due to rounding.

4 Difference in costs divided by difference in effectiveness between a strategy and the next nondominated most effective strategy.

5 Percent appropriate triage for patients with ACI.

###### Prevalence of ACI

To determine the effect of varying ACI prevalence, sensitivity analysis on the prevalence of ACI was performed. As the prevalence of ACI increases, the total cost per patient of applying a technology increases, as expected. The value associated with effectiveness (appropriate triage for ACI) also increases because as prevalence increases, the proportion of patients with ACI increases, increasing the positive predictive value of a test. The CE of the various strategies decreases in an exponential fashion as shown in Figure 29. As prevalence increases, the differences in cost effectiveness of the technologies become smaller because costs do not increase as much as triage accuracy. However, there is little change in relative cost effectiveness of the technologies: At a prevalence as high as 90 percent, ACI-TIPI retains its dominant cost-effectiveness, followed by troponin T-echocardiography and the artificial neural network.

Figure 29. General population model: Cost per appropriate triage for patients with ACI as prevalence of ACI changes

Shown are the five most effective technologies. Reference lines show range of ACI prevalence most commonly encountered in ED (17-25 percent).

#### Subgroup Model

This model estimates the costs and effectiveness of applying technologies to a population of ED patients with signs and symptoms of ACI who have a nondiagnostic initial ECG. The prevalence of ACI in this population is 21 percent; 6 percent of patients have AMI. All technologies can be applied to this population, and thus all imaging studies, stress testing, and serial ECG are included.

##### Triage Accuracy

Figure 30 shows the triage accuracy of the technologies applied in the Subgroup Model. The biomarkers have poor triage accuracy. Even serial testing fails to identify over half the patients with ACI. The Goldman protocol, artificial neural network, and continuous and serial ECG all have similar triage accuracy for ACI, between that of the single and serial or combination biomarkers. The combination technologies have better triage accuracy than the biomarkers and ECG-based technologies, with the exception of stress ECG. Of the combinations, troponin T-echocardiography has the best triage accuracy for ACI.

Figure 30. Subgroup model: Technology rankings by percent inappropriate triage (ED discharge) of patients with ACI at ACI prevalence of 21 percent

ANN: artificial neural network applied to patients with AMI excluded by ECG.

Sestamibi imaging (both resting and stress) has the best diagnostic performance among the technologies. Sestamibi stress imaging has the best diagnostic performance (detects 82 percent of patients with ACI), followed by sestamibi rest scanning and exercise ECG. If data from clinical impact studies are included, ACI-TIPI has the best triage accuracy (97 percent of patients with ACI appropriately triaged).

##### Cost-Effectiveness Analysis

The results of the cost-effectiveness analysis for the Subgroup Model are shown in Table 74. The costs and effectiveness of each technology are shown in Figure 31. The CE rankings are similar to those in the General Population Model and are shown in Figure 32.

Table 74. Subgroup model: Cost-effectiveness of technologies for appropriate triage of patients with ACI

Technology | Cost ^1^ | Marginal cost | ACI triage ^2^ | Marginal ACI triage | CE ^3^ | Marginal CE ^4^ | ACI triage (%) ^5^
CK-MB single | $1,685.1 | | 0.03 | | $56,589 | | 14
Troponin I | $1,713.9 | $29 | 0.051 | 0.021 | $33,517 | $1,349 | 24
Troponin T initial | $1,722.8 | $9 | 0.062 | 0.011 | $27,743 | $807 | 30
Myoglobin initial | $1,743.3 | $21 | 0.038 | −0.024 | $45,990 | Dominated | 18
CK-MB serial | $1,759.2 | $37 | 0.061 | −0.001 | $28,817 | (Dominated) | 29
Neural network | $1,786.0 | $63 | 0.065 | 0.003 | $27,585 | $23,883 | 31
Troponin T serial | $1,796.0 | $10 | 0.083 | 0.019 | $21,531 | $536 | 40
Nonstandard ECG | $1,841.2 | $45 | 0.072 | −0.011 | $25,414 | (Dominated) | 34
Goldman | $1,845.9 | $50 | 0.054 | −0.029 | $34,056 | (Dominated) | 26
Myoglobin doubling | $1,853.8 | $58 | 0.083 | −0.001 | $22,389 | (Dominated) | 40
CK-MB & myoglobin | $1,860.4 | $64 | 0.087 | 0.004 | $21,296 | $16,324 | 41
Cont/serial ECG | $1,980.0 | $120 | 0.054 | −0.033 | $36,545 | (Dominated) | 26
Myoglobin & ANN ^6^ | $2,103.3 | $243 | 0.11 | 0.023 | $19,088 | $10,640 | 52
CK-MB & serial ECG | $2,194.4 | $91 | 0.123 | 0.012 | $17,890 | $7,305 | 59
Troponin T & ECHO | $2,259.5 | $65 | 0.135 | 0.012 | $16,757 | $5,345 | 64
ECHO rest | $2,344.3 | $85 | 0.109 | −0.026 | $21,542 | (Dominated) | 52
ACI-TIPI | $2,363.9 | $104 | 0.204 | 0.069 | $11,570 | $1,502 | 97
Stress ECG | $2,724.3 | $360 | 0.15 | −0.055 | $18,192 | (Dominated) | 71
Sestamibi stress | $2,731.8 | $368 | 0.172 | −0.032 | $15,872 | (Dominated) | 82
ECHO stress | $2,758.1 | $394 | 0.131 | −0.073 | $21,024 | (Dominated) | 62
Sestamibi rest | $2,816.0 | $452 | 0.168 | −0.036 | $16,716 | (Dominated) | 80

1 Total cost of applying technology to one ED patient with possible ACI (includes cost of technology, admission and/or return ED visits and/or outpatient followup).

2 "Effectiveness" value: the probability of appropriate triage for ACI for an ED patient at ACI prevalence of 21 percent.

3 Cost-effectiveness ratio: total cost of applying technology to an ED patient with possible ACI divided by the probability of appropriate triage for a patient with ACI. Calculated values may be different due to rounding.

4 Marginal cost-effectiveness: ratio of the difference in costs to difference in effectiveness between two adjacent nondominated technologies.

5 Percent appropriate triage for patients with ACI.

6 Artificial neural network applied in subgroup ED patient population.

Figure 31. Subgroup model: Cost of applying technology to 1,000 ED patients and number of patients appropriately triaged for ACI at 21 percent prevalence of ACI (reference line)

A: ACI-TIPI; AN: artificial neural network; CK: CK-MB, single; CE: continuous/serial ECG; CS: CK-MB, serial; ER: resting ECHO; ES: stress ECHO; ET: exercise ECG; G: Goldman chest pain protocol; I: troponin I; M: myoglobin initial; MD: myoglobin doubling; NS: nonstandard ECG; SES: stress sestamibi; SR: resting sestamibi; T: troponin T, initial; TS: troponin T serial; 1: CPK-MB and myoglobin; 2: myoglobin and artificial neural network; 3: CK-MB and serial ECG; 4: troponin T and ECHO.

Figure 32. Subgroup model: Total cost of applying technology to 1,000 ED patients per appropriate triage for one patient with ACI

ANN: artificial neural network applied in ED patients with AMI excluded by ECG.

In the Subgroup Model, ACI-TIPI is still the most cost-effective technology if clinical impact data are included in the decision analysis: It has the greatest triage accuracy for ACI at a cost that is lower than the next most effective technology, stress sestamibi imaging. If only diagnostic performance data are used, stress sestamibi imaging is the most cost-effective, followed by troponin T-echocardiography. Stress sestamibi imaging costs about $470 more per ED patient but leads to appropriate triage for an additional 37 patients with ACI compared with troponin T-echocardiography. The incremental CE is $12,757, similar to the incremental CE between the two most cost-effective strategies in the General Population Model.

The per ED patient cost of sestamibi imaging is over $2,700, approximately $400 more than that of ACI-TIPI. The incremental CE between ACI-TIPI and the combination of troponin T-echocardiography is only $1,502 per additional appropriate triage for a patient with ACI, a negligible increase for improved triage accuracy.

##### Sensitivity Analysis

###### Triage accuracy and cost-effectiveness for AMI only

The triage accuracy of technologies for patients with AMI is shown in Figure 33. The rankings for the biomarkers are similar to those in the General Population Model. The biomarkers do not perform as well as the Goldman protocol or the imaging studies. The triage accuracy of the Goldman protocol for patients with AMI is significantly better than that for patients with ACI. Exercise ECG, stress imaging, and the combination of troponin T-echocardiography have the highest triage accuracy (99 percent). ACI-TIPI also has excellent triage accuracy (98 percent).

Figure 33. Subgroup model: Technology rankings by percent inappropriate triage (ED discharge) of patients with AMI at AMI prevalence of 6 percent

Results of the cost-effectiveness for triage of AMI patients only are shown in Table 75. The combination of troponin T-echocardiography is the most cost-effective: At a cost of $2,260 per ED patient, it is less expensive than all the imaging technologies as well as ACI-TIPI and appropriately triages nearly 99 percent of patients with AMI. Exercise ECG and stress sestamibi imaging also have 99 percent sensitivity for patients with AMI; however, the per ED patient costs of these two technologies is about $500 more than that of troponin T-echocardiography. Although the triage accuracy of ACI-TIPI is nearly identical to that of troponin T-echocardiography (98 percent), the per ED patient cost is about $100 more and its CE is $2,000 more per accurate triage for a patient with ACI. When the analysis was performed with cost of ACI-TIPI at $0, the cost-effectiveness of ACI-TIPI and the combination of troponin T-echocardiography are essentially equivalent as their total costs and effectiveness values are nearly identical.

Table 75. Subgroup model: Cost-effectiveness of technologies for appropriate triage for patients with AMI

Technology | Cost ^1^ | Marginal cost | AMI triage ^2^ | Marginal effectiveness | CE ^3^ | Marginal CE ^4^ | AMI triage (%) ^5^
CK-MB single | $1,685 | | 0.0268 | | $62,886 | | 44
Troponin I | $1,714 | $29 | 0.0213 | −0.00550 | $80,408 | (Dominated) | 35
Troponin T initial | $1,723 | $38 | 0.0323 | 0.00550 | $53,374 | $6,871 | 53
Myoglobin initial | $1,743 | $21 | 0.0304 | −0.00180 | $57,250 | (Dominated) | 50
CK-MB serial | $1,759 | $37 | 0.0536 | 0.02130 | $32,826 | $1,710 | 88
Neural network | $1,786 | $27 | 0.0304 | −0.02310 | $58,652 | (Dominated) | 50
Troponin T serial | $1,796 | $37 | 0.0536 | 0.00000 | $33,512 | (Dominated) | 88
Nonstandard ECG | $1,841 | $82 | 0.0426 | −0.01100 | $43,191 | (Dominated) | 70
Goldman | $1,846 | $87 | 0.0542 | 0.00060 | $34,056 | $142,329 | 89
Myoglobin doubling | $1,854 | $8 | 0.0530 | −0.00120 | $34,989 | (Dominated) | 87
CK-MB & myoglobin | $1,860 | $15 | 0.0426 | −0.01160 | $43,641 | (Dominated) | 70
Cont/serial ECG | $1,980 | $134 | 0.0244 | −0.02980 | $81,281 | (Dominated) | 40
Myoglobin & ANN | $2,103 | $257 | 0.0505 | −0.00370 | $41,611 | (Dominated) | 83
CK-MB & serial ECG | $2,194 | $349 | 0.0481 | −0.00610 | $45,612 | (Dominated) | 79
Troponin T & ECHO | $2,260 | $414 | 0.0603 | 0.00610 | $37,477 | $67,922 | 99
ECHO rest | $2,344 | $85 | 0.0566 | −0.00370 | $41,392 | (Dominated) | 93
ACI-TIPI | $2,364 | $104 | 0.0597 | −0.00060 | $39,608 | (Dominated) | 98
Stress ECG | $2,724 | $465 | 0.0603 | 0.00000 | $45,185 | (Dominated) | 99
Sestamibi stress | $2,732 | $472 | 0.0603 | 0.00000 | $45,310 | (Dominated) | 99
ECHO stress | $2,758 | $499 | 0.0566 | −0.00370 | $48,698 | (Dominated) | 93
Sestamibi rest | $2,816 | $557 | 0.0566 | −0.00370 | $49,720 | (Dominated) | 93

1 Total cost of applying technology to one ED patient with possible ACI (includes cost of technology, hospital admission and/or return ED visits and/or outpatient followup).

2 "Effectiveness" value: the probability of appropriate triage for AMI for an ED patient at AMI prevalence of 6 percent.

3 Cost-effectiveness ratio: total cost of applying technology to an ED patient with possible ACI divided by the probability of appropriate triage for a patient with AMI. Calculated values may be different due to rounding.

4 Difference in costs divided by difference in effectiveness between a strategy and the next nondominated most effective strategy.

5 Percent appropriate triage for patients with AMI.

The next most cost-effective strategy, the Goldman protocol, costs $414 less per ED patient but leads to appropriate triage of six fewer patients with AMI compared with troponin T-echocardiography. This yields an incremental cost-effectiveness of nearly $68,000, half that of the two most cost-effective strategies in the General Population Model.

###### Prevalence of ACI

As in the General Population Model, as prevalence of ACI increases, the cost-effectiveness of the technologies decreases. There is little change in the relative CE among the technologies. Sestamibi stress and sestamibi rest imaging become equally cost-effective at an ACI prevalence greater than 35 percent (Figure 34).

Figure 34. Subgroup model: Cost per appropriate triage for patients with ACI as prevalence of ACI changes

Dominated strategies excluded (except for resting sestamibi imaging which is shown for comparison with stress sestamibi imaging. ACI-TIPI is shown in the General Population Model).

Reference lines show range of ACI prevalence most commonly encountered in the ED (17-25 percent).

#### 30-Day Survival Analysis

The decision analysis was also performed using 30-day survival as an outcome. The effectiveness values are the number of patients with ACI who survived for 30 days; total costs are for 1,000 ED patients evaluated in the ED. There is little change in the rankings of the technologies using 30-day survival as an outcome, shown in Figure 35, compared with triage accuracy rankings in both the General Population Model and Subgroup Model. The figure gives the percentage of survival for a patient with ACI for each technology. The optimal survival rate of those with ACI would be the survival rate of admitted patients (because all patients with ACI would be appropriately hospitalized), which is 95.4 percent given the 89-percent survival rate of those with AMI and 98-percent survival rate for those with UAP.

Figure 35. Subgroup model: Percent survival of patients with ACI

Reference line shows optimal survival rate if all patients with ACI appropriately triaged (none inappropriately discharged from the ED).

* Includes admitted patients who died.

In the Subgroup Model, ACI-TIPI has the highest 30-day survival rate, followed by sestamibi imaging (both rest and stress), stress ECG, and then three strategies with the same survival rate: stress echocardiography, and the combinations CK-MB -- serial ECG and troponin T-echocardiography. Differences in survival rates are very small: a difference of one patient with ACI surviving to 30 days between each subsequent ranking among all the technologies.

The most cost-effective strategy in both the General Population Model and the Subgroup Model is ACI-TIPI. In the General Population Model, the marginal cost-effectiveness between ACI-TIPI and the next most effective strategy, the combination of troponin T-echocardiography, is $53,700 per survival of an additional patient with ACI. In the Subgroup Model, the marginal cost-effectiveness between ACI-TIPI and the next most cost-effective strategy, the combination of CK-MB and serial ECG, is $125,563 per survival of an additional patient with ACI. The marginal CE between the next more effective and less costly strategy, the combination of myoglobin-artificial neural network, is $241,765.

When the analysis was repeated at a cost of $0 for ACI-TIPI, it dominated all other strategies.

Sensitivity analysis was also performed on cost of death of a patient inappropriately discharged from the ED. As the cost of death from "missed" ACI increased from a low of $600 for a return ED visit and resuscitation attempt to the cost of a malpractice settlement ($2 million), ACI-TIPI retained its cost-effectiveness. At very high "cost-of-death" values, it dominated all other strategies.

#### Cost of ACI-TIPI

If clinical impact data are included in the decision analyses, ACI-TIPI is the most effective and most cost-effective strategy for diagnosing patients with ACI in both population models. It also has a small incremental CE (about $1,500) compared with the next most cost-effective technology. These analyses were performed using a "conservative" cost for ACI-TIPI: that of an ECG ($68). Reducing the cost of ACI-TIPI to $0 only increases its cost-effectiveness and lowers its incremental cost-effectiveness even more (to about $400 in the General Population Model).

Because not every ED has ECG machines in which ACI-TIPI has been incorporated, hospitals may have to purchase an ECG with the predictive instrument. (Hewlett Packard has incorporated ACI-TIPI into all ECG machines beginning in 1998 [Joni Beshansky, personal communication]. GE Marquette will release ECG machines with ACI-TIPI beginning in January 2000 [Paul Elko, GE Marquette, personal communication]). We therefore performed analyses to determine how much more ACI-TIPI would have to cost for it to be no longer cost-effective.

Figure 36 shows the relative costs per appropriate ACI triage as ACI-TIPI increases in cost. For ACI-TIPI to no longer be the most cost-effective strategy, it would have to cost approximately $1,000 per patient use. The addition of the predictive instrument adds $800 to $1,000 to the total retail cost of an ECG machine (Paul Elko, GE Marquette, personal communication). Thus, the per patient cost of using an ECG machine that has the predictive instrument would be considerably lower than $1,000, and it is inconceivable that the cost per patient use of ACI-TIPI would ever come close to $1,000.

Figure 36. Total cost of applying technology to 1,000 ED patients per appropriate ACI triage and cost of ACI-TIPI

* Artificial neural network and combination of troponin T and ECHO applied in General Population Model.

### Discussion

The results of the decision analysis indicate that the biomarkers have the lowest triage accuracy and cost-effectiveness for appropriate triage of patients with ACI in the ED, primarily because their diagnostic performance in patients with UAP is poor. The ECG-based technologies, algorithms, and combinations of technologies perform better. Sestamibi imaging and stress tests have excellent diagnostic accuracy for ACI but are more costly than the other technologies and cannot be performed on all ED patients. Although sestamibi imaging, exercise ECG, and the combination of troponin T-echocardiography are effective for detecting ACI, and very effective for detection of AMI, their effects on the triage of patients with ACI have not been prospectively studied.

If data from clinical impact studies are included in the cost-effectiveness analysis, ACI-TIPI has the best triage accuracy for ACI, is the most cost-effective, and has a lower marginal CE than other technologies in both models. Furthermore, the predictive instrument's effect on ED patient triage in patients with ACI has been evaluated in a large clinical trial.

ACI-TIPI is also the most cost-effective strategy in the 30-day survival analysis. Interestingly, technologies that detect UAP at a much lower rate than that for AMI have lower rates for survival than would be expected given their AMI triage accuracy. This is likely because of the large difference in death rates between UAP and AMI. The survival analysis needs to be refined so that technologies that detect AMI are not penalized.

The prevalence of UAP used in the decision analysis is double that of AMI, making the model more sensitive to diagnostic performance in patients with UAP. Unfortunately the data on the diagnostic performance of technologies for UAP are very sparse. As ACI-TIPI has very high triage accuracy for unstable angina, we attempted to be fairly generous in our estimates of diagnostic performance of technologies for patients with UAP.

We did attempt to mitigate the effect of unknown values for UAP by analyzing the triage accuracy and cost-effectiveness for patients with AMI only, as the values for technology diagnostic performance for patients with AMI are based on a greater number of studies than those for patients with UAP. The most cost-effective strategy for AMI triage in both models is the combination troponin T-echocardiography; its marginal cost-effectiveness, however, is considerably greater than that of ACI-TIPI for ACI triage ($68,000 for the Subgroup Model and $137,000 for General Population Model vs. about $1,500 for ACI-TIPI). The artificial neural network in the General Population Model and the Goldman protocol in the Subgroup Model are the next most cost-effective strategies. Although evaluating only AMI patients is an artificial construct, since the ED physician does not know a priori which patients have AMI or UAP, this analysis does not rely on uncertain and unverifiable estimates for detection of UAP.

The results of this decision analysis do not explicitly incorporate the positive predictive value of a technology into the triage outcome for a patient. The predictive value of a test result may be a better estimate of triage accuracy and outcomes than test diagnostic performance, since ED physicians rarely base their decision to admit a patient solely on the results of a test. However, attempting to estimate the positive predictive value adds still another layer of uncertainty to the model estimates. Furthermore, by allowing for changes in the ED prevalence levels for ACI, the decision model does incorporate effects of pretest likelihood of ACI. For example, a 17-percent prevalence may indicate a 45-year-old man with no symptoms but some risk factors, whereas a 90-percent prevalence may indicate a 45-year-old man with typical angina (Patterson, Eng, Horowitz, et al., 1984).

The model also does not take into account the lower severity of disease in patients with ACI who have false negative test results. Certain technologies, especially the imaging studies, may be able to pick up the "sickest" ACI patients, and this may be reflected in different death rates for "missed" ACI among the technologies. An attempt to perform this analysis with our model, however, did not capture the negative effects of inappropriate triage of patients with ACI, since the death rate of admitted patients with AMI (presumably the sickest) is the same as that for patients inappropriately discharged from the ED. This is because, although the patients with false negative tests have less severe ACI than patients with true positive tests, their death rates are disproportionately higher than if they had been admitted. The analysis may need to be done separately for AMI and UAP in order to incorporate the different death rates and reflect the benefit of appropriate triage for ACI patients.

The results of the decision and cost-effectiveness analyses should not be used as a definitive analysis of technology triage accuracy as data on actual effect on triage are lacking for most of the technologies. Furthermore, the values for sensitivity of technologies for patients with UAP are estimates based on sparse data, which adds to the uncertainty of the model. The decision analysis is also not meant to be used for clinical recommendations for individual patients as pretest likelihoods are not explicitly modeled. Rather, these results should be used as an aid in decisionmaking and in understanding the factors that are involved in triage of patients with ACI in the ED. Prospective trials on the effect of technologies on actual ED patient triage are required before definitive conclusions can be made.