# Evidence Tables

Evidence Table 1a. Diagnostic performance studies evaluating prehospital 12-lead electrocardiography for the diagnoses of acute cardiac ischemia

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Reference criteria for ACI | Diagnostic criteria for AMI/ACI: sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Aufderheide 1990 91052573 | Country: USA Mean age: Male 60 Female 69 Enrolled: 166 Evaluated: 151 52.3% male Race: ND | Stable patients with nontraumatic chest pain, Hx CAD allowed | SBP <90 mmHg, Potentially life-threatening cardiac arrhythmias | Prehospital 12-lead ECG obtained during initial evaluation and stored for weekly retrieval at centralized hospital. Patient received standard care based on clinical evaluation & single-lead ECG telemetry. | AMI 15.9% (24/151) Angina/UA 40.4% (61/151) | Cardiologist blinded to patient information and reviewed prehospital & ED ECGs randomly. | Cardiologist blinded to patient information and reviewed prehospital & ED ECGs randomly. | Final diagnosis defined as etiology of chest pain during paramedic evaluation, review of hospital records, & treating physician's final diagnosis. AMI: Abnormal CK elevation and/or LDH within 72 hr of admission Ischemia: angina pectoris | AMI: ST-segment elevation >0.10 mV in at least 2 of 3 diaphragmatic leads (II, III, and aVF), in at least 2 adjacent precordial leads (V_1_ through V_6_), or in leads I & aVL. Ischemia: ST-segment depression, T-wave inversion, or abnormal Δ per cardiologists. Active chest pain present with ECG changes considered significant. AMI: Sens - 54.2% Spec - 99.2% | "It is feasible to apply prehospital 12-lead electrocardiography to most stable prehospital chest pain patients. Prehospital 12-lead ECGs have the potential to significantly increase the diagnostic accuracy in chest pain patients, approach congruity with ED12-lead ECG diagnoses, and may allow for consideration of altering and improving prehospital and hospital-based management in this patient population". | ND | Prehospital & ED ECGs were read retrospectively, along with hospital charts for final diagnosis. 11 pts with ECGs with left & right BBB, fully placed rhythms classified nonischemic, and 4 pts with right BBB & 2 with left ventricular hypertrophy considered to have abnormal changes & classified ischemic. Average time from paramedic arrival to prehospital 12-lead ECG acquisition, 6.7 min for AMI subgroup & 8.4 min overall. 94 of 151 (62.3%) patients had symptoms under 6 hours before paramedic arrival.
Kudenchuk 1991 91236958 | Country: USA Mean age: 56.8 Enrolled: 1,189 Evaluated: 1,189 66.4% male Race: 862 pts 92.9% White 3.7% Black 2.3% Asian 0.6% Hispanic 0.5% Native American | <74 yr, Paramedic checklist of hx & physical exam criteria, Symptoms <6 hr, Hx CAD allowed | Existing conditions that may increase potential for bleeding. | Prehospital 12-lead ECG with computer-interpretive & cellular telephone transmission capabilities obtained by paramedics. An ED receiving unit printed out transmission for physician review. | ACI 46.1% AMI 32.9% (391/1,189) UA 13.2% (157/1,189) | ECG Interpretation by at least 2 physicians without knowledge of pt identity or results of computer interpretation. | NA | AMI: > two times increase in CK-MB isoenzyme or LDH fraction 1 > than fraction 2 in 323 of 391 pts, Elevation of total CK in 50 pts, 13 of whom had > two times increase in total CK, but isoenzymes not measured. | AMI by computer interpretation based on ST-segment elevation. Sens - 51.7% Spec - 98.4% | "Prehospital screening of possible candidates for thrombolytic therapy with the aid of a computerized ECG is feasible, highly specific and with further enhancement can speed the care of all patients with acute myocardial infarction." | ND | Because of 19 sites, differing standards for final diagnosis. ECG obtained mean 1.5±1.2 hours after symptom onset. Population included in study Kudenchuk, 1998, 98331907.
Dalzell 1991 91262058 | Country: N Ireland Mean age: 60.5 Enrolled: 94 Evaluated: 94 67% male Race: ND | Chest pain >15 min & <6 hr, Hx CAD allowed | ND | MCCU staffed with physician & nurse, records clinical diagnosis including initial ECG. | ACI 91.5% AMI 51.1% (48/94) UA 40.4% (38/94) | ND | Initial ECG reviewed by 2 independently, blinded observers. | AMI: transient increase > twice normal CK levels for 1^st^ 72 hr of admission and/or ST segment elevation. UA: new onset severe or accelerated angina or angina at rest in absence of increase > twice normal CK levels. | AMI: ST segment elevation >0.1 mV measured 80 ms from J point. Sens - 77.1% Spec - 97.8% | "Out-of-hospital administration of thrombolytic therapy has the potential to maximize myocardial salvage and even abort infarction, but it must be recognized that the initial ECG recorded early after the onset of symptoms may not display ST segment elevation." | 3 patients admitted twice. | Patients are referred from general practitioners, or ambulance personnel, & lay persons. Primary responder by patient was MCCU in 69 cases, GP in 24, & ambulance personnel in 1 case. 65 of 94 (69%) seen within 2 hrs after onset of pain.
Bertini 1991 92064936 | Country: Italy Mean age: Male 63.7 Female 70 Enrolled: 706 Evaluated: 605 67.8% male Race: ND | ND | ND | MCCU equipped with monitor defibrillator, 12-lead ECG, automatic ventilator, & equipment for cardiopulmonary resuscitation. Staff includes cardiologists & paramedical volunteers. Pts undergo clinical evaluation including hx, physical exam, & ECG. Initial diagnosis is made to determine hospitalization. | ACI 52.4% AMI 26.0% (157/605) UA 26.4% (160/605) See Potential verification bias column | ND | NA | AMI: Hospitalized pts - Characteristic CK/CK-MB changes or new pathologic Q waves | AMI: Sens - 76.4% Spec - 93.5% | "The protocol of the Florence MCCU provides high accuracy in the diagnosis of AMI and acute coronary insufficiency; close adherence to the protocol can decrease the number and the costs of undue hospital admissions while protecting the safety of patients." | Diagnosis unknown for 95 pts, 19 hospitalized & 76 not hospitalized. Additional 6 pts died during MCCU intervention. | Mean 60 minutes between symptom onset & MCCU activation with mean intervention of 10 minutes. 83% had symptoms under 6 hours before MCCU arrival. Followup included use of questionnaire to detect events. Nonhospitalized pts followup by phone 3 months later.
Aufderheide 1992a, 1992b 92221958 92202841 | Country: USA Mean age: Male 64 Female 67 Enrolled: 680 Evaluated: 439 46% male Race: ND | >18 yr, Stable patients with nontraumatic chest pain | Ventricular tachycardia, Ventricular fibrillation, 2° or 3° heart block, SBP <90 | Prehospital 12-lead ECG with cellular telephone transmission capabilities obtained by paramedics and transmitted to base physician. 20-item checklist for r-TPA contraindication was completed by paramedic. The information was communicated to base physician for selection for thrombolysis. No tx given. | AMI 20.7% (91/439) Angina/UA 33.7% (148/439) | ND | NA | AMI: Abnormal CK-MB elevation and/or LDH within 72 hr of admission Angina pectoris: new-onset, unstable & stable angina, based on hospital chart review | AMI: ST-segment elevation >1 mm in at least 2 anatomically adjacent leads. Sens - 41.8% Spec - 99.7% | "The safety committee concluded that acceptable accuracy of emergency physician prehospital electrocardiographic interpretation, checklist and case selection was achieved. It is concluded that emergency physicians can accurately identify candidates for prehospital thrombolytic therapy." | Of original 680 ECGs obtained, 24 were of poor quality. Additional 241 excluded from hospital chart review; 149 ECGs failed to transmit, 72 pts requested transport to nonparticipating sites, & unavailable medical records for 20. | Average time from paramedic arrival to prehospital 12-lead ECG acquisition, 10.2±7.0 minutes. Mean scene time, 28.5±6.5 minutes. r-TPA status determined by base physician, therapy not administered. 12 pts of 38 with prehospital 12-lead ECG interpreted positive for AMI qualified for prehospital thrombolytic therapy by checklist & were selected by base physicians. They also met WHO criteria for final AMI diagnosis.
Arntz 1992 92351854 | Country: Germany Mean age: ND Enrolled: 1,226 Evaluated: 1,226 ND % male Race: ND | ND | ND | MICU staffed with physician recorded clinical diagnosis including 12-lead ECG. | AMI 34.0% (417/1,226) | ND | ND | Hospital discharge diagnosis | AMI: ST elevation >0.1 mV or tall peaked T waves in >2 contiguous leads with no BBB or ventricular pacing. Sens - 64.3% Spec - 99.5% | "Because > 50% of all patients in the community, hospitalized because of AMI, made use of the MICU and 3/4 of them had called within 4 hours from symptom onset, a large proportion of all patients with AMI were candidates for and actually received prehospital thrombolysis." | ND | 8% presented ST elevations not recognized onscene by MICU staff. 76%, 317 of 417, had onset of chest pain <4 hrs before arrival of MICU.
Otto 1994 94099538 | Country: USA Mean age: Male 64 Female 67 Enrolled: 439 Evaluated: 428 45.1% male Race: ND | 18 yr, Stable patients with nontraumatic chest pain | Ventricular tachycardia, Ventricular fibrillation, 2° or 3° heart block, SBP <90 | Prehospital 12-lead ECG with cellular telephone transmitting simultaneously printing copy for paramedic. | ACI 60.0% AMI 23.4% (100/428) Angina/UA 36.7% (157/428) | Final diagnosis completed prior to retrospective review. | ECGs reviewed retrospectively by at least 2 reviewers blinded to patient outcome. | WHO criteria for AMI: Clinical hx, ECG, & cardiac enzyme tests. Angina pectoris: new-onset, unstable & stable angina | AMI: ST elevation >1 mm in 2 contiguous leads. Sens - 60.0% Spec - 80.8% Other criteria available, see study | "ST segment elevation alone lacks the positive predictive value necessary for reliable prehospital myocardial infarction diagnosis. Inclusion of reciprocal changes in prehospital 12-lead ECG myocardial infarction criteria improved the positive predictive value to more than 90% and included a significant majority (62% to 86%) of acute myocardial infarction patients with ST segment elevation who received thrombolytic therapy within five hours after hospital arrival. ST segment elevation criteria that include reciprocal changes identify patients who stand to benefit most from early interventional strategies." | 11 of 439 patients with prehospital 12-lead ECGs were excluded, 8 had fully paced rhythms, & 3 ECGs were of poor quality. | Same study population as Aufderheide, 1992b, 92202841
Foster 1994 94114004 | Country: USA Mean age: ND Enrolled: 155 Evaluated: 155 % male ND Race: ND | Chest, epigastric, arm, shoulder, neck, or jaw discomfort of nontraumatic origins | Advance malignancy, <21 yr, "Do not resuscitate" documentation, Unable to give hx, Full cardiac arrest | Prehospital 12-lead ECG conducted by ALS staffed with paramedic or prehospital nurse provider. | AMI 13.5% (21/155) | ND | ND | "…AMI based on conventional ECG and enzyme criteria" | AMI: ST elevation >1 mm in >2 contiguous leads, & with reciprocal depression in opposite wall. Sens - 81.0% Spec - 100% | "It is concluded that hospital-based paramedics and nurses can successfully be taught to evaluate (i.e., sight read) a prehospital 12-lead ECG for the presence of AMI with accuracy." | ND | No time limit from onset of symptoms as part of exclusion criteria. Average time-on-scene 14±5.1 min. Average time from arrival to thrombolysis therapy decision 9± 5.1 min. Actual therapy commenced in ED.
Millar-Craig 1997 98076704 | Country: England Mean age: 66-CCU pts Enrolled: 162 Evaluated: 162 79.8% male-CCU pts Race: ND | ND | ND | Prehospital 12-lead ECG conducted & evaluated by paramedic & if evidence of ACI, communicated by VHF radio to prepare for direct patient admission to CCU. | ACI 66.0% AMI 44.4% (72/162) UA 21.6% (35/162) | ND | ND | Serial ECG & cardiac enzymes | AMI: Sens - 98.6% Spec - 41.1% | "Trained paramedics can reliably diagnose myocardial infarction by ECG. The use of a direct admission procedure, by a VHF radio link to the CCU, substantially reduces the time interval for thrombolytic treatment after acute myocardial infarction." | ND | 124 patients admitted to CCU.
Brown 1997 98131126 | Country: USA Mean age: ND Enrolled: ND Evaluated: 32 % male ND Race: ND | Maryland state medical protocol for AMI | ND | "Quasi-experimental design" with advance life support units without 12-lead ECG & units augmented by equipped EMS district officer units. Augmented units recorded ECG & transmitted ECG via cellular or land phone & completed thrombolytic survey for ED physician. | AMI 21.9% (7/32) | ND | ND | ND | AMI: Sens - 100% Spec - 80.0% | See Limitations/comments section | ND | Reporting of data in study for sensitivity/specificity incorrect.
Kudenchuk 1998 98331907 | Country: USA Mean age: 60 Enrolled: 3,027 Evaluated: 3,027 66.1% male Race: ND | Hx CAD allowed | ND | Prehospital 12-lead ECG with computer-interpretive & cellular telephone transmission capabilities obtained by paramedic & sent to ED-based physicians for review. Additional ECG obtained upon hospital arrival. | ACI 53.3% AMI 38.0% (114,9/3,027) UA 15.3% (464/3,027) | Prehospital records utilized in patient outcome | Prehospital & hospital ECGs read independently by reviewers blinded to corresponding ECG, patient, & patient outcome | ACI: Prehospital & hospital records of patients | ACI: | "The findings of this study suggest that ECG abnormalities are an early manifestation of acute coronary ischemia and can be readily identified by prehospital electrocardiography. Such changes were commonly observed early (mean ~60 to 90 min) after symptom onset in patients with acute myocardial ischemia or infarction." | Prehospital or hospital ECGs were uninterpretable in 10 patients. | Prehospital 12-lead ECG obtained mean 91±76 min after onset of symptoms. 19 sites participated. Subgroup included in study Kudenchuk, 1991, 91236958.
  ST segment elevation | Sens - 45.9% Spec - 96.0%
  ST segment depression | Sens - 39.1% Spec - 88.3%
  T wave inversion | Sens - 20.8% Spec - 67.5%
  Q wave | Sens - 39.0% Spec - 88.2%
  Left BBB | Sens - 47.0% Spec - 97.3%
  Any ST segment, T or Q wave, or LBBB
  | Sens - 14.4% Spec - 60.2%

ALS-Advanced Life Support; BBB-bundle branch block; GP-general practitoner; hx-history; MCCU-mobile coronary care unit; MICU-mobile intensive care unit; ms-millisecond; mV-millivolt; ND-no data; pt(s)-patients(s); r-TPA-r-tissue plasminogen activator; SBP-systolic blood pressure; sens-sensitivity; spec-specificity; tx-treatment; δ-change.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 1b. Clinical impact of randomized studies involving prehospital diagnoses to manage acute cardiac ischemia

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Comparisons | Treatment protocol | Outcomes | Study conclusions | Limitations/comments
Castaigne 1989 89300590 | Country: France Mean age: 56 Enrolled: 100 Evaluated: Test 57 Placebo 43 91.0% male Race: ND | <75 yr, Ischemic chest pain >30 min & <3 hr, Unresponsive to nitrates, ST elevation >0.2 mV in >2 standard or 3 precordial leads | Hx severe hypertension, Contraindication to thrombolysis | Time from symptom onset to treatment, Mortality, Ejection fraction | MICU staffed with anesthesiologist randomized pts at home to APSAC or placebo. Blood samples taken for fibrinogen & CK levels before therapy. Physician blinded to treatment assignment. All pts admitted to CCU & code broken. Pts receiving placebo at home were treated in the hospital accordingly. | Mean time for injection (APSAC or placebo) was 131 minutes compared with 180 minutes for in-hospital pts who had placebo. Ejection fraction was higher in the prehospital group, 56.7%, than in the control group, 53.4%, not significant. 2 pts died, 1 from each group, before admission, & 3 pts died during hospitalization. | "Data indicate that prehospital thrombolysis with APSAC is both feasible and safe if the mobile care unit team is specifically trained. In terms of mortality, the efficacy of prehospital thrombolysis needs to be demonstrated." | 100 of 320 patients screened with AMI were included in the trial; 90 of 100 had confirmed AMI and another 7 had aborted AMI. Protocol violations included 14 pts, 7 with cardiologist's determination that code be broken. 7 other pts didn't received thrombolytic therapy, but had placebo at home.
Barbash 1990 90313638 | Country: Israel Mean age: 58 Enrolled: 87 Evaluated: Test 43 Control 44 80% male Race: ND | <72 yr, Chest pain >30 min & <4 hr, ST elevation 0.1 mV in>2 contiguous leads, Hx AMI allowed | LBBB, Hx congestive heart failure, Cardiac surgery, DBP <120 mmHg, Hx terminal illness, Bleeding disposition | Time from symptom onset to treatment, Mortality, Ejection fraction | MICU pts randomized by month to prehospital vs in-hospital treatment groups. Depending on the month, pts were treated at home or CCU with r-TPA. | Mean time to treatment was 1.6±0.6 hours compared with 2.2±0.7 for in-hospital pts, p<0.0001. At 60 days, 1 of prehospital group died & 3 from the in-hospital died. At 24 months, 3 from each group died. Immediate LVEF was 48±15% in each group. | "Prehospital initiation of r-TPA appeared to be safe and feasible and resulted in a 40-minute decrease in the time from symptom onset to treatment initiation." | Treating physicians blinded to time from onset of pain to treatment.
Karagounis 1990 91022390 | Country: USA Mean age: ND Enrolled: 71 Evaluated: Test 34 Control 37 % male ND Race: ND | <76 yr, Chest pain >20 min, Unresponsive to nitroglycerin, ST elevation 0.1 mV in >2 limb leads and/or >0.2 mV in >2 precordial leads | Contraindications to thrombolysis | Time from hospital arrival to treatment, Time on scene | Patients were randomized to have in-field 12-lead ECG obtained & cellular phone transmitted by paramedics to assess the potential for thrombolytic therapy in-field. Patients not randomized to in-field ECG were given standard care. | Of in-field ECG group, 5 AMI pts qualified & received thrombolytic care in hospital. Time from arrival to care was 48±12 vs 68±29 min for the controls. Time on scene was 16.4±9.7 vs 16.1±7.0 min, in-field group to controls. | "…in field ECG causes negligible delays in paramedic time, leads to significant decreases in time to in-hospital thrombolysis and may make in-field therapy feasible. In-field ECG my be an important addition to reperfusion strategies." | Data pertain to 6+6 patients receiving thrombolysis; among 51 historic controls mean time was 103 min (SD 44).
Schofer 1990 91068670 | Country: Germany Mean age: 55 Enrolled: 78 Evaluated: Test 40 Placebo 38 84.6% male Race: ND | <70 yr, Chest pain >30 min, Arrival of ambulance physician <4 hr after onset of symptoms, ST elevation >2 mm in >2 leads for inferior AMI & >3 mm in >2 precordial leads for anterior AMI | Hx AMI, Contraindications to thrombolysis | Time from symptom onset to treatment, Mortality, Ejection fraction, Wall motion | In a double-blind study, AMI patients were randomized to receive 2 million units of urokinase as IV bolus either before or after hospital admission. The mobile care unit staffed by physician & 2 emergency medical technicians. Ampules pairs containing urokinase in ampule A & placebo in ampule B, or vice versa, were administered to each pt. | Mean time to treatment was 85±51 for treatment group compared to 137±50 min for placebo group, p<0.0005. 1 treatment pt & 2 placebo pts died 7 to 14 days after admission. Ejection fraction was 51±10% & 53±14% for 28 in each group. Wall motion at −2.3±1.3 vs −2.2±1.1, also not significant. | "Prehospital thrombolysis using a bolus injection of urokinase has a low risk when performed by a trained physician with a mobile care unit. The saving of 45 minutes in the early stage of an acute infarction through prehospital thrombolysis did not appear to be important for salvage of myocardial function." | AMI could not be confirmed in 1 patient.
Kereiakes 1992 92197457 | Country: USA Mean age: ND Enrolled: ND Evaluated: Test 11 Control 11 % male ND Race: ND | ND | ND | Time from hospital to treatment | Patients transported by ambulance were randomized to receive cellular telephone transmission of prehospital 12-lead ECG. | Time from hospital arrival to treatment was median 35 for the prehospital 12-lead ECG group vs. 50 minutes for the group without a prehospital 12-lead ECG. | "A significant reduction in hospital time delay to treatment was observed only in patients transported by the emergency medical system who had cellular transmission of a prehospital 12-lead ECG from the field." | Randomization occurred after ECG leads attached on route.
McAleer 1992 92392794 | Country: Ireland Mean age: 60 Enrolled: ND Evaluated: Test 43 Control 102 77.9% male Race: ND | Symptoms <6 hr, ST elevation>0.1 mV in>2 standard leads and/or>0.2 mV in >2 precordial leads, Hx CAD or AMI allowed | Bleeding disorders, Anticoagulant therapy, Active peptic ulceration, Recent stroke, Recent surgery, Hypertension - BP >220/120 mmHg, Life expectancy <2 yr | Mortality | Patients randomized to thrombolysis at home or after transfer to CCU. MCCU staffed by physician & nurse. | Mortality at 14 days was 2.3% (1) for the prehospital group vs 11.7% (12) for the hospital group, p<0.05. At 1 year, the prehospital group had 6.1% vs 20.0% for the hospital group, p=0.04, and at 2 years, 9.1% vs 30.6%, p=0.03. | "Thus, prehospital thrombolysis by streptokinase is feasible and allows significant reduction in the delay time to treatment initiation. There are encouraging improvements in both short- and long-term survival with no apparent reduction in safety profile." | Mean delay time from hospital. All pts followed for 12 months, 2/3 for 2 years.
Grampian Region Early Anistreplase Trial (GREAT) 1992 Rawles 1994, 1997 93006371 94103525 98010395 | Country: Scotland Mean age: 63 Enrolled: 311 Evaluated: Test 163 Placebo 148 69.5% male Race: ND | Strong clinical suspicion of AMI by GP, Symptoms>20 min &>4 hr, ECG recorded by GP, Hx CAD or AMI allowed | Thrombolytic therapy <6 months, Surgery or major trauma past 10 days, Active gastrointestinal bleeding or hx internal bleeding <6 months, Cerebrovascular accident or neurosurgical procedure <2 months or known intracranial neoplasm or aneurysm, Hx thrombocytopenia or haemorrhagic diathesis or anticoagulant treatment, Risk of pregnancy or heavy vaginal bleeding, Diabetic proliferative retinopathy, BP >200/120 mmHg, Recent resuscitation with chest compression | Mortality | Double-blind study randomizing pts to either prehospital treatment of anistreplase followed by placebo in hospital or prehospital placebo followed by anistreplase in hospital. Treatment administered at home by GP. | Median time from onset of symptoms to prehospital treatment was 101 vs. 240 minutes for in-hospital treatment. Mortality at discharge was 11 for the prehospital vs 20 for the in hospital group, p=0.05. At 1 year, total of 17 deaths for the prehospital vs 32 for the in-hospital group. At 5 years, total of 41 for the prehospital vs 53 for the in-hospital group. | "Compared with later administration in hospital, giving anistreplase at home resulted in reduction in mortality, fewer cardiac arrests, fewer Q wave infarcts, and better left ventricular function." | ECG interpretation not required by GP before administering of treatment.
European Myocardial Infarction Group (EMIG) 1993 93316997 | Country: Europe & Canada Mean age: ~61 Enrolled: 5,469 Evaluated: Test 2,750 Placebo 2,719 ~77% male Race: ND | Chest pain >30 & <6 hr, ST elevation >1 mm in 2 limb leads, elevation >2 mm in >2 precordial leads, or both, Hx ACI allowed | Treatment with oral anticoagulant, Hemorrhagic diathesis or recent active peptic ulcer, Stroke, surgery, or major trauma in past 6 months, External cardiac massage for present symptoms, SBP >200 mmHg or DBP >120 mmHg, Pregnant, Percutaneous transluminal coronary angioplasty in past 2 wk, Contraindication to thrombolysis | Time from symptom to treatment, Mortality | Double-blind study randomizing pts to either prehospital treatment of anistreplase followed by placebo in hospital or prehospital placebo followed by anistreplase in hospital. Ambulance staffed with physician. | Median time from onset of symptoms to prehospital treatment was 130 vs 190 min for in-hospital treatment. Mortality at 30 days was 266 for the prehospital group vs 303 for the in-hospital group, not significant. | "Prehospital thrombolytic therapy for patients with suspected myocardial infarction is both feasible and safe when administered by well-equipped, well-trained mobile emergency medical staff. Although such therapy appears to reduce mortality from cardiac causes, our data do not definitely establish that it reduces overall mortality." | Final diagnosis of AMI was confirmed for approximately 92.4% of patients. Patients without ST elevation, but convincing overall picture were allowed (12.2% of total). An increase in prehospital fibrillation was also noted (p=0.02).
Weaver 1993 Brouwer 1996 93360393 96399955 | Country: USA Mean age: 58 Enrolled: 360 Evaluated: Test 175 Control 185 82% male Race: ND | <75 yr, Chest pain <6 hr, ST-segment elevation >1 mm in>2 leads, Hx CAD or ACI allowed | Risk for serious bleeding including: Hx stroke, recent bleeding or surgery, known liver or kidney disease, or uncontrolled SBP <180 mmHg or DBP <120 mmHg, hypertension | Ejection fraction, Infarct size, Mortality, Time from symptom onset to treatment | Patients randomized to aspirin & alteplase to be administered prehospital or in hospital. No placebo given. Followup by annual questionnaires, review of hospital records, telephone contacts, & review of National Death Index. | Nonsignificant differences between pre- vs in-hospital groups for mean ejection fraction, 53.0±12.0% vs 54.0±12.0%, mean infarct size, 6.1±8.3% vs 6.5±9.4%, & mortality, 10 vs 15. Mean time from onset of symptoms to treatment, 77 vs 110 min, pre- vs in hospital, p<0.01. 1 yr survival, prehospital 89% vs 91% for inhospital group, p=0.46. | "There was no improvement in outcome associated with initiating treatment before hospital arrival; …very early treatment did not decrease either subsequent survival or the number of cardiac events after hospital discharge." | Paramedic sent pt hx & data from computer-interpreted 12-lead ECG to ED physician for review. Of 8,863 patients with chest pain, 1,973 met criteria and had ECG, 483 had ST elevation, 353+7 were randomized; 353/360, 98.1%, had AMI confirmed.

APSAC-anisoylated plasminogen streptokinas activator complex; BP-blood pressure; DBP-diastolic blood pressure; GP-general practitioner; hx-history; LBBB-bundle branch block; LVEF-left ventricular ejection fraction; MCCU-mobile coronary care unit; MICU-mobile intensive care unit; pt(s)-patient(s); r-TPA-tissue plasminogen activator; SBP-systolic blood pressure.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

Evidence Table 1c. Clinical impact of nonrandomized studies involving prehospital diagnoses to manage acute cardiac ischemia

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Study design/comparisons | Treatment protocol | Outcomes | Study conclusions | Limitations/comments
Koren 1985 86040282 | Country: Israel Mean age: 55 Enrolled: 53 Evaluated: 51 92.5% male Race: ND | <75 yr, Myocardial ischemic pain >30 min & <4 hr, Unresponsive to 5 mg isosorbide dinitrate & 10 mg nifedipine, ECG ST elevation >0.2 mV, persisting 0.08 sec after J point in >2 surface leads & associated with reciprocal changes, Hx CAD allowed | SBP >220 mmHg, Hx severe hypertension, Previous coronary artery bypass graft operation, Malignant tumors or terminal noncardiac illness, Contraindications to streptokinase administrations | Cohort - prospective/NA | IV streptokinase administration in AMI pts, 9 by MICU at home. Early streptokinase administration in 44 hospital patients during same period. | 2 deaths in hospital pts, 0 in mobile-care group. Therapy administered by MICU resulted in significantly higher ejection fraction 67±15 vs the admitted pts, 48±14 & infarct-related regional ejection fraction, 56±18 vs 39±21, & lower QRS score, 2.3±2.8 vs 8.1±5.2, respectively. | "We conclude that thrombolytic therapy with streptokinase is most effective if given within the first 1.5 hours after the onset of symptoms of acute myocardial infarction." | Small sample of prehospital patients.
Weiss 1987 87245611 | Country: Israel Mean age: 57 Enrolled: Case 34 Control 84 Evaluated: 113 85.0% male Race: ND | Classic ischemic pain <4 hr, Evidence of transmural ischemia with ST segment >2 mm in >2 leads & reciprocal changes, Unresponsive to 5 mg isosorbide dinitrate & 10 mg nifedipine, Hx CAD allowed | >76 yr, Active peptic ulcer, Previous cerebrovascular accident, Bleeding tendency, SBP >200 mmHg, Hx AMI | Case-control/Time from symptom onset to treatment, Ejection fraction | IV streptokinase administration in AMI pts, diagnosed by hx & 12-lead ECG from MICU. Pts directly admitted to CCU. Early streptokinase administration for hospital patients. | Therapy administered by MICU resulted in significantly higher ejection fraction 62±8 vs the hospital pts, 55±14. Mean time from onset of pain to treatment was 1.0±0.4 hr for prehospital patients vs 1.9±0.9 hr for hospital patients. | "This study has shown that prehospital streptokinase infusion is feasible, practical, and relatively safe. By eliminating delays due to transport, hospital triage, and reevaluation, this strategy reduces the time from symptom onset to treatment initiation to a minimum." | Controls concurrent with study patients.
Roth 1990 90187590 | Country: Israel Mean age: 59 Enrolled: 118 Evaluated: 116 Case 72 Control 44 81% male Race: ND | <73 yr, Typical ACI pain >30 min & <4 hr, ST segment elevation >0.1 mV in >2 contiguous leads Hx AMI allowed | DBP >120 mmHg, Left BBB, Hx congestive heart failure or cardiac surgery, Terminal illness, Bleeding predisposition | Case-control/Time from symptom onset to treatment, Ejection fraction, Mortality | IV r-TPA administration in AMI pts by MICU. Pts directly admitted to CCU. Early r-TPA administration in hospital patients. | The ejection fraction for the prehospital patients was nonsignificant, 47±14 vs 48±15 for the hospital pts. Mean time from onset of pain to treatment was 94±35 min for prehospital patients vs 137±45 min for hospital patients, p<0.0001. Mortality at 60 days for prehospital patients was 4 & 3 for the hospital patients. | "It is concluded that myocardial infarction can be accurately diagnosed and thrombolytic therapy initiated relatively safely during the prehospital phase by the mobile intensive care team, thus instituting a beneficial clinical trend in favor of prehospital thrombolysis." | Patient allocation of treatment by MICU or CCU on alternating month basis. 2 pts excluded, 1 for pericarditis & 1 because ECG did not meet entry criteria. All deaths after 3 days & 1 death during 60-day period after discharge.
Kereiakes 1990 91022337 | Country: USA Mean age: ND Enrolled: ND Evaluated: Case 13 Control 196 % male ND Race: ND | ND | ND | Case-control/Time from admission to treatment | Prehospital 12-lead ECG with cellular telephone transmission capabilities obtained by paramedics and transmitted to ED physician. Time delays were tabulated. Time delays tabulated retrospectively for all AMI in-hospital patients treated after prehospital study period ended. | Mean time from hospital arrival to treatment for prehospital group, 36.3±11.3 vs 62.9±14.7 min for the controls, p<0.001. | "These results show that the magnitude of time required to evaluate, transport, and initiate thrombolytic therapy will preclude initiation of treatment to most patients within the first hour of symptoms. Implementation of a protocol-driven prehospital diagnostic strategy may be associated with a reduction in time to thrombolytic therapy." | Controls retrospectively tabulated. Eight other projects reported, but insufficient detail for inclusion.
Bouten 1992 92354594 | Country: Netherlands Mean age: Case 58 Control 60 Enrolled: ND Evaluated: Case 226 Control 220 % male Case 87.2% Control 74.5% Race: ND | <75 (70) yr, Chest pain >30 min & <6 (3) hr, Unresponsive to nitroglycerin sublingually, ST elevation >0.3 mV in >2 leads of V_1_-V_6_ or 0.2 mV in 2 leads of II/III/aVF with total ST deviation of >1.0 mV in absence of QRS complex >130 ms | Cardiac massage before evaluation, Stupor, Paresis or paralysis, Hx cerebrovascular accident, Uncontrolled hypertension, Bleeding disorder, Fall or head injury after onset of symptoms (Use of coumadins) | Case-control/Time from symptom onset to treatment, Mortality | 12-lead ECG was recorded & diagnosed by computer program if patient prehospital thrombolytic treatment eligibility was established by questionnaire administered by GP or ambulance nurse. Controls, also transported by ambulance, not eligible for prehospital thrombolytic therapy, received thrombolytic therapy after hospital evaluation. | Mean time from symptom onset to thrombolysis, 100±56 vs 166 min, case compared with controls. 6 pts died after hospital admission. In 1^st^ year after prehospital thrombolytic treatment, additional 4 pts died. | "The developed procedure allows rapid and safe initiation of thrombolytic therapy in selected patients, even in the absence of a physician. The observed low mortality supports the concept that prehospital thrombolytic therapy is indeed beneficial to the patient." | 426 of 9,052 pts with chest pain were eligible for hospital therapy. 226 of 426 pts selected by computer algorithm for treatment. At month 19 of 30-month study, change in inclusion/exclusion criteria. Appears in parentheses in Inclusion/exclusion columns. 6 pts treated twice during study period. Because of technical problems, 10 eligible pts were treated upon ED/CCU arrival.
Rozenman 1995 96020359 | Country: Israel Mean age: Case 58 Control 57 Enrolled: 760 Evaluated: Case 114 Control 646 81.6% male Race: ND | Ischemic chest pain <4 hr, ST segment >2 mm in >2 leads, Unresponsive to sublingual vasodilators, Hx CAD & ACI allowed | Bleeding tendency, Peptic ulcer, or previous recent cerebrovascular accident, Additional criteria for minority of patients: >75 yr, Hypertension >180/100 mmHg | Case-control/Time from symptom onset to treatment, Mortality | MICU staffed by physician, paramedic, & driver treated pts in their homes with thrombolytic therapy. ED pts treated with the same thrombolytic therapy as prehospital pts. | Mean time from symptom onset to thrombolysis, 1.4±08 vs 2.1±1.0 hr, prehospital pts compared with hospital pts, p<0.001. 5 prehospital pts died after hospital admission compared with 11 in-hospital treated pts, nonsignificant. | "We conclude that prehospital thrombolytic therapy is feasible and safe. Reperfusion is achieved earlier and more myocardium is salvaged using this strategy without increasing the rate of complications." | ND

BBB-bundle branch block; DBP-diastolic blood pressure; GP-general practitioner; hx-history; MICU-mobile intensive care unit; ms-millisecond; mV-millivolt; NA-not applicable; ND-no data; pt(s)-patient(s); r-TPA-r-tissue plasminogen activator; SBP-systolic blood pressure.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

Evidence Table 2. Diagnostic performance studies evaluating continuous/serial electrocardiography for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Diagnostic criteria for AMI | Diagnostic criteria for AMI/ACI: sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Hedges 1992 93073193 | Country: USA Mean age: 60.8 Enrolled: 420 Evaluated: 261 84% male Race: ND | >30 yr | ECG diagnostic for ACI, Chest discomfort explained by x-rays or trauma, Cardioversion within 24 hrs, Hematocrit <30%, Hemodynamically unstable, Potential thrombolysis candidate | 12-lead ECG at presentation, if ST-segment elevation <0.1 mV, second ECG at 3-4 hours. | ACI 40.2% AMI 10.7% (28/261) UA 29.5% (77/261) | ND | Two investigators' interpretations of SECGs were blinded to reference test and each other's results. | 2 of 3 criteria: Chest discomfort Serial cardiac enzyme elevations Evolution of ECG Q wave | 2 or more electrically contiguous ECG leads, one of following: ST-segment elevation or depression >0.1 mV ST-segment elevation or depression >0.05 <0.1 mV; T-wave inversion or normalization Q-wave development >20-msec and >0.33 total QRS height | "Serial changes in ECGs during a three- to four-hour interval were associated with the diagnosis of myocardial infarction but were infrequent and less accurate than serial CK-MB levels obtained for the same interval." | ND | 38% (159/420) of initial patients excluded for incomplete data. 66% patients from Veteran Affairs Medical Center. Did not include incremental information yield of additional test such as usefulness of SECG after serial CK-MB or vice versa. Sensitivity/specificity data could not be verified with data reported.
  AMI: Sens - 39.3% | Spec - 88.4%
  ACI: Sens - "25%" | Spec - "92%"
Gibler 1995 95100634 | Country: USA Avg age: 45.0 Enrolled: 1,010 Evaluated: 1,010 50.7% male Race: 59.7% Black 38.7% White 0.6% Asian 1.0% Other | >25 yr, or <25 yr with recent cocaine or sympathomimetic amine drug use, Chest pain unexplained radiograph | ECG diagnostic for ACI, SBP <90 mmHg, Hx CAD, Persistent or recurring chest pain suggesting unstable angina | 9-hour Heart ER Program based on: serial CK-MB at presentation, 3, 6 & hr 9; SECG at 20 sec interval for 9 hrs; at hr 9, hx & physical exam by cardiologist; 2-D echocardiography at rest; & graded exercise (maximal Bruce protocol) test. | ACI 4.3% AMI 1.2% (12/1,010) Angina/UA 3.1% (31/1,010) | NA | NA | ND | ACI: ST-segment increase or decrease >0.1 mV in 2 contiguous leads or >0.2 mV in 1 lead. Sens - 21.2% Spec - 99.4% | "The Heart ER program provides an effective method for evaluating low- to moderate-risk patients with possible acute ischemic coronary syndrome in the ED setting." | 28 released against medical advice before completion of Heart ER protocol. | Retrospective review of consecutive patients. One patient with negative evaluation returned to the ED 3 days later with AMI. 113 patients had cocaine use, of whom 10 were admitted by SECG detection, 3 had chest pain suggesting unstable angina, 2 had elevated CK-MB levels, & 1 had stroke.

hx-history; mV-millivolt; NA-not applicable; ND-no data; SBP-systolic blood pressure; SECG-serial electrocardiography; sens-sensitivity; spec-specificity.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 3. Diagnostic performance evaluating nonstandard electrocardiography for the diagnoses of acute cardiac ischemia in the emergency department (all patients admitted)

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Reference criteria for AMI | Diagnostic criteria for AMI or ACI: sensitivity/specificity | Study conclusion | Potential verification bias | Limitations/comments
Justis 1992 92171273 | Country: USA Mean age: 55.7 Enrolled: 212 Evaluated: 188 69.7% male Race: ND | ND | ND | 22-lead ECG performed within 3 hrs of presentation using digital cardiac electrogram technology. Each lead provides QRS data. | AMI 21.8% (41/188) (See Comments/limitations section) | Emergency physician blinded to 22-lead ECG results. ND on blinding of repeated ECG tests. | ND on prospective reading of 22-lead ECG. Retrospective reading not blinded to reference test. | CK-MB assay results >23 IU/mL taken at presentation & at 4 hr for 24 hrs, and at 24 hrs. | AMI: index >85. 22 leads with individual difference scores were converted to (ischemic) index. Sens "83%" Spec "76%" | "Combined with clinical judgement, 22-lead ECG could provide a 97.6% sensitivity for AMI diagnosis while reducing unnecessary admissions for 'rule out MI' by 69%." | 24 had incomplete 22-lead ECG data. 21 discharged from ED with noncardiac chest pain diagnosis or low risk of AMI and 19 returned for repeat 22- & 12-lead ECG and CK-MB analysis. | Sensitivity and specificity could not be verified with data reported. 188, not 163 as reported, was the evaluated study size. All 163 were admitted. The remaining 25 pts discharged, 24 with noncardiac chest pain or at low risk of AMI, and 1 had AMI.
Zalenski 1993 93228250 | Country: USA Mean age: 63.9 Enrolled: 149 Evaluated: 149 56.4% male Race: 97% White | Typical symptoms | <18 yr, Admitted for provisional diagnosis other than MI or UA | 15-lead ECG including standard 12-lead ECG with V_4R_, V_8_, and V_9_. | AMI 22.8% (34/149) | ND | Cardiologist blinded to patient clinical outcome. | Elevated CK total & CK-MB fraction >5% of total measured at 8 hr 3 times, or ECG ST-segment elevation with existing Q waves, or new pathologic Q waves. For UA, attending physician's diagnosis accepted. | 2 criteria for AMI: (1) ST-segment elevation: >0.1 mm rise in at least 1 lead, or >0.5 mm in posterior leads if R waves <10 mm. Sens 58.8% Spec 93.0% (2) Thrombolytic therapy: >1.0 mm ST-segment elevation in 2 anatomically contiguous leads, posterior leads considered contiguous to inferior or lateral leads, & V_4R_ considered contiguous to inferior leads. Sens 44.1% Spec 99.1% | "15-lead ECG provides increased sensitivity and odds of detecting ST-segment elevation in AMI with no loss in specificity." | ND | Hospital admission not consecutive.
Spadafore 1996 97035893 | Country: USA Mean age: 59.6 Enrolled: 75 Evaluated: 52 63.4% male Race: ND | >30 yr, Cardiac-related chest pain >5 min, Hx CAD allowed | Left or right bundle branch block, Atrial fibrillation as baseline cardiac rhythm | 24-lead VC including 12-lead ECG plus 12 auxiliary leads capable of inputting computer data. | ACI 48.1% AMI 25.0% (13/52) UA 23.1% (12/52) | Physicians blinded to VC results. | Readers of VC not blinded to reference results. | Characteristic clinical presentation and either: ST-segment elevation in 2 contiguous chest leads >0.2 mV or 2 contiguous limb leads >0.1 mV, or CK-MB >8 ng/mL with elevated CK index within 24 hr of admission. | ACI: index >75. Individual lead variances are mathematically combined to derive overall index. Sens 96.0% Spec 40.7% | VC with index <75, "in addition to clinical impression and initial ECG, may identify chest pain patients who do not have significant CAD." | 23 excluded: VC malfunction (6), patient request and/or misplacement of data (4), bundle branch block or atrial fibrillation (7), inadequate cardiac evaluation (5), death from MI (1). | All AMI pts were male. All pts with positive 12-lead ECGs were enrolled.
Zalenski 1997b 97345852 | Country: USA Mean age: 65.9 Enrolled: 603 Evaluated: 533 62.6% male Race: 92.6% White | >35 yr | Clinically unstable for acquisition of extra leads, >5 min to separate initial 12 and 6 extra leads, No followup ECG (>12 hr after initial ECG), <2 CK determinations >12 hrs apart | 18-lead ECG including 12-lead ECG plus 3 posterior leads, V_7_, V_8_, V_9_, and 3 right ventricular leads, V_4R_, V_5R_, V_6R_. Followup 18-lead ECGs during hospital course. | AMI 64.7% (345/533) | Cardiologist reading initial 12-lead ECG blinded to clinical, outcome and 18-lead ECG results. Physicians treating patients not blinded to 18-lead ECG results. | Cardiologist blinded to first reader's results and reference results. | Elevated or twofold doubling CK total & CK-MB fraction >5% of total, or pathologic Q waves >2 leads. | AMI: >0.1 mV ST-segment elevation in 2 anatomically contiguous leads. Sens 66.1% Spec 84.0% | For detection of AMI, the 15-lead ECG offers [a modest improvement]. | Data for 66 of 70 excluded: lengthy time relapse between 12 & 6 extra leads tracings (26), no serial CK or ECGs >12 hrs apart (17), other exclusion factors (23). | Single cardiologist used to read all ECG results. No difference between included & excluded group for gender & race, but excluded were younger, 61.1 vs 65.9 yrs.

hx-history; mV-millivolt; ND-no data; pt(s)-patient(s); sens-sensitivity; spec-specificity; VC-variance cardiography.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 4a. Diagnostic performance studies evaluating electrocardiographic exercise stress test for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Reference criteria for AMI | Diagnostic criteria for ACI: sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Kirk 1998 98321097 | Country: USA Avg age: 49 Enrolled: 223 Evaluated: 212 57% male Race: ND | Low-risk patients by ECG, Hx CAD allowed | ECG diagnostic for ACI or repolarization abnormalities, Inability to perform exercise test, Clinically evident left ventricular dysfunction | Modified Bruce protocol | ACI 6.1% AMI 1.4% (3/212) UA 4.7% (10/212) | ND | ND | AMI: rise & fall of CK-MB fraction to normal levels. | >1 mm horizontal or downsloping ST-depression or elevation for 80 ms after J point. Sens - 100% Spec - 92.5% | "This study demonstrates the safety and utility of immediate exercise testing in a large group of low-risk patients presenting to the ED with chest pain." | ND | Test deferred in 11 patients by ED physician, but no cardiac events occurred.
Lewis 1999 99289029 | Country: USA Mean age: 58 Enrolled: 100 Evaluated: 100 64% male Race: ND | Low-risk patients who were subsequently admitted to ED chest pain unit, Patients with CAD hx | ECG diagnostic for ACI, ST-segment & T-wave Δ that would preclude accurate interpretation of exercise ECG results, Inability to perform exercise test, X-ray showing acute pulmonary or vascular disease, Heart failure, Pulse deficits implying aortic dissection, Noncardiac chest pain | Modified Bruce protocol; two 1.7-mph stages at 0% & 5% incline preceding standard Bruce protocol. | ACI 10.0% AMI 2.0% (2/100) UA 8.0% (8/100) | Stress test results not blinded & used in final diagnosis of UA. | ND | Chest pain and either serial ECG Δ or abnormal cardiac isoenzymes. | Diagnostic ECG Δ (>1 mm horizontal or down-sloping ST-segment depression or elevation 80 ms after J point), significant arrhythmia, systolic blood pressure decrease of >10 mmHg or significant symptoms. Sens 70.0% Spec 82.2% | For low-risk patients with chest pain & known CAD, immediate exercise stress test is effective in further stratification for discharge or admission. | ND | Study sample not consecutive patients, based on physician referral. 14 had no records for hx CAD verification.

hx-history; ms-millisecond; ND-no data; sens-sensitivity; spec-specificity; Δ-change.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 4b. Clinical impact studies evaluating electrocardiographic exercise stress test to manage acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Prevalence of disease | Study design/comparisons | Diagnostic protocol | Diagnostic criteria for ACI | Outcomes | Study conclusions | Limitations/comments
Tsakonis 1991 92029201 | Country: USA Mean age: 44.8 Enrolled: 28 Evaluated: 28 82.1% male Race: ND | Patients <66 yr, Able to exercise on treadmill, Likelihood patient required admission | Hx of symptoms consistent with angina or chest pain associated with dyspnea & diaphoresis, Cardiac hx, Cardiac meds (except antihypertensive meds) Abnormal ECG including: bundle branch block, evidence of hx MI, left ventricular hypertrophy with strain, 2° or 3° atrioventricular heart block, ST-segment elevation or depression >1 mV, T-wave inversion except leads II, aVR, or V_1_ | 0/28 cardiac events | Cohort - prospective/NA | Modified Bruce protocol with continuous heart rate and 3-lead ST-segment monitoring. 12-lead ECG at rest, post-peak exercise, and study conclusion. | >.1 mV ST-depression for 80 ms after J point at peak exercise. 17.9% (5/28) had positive test. 4 were discharged and 1 refused further workup & was lost to followup. The remaining 23 tested negative. | No cardiac events reported. 1, 6, 12 months by telephone (mean 6.1). | "It was concluded that early exercise treadmill test of selected ED patients with chest pain is safe, and an exercise test administered during the ED visit which is negative can preclude unnecessary hospitalization." | Selected study patients for preliminary report. Chest pain experienced by 1 patient but completed test.
Kerns 1993 93228251 | Country: USA Mean age: Cases - 35 Controls - 40 Enrolled: Cases - ND Controls - 50 Evaluated: Cases - 32 Controls - 26 Cases: 62.5% male Controls: 50.0% male Race: ND | Cardiac chest pain not suggestive of angina by quality, duration, precipitating factors, & associated symptoms, Men 18-39 yr, Women 18-49 yr, None or only 1 risk factor: 10 pack-year smoking hx, Documented hx total serum cholesterol >260 mg/dL or family hx MI <60 yr | Moderate suspicion of ACI based on hx or ECG 2 or more risk factors: Documented hx CAD, Hx insulin-dependent or noninsulin-dependent diabetes, Meds including beta-blockers, calcium channel blockers, or digoxin, Hx hypertension tx or ED readings SBP >160 mmHg or DBP >95 mmHg, Cocaine use <24 hr, Inability to perform exercise test | 0/32 cardiac events | Case-control/Retrospective, inpatient controls | Bruce protocol with age-predicted target heart rate. The study group (cases) & controls tested with same technology. | For cases & controls, all results were normal, no symptoms or ECG changes suggestive of ischemia. All cases discharged. | No cardiac event or sudden death reported. 3 & 6 months by telephone. | Exercise test "is a safe, efficient, cost-effective, and practical method of evaluating selected ED patients with chest pain. It is a useful aid for clinical decision making & may help to prevent unnecessary hospital admissions." | Average ED stay 5.5 hr, for majority, 2.5 hr for test. Retrospective controls of selected inpatients with same inclusion/exclusion criteria as cases. There are no ACI events in either case or control group.
Kirk 1998 98321097 | Country: USA Avg age: 49 Enrolled: 223 Evaluated: 212 57% male Race: ND | Low-risk patients by ECG, Hx CAD allowed | ECG diagnostic for ACI or repolarization abnormalities, Inability to perform exercise test, Clinically evident left ventricular dysfunction | ACI 6.1% (13/212) AMI 1.4% (3/212) UA 4.7% (10/212) | Cohort - prospective/NA | Modified Bruce protocol | >1 mm horizontal or downsloping ST-depression or elevation for 80 ms after J point. | 59.0% (125/212) tested negative & 27.8% (59/212) had nondiagnostic tests. All negative & 55 nondiagnostic patients were discharged. 13 of 28 test positive resulted in 3 MI, 10 UA. No mortality or morbidity for 95% (205) patients followed for 30 days. | "This study demonstrates the safety and utility of immediate exercise testing in a large group of low-risk patients presenting to the ED with chest pain." | Test deferred in 11 patients by ED physician, but no cardiac events occurred. Followup by telephone, review of coroner's records, & medical record of return visits or hospitalization.

hx-history; meds-medications; ms-millisecond, mV-millivolt; NA-not applicable; ND-no data; SBP-systolic blood pressure.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

Evidence Table 5a. Diagnostic performance studies evaluating presentation CK for AMI in the ED

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Eisenberg 1979 79216896 | Country: USA Mean age: ND Age range: ND Enrolled: 129 Evaluated: 80 % male: ND Race: ND | Chest pain, Age >30 yrs | Chest trauma | WHO criteria: 2 of: history of typical chest pain; an ECG diagnostic of AMI; cardiac enzyme values diagnostic of AMI | 16% (13/80) | Cardiologist reading ECG blind to test results | Pathologist categorizing test results blind to clinical and ECG data | ND | 54 | 82 | "The availability of immediate CK determinations might have appropriately changed the clinical course of only 1 patient…and could have caused the inappropriate discharge of 5 and inappropriate admission of 11…. As a result of these findings the Hospital of the University of Pennsylvania decided not to provide CK determinations as a 'stat' procedure for the emergency room." | 29 patients missing data or refused consent were omitted from analysis. None of excluded was admitted to the ICU. Compared to 46 included subjects also not admitted to the ICU, no difference in age, race, sex, chief complaint, or percent dead or diagnosed with AMI at 2, 10, and 18 month followup.
Roxin 1984 84253059 | Country: Sweden Median age: 67 yrs Age range: 20-89 yrs Enrolled: ND Evaluated: 305 65% male Race: ND | "Referred to hospital on suspicion of AMI." | ND | WHO criteria: central CP of at least 15-minute duration, or shock or pulmonary edema without any other known cause, in combination with either evolving typical ECG changes or elevations of serum enzymes (AST) | 26% (80/305) | ND | ND | CK >326.5 U/L at presentation (Data reported for CK >200 U/L) ^4^ [Data reported for CK >326.5 U/L] ^4^ | 28 (40) ^4^ [27] ^4^ | 96 (86) [96] | "This investigation clearly demonstrated the advantages of serum myoglobin determinations in the early diagnosis of AMI…compared to CK." | 22 patients diagnosed with "probable AMI" and 125 with "possible AMI" were omitted from reported analysis. Included in meta-analysis as no AMI.
Lee 1987 87099052 | Country: USA Mean age: 54 yrs Age range: ND Enrolled: 1,055 Evaluated: 639 48% male Race: ND | Chief complaint of chest pain, Age >30 yrs | Local trauma, Abnormal CXR explaining CP, Failure to follow up at 48-72 hrs | 1 of: characteristic evolution of serum enzyme levels (CK-MB or LDH); characteristic ECG changes; positive Technicium-99 scintiscan; sudden death within 72 hours | 16% (104/639) | No | ND | CK >180 U/L in men or >160 U/L in women at presentation | 38 | 80 | "Single values of cardiac enzymes are not sensitive enough to be used to exclude AMI." | 416 patients omitted: 411 patients missing data, 3 patients transferred to other hospitals, 2 patients could not have AMI verified or excluded. | Data also available by duration of symptoms.
Hedges 1987 87126033 | Country: USA Mean age: 54 yrs (60% < 50 yrs) Age range: ND Enrolled: 861 Evaluated: 773 39% male Race: ND | Chest pain, Age >30 yrs | Thoracic trauma, CXR explaining CP | 1 of: characteristic serial cardiac isoenzyme changes; ECG changes indicating an acute infarct pattern; radionuclide imaging consistent with AMI | 7% (51/773) | No | ND | CK >120 U/L in men or >100 U/L in women at presentation (Data available for CK >200 in men and women) | 55 (43) | 65 (91) | "Clinical suspicion must be given credence over a negative cardiac enzyme test in the ED." | 97 patients had missing lab data. 2 of these had AMI. However, there is an error in either the number of nonevaluable subjects or in the total number enrolled.
Viskin 1987 87187445 | Country: Israel Mean age: 56 yrs Age range: 27-89 yrs Enrolled: 300 Evaluated: 252 71% male Race: ND | Chest pain, Age >25 yrs | Traumatic chest pain | 1 of: elevated CK-MB, LDH, or AST; characteristic ECG changes; postmortem examination | 30% (76/252) | No | ND | CK >140 U/L in men or >100U/L in women at presentation | 38 | 93 | "The CK test is a very important step in the ED evaluation of patients' CP." | 48 patients omitted: 37 had incomplete ED data, 10 had incomplete followup after 3 months, 1 had Duchenne's muscular dystrophy. | Discharge patients had followup in 3-7 days and within 4 months. Data also available by duration of symptoms.
Mair 1991a 91266415 | Country: Austria Mean age: ND Age range: ND Enrolled: ND Evaluated: 96 % male: ND Race: ND | ND | ND | WHO criteria | 24% (23/96) | Cardiologist blind to test results | ND | CK >80 U/L in men or >70 U/L in women at presentation | 35 | 89 | None specific to presentation CK | ND
Mair 1991b 92081650 | Country: Austria Mean age: ND Age range: ND Enrolled: ND Evaluated: 126 % male: ND Race: ND | Chief complaint CP | Chest contusion or trauma | WHO criteria | 40% (51/126) | Cardiologist blind to test results | ND | CK >80 U/L in men or >70 U/L in women at presentation | 44 | 82 | None specific to presentation CK | ND
Thomson 1995 95150309 | Country: USA Mean age: 63 yrs Age range: 31-94 yrs Enrolled: 511 Evaluated: 383 61% male Race: ND | Anterior or left lateral CP, Age >20 yrs | Infection in the previous week, exogenous glucocorticoid use within the previous month, Malignancy in the previous 5 yrs, Transfer from other hospital, Major trauma, major gastrointestinal bleeding, surgery, dialysis, or resuscitation in the previous week, Insufficient data to exclude AMI, Insufficient followup | 1 of: elevated CK-MB within 48 hours; sudden, unexplained death within 72 hours | 18% (69/383) | Cardiologists blind to test results | ND | CK >336 U/L in men or >176 U/L in women at presentation | 42 | 93 | "Individual peripheral blood markers lacked the extremely high specificity needed to produce clinically useful high positive predictive values." | 17/20 discharged patients did not return for followup, 17 admitted patients had incomplete lab data, 94 omitted due to exclusion criteria. | 11 patients who presented twice and 3 patients who presented 3 times were included for each visit. "Exclusion of the 17 repeat visits…had little effect on the results; the major effect was only a 1 to 2% increase in the sensitivity."
Gornall 1996 96426690 | Country: Canada Mean age: ND Age range: 29-86 yrs Enrolled: ND Evaluated: 98 63% male Race: ND | CP in the ED in whom the diagnosis was not clear | Diagnostic ECG, History and physical examination in the ED was able to identify an alternative cause of the pain and the ECG was normal, Trauma | WHO criteria: 2 of: typical CP; elevated serial CK-MB; evolution of changes on serial ECGs | 41% (40/98) | No | ND | CK >170 U/L in men or >140 U/L in women at presentation | 28 | 86 | "The traditional enzyme tests [including CK] have…virtually no value in assessing patients with acute chest pain in the emergency room." | ND | Study supported by Dade Diagnostics division of Baxter Canada
Hetland 1996 97186735 | Country: Norway Mean age: ND Age range: 31-94 yrs Enrolled: ND Evaluated: 133 69% male Race: ND | Chest discomfort, suggestive of AMI, Arrive in ED between 8 am and 10 pm | CP >6 hours, Trauma | Characteristic CP >20 minutes and evolution of serial ECG changes and elevated serial CK-MB | 34% (45/133) | ND | ND | CK >200 U/L at presentation | 7 | 93 | None specific to presentation CK | ND
Laurino 1997 97448847 | Country: USA Mean age: 64 yrs Age range: ND Enrolled: ND Evaluated: 115 57% male Race: ND | Chief complaint of CP, Symptoms consistent with AMI or ischemia | Thrombolytic therapy | WHO criteria: 2 of: clinical features/CP; ECG changes; elevated CK and CK-MB | 22% (25/115) | ND | Laboratory personnel blind to patient diagnosis | CK >220 U/L at presentation (Data reported for CP <6 hours) [Data reported for CP >6 hours] | 16 (0) [50] | ND (ND) [ND] | None specific to presentation CK | ND | Although patients without AMI were included, specificity data were not presented.

CP-chest pain; CXR-chest radiograph; ICU-intensive care unit; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

147 of 305 patients with possible or "cannot rule out" AMI not included.

Evidence Table 5b. Diagnostic performance studies evaluating presentation CK for AMI in the ED (other clinical studies)

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Tucker 1994 94379543 | Country: USA Mean age: ND Age range: ND Enrolled: 193 Evaluated: 133 % male: ND Race: ND | Chest discomfort, Symptoms prompting physician to order cardiac enzymes in ED, Admission to hospital | CP >24 hours | ND | 29% (39/133) | ND | ND | ND | 51 | 82 | None specific to presentation CK | 60 patients omitted: 30 discharged from ED; 17 had more than 24 hours of symptoms; 6 had improper lab work collection; 6 had no consent; 1 was transferred to another facility | "The high prevalence of AMI in the study population may reflect our center's emphasis on cardiac disorders and subsequent self-referral of individuals with suspected ischemic heart disease to our ED."
Tucker 1997 97264134 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 177 62% male Race: ND | Chest discomfort, Clinical suspicion of AMI was sufficiently great for physician to order ECG and cardiac lab work, Age >30 years, Admission to hospital | CP >24 hours, Diagnostic ECG, Cardiopulmonary resuscitation, Trauma, Fewer than 4 of 5 planned blood draws | WHO criteria: 2 of: clinical history of chest discomfort > 30 minutes; evolution of serial ECG changes; elevated serial CK and CK-MB | 15% (27/177) | No | ND | CK >170 U/L in men or >135 U/L in women at presentation | 30 | 84 | None specific to presentation CK | Patients discharged from ED excluded | Multiple authors employed or supported by Baxter Diagnostics of Dade International.
Young 1993 93371607 | Country: USA Mean age: 57 Age range: ND Enrolled: 222 Evaluated: 222 95% male Race: ND | Admitted to CCU via ED with "rule out" AMI or UAP | Discharge from ED | WHO criteria | 19% (43/222) | ND | No | CK >232 U/L at presentation (Data reported for patients with <24 hours CP) | 40 (52) | ND (ND) | "CK was as accurate as CK-MB in the ED and cardiac enzymes drawn in the ED detected more than 50% of the AMI patients presenting within 24 hours of symptoms onset." | None reported | Although patients without AMI were included, specificity data were not presented. Retrospective study of CCU admissions via the ED at a Veterans Affairs hospital.

CP-chest pain; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 6. Diagnostic performance studies evaluating serial CK for AMI in the ED

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Gerhardt 1982 82115732 | Countries: Scandinavia Mean age: ND Age range: ND Enrolled: ND Evaluated: 481 % male: ND Race: ND | Symptoms indicative of patients having had an AMI within the previous 24 hours | ND | WHO criteria: 2 of: patients history; evolution of ECG changes; elevated serial AST, LDH, or CK | 43% (207/481) | Yes | ND | CK >200 U/L in men or >150 U/L in serial tests drawn at hours 10 and 16 after onset of CP | 99 | 68 | "CK remained a poor tool for verification of AMI. In contrast, CK appeared to be an excellent tool for early exclusion of AMI." | ND | Blood work was drawn at times dependent on onset of CP, not dependent on arrival time to ED.
Roxin 1984 84253059 | Country: Sweden Median age: 67 yrs Age range: 20-89 yrs Enrolled: ND Evaluated: 305 65% male Race: ND | "Referred to hospital on suspicion of AMI." | ND | WHO criteria: central CP of at least 15-minute duration, or shock or pulmonary edema without any other known cause, in combination with either evolving typical ECG changes or elevations of serum enzymes (AST) | 26% (80/305) | ND | ND | CK >326.5 U/L in serial tests drawn at presentation and every 2-4 hours for 15 hours (Data reported for CK > 200 U/L in serial tests for 4 hours) ^4^ [Data reported for CK >200 in serial tests for 15 hours] ^4^ {Data available for CK >326.5 U/L in serial tests for 4 hours} ^4^ <Data available for CK >326.5 U/L in serial tests for 15 hours> ^4^ | 89 (69) ^4^ [95] ^4^ {59} ^4^ <89> ^4^ | 89 (84) ^4^ [82] ^4^ {94} ^4^ <92> ^4^ | "This investigation clearly demonstrated the advantages of serum myoglobin determinations in the early diagnosis of AMI…compared to CK." | 22 patients diagnosed with "probable AMI" and 125 with "possible AMI" were omitted from analysis.

CP-chest pain; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

4 147 of 305 patients with possible or "cannot rule out" AMI not included.

Evidence Table 7a. Diagnostic performance studies evaluating presentation CK-MB for AMI in the ED

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Mair 1991b 92081650 | Country: Austria Mean age: ND Age range: ND Enrolled: ND Evaluated: 126 % male: ND Race: ND | Chief complaint CP | Chest contusion or trauma | WHO criteria | 40% (51/126) | Cardiologist blind to test results | ND | CK-MB >7 ng/ml at presentation (Data available for CK-MB >10 U/L & >6% at presentation) | 57 (32) | 92 (92) | None specific to presentation CK-MB | ND
Collins 1993 93358506 | Country: United Kingdom Mean age: ND Age range: ND Enrolled: ND Evaluated: 195 % male: ND Race: ND | CP suggestive of AMI, Patients referred acutely to the cardiologists | ND | ECG and CK, CK-MB analysis | 42% (81/195) | No | ND | CK-MB >7 ng/ml at presentation (Data available for CK-MB thresholds of 0 ng/ml to 12 ng/ml) | 52 | 97 | "This assay of CK-MB (ICON QSR) can increase the number of diagnoses of AMI made within the time scale required for the successful administration of thrombolytic therapy." | Patients discharged from ED excluded
Brogan 1994 94379537 | Country: USA Mean age: 59 yrs Age range: ND Enrolled: ND Evaluated: 189 % male: ND Race: ND | Chief complaint of 1 or more of: chest discomfort, shortness of breath, syncope, congestive heart failure, pulmonary edema, epigastric pain, new symptomatic dysrhythmia | Symptoms >12 hours, Trauma, Renal failure, Muscular dystrophy | WHO criteria: clinical presentation, serial ECGs, cardiac enzymes (CK) | 12% (22/189) | ND | ND | CK-MB >9 ng/ml and >2% at presentation | 23 | 99 | None specific to presentation CK-MB | ND | Study supported in part by a grant and supplies from Baxter Diagnostics
Castaldo 1994 94368914 | Country: Italy Median age: 59 yrs Age range: 33-80 yrs Enrolled: ND Evaluated: 157 64% male Race: ND | CP, Referred from the emergency cardiology department, Only subjects with a high prediction of AMI | CP >2 hours | WHO criteria | 37% (58/157) | ND | ND | CK-MB >5% at presentation | 22 | 98 | Release of CK-MB occurs later than myoglobin in AMI. | ND | Data collected by duration of CP, not by time in ED
Montague 1995 96026068 | Country: USA Mean age: 65 yrs Age range: 39-91 yrs Enrolled: 132 Evaluated: 89 70% male Race: ND | CP or suspected AMI | Trauma, Renal failure or insufficiency | WHO criteria: clinical history and cardiac enzymes | 28% (25/89) | Yes; however, one patient reclassified after myoglobin results | ND | CK-MB >5 ng/ml at presentation (Data available for CK-MB >2.5%) | 36 (32) | 98 (89) | "The sensitivity of myoglobin exceeded that of CK-MB…at presentation…. The specificity of myoglobin was less than that of CK-MB." | 43 patients omitted: 37 with only one blood draw, 6 with renal failure | Supplies provided by Dade International, Inc.
Thomson 1995 95150309 | Country: USA Mean age: 63 yrs Age range: 31-94 yrs Enrolled: 511 Evaluated: 375 61% male Race: ND | Anterior or left lateral CP, Age >20 yrs | Infection in the previous week, Exogenous glucocorticoid use within the previous month, Malignancy in the previous 5 yrs, Transfer from other hospital, Major trauma, major gastrointestinal bleeding, surgery, dialysis, or resuscitation in the previous week, Insufficient data to exclude AMI, Insufficient followup | 1 of: elevated CK-MB within 48 hours; sudden, unexplained death within 72 hours | 18% (68/375) | Cardiologists blind to test results | ND | CK-MB >4.7 ng/ml at presentation | 56 | 93 | "Individual peripheral blood markers lacked the extremely high specificity needed to produce clinically useful high positive predictive values." | 17/20 discharged patients did not return for followup, 25 admitted patients had incomplete lab data, 94 omitted due to exclusion criteria. | 11 patients who presented twice and 3 patients who presented 3 times were included for each visit. "Exclusion of the 17 repeat visits…had little effect on the results; the major effect was only a 1 to 2% increase in the sensitivity."
Hetland 1996 97186735 | Country: Norway Mean age: ND Age range: 31-94 yrs Enrolled: ND Evaluated: 133 69% male Race: ND | Chest discomfort suggestive of AMI, Arrive in ED between 8 am and 10 pm | CP >6 hours, Trauma | Characteristic CP >20 minutes and evolution of serial ECG changes and elevated serial CK-MB | 34% (45/133) | ND | ND | CK-MB >5 ng/ml at presentation (Data available for CK-MB >12 U/L) | 44 (24) | 98 (99) | "Beyond 3 hours [from onset of CP] CK-MB… provide[s] information additional to that of the ECG for ruling in AMI." | ND
Mair 1996 96233850 | Country: Austria Mean age: 62 yrs Age range: ND Enrolled: 101 Evaluated: 100 68% male Race: ND | CP | Trauma | 2 of: typical severe symptoms for more than 20 minutes; new abnormalities on serial ECGs; elevated serial CK and CK-MB | 39% (39/100) | No | ND | CK-MB >5 ng/ml at presentation | 59 | 89 | "CK-MB mass… [was] significantly more sensitive before thrombolytic therapy within 4 hours after onset of AMI." | 1 patient missing from CK-MB analysis; discrepancy not explained.
Gornall 1996 96426690 | Country: Canada Mean age: ND Age range: 29-86 yrs Enrolled: ND Evaluated: 98 63% male Race: ND | CP in the ED in whom the diagnosis was not clear | Diagnostic ECG, History and physical examination in the ED was able to identify an alternative cause of the pain and the ECG was normal, Trauma | WHO criteria: 2 of: typical CP; elevated serial CK-MB; evolution of changes on serial ECGs. | 41% (40/98) | No | ND | CK-MB >8 ng/ml at presentation | 25 | 98 | "The traditional enzyme tests [including CK-MB] have… virtually no value in assessing patients with acute chest pain in the emergency room." | ND | Study supported by Dade Diagnostics division of Baxter Canada
Hedges 1996 96363164 | Country: USA Mean age: 57 yrs Age range: ND Enrolled: 1,055 Evaluated: 1,042 68% male Race: ND | Chest discomfort, Age >25 yrs | Diagnostic ECG, Cardioversion within 24 hours Clinically unstable, Trauma, CXR explaining CP, Transfer from another institution | WHO criteria: 1 of: elevated serial CK-MB and other cardiac enzyme; new Q waves on serial ECGs | 6% (67/1,042) | No | ND | CK-MB >7 ng/ml at presentation | 57 | 96 | None specific to presentation CK-MB | 13 patients omitted due to incomplete data "The clinical follow-up of patients released from the ED was limited." | Study funded in part by Hybritech Corporation and Genentech Corporation
Laurino 1997 97448847 | Country: USA Mean age: 64 yrs Age range: ND Enrolled: ND Evaluated: 115 57% male Race: ND | Chief complaint of CP, Symptoms consistent with AMI or ischemia | Thrombolytic therapy | WHO criteria: 2 of: clinical features/CP, ECG changes, elevated CK and CK-MB | 22% (25/115) | ND | Laboratory personnel blind to patient diagnosis | CK-MB >6 ng/ml at presentation (Data reported for CP <6 hours) [Data reported for CP >6 hours] | 20 (0) [63] | ND (ND) [ND] | None specific to presentation CK-MB | ND | Although patients without AMI were included, specificity data were not presented.

CP-chest pain; CXR-chest radiograph; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 7b. Diagnostic performance studies evaluating presentation CK-MB for AMI in the ED (other clinical studies)

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Gibler 1987 87296931 | Country: USA Mean age: ND Age range: ND Enrolled: 73 Evaluated: 59 % male: ND Race: ND | CP, Age >30 yrs, Admission to hospital | Trauma, Abnormal CXR explaining CP | WHO criteria: CP; new Q waves on serial ECGs; elevated serial CK, LDH | 36% (21/59) | ND | ND | ND on threshold CK-MB level. Blood work drawn at presentation | 14 | 97 | "While CK-MB is a highly specific indicator of myocardial cell injury and death, it remains less sensitive than myoglobin as an early indicator of AMI." | Patients discharged from ED excluded 14 subjects omitted: 9 with missing lab work, 5 without consent | Study supported in part by the Proctor & Gamble Company
Gibler 1990 91052596 | Country: USA Mean age: 62 yrs Age range: 33-87 yrs Enrolled: 186 Evaluated: 183 77% male Race: ND | CP, Age >30 yrs, Admission to hospital | Trauma, Abnormal CXR explaining CP | WHO criteria: CP; new Q waves on serial ECGs; elevated serial CK, CK-MB | 17% (31/183) | Yes | ND | CK-MB >7.5 ng/ml on Corning Magic™-Lite at presentation (Incomplete data available for different thresholds on different machines) | 55 (Range 50-62) | 97 (Range 84-97) | "CK-MB determination offers an attractive test for early AMI diagnosis as it is recognized by the majority of physicians treating patients with CP as a specific indicator for myocardial damage…. The determination of the initial CK-MB concentration…is reliable only 50% of the time on presentation to the ED." | Patients discharged from ED excluded 3 subjects omitted: 1 with initial CK >4000; 1 with incomplete data; 1 whose CP occurred in hospital | Study supported in part by Hybritech, Inc., and Ciba-Corning Diagnostics, Inc.
Marin 1992 92142994 | Country: USA Mean age 66 yrs Age range: ND Enrolled: 400 Evaluated: 313 59% male Race: ND | CP consistent with AMI or ischemia, Admission to hospital | CP >12 hours, CP readily explained by physical or radiographic findings, Transfer to other hospital, No final diagnosis available | 1 of: abnormal serial ECG changes; elevated serial CK-MB | 22% (70/313) | ND | Yes | CK-MB >7.5 ng/ml at presentation (Data available for CK-MB >4 ng/ml) | 41 (76) | 95 (72) | CK-MB as a single test is not "sufficiently discriminatory to be useful for diagnosis." | Patients discharged from ED excluded 87 patients omitted: 62 had no diagnosis due to insufficient data documenting the cause of CP; 22 enrolled more than 12 hours after symptom onset; 3 had missing data | Study supported in part by Genentech, Inc., and Ciba-Corning Diagnostics, Inc.
Tucker 1994 94379543 | Country: USA Mean age: ND Age range: ND Enrolled: 193 Evaluated: 133 % male: ND Race: ND | Chest discomfort, Symptoms prompting physician to order cardiac enzymes in ED, Admission to hospital | CP >24 hours | ND | 29% (39/133) | ND | ND | CK-MB >5 ng/ml at presentation | 33 | 99 | None specific to presentation CK-MB | 60 patients omitted: 30 discharged from ED; 17 had more than 24 hours of symptoms; 6 had improper lab work collection; 6 had no consent; 1 was transferred to another facility | "The high prevalence of AMI in the study population may reflect our centers emphasis on cardiac disorders and subsequent self-referral of individuals with suspected ischemic heart disease to our ED."
Apple 1995 95393615 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 98 % male: ND Race: ND | CP, Admission to hospital | ND | CP, ECG changes and elevated serial changes in CK-MB levels | 6% (6/98) | ND | ND | CK-MB >5 ng/ml at presentation | 100 | 86 | CK-MB is equally sensitive as troponin I, but less specific | Patients discharged from ED excluded | Immunoassay kits (for troponin T) provided by Boehringer Mannheim Corporation Mean time from onset of CP for all patients was 14 hours; for patients with AMI was 7.4 hours
Tucker 1997 97264134 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 177 62% male Race: ND | Chest discomfort, Clinical suspicion of AMI was sufficiently great for physician to order ECG and cardiac lab work, Age >30 years, Admission to hospital | CP >24 hours, Diagnostic ECG, Cardiopulmonary resuscitation, Trauma, Fewer than 4 of 5 planned blood draws | WHO criteria: 2 of: clinical history of chest discomfort >30 minutes; evolution of serial ECG changes; elevated serial CK and CK-MB | 15% (27/177) | No | ND | CK-MB >5 ng/ml at presentation | 26 | 97 | None specific to presentation CK-MB | Patients discharged from ED excluded | Multiple authors employed or supported by Baxter Diagnostics of Dade International.
Kontos 1997a 97156085 | Country: USA Mean age: 58 yrs Age range: ND Enrolled: 110 Evaluated: 101 55% male Race: ND | CP, Admission to CCU | ND | WHO criteria: 2 of: evolving diagnostic ECG changes; elevated serial CK and CK-MB; prolonged cardiac CP | 20% (20/101) | ND | ND | CK-MB >4.7 ng/ml on Baxter Straus II or CK-MB >8 ng/ml on Behring Opus Plus at presentation | 30 | 100 | None specific to presentation CK-MB | Patients discharged from ED and patients admitted to non-CCU beds excluded 9 patients omitted due to missing lab work
Fesmire 1998 98368382 | Country: USA Mean age: 56 yrs Age range: ND Enrolled: 1,000 Evaluated: 764 59% male Race: ND | CP, Admission to hospital | Recent cocaine use, Tachyarrhythmia, Pulmonary edema, Demand pacemaker | WHO criteria: elevated serial CK and CK-MB; new Q waves on serial ECGs; patient death within 24 hours | 20% (155/764) | ND | ND | CK-MB >6 ng/ml at presentation | 44 | 97 | None specific to presentation CK-MB | 236 patients did not have lab work at 2 hours after presentation and were excluded from all analyses | 54 patients (52 with AMI) were excluded from article's analysis because initial CK-MB >12 U/L. These patients were included in the calculations in this report.
Kontos 1999a 99171821 | Country: USA Mean age: 58 yrs Age range: ND Enrolled: 2,784 Evaluated: 2,093 % male: ND Race: ND | Admission to CCU from ED with suspected AMI | Diagnostic ECG, Cardiac or respiratory arrest | Symptoms consistent with AMI and elevated serial CK-MB. Some also required elevated serial troponin I | 9% (186/2,093) | ND | ND | CK-MB >8 ng/ml and >4% at presentation | 46 | 99 | None specific to presentation CK-MB | Patients discharged from ED and patients admitted to non-CCU beds excluded 691 patients omitted: 241 had diagnostic ECG; 44 received cardiopulmonary resuscitation; 406 had missing lab data | Patients were discharged from ED (and thus excluded from analysis) only if rest myocardial perfusion imaging was negative or unchanged from previous studies.
Young 1993 93371607 | Country: USA Mean age: 57 Age range: ND Enrolled: 222 Evaluated: 222 95% male Race: ND | Admitted to CCU via ED with "rule out" AMI or UAP | | WHO criteria | 19% (43/222) | ND | No | CK-MB >23 U/L at presentation (Data reported for patients with <24 hours CP) | 35 (48) | ND (ND) | "CK was as accurate as CK-MB in the ED and that cardiac enzymes drawn in the ED detected more than 50% of the AMI patients presenting within 24 hours of symptoms onset." | None reported | Although patients without AMI were included, specificity data were not presented. Retrospective study of CCU admissions via the ED at a Veterans Affairs hospital.

CP-chest pain; CXR-chest radiograph; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 8a. Diagnostic performance studies evaluating serial CK-MB for AMI in the ED

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Gerhardt 1982 82115732 | Countries: Scandinavia Mean age: ND Age range: ND Enrolled: ND Evaluated: 481 % male: ND Race: ND | Symptoms indicative of patients having had an AMI within the previous 24 hours | ND | WHO criteria: 2 of: patient's history; evolution of ECG changes; elevated serial AST, LDH, or CK | 36% (21/59) | Yes | ND | CK-MB >12 U/L in serial tests drawn at hours 10 and 16 after onset of CP | 100 | 97 | None specific to serial CK-MB | ND | Blood work was drawn at times dependent on onset of CP, not dependent on arrival time to ED. Study focused on CK-B (MB and BB combined); in a subanalysis a correction was made to remove CK-BB.
Hedges 1992 93073193 | Country: USA Mean age: 61 yrs Age range: 31-96 yrs Enrolled: 420 Evaluated: 261 84% male Race: ND | Chest discomfort warranting an ECG, Age >30 yrs | Diagnostic ECG, Cardioversion within 24 hours, Clinically unstable (shock, arrhythmia), Hematocrit <30%, Trauma, Abnormal CXR explaining symptoms | WHO criteria: 2 of: typical chest discomfort; elevated serial CK-MB; evolution of ECG changes | 11% (28/261) | No | ND | CK-MB >8 ng/ml in serial tests drawn at presentation and hourly to hour 3 | 68 | 95 | "Serial CK-MB measurements over three to four hours are more sensitive and specific for AMI than serial ECG tracings in this population." | 159 patients omitted: 45 could not be reached for followup after discharge from ED; 114 lacked serial ECG | Study funded in part by Hybritech Corporation
Brogan 1994 94379537 | Country: USA Mean age: 59 yrs Age range: ND Enrolled: ND Evaluated: 189 % male: ND Race: ND | Chief complaint of 1 or more of: chest discomfort, shortness of breath, syncope, congestive heart failure, pulmonary edema, epigastric pain, new symptomatic dysrhythmia | Symptoms >12 hours, Trauma, Renal failure, Muscular dystrophy | WHO criteria: clinical presentation, serial ECGs, cardiac enzymes (CK) | 12% (22/189) | ND | ND | CK-MB >9 ng/ml and >2% in serial tests at presentation and hour 1 | 41 | 99 | "Misdiagnosed AMI patients with atypical ED presentations may be discharged after brief ED evaluations, making serial CK-MB determinations impractical…. Serial sampling of myoglobin…demonstrated a significantly higher sensitivity than CK-MB in patients presenting within 12 hours of symptom onset." | ND | Study supported in part by a grant and supplies from Baxter Diagnostics
Castaldo 1994 94368914 | Country: Italy Median age: 59 yrs Age range: 33-80 yrs Enrolled: ND Evaluated: 157 64% male Race: ND | CP, Referred from the emergency cardiology department, Only subjects with a high prediction of AMI | CP >2 hours | WHO criteria | 37% (58/157) | ND | ND | CK-MB >5% in serial tests at 3 and 6 hours after symptom onset | 62 | 95 | Release of CK-MB occurs later than myoglobin in AMI. | ND | Data collected by duration of CP, not by time in ED
Montague 1995 96026068 | Country: USA Mean age: 65 yrs Age range: 39-91 yrs Enrolled: 132 Evaluated: 89 70% male Race: ND | CP or suspected AMI | Trauma, Renal failure or insufficiency | WHO criteria: clinical history and cardiac enzymes | 28% (25/89) | Yes; however, one patient reclassified after myoglobin results | ND | CK-MB >5 ng/ml in serial tests at presentation and hour 2 (Data available for CK-MB >2.5% in serial tests at presentation and hour 2) | 68 (76) | 92 (84) | "The sensitivity of myoglobin exceeded that of CK-MB…at presentation and at 2 hours. The difference in sensitivity narrowed on the second draw as was expected, as CK and CK-MB rise later than myoglobin…. The specificity of myoglobin was less than that of CK-MB." | 43 patients omitted: 37 with only one blood draw, 6 with renal failure | Supplies provided by Dade International, Inc.
Gibler 1995 95100634 | Country: USA Mean age: 45 yrs Age range: 19-89 yrs Enrolled: ND Evaluated: 1,010 51% male Race: black 60%, white 39% | CP, Evaluation in the "Heart emergency room program," Age >25 yrs or, if recent cocaine use, >18 yrs | Diagnostic ECG, Hypotension, History suggestive of UAP, CAD, or AMI, Trauma | ND | 1% (12/1,010) | No | ND | CK-MB >6 mg/ml by Stratus assay or >7 ng/ml by ICON-QSR assay in serial tests at presentation and hours 3, 6, 9 | 100 | 98 | "Serial sampling for CK-MB in the ED over a period of 9 hours effectively identifies the patient with myocardial necrosis." | Patients "admitted directly to the CCU" were not included in analysis. 75% of discharged patients (approximately 640 patients) did not return for 1-day followup
Hedges 1996 96363164 | Country: USA Mean age: 57 yrs Age range: ND Enrolled: 1,055 Evaluated: 1,042 68% male Race: ND | Chest discomfort, Age >25 yrs | Diagnostic ECG, Cardioversion within 24 hours, Clinically unstable, Trauma, CXR explaining CP, Transfer from another institution | WHO criteria: 1 of: elevated serial CK-MB and other cardiac enzyme; new Q waves on serial ECGs | 6% (67/1,042) | No | ND | CK-MB >7 ng/ml in serial tests at presentation and hour 3 | 88 | 95 | "Serial CK-MB mass determinations can diagnose AMI within hours of hospital admission and that such information can help guide in-hospital disposition." | 13 patients omitted due to incomplete data "The clinical followup of patients released from the ED was limited. " | Study funded in part by Hybritech Corporation and Genentech Corporation
Sayre 1998 98242237 | Country: USA Mean age: 53 yrs Age range: 22-93 yrs Enrolled: 700 Evaluated: 667 ^2^ 48% male Race: black 60%, white 40, Asian 0.4% | Chest pain or other symptoms suggestive of ACI, Age >25 yr, or <25 yr with recent cocaine use | Symptoms explained by chest radiography, Trauma | WHO criteria including one positive CK-MB enzyme assay or 12-lead ECG within 24 hr of ED presentation | 5% (34/667) | No | Yes | CK >100 U/L and CK-MB >6 or 7 ng/ml dependent on analyzer Presentation or serial tests to 3 hours Presentation or serial tests to 6 hours Presentation or serial tests to 9 hours Presentation or serial tests to 12 hours Presentation or serial tests to 24 hours | 40 50 94 94 100 | 99.8 99.8 99.6 99.6 99.6 | "CK-MB level was more specific for AMI than the troponin T level. " | 33 patients omitted from all analyses because of missing blood samples (often due to ED discharge prior to study blood draw). | Study funded in part by Boehringer Mannheim Corporation. 128 patients had only one blood sample drawn (presumably on presentation), but were included in serial test analysis.

CP-chest pain; CXR-chest radiograph; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Fewer than 667 patients included in test performance calculations at each time point evaluated.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 8b. Diagnostic performance studies evaluating serial CK-MB for AMI in the ED (other clinical trials)

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Gibler 1987 87296931 | Country: USA Mean age: ND Age range: ND Enrolled: 73 Evaluated: 59 % male: ND Race: ND | CP, Age >30 yrs, Admission to hospital | Trauma, Abnormal CXR explaining CP | WHO criteria: CP; new Q waves on serial ECGs; elevated serial CK, LDH | 36% (21/59) | ND | ND | ND on threshold CK-MB level. Blood work drawn in serial tests drawn at presentation and hours 3 and 6 (Data available for serial tests drawn at presentation and hour 3 only) | 100 (90) | 92 (95) | "While CK-MB is a highly specific indicator of myocardial cell injury and death, it remains less sensitive than myoglobin as an early indicator of AMI." | Patients discharged from ED excluded 14 subjects omitted: 9 with missing lab work, 5 without consent | Study supported in part by the Proctor & Gamble Company
Gibler 1992 92238601 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 616 % male: ND Race: ND | Chief complaint of CP, Age >30 yrs, Admission to hospital | Diagnostic ECG, CP explained by trauma, CP explained by CXR | WHO criteria: 2 of: typical CP; elevated serial cardiac enzymes; evolution of changes in serial ECGs | 12% (69/577) | ND | ND | CK-MB >8 ng/ml in serial tests drawn at presentation and hours 1, 2, 3 (Data available including patients with diagnostic ECG; prevalence=18%) | 80 (82) | 94 (94) | "The rapid immunochemical assay used in this study was a sensitive and specific indicator of AMI in patients with nondiagnostic ECGs. The availability of a rapid, accurate immunochemical CK-MB assay for serial CK-MB sampling methodology in the ED may allow for earlier identification of AMI patients with atypical presentations to prevent the unintended release of AMI patients for the ED and appropriate disposition of AMI patients with nondiagnostic ECGs to ICU settings." | Patients discharged from ED excluded Discharged patients did not have followup cardiac enzymes or ECG for AMI diagnosis 52 patients omitted: all had diagnostic ECGs, 13 also did not have sufficient serial blood work
Marin 1992 92142994 | Country: USA Mean age: 66 yrs Age range: ND Enrolled: 400 Evaluated: 313 59% male Race: ND | CP consistent with AMI or ischemia, Admission to hospital | CP >12 hours, CP readily explained by physical or radiographic findings, Transfer to other hospital, No final diagnosis available | 1 of: abnormal serial ECG changes; elevated serial CK-MB | 22% (70/313) | ND | Yes | CK-MB >7.5 ng/ml in serial tests drawn at presentation and hours 1, 2, 3 (Serial data available at hours 1 and 2) | 90 | 93 | "These data confirm prior study results indicating that the temporal CK-MB pattern can be used to differentiate patients with acute CP caused by AMI from patients with CP resulting from other causes. Because these assays were performed serially during initial triage, the data indicate that this distinction can be made within 2 to 4 hours of hospital arrival." | Patients discharged from ED excluded 87 patients omitted: 62 had no diagnosis due to insufficient data documenting the cause of CP; 22 enrolled more than 12 hours after symptom onset; 3 had missing data | Study supported in part by Genentech, Inc., and Ciba-Corning Diagnostics, Inc.
Hoekstra 1994 95346595 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 5,120 % male: ND Race: ND | Chief complaint of CP or chest discomfort consistent with AMI, Age >30 yrs, Admission to monitored bed in hospital | Diagnostic ECG, Chest wall trauma, CP explained by CXR | From hospital discharge diagnosis. Serial CK-MB levels, ECG changes, angiographic findings, or combination of methods | 7% (368/5,063) | No | ND | CK-MB level in serial tests drawn at presentation at 2 hours. Threshold varied depending on assay used; ranged from 5.6 ng/ml to 7.5 ng/ml. | 63 | 95 | "While the predictive value of a positive ED CK-MB may be helpful in the disposition of the stable patient with CP to the CCU setting, the converse may not be true for negative ED CK-MB… one-third of the AMIs… in this study were not identified by an ED CK-MB." | Patients discharged from ED or admitted to a nonmonitored bed excluded | Study funded and organized by Genentech Corporation
Levitt 1996 96142116 | Country: USA Mean age: 57 yrs Age range: 26-95 yrs Enrolled: ND Evaluated: 190 58% male Race: 54% black, 12% Hispanic, 12% white, 11% Asian, 11% other | CP consistent with acute ischemic coronary syndrome, Age >18 yrs, Admission to hospital | Diagnostic ECG | WHO criteria: patients clinical history; ECG abnormalities; serial markers | 11% (21/190) | Yes | ND | CK-MB >11.9 ng/ml in serial tests at presentation and hour 3 | 81 | 99 | "Being able to obtain… CK-MB levels in the ED would be clinically useful…. Serum myoglobin is a more sensitive but less specific marker than serum CK-MB in the early detection of AMI in the ED." | Patients discharged from ED excluded | Study funded in part by Behring Diagnostics Inc. Threshold for abnormal CK-MB chosen post hoc
Kontos 1997a 97156085 | Country: USA Mean age: 58 yrs Age range: ND Enrolled: 110 Evaluated: 101 55% male Race: ND | CP, Admission to CCU | ND | WHO criteria: 2 of: evolving diagnostic ECG changes; elevated serial CK and CK-MB; prolonged cardiac CP | 20% (20/101) | ND | ND | CK-MB >4.7 ng/ml on Baxter Straus II or CK-MB >8 ng/ml on Behring Opus Plus at presentation and hour 4 | 90 | 100 | None specific to serial CK-MB alone | Patients discharged from ED and patients admitted to non-CCU beds excluded 9 patients omitted due to missing lab work
Kontos 1999a 99171821 | Country: USA Mean age: 58 yrs Age range: ND Enrolled: 2,784 Evaluated: 2,093 % male: ND Race: ND | Admission to CCU from ED with suspected AMI | Diagnostic ECG, Cardiac or respiratory arrest | Symptoms consistent with AMI and elevated serial CK-MB. Some also required elevated serial troponin I. | 9% (186/2,093) | ND | ND | CK-MB >8 ng/ml and >4% at presentation and hour 3 | 78 | 99 | "Myocardial marker sampling [CK-MB] could identify most patients with AMI within 3 hours of presentation. However, a significant minority still remained unidentified, required further marker sampling." | Patients discharged from ED and patients admitted to non-CCU beds excluded 691 patients omitted: 241 had diagnostic ECG; 44 received cardiopulmonary resuscitation; 406 had missing lab data | Patients were discharged from ED (and thus excluded from analysis) only if rest myocardial perfusion imaging was negative or unchanged from previous studies.

CP-chest pain; CXR-chest radiograph; ICU-intensive care unit; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 9a. Diagnostic performance studies evaluating presentation troponin I for acute myocardial infarction in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Mair 1996 96233850 | Country: Austria Mean age: 62 Age range: ND Enrolled: ND Evaluated: 101 68% male Race: ND | CP | Trauma | 2 of: typical severe symptoms for more than 20 minutes; new abnormalities on serial ECGs; elevated serial CK and CK-MB | 38.6% (39/101) | Diagnosis by cardiologist blinded to test results | ND | >0.1 ng/L | 23 | 95 | "Our results demonstrate that cTnI is a highly specific marker for myocardial damage…. it should be mentioned that since we have completed this study the sensitivities of the used … cTnI assays could be improved…" | ND | Average onset of pain to ED presentation, 2.6 hr (0.3-48 hr).
Hamm 1997 98035971 | Country: Germany Mean age: 62 Enrolled: ND Evaluated: 773 59% male Race: ND | Anterior, precordial, or left-sided CP <12 hrs | No ST elevation, AMI <2 weeks | Total CK > twice upper limit of normal associated with elevated CK-MB | 6% (47/773) | ND | Yes | >0.1 ng/L | 66 | 89 | "Bedside tests for cardiac-specific troponins are highly sensitive for the early detection of myocardial-cell injury in acute coronary syndromes." | ND | Mean time of pain onset to ED presentation, 5 hr.

CP-chest pain; cTNl-cardiac troponin l; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 9b. Diagnostic performance studies evaluating presentation troponin I for acute myocardial infarction in the emergency department (all patients admitted)

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Apple 1995 95393615 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 98 % male: ND Race: ND | CP, Admission to hospital | ND | CP, ECG changes and elevated serial changes in CK-MB levels | 6% (6/98) | ND | ND | Troponin I >3.1 ng/L drawn at presentation | 100 | 92 | "…cTnI measurement appears to be as sensitive as, but more specific than [other biomarkers] with regard to early detection of AMI on chest pain patients admitted through the emergency department." | Patients discharged from ED excluded | Immunoassay kits (for troponin T) provided by Boehringer Mannheim Corporation Mean sampling time from onset of CP for all patients was 14 hours; for patients with AMI was 7.4 hours
Tucker 1997 97264134 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 177 62% male Race: ND | CP, Clinical suspicion of AMI was sufficiently great for physician to order ECG and cardiac lab work, Age >30 years, Admission to hospital | CP >24 hours, Diagnostic ECG, Cardiopulmonary resuscitation, Trauma, Fewer than 4 of 5 planned blood draws | WHO criteria: 2 of: clinical history of chest discomfort >30 minutes; evolution of serial ECG changes; elevated serial CK and CK-MB | 15% (27/177) | Yes | ND | Troponin I >0.6 ng/ml at presentation | 3.7 | 98 | "The cardiac troponins are of benefit in identifying AMI >6 hours after presentation." | Patients discharged from ED excluded | Multiple authors employed or supported by Baxter Diagnostics of Dade International. Mean time from onset of CP for all patients was 4.0, median 2.2 hr.
D'Costa 1997 98013143 | Country: Canada Mean age: ND Age range: ND Enrolled: 316 Evaluated: 316 % male: ND Race: ND | CP | CP >24 hours, Trauma, Renal insufficiency | WHO criteria: typical history and physical, characteristic ECG changes, and cardiac enzyme (CK and CK-MB) | 20% | Yes | Laboratory personnel blind to patient diagnosis | Troponin I >1.0 ng/ml at presentation | 79 | ND | Troponin I may be elevated earlier than CK-MB. Troponin I has improved cardiospecificity to CK-MB. | ND | Reagents provided by Dade International.
Laurino 1997 97448847 | Country: USA Mean age: 64 yrs Age range: ND Enrolled: ND Evaluated: 115 57% male Race: ND | Chief complaint of CP, Symptoms consistent with AMI or ischemia | Thrombolytic therapy | WHO criteria: 2 of: clinical features/CP, ECG changes, elevated CK and CK-MB | 22% (25/115) | ND | Laboratory personnel blind to patient diagnosis | | 32 | ND | None specific to troponin I | ND | Although patients without AMI were included, specificity data were not presented.

CP-chest pain; cTnl-cardiac troponin l; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 9c. Diagnostic performance studies evaluating serial troponin I for acute myocardial infarction in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Hamm 1997 98035971 | Country: Germany Mean age: 62 Enrolled: ND Evaluated: 773 59% male Race: ND | Anterior, precordial, or left-sided CP <12 hrs | No ST elevation, AMI <2 weeks | Total CK > twice upper limit of normal associated with elevated CK-MB | 6% (47/773) | ND | Yes | >0.1 ng/L, At least 2 tests, presentation & 4 or more hours later | 100 | 83 | "Bedside tests for cardiac-specific troponins are highly sensitive for the early detection of myocardial-cell injury in acute coronary syndromes." | ND | Mean time of pain onset to ED presentation, 5 hr.

CP-chest pain; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 9d. Diagnostic performance studies evaluating serial troponin I for acute myocardial infarction (patients admitted to CCU)

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Kontos 1999b 99233982 | Country: USA Mean age: 56 Enrolled: 721 Evaluated: 620 46.5% male Race: ND | Low- or moderate-risk patients, Patients admitted to CCU | PTCA <6 months, Serial cTnI samples not obtained, Hx CAD | CK-MB >8.0 ng/mL with relative index ([CK-MB/total CK].100) >4.0 | AMI 9.5% (59/620) | cTnI results were available to treating physician. | ND | >0.2 ng/L | 90 | 96 | "In conclusion, both cTnI and myocardial perfusion imaging have high sensitivities for identifying patients with MI." | 101 excluded, 3 with uninterpretable images, 71 had initial troponin I sampling only, & 27 underwent PTCA before admission. | Blood sampling over 8 hrs, no data on time points, but references made to other studies as a guide.

CTnl-cardiac troponin l; hx-history; ND-no data; PTCA-percutaneous transluminal coronary angioplasty.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 10a. Diagnostic performance studies evaluating presentation troponin T for acute myocardial infarction in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Mair 1991a 91266415 | Country: Austria Mean age: ND Age range: ND Enrolled: ND Evaluated: 96 % male: ND Race: ND | ND | ND | WHO criteria: Clinical history & symptoms; ECG results; Increased cardiac enzyme levels | 24% (23/96) | Cardiologist blind to test results | ND | >0.5 ng/L | 57 | 96 | "Troponin T measurements are a specific and sensitive method for the early…diagnosis of acute myocardial infarction and could, therefore, provide a new criterion in laboratory diagnosis of its occurrence." | ND | No information on time from pain onset to ED presentation.
de Winter 1995 96103032 | Country: Netherlands Mean age: 63 yrs Age range: ND Enrolled: 317 Evaluated: 309 66% male Race: ND | CP, Evaluated in "cardiac emergency room," Hx AMI allowed | CP >12 hours, Diagnostic ECG, Cardiopulmonary resuscitation, Severe skeletal muscle damage or trauma | Clinical history and symptoms, ECG abnormalities, elevated serial CK-MB | 53% (163/309) | Yes | ND | >0.1 ng/L at 3 hr from pain onset ^5^ >0.1 ng/L at 6 hr from pain onset ^5^ >0.1 ng/L at 12 hr from pain onset ^5^ | 34 73 94 | 91 88 86 | "…we conclude that troponin T appears not to be a suitable early marker for ruling out AMI." | Entry criteria for "cardiac emergency room" unclear. 8 patients omitted: 4 unable to draw sufficient blood; 4 incorrect or incomplete data | Supplies provided by Boehringer Mannheim, Behringwerke, and CIBA Corning. Median time pain onset to cardiac ER admission, 135 min. 89% of total pts within 6 hrs after pain onset. Additional sensitivity/specificity data given, but cannot be verified. Number of pts at different time points unknown.
Mair 1996 96233850 | Country: Austria Mean age: 62 yrs Enrolled: ND Evaluated: 101 68% male Race: ND | CP | Trauma | 2 of: typical severe symptoms for more than 20 minutes; new abnormalities on serial ECGs; elevated serial CK and CK-MB | 38.6% (39/101) | Diagnosis by cardiologist blinded to test results. | ND | >0.2 ng/L | 28 | 92 | "…it should be mentioned that since we have completed this study the sensitivities of the used … cTnT assays could be improved…" | ND | Mean time of pain onset to ED presentation, 2.6 hr (0.3-48 hr).
Hetland 1996 97186735 | Country: Norway Mean age: ~65 Enrolled: 133 Evaluated: 133 70% male Race: ND | CP< 6 hr, Hx CAD allowed | Trauma | CP >20 min, ECG with evolution of Q waves and/or ST elevation/depression >0.1 mV in >2 leads, Total CK & CK-MB activity, & CK-MB index | 34% (45/133) | Yes | ND | >0.05 ng/L at presentation, 0.06 ng/L, discriminator at max efficiency | 53 49 | 86 92 | "problems…with use of cTnT as an early marker for AMI…for purposes of diagnosing acute coronary syndromes in general among patients presenting to hospital with a suspicion of AMI, the cardiospecificity of troponin T seems to offer new diagnostic possibilities." | ND | Median time of pain onset to ED presentation, 3 hr for non-AMI pts, 2 hr for AMI female pts, & 4 hr for AMI male pts.
Hamm 1997 98035971 | Country: Germany Mean age: 62 Enrolled: ND Evaluated: 773 59% male Race: ND | Anterior, precordial, or left-sided CP <12 hrs | ST elevation, AMI <2 weeks | Total CK > twice upper limit of normal associated with elevated CK-MB | 6% (47/773) | No | ND | >0.18 ng/L at presentation | 51 | 92 | "Bedside tests for cardiac-specific troponins are highly sensitive for the early detection of myocardial-cell injury in acute coronary syndromes." | ND | Mean time of pain onset to ED presentation, 5 hr.
Gust 1998 98223348 | Country: Germany Mean age: 69 Enrolled: 68 Evaluated: 68 69% male Race: ND | Chest pain radiating to neck and/or arms, Hx AMI allowed | Time onset of pain unknown, Hx MI, thrombolytic tx, or PTCA <2 weeks | WHO criteria: typical chest pain, unequivocal ECG changes, & increased activity of CK & CK-MB concentrations in serial collections. If no ECG changes, chest pain & increases in CK & CK-MB | 24% (16/68) | Final diagnosis by independent physician blinded to test results. | Yes | >0.2 ng/L, if negative test reread after 20 min | 25 | 98 | "In summary, the results of the present study demonstrate that the new rapid bedside troponin T assay does not offer a reliable and safe method to diagnose MI in a prehospital setting." | ND | Prehospital bedside assay by emergency physician with EMS. Time between pain onset & EMS arrival, 0.5-10.0 hr, mean 4.3. Mean time for AMI pts was 2.6 hr.

CP-chest pain; cTnT-cardiac troponin T; hx-history; mV-millivolt; ND-no data; pt(s)-patient(s); PTCA-percutaneous transluminal coronary angioplasty; tx-treatment.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

5 Additional blood draw data available, see study.

Evidence Table 10b. Diagnostic performance studies evaluating presentation troponin T for acute myocardial infarction (other settings)

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Mach 1995 95233326 | Country: Switzerland Mean age: 68 Enrolled: 32 Evaluated: 32 68% male Race: ND | CP, Suspected AMI according to IMIR | CP >12 hr | WHO criteria: serial ECG; elevated serial CK | 78% (25/32) | Yes | Yes | Troponin T >0.2 ng/ml at presentation | 40 | 80 | "Bedside whole blood Troponin T immunoassay possesses similar or better sensitivity and specificity than CK-MB for diagnosing AMI." | Very high prevalence | Mean time of pain onset to ED presentation, 4.13±1.8 hr. 7 non-AMI pts - stable angina 1, UA 5, myopericarditis 1. Bedside immunoassay performed in ED or ICU. "…the reading of positivity was performed by the eye and with occasional interference from hemolyzed blood."
Tucker 1997 97264134 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 177 62% male Race: ND | Chest discomfort, Clinical suspicion of AMI was sufficiently great for the physician to order an ECG and cardiac lab work, Age >30 years, Admission to hospital | CP >24 hours Diagnostic ECG, Cardiopulmonary resuscitation, Trauma, Fewer than 4 of 5 planned blood draws | WHO criteria: 2 of: clinical history of chest discomfort > 30 minutes; evolution of serial ECG changes; elevated serial CK and CK-MB | 15% (27/177) | ND | ND | Troponin T >0.1 ng/ml at presentation (Troponin T >0.2 ng/ml at presentation) | 33 (15) | 91 (97) | "The cardiac troponins are of benefit in identifying AMI >6 hours after presentation." | Patients discharged from ED excluded | Multiple authors employed or supported by Baxter Diagnostics of Dade International. Mean time from onset of CP for all patients was 4.0, median 2.2 hr.

CP-chest pain; ICU-intensive care unit; IMIR-Imminent Myocardial Infarction Rotterdam; ND-no data; pt(s)-patient(s).

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 11a. Diagnostic performance studies evaluating serial troponin T for acute myocardial infarction in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Hamm 1997 98035971 | Country: Germany Mean age: 62 Enrolled: ND Evaluated: 773 59% male Race: ND | Anterior, precordial, or left-sided CP <12 hrs | Diagnostic ECG, AMI within previous 2 weeks | Total CK > twice upper limit of normal associated with elevated CK-MB | 6% (47/773) | No | ND | >0.18 ng/L at presentation, >0.18 ng/L for at least 2 tests, presentation & 4 or more hrs later | 51 94 | 92 89 | "Bedside tests for cardiac-specific troponins are highly sensitive for the early detection of myocardial-cell injury in acute coronary syndromes." | ND | Mean time of pain onset to ED presentation, 5 hr.
Sayre 1998 98242237 | Country: USA Mean age: 52.6 Range (22-93) Enrolled: 700 Evaluated: 667 48% male Race: Asian 0.4%, Black 60%, White 40% | >25 yr, or <25 yr with recent cocaine, Chest pain or other symptoms suggestive of ACI | Symptoms explained by chest radiography, Trauma | WHO criteria including one positive CK-MB enzyme assay or 12-lead ECG within 24 hr of ED presentation | 5% (34/667) | Yes | Yes | >0.2 ng/L at 0-3 hr >0.2 ng/L at 0-6 hr >0.2 ng/L at 0-9 hr >0.2 ng/L at 0-12 hr | "64.5" "78.8" "85.3" "88.2" | "92.6" "93.1" "92.7" "92.2" | "Measurement of cTnT will accurately identify myocardial necrosis in patients presenting to the ED with possible acute ischemic coronary syndrome." | 33 patients omitted from all analyses because of missing blood samples (often due to ED discharge prior to study blood draw). | Median time of pain onset to ED presentation for 522 pts, 6.4 hr. 112 pts arrived >24 hr of symptom onset, 145 missing data on symptoms onset. Pts with diagnostic ECGs enrolled. Sensitivity/specificity data cannot be verified with data reported. The total number of pts in first time interval was 546. The number of pts unknown for other time intervals.

CP-chest pain; cTnT-cardiac troponin T; ND-no data; pt(s)-patient(s).

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 11b. Diagnostic performance studies evaluating serial troponin T for acute myocardial infarction (other studies)

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Mach 1995 95233326 | Country: Switzerland Mean age: 68 Age range: ND Enrolled: 32 Evaluated: 32 68% male Race: ND | CP, Suspected AMI according to IMIR | CP >12 hr | WHO criteria: serial ECG; elevated serial CK | 78% (25/32) | Yes | Yes | >0.2 ng/ml at presentation and 4 hr | 100 | 86 | "Bedside whole blood Troponin T immunoassay possesses similar or better sensitivity and specificity than CK-MB for diagnosing AMI." | Very high prevalence | Mean time of pain onset to ED presentation, 4.13±1.8 hr. 7 non-AMI pts - stable angina 1, UA 5, myopericarditis 1. Bedside immunoassay performed in ED or ICU. "…the reading of positivity was performed by the eye and with occasional interference from hemolyzed blood."
Mohler 1998 98149617 | Country: USA Mean age: 56 Age range: ND Enrolled: 100 Evaluated: 100 57% male Race: ND | CP cardiac in origin | Age <18 years ED diagnosis of noncardiac CP, Arrival in ED not in daytime hours | WHO criteria: 2 of typical angina-like CP for at least 30 minutes, ECG changes, elevated CK-MB | 21% | ND | Yes | >0.1 ng/ml at presentation and 4 hr | 90 | 80 | Troponin T may be more sensitive than CK-MB to diagnose AMI. | ND | Patient accrual limited to daytime hours.

CP-chest pain; IMIR-Imminent Myocardial Infarction Rotterdam; ND-no data; pt(s)-patient(s).

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 12. Diagnostic performance studies evaluating presentation myoglobin for AMI in the ED

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Gilkeson 1978 78078100 | Country: USA Median age: 56 yrs Age range: 21-90 yrs Enrolled: ND Evaluated: 71 % male: ND Race: ND | CP | ND | ND | 18% (13/71) | ND | ND | Presentation myoglobin >85 ng/ml | 38 | 93 | "The difficulty in dating the onset of AMI in patients…represents a definite limitation in the utilization of the rapid determination of serum myoglobin in the recognition of AMIs." | ND | ND
Roxin 1984 84253059 | Country: Sweden Median age: 67 yrs Age range: 20-89 yrs Enrolled: ND Evaluated: 305 65% male Race: ND | "Referred to hospital on suspicion of AMI." | ND | WHO criteria: central CP of at least 15-minute duration, or shock or pulmonary edema without any other known cause, in combination with either evolving typical ECG changes or elevations of serum enzymes (AST) | 26% (80/305) | ND | ND | Presentation myoglobin >97 ng/ml | 71 | 83 | "This investigation has clearly demonstrated the advantages of serum myoglobin determinations in the early diagnosis of AMI." | 22 patients diagnosed with "probable AMI" and 125 with "possible AMI" were omitted from analysis. | ND
Mair 1992 93103894 | Country: Austria Median age: ND Age range: ND Enrolled: ND Evaluated: 126 % male: ND Race: ND | Chief complaint of CP | Trauma | WHO criteria | 40% (51/126) | Cardiologist blind to test results | ND | Presentation myoglobin >80 ng/ml | 45 | 91 | "Myoglobin… [was not] clinically efficient for diagnosing AMI within the first two hours after the onset of chest pain." | ND | ND
Castaldo 1994 94368914 | Country: Italy Median age: 59 yrs Age range: 33-80 yrs Enrolled: ND Evaluated: 157 64% male Race: ND | CP, Referred from the emergency cardiology department, Only subjects with a high prediction of AMI. | CP >2 hours | WHO criteria | 37% (58/157) | ND | ND | Myoglobin >100 ng/ml at 3 hours after onset of CP | 38 | 100 | "At the moment, myoglobin appears to be the most reliable biochemical marker for the early diagnosis of AMI." | ND | Data collected by duration of CP, not by time in ED
Brogan 1994 94379537 | Country: USA Mean age: 59 yrs Age range: ND Enrolled: ND Evaluated: 189 % male: ND Race: ND | Chief complaint of 1 or more of: chest discomfort, shortness of breath, syncope, congestive heart failure, pulmonary edema, epigastric pain, new symptomatic dysrhythmia | Symptoms >12 hours, Trauma, Renal failure, Muscular dystrophy | WHO criteria | 12% (22/189) | ND | ND | Presentation myoglobin >110 ng/ml | 55 | 98 | None specific to presentation myoglobin | ND | Study supported in part by a grant and supplies from Baxter Diagnostics
Montague 1995 96026068 | Country: USA Mean age: 65 yrs Age range: 39-91 yrs Enrolled: 132 Evaluated: 89 70% male Race: ND | CP or suspected AMI | Trauma, Renal failure or insufficiency | WHO criteria | 28% (25/89) | No | ND | Presentation myoglobin >70 ng/ml | 56 | 81 | "[The] low specificity… reflects myoglobin's more ubiquitous presence in skeletal muscle." | 43 patients omitted: 37 because only one sample was drawn; 6 with renal failure 1 patient reclassified as having AMI by myoglobin level | Study supported in part by supplies from Dade International, Inc.
Mair 1996 96233850 | Country: Austria Mean age: 62 yrs Age range: ND Enrolled: ND Evaluated: 101 68% male Race: ND | CP | Trauma | 2 of: typical severe symptoms for more than 20 minutes; new abnormalities on serial ECGs; elevated serial CK and CK-MB | 28% (25/89) | Yes | ND | Presentation myoglobin >70 ng/ml | 46 | 89 | None specific to presentation myoglobin | ND | ND
Gornall 1996 96426690 | Country: Canada Mean age: ND Age range: 29-86 yrs Enrolled: ND Evaluated: 98 63% male Race: ND | CP in the ED in whom the diagnosis was not clear | Diagnostic ECG, History and physical examination in the ED was able to identify an alternative cause of the pain and the ECG was normal, Trauma | WHO criteria: 2 of: typical CP; elevated serial CK-MB; evolution of changes on serial ECGs | 41% (40/98) | No | ND | Presentation myoglobin >100 ng/ml | 43 | 98 | "Serial myoglobin measurements provide a… sensitivity much better than a single myoglobin assay." | ND | Study supported by Dade Diagnostics division of Baxter Canada.
Hetland 1996 97186735 | Country: Norway Mean age: ND Age range: 31-94 yrs Enrolled: ND Evaluated: 133 69% male Race: ND | Chest discomfort suggestive of AMI, Arrive in ED between 8 am and 10 pm | CP >6 hours, Trauma | Characteristic CP >20 minutes and evolution of serial ECG changes and elevated serial CK-MB | 34% (45/133) | ND | ND | Presentation myoglobin >70 ng/ml | 51 | 94 | "The results of the present study do not support significant differences in the performance of myoglobin compared to CK-MB mass, as based upon samples not influenced by thrombolytic treatment." | ND | ND
Kennedy 1997 97187221 | Country: Scotland Mean age: ND Age range: ND Enrolled: 91 Evaluated: 86 % male: ND Race: ND | Suspected ischemic CP | CP >4 hours, Diagnostic ECG | WHO criteria: 2 of: clinical history, ECG or biochemical markers | 23% (21/91) | Yes | ND | Presentation myoglobin >90 ng/ml | 38 | 96 | "The major problem with biochemical markers is that they take up to 4 hours after the onset of symptoms to become positive." | 5 patients omitted because the opinion of the admitting physician was not recorded. | Study supported by Altim Medical Systems, Derbyshire, England

CP-chest pain; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 13a. Diagnostic performance studies evaluating serial myoglobin for AMI in the ED

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Roxin 1984 84253059 | Country: Sweden Median age: 67 yrs Age range: 20-89 yrs Enrolled: ND Evaluated: 305 65% male Race: ND | "Referred to hospital on suspicion of AMI" | ND | WHO criteria: central CP of at least 15-minute duration, or shock or pulmonary edema without any other known cause, in combination with either evolving typical ECG changes or elevations of serum enzymes (AST) | 26% (80/305) | ND | ND | Myoglobin >97 ng/ml in serial tests drawn at presentation and every 2 to 4 hours for 4 hours | 98 | 83 | "The two major limitations of serum myoglobin as a means in the diagnosis of AMI are the fast elimination of myoglobin from the blood, and the non-specificity." | 22 patients diagnosed with "probable AMI" and 125 with "possible AMI" were omitted from analysis. | ND
Brogan 1994 94379537 | Country: USA Mean age: 59 yrs Age range: ND Enrolled: ND Evaluated: 189 % male: ND Race: ND | Chief complaint of 1 or more of: chest discomfort, shortness of breath, syncope, congestive heart failure, pulmonary edema, epigastric pain, new symptomatic dysrhythmia | Symptoms >12 hours, Trauma, Renal failure, Muscular dystrophy | WHO criteria: clinical presentation, serial ECGs, cardiac enzymes (CK) | 12% (22/189) | ND | ND | Myoglobin >110 ng/ml in serial tests drawn at presentation and 1 hour (Myoglobin >110 ng/ml or increase by more than 40 ng/ml in serial tests drawn at presentation and 1 hour) | 73 (91) | 96 (96) | Myoglobin levels rise faster than CK-MB. | ND | Study supported in part by a grant and supplies from Baxter Diagnostics
Castaldo 1994 94368914 | Country: Italy Median age: 59 yrs Age range: 33-80 yrs Enrolled: ND Evaluated: 157 64% male Race: ND | CP, Referred from the emergency cardiology department, Only subjects with a high prediction of AMI | CP >2 hours | WHO criteria | 37% (58/157) | ND | ND | Myoglobin >100 ng/ml in serial tests drawn at presentation and at 3 or 6 hours after onset of CP | 90 | 100 | "At the moment, myoglobin appears to be the most reliable biochemical marker for the early diagnosis of AMI." | ND | ND
Montague 1995 96026068 | Country: USA Mean age: 65 yrs Age range: 39-91 yrs Enrolled: 132 Evaluated: 89 70% male Race: ND | CP or suspected AMI | Trauma, Renal failure or insufficiency | WHO criteria: clinical history and cardiac enzymes | 28% (25/89) | No | ND | Myoglobin >70 ng/ml in serial tests drawn at presentation and 2 hours (Myoglobin value doubles between presentation and 2 hours)) | 100 (64) | 77 (98) | "A negative myoglobin, particularly on serial samples, is a reliable test for excluding AMI in patients presenting to the ED with CP." | 43 patients omitted: 37 with only one blood draw, 6 with renal failure 1 patient reclassified as having AMI by myoglobin level | Supplies provided by Dade International, Inc.
Gornall 1996 96426690 | Country: Canada Mean age: ND Age range: 29-86 yrs Enrolled: ND Evaluated: 98 63% male Race: ND | CP in the ED in whom the diagnosis was not clear | Diagnostic ECG, History and physical examination in the ED was able to identify an alternative cause of the pain and the ECG was normal, Trauma | WHO criteria: 2 of: typical CP; elevated serial CK-MB; evolution of changes on serial ECGs | 41% (40/98) | No | ND | (Myoglobin value doubles between presentation and 2 hours) | (93) | (100) | "Serial myoglobin measurements provide a… sensitivity much better than a single myoglobin assay." | ND | Study supported by Dade Diagnostics division of Baxter Canada.
Kennedy 1997 97187221 | Country: United Kingdom Mean age: ND Age range: ND Enrolled: 91 Evaluated: 86 % male: ND Race: ND | Suspected ischemic CP | CP >4 hours, Diagnostic ECG | WHO criteria: 2 of: clinical history, ECG or biochemical markers | 23% (21/91) | Yes | ND | Myoglobin >90 ng/ml in serial tests drawn at presentation and 3 hours | 86 | 96 | "Myoglobin estimations provided a highly accurate means of diagnosing and excluding AMI." | 5 patients omitted because the opinion of the admitting physician was not recorded | Study supported by Altim Medical Systems, Derbyshire, England

CP-chest pain; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 13b. Diagnostic performance studies evaluating serial myoglobin for AMI in the ED (other clinical trials)

Study, year, identifier ^1^ | Location, population | Inclusion criteria | Exclusion criteria | Reference criteria for AMI | Prevalence of AMI | Reference test results blinding ^2^ | Experimental test results blinding ^3^ | Test criteria for AMI | Sensitivity (%) | Specificity (%) | Study conclusions | Potential verification bias | Limitations/comments
Gibler 1987 87296931 | Country: USA Mean age: ND Age range: ND Enrolled: 73 Evaluated: 59 % male: ND Race: ND | CP, Age >30 yrs, Admission to hospital | Trauma, Abnormal CXR explaining CP | WHO criteria: CP; new Q waves on serial ECGs; elevated serial CK, LDH | 36% (21/59) | ND | ND | Myoglobin drawn in serial tests drawn at presentation and 3 hours. No data on threshold | 100 | 82 | "Elevated serum myoglobin levels were useful for the early detection of patients with CP and AMI." | Patients discharged from ED excluded 3 subjects omitted: 1 with initial CK > 4000; 1 with incomplete data; 1 whose CP occurred in hospital | Study supported in part by Hybritech, Inc., and Ciba-Corning Diagnostics, Inc.
Davis 1996 96326749 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 101 % male: ND Race: ND | CP and 1 of: diaphoresis, nausea, shortness of breath, any ECG changes, or other risk factors such as: family history, congestive heart failure, or diabetes, Age from 18 to 85, Admission to hospital | ND | ND | 33% (14/42) | Yes | ND | Myoglobin >100 ng/ml in serial tests drawn at presentation and 2 hours | 57 | 93 | "We found serum myoglobin to have useful test performance characteristics in this small, highly selected patient population." | ND | Study supported in part by Genentech, Inc., and Behring Diagnostic, Inc.
Kontos 1997a 97156085 | Country: USA Mean age: 58 yrs Age range: ND Enrolled: 110 Evaluated: 101 55% male Race: ND | CP, Admission to CCU | ND | WHO criteria: 2 of: evolving diagnostic ECG changes; elevated serial CK and CK-MB; prolonged cardiac CP | 20% (20/101) | ND | ND | Myoglobin >90 ng/ml in serial tests drawn at presentation and 4 hours | 85 | 80 | "There was a significantly higher sensitivity of myoglobin than CK-MB mass for diagnosis of AMI…. Myoglobin sensitivity was significantly increased… if diagnosis was based on the presence of an elevation of either the 0- or 1-hour sample." | Patients discharged from ED and patients admitted to non-CCU beds excluded 9 patients omitted due to missing lab work | ND
Tucker 1997 97264134 | Country: USA Mean age: ND Age range: ND Enrolled: ND Evaluated: 177 62% male Race: ND | Chest discomfort, Clinical suspicion of AMI was sufficiently great for the physician to order an ECG and cardiac lab work, Age >30 years, Admission to hospital | CP >24 hours, Diagnostic ECG, Cardiopulmonary resuscitation, Trauma, Fewer than 4 of 5 planned blood draws | WHO criteria: 2 of: clinical history of chest discomfort >30 minutes; evolution of serial ECG changes; elevated serial CK and CK-MB | 15% (27/177) | ND | ND | Myoglobin >110 ng/ml in serial tests drawn hourly to 2 hours | 89 | 96 | "Of the studied markers, serial serum myoglobin levels are the best early markers for AMI, with a high sensitivity, specificity, and negative predictive value." | Patients discharged from ED excluded | Multiple authors employed or supported by Baxter Diagnostics of Dade International.

CP-chest pain; CXR-chest radiograph; ND-no data.

1 MEDLINE or unique identifying number assigned by EPC.

2 Interpretation of reference test results blinded to experimental test results and clinical information.

3 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 14a. Diagnostic performance studies evaluating two-dimensional rest echocardiography for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of AMI | Reference test results blinding ^4^ | Experimental test results blinding ^5^ | Reference criteria for AMI | Diagnostic criteria for AMI/ACI ^6^ : sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Peels 1990 90195885 | Country: Netherlands Mean age: 54 Enrolled: 43 Evaluated: 43 74% male Race: ND | ND | ECG diagnostic for ACI, Hx CAD or AMI | Echocardiogram at rest using ADR 4000 with 2.5 MHz transducer taken before any medications given. Images included four standard views ^3^ . | 30.2% (13/43) | ND | ND on two independent reviewers of echocardiogram to blinding of reference test results. | Elevated CK total and CK-MB > twice normal value & >10% of total. CK and CK-MB levels measured at admission, 6 hr, & if elevated, twice daily for first 48 hrs. | Asynergy in >1 segment and 11 of 13 segments to be interpretable. | "Two dimensional echocardiography during pain and a non-diagnostic electrocardiogram…can accurately rule out an acute myocardial infarction." | ND | No information on number of patients excluded because of inadequate echocardiogram images.
  AMI: Sens-92.3% | Spec-53.3%
  ACI: Sens-88.0% | Spec-77.8%
Sabia 1991 91356713 | Country: USA Mean age: 62 Enrolled: 180 Evaluated: 169 51.7% male Race: ND | Men >30 yr, Women >40 yr, Cardiac-related chest pain and/or acute shortness of breath >30 min <4 hr of presentation, Hx of CAD or ACI allowed | ND | Echocardiogram at rest using Kontron Instruments with 3 MHz transducer. | 16.7% (30/180) | ND | Three reviewers blinded to the reference test results. | CK total >204 U/L and CK-MB >4% of total, or LDH >40% of LDH total in absence of hemolysis or renal infarction. Serum samples at presentation & at 6 hrs at least 24 hrs for admitted patients. Discharged patients were to return within 24 hrs for repeat sample. | Regional wall motion abnormality in any of 12 segments. | "We conclude that two-dimensional echocardiography is superior to conventional methods in the emergency room for the diagnosis of AMI, prediction of in-hospital complications, and reduction of unnecessary hospital admissions." | 22 did not have 2^nd^ CK & were excluded from analysis. Additional 11 had technically inadequate echocardiography. | ND
  AMI: Sens-93.1% | Spec-57.1%
Kontos 1998 98449508 | Country: USA Mean age: 51 Enrolled: 186 Evaluated: 185 48.6% male Race: ND | Low-risk patients: typical symptoms <30 min or atypical symptoms >30 min, Moderate-risk patients: symptoms >30 min | ECG diagnostic for ACI | Echocardiogram at rest using Hewlett-Packard 500, 1000, 1500. Images included four standard views ^3^ . | 3.2% (6/185) | Physician blinded to echocardiogram results. | Two reviewers blinded to reference test results. Disagreements resolved by third reviewer. | 2 of 3 criteria: ACI symptoms >30 minutes, Evolving diagnostic ECG changes, CK-MB by mass assay >8.0 ng/dL with relative index >4.0 | Asynergy of 2 or contiguous segments, wall motion abnormality of 1 segment visible in 2 views, or global hypokinesis with moderate to severe systolic dysfunction. | Echocardiography "identified patients at high risk who required admission and those who could be safely discharged directly from the ED." | One patient with unreadable echocardiogram. | Patients admitted based on initial risk evaluation, mainly moderate-risk patients and those with positive images.
  AMI: Sens-100% | Spec-82.7%
  ACI: Sens-71.4% | Spec-86.0%

hx-history; ND-no data; sens-sensitivity; spec-specificity.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Parasternal long and short axis and the apical four and two-chamber views.

4 Interpretation of reference test results blinded to experimental test results and clinical information.

5 Interpretation of experimental test results blinded to reference test results and clinical information.

6 ACI includes AMI, or significant or any CAD by angiography or stress scan.

Evidence Table 14b. Diagnostic performance studies evaluating two-dimensional stress echocardiography for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Reference criteria for AMI | Diagnostic criteria for ACI: sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Trippi 1997 97429168 | Country: USA Mean age: 49.8 Enrolled: 173 phase 1, n=10 phase 2, n=27 phase 3, n=51 phase 4, n=75 Evaluated: 163 52.1% male Race: ND | Normal initial CK <170 U/L, phase 4, CK <400 U/L | Abnormal ECG - phase 1 & 2, ECG diagnostic for MI-phase 3 & 4, Abnormalities on rest tele-echocardiogram, Any cardiac hx - phase 1 & 2, Hx MI for phase 3 & 4 | Patients with normal rest teleechocardiograms underwent DSTE with incremental dose up to 50 mg/kg/min in 3-minute stages, optional 1 mg supplemental atropine. | ACI (11.6-13.7%) (19/(139-163)) AMI 3.7-4.3% (6/(139-163)) (See Comments/limitations column) | NA | Cardiologist not blinded, but also interpreted ECGs. | Clinical diagnosis for CAD from cardiac catheterization results, telephone survey or physician contact with mean of 3.03 months followup. | Stress-induced wall motion abnormalities. Sens 89.5% Spec 88.9% | "The use of DSTE in the evaluation of patients…may improve screening for those who can be safely released from the ED." | 34 excluded from analysis: 24 had abnormal rest echocardiogram, 4 refused participation after consent, 5 had technically inadequate echocardiogram, 1 recurring chest pain | Patients entering phase 1 to 3 required admission except for phase 4, unless abnormal DSTE. 1 pt reported "had persistent typical angina pectoris" interpreted as UA. The reported sensitivity and specificity results and calculation of prevalence cannot be verified with data reported in the text and tables.

DSTE-dobutamine stress tele-echocardiography; hx-history; ND-no data; pt(s)-patient(s); sens-sensitivity; spec-specificity.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 15. Diagnostic performance studies evaluating technetium-99m sestamibi for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^4^ | Experimental test results blinding ^5^ | Reference criteria for AMI/ACI ^6^ | Diagnostic criteria sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Hilton 1994 94193906 | Country: USA Mean age: 50 Enrolled: 102 Evaluated: 102 % male ND Race: ND | Chest pain score >4 | Hx or ECG results of previous MI, Atypical chest pain, ECG diagnostic for ACI, Contraindications to radionuclide imaging | 10-30 mCi of ^99m^Tc was injected into patient. SPECT imaging was obtained 30-110 minutes later. | ACI 13.7% 14/102 AMI 11.8% (12/102) | NA | Two readers blinded to clinical characteristics, ECG results, & outcome. | AMI: unclear criteria ACI: predischarge cardiac death, nonfatal MI, or need for cardiac intervention (PTCA/CABG/thrombolysis) | Equivocal or abnormal ACI: Sens 93.3%, Spec 79.3% AMI: Sens 100%, Spec 77.8% | "Sestamibi when applied in emergency room patients with typical angina and a normal or nondiagnostic ECG appears to be highly accurate in distinguishing between low and high risk subjects." | ND | All patients experienced chest pain at time of injection. At least 90-day followup.
Stewart 1996 96420043 | Country: USA Mean age: 52 Enrolled: 68 Evaluated: 68 54% male Race: ND | Nondiagnostic hx, Nondiagnostic physical examination, Normal or nondiagnostic ECG, Normal cardiac enzymes (when available), Hx of MI allowed | AMI, Diagnostic hx & physical examination for UA, Contraindications to adenosine use | 10 mCi of ^99m^Tc was injected into patient. SPECT imaging was obtained 30 minutes later at rest. | ACI 8.8% (6/68) AMI 1.5% (1/68) | NA | ND | AMI: apparently hospital discharge ACI: AMI, or revascularization (PTCA/CABG) over 9 months followup | Perfusion defect ACI: Sens 100%, Spec 53.2% AMI: Sens 100%, Spec 49.3% | "…a valuable diagnostic tool for risk stratification, and can safely predict the occurrence of major cardiac events at 9 month clinical follow-up period in this low-risk patient population. A negative scan excluded adverse cardiac event…" | Only 36 of 46 negative and/or indeterminate rest sestamibi results received stress Tc-99m sestamibi of 20 mCi. 12 positive & 24 negative. | Test results used by ED cardiologist in patient care.
Kontos 1997b ^3^ 97462257 | Country: USA Mean age: 55 Enrolled: 542 Evaluated: 532 45.5% male Race: ND | Low- or moderate-risk patients, Hx of CAD and/or MI allowed | High-risk patients: Abnormal ECG or nondiagnostic ECG, Known coronary disease & typical symptoms | Approximately 20 mCi of ^99m^Tc was injected & gated SPECT imaging obtained with triple-headed gamma camera at 60-90 minutes after injection. | ACI 17.1% (91/532) AMI 5.3% (28/532) | Physician blinded to perfusion imaging results. | ND | AMI: CK-MB by mass assay >8.0 ng/dL with relative index >4.0 ACI: AMI, revascularization or significant stenosis >70% by angiography | Discrete perfusion defect with associated wall motion abnormality and/or thickening ACI: Sens 79.8%, Spec 80.9% AMI: Sens 92.9%, Spec 71.2% | "Positive rest perfusion imaging accurately identified patients at high risk for adverse cardiac outcomes, whereas negative perfusion imaging identified a low risk patient group." | 47 patients not meeting protocol guidelines were included in analyses. Ten patients were excluded from analyses; 5 refused to be imaged & 5 images were not interpretable. | No patient was injected with ^99m^Tc after 6 hrs last episode of pain.
Kontos 1998 ^3^ 98449508 | Country: USA Mean age: 51 Enrolled: 186 Evaluated: 185 48.6% male Race: ND | Low-risk (typical symptoms <30 min or atypical symptoms >30 min) or moderate-risk (symptoms >30 min) patients | High-risk patients for ACI: Abnormal ECG, Known coronary disease & typical symptoms | 20-30 mCi of ^99m^Tc was injected into patient. After 30 min, SPECT was performed with triple-headed gamma camera. | AMI 3.2% (6/185) | Physician blinded to perfusion imaging results. | ND | 2 of 3 criteria for AMI: (1) symptoms >30 minutes, (2) evolving diagnostic ECG changes, (3) CK-MB by mass assay >8.0 ng/dL with relative index >4.0. | Discrete perfusion defect with associated wall motion abnormality and/or thickening AMI: Sens 100%, Spec 84.4% | Myocardial perfusion imaging "identified all patients who had MI or who underwent revascularization. In addition, negative results…reliably excluded both these end points." | One patient with negative perfusion imaging results excluded from analysis. | Patients with negative images were discharged, to return for followup stress test within 24-72 hrs.

hx-history; mCi-millicurie; ND-no data; PTCA-percutaneous transluminal coronary angioplasty; sens-sensitivity; spec-specificity.

1 MEDLINE or unique identifying number assigned by EPC

2 All presenting with chest pain or discomfort.

3 53 patients were included in both studies - Kontos (1997b) and Kontos (1998).

4 Interpretation of reference test results blinded to experimental test results and clinical information.

5 Interpretation of experimental test results blinded to reference test results and clinical information.

6 ACI definition not in accordance to the National Heart Attack Alert Program.

Evidence Table 16a. Diagnostic performance studies evaluating ACI predictive instrument and ACI time-insensitive predictive instrument for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^4^ | Experimental test results blinding ^5^ | Reference criteria for AMI/ACI | Diagnostic criteria for ACI: sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Pozen 1980 80107707 | Country: USA Mean age: Test - 55 Control - 58 Enrolled: 856 Evaluated: Test - 401 Control - 455 Test: 61% male Control: 55% male Race: Test - 49% White Control - 55% White | Men >30 yr, Women >40 yr, 1 of 9 IMIR criteria: Chest pain, Breathing difficulty, Upper abdominal pain and/or nausea, Fainting and/or dizziness, Palpitations, Pedal edema, Unexplained tiredness and/or weakness, Unexplained irritability, Pain in arms, shoulders, neck, or throat, Hx CAD allowed | ND | Empirically derived instrument based on 9 clinical, hx, & ECG predictive variables. Predictive instrument tested on alternate months for 10-month study as a supplemental diagnostic aid for ED physicians, who were given autonomy whether to incorporate instrument's probability of ACI in decisionmaking. | ACI - Test months 16.5% (66/401) Control months 17.4% (79/455) | Final diagnosis by cardiologist blinded to predictive instrument probability estimate. | NA | Retrospective review of serial ECGs & cardiac enzymes. Additional clinical information was evaluated for admitted patients. ACI includes AMI, unstable preexisting angina (including stable 3-month angina hx), or new onset angina (symptoms of 1^st^ time angina pectoris) & documented ECG changes in ST-T waves during pain, positive exercise stress test, or positive coronary arteriogram. | Sens - 86.4% Spec - 91.6% | "The mathematical instrument studies, which accurately predict acute ischemic heart disease using clinical data routinely collected in emergency rooms, has been shown to be successful in reducing physician's overadmission rates for patients with suspected acute ischemic heart disease while still maintaining a low false-negative discharge rate." | Overall followup rate for all patients was 92%. Patients followed up during hospital stay or returned for followup within 72 hours for additional questionnaire, followup ECG, and followup enzymes. | Logistic regression was used to control for significant differences between the control & test groups for variables, age & race, in addition to other covariates; sex, MI hx & angina hx. The results were the test months had higher dx accuracy & lower false positive rates.
Pozen 1984 84191327 | Country: USA Mean age: 62 Enrolled: 2,320 Evaluated: 2,320 Test - 1,288 Control - 1,032 56% male Race: ND | Men >30 yr, Women >40 yr, Chief symptom of chest pain, left arm or jaw pain, shortness of breath, or changed pattern of angina pectoris (based on IMIR criteria) | ND | Empirically derived predictive instrument based on 7 clinical, hx, & ECG variables from 2,801 patients at 6 ED sites. 2 study designs to test the instrument. (1) 1^st^ 3 sites, instrument tested on alternate months for 11-month study as supplemental diagnostic aid for ED physicians. (2) 2^nd^ 3 sites, time-series of 6-month test period followed by 5-month control period. For each design, 1 hospital at 3 different teaching-status levels. ED physicians given autonomy whether to incorporate instrument's probability of ACI in decisionmaking. | Overall ACI - Test "32%" Control "29%" | Final diagnosis by investigator blinded to ED diagnosis. | NA | WHO criteria for MI: clinical hx, ECG, and cardiac enzyme test results. Unstable preexisting angina: included stable 3-month hx of angina with increased frequency or severity. New onset angina: 1^st^ time symptoms & documented ECG changes in ST-T waves during pain, positive exercise stress test, or positive coronary arteriogram. | Sens - "94.5%" Spec - "78.1%" | "In a prospective trial that included 2320 patients in the six hospitals, physicians' diagnostic specificity for acute ischemia increased when the probability value determined by the instrument was made available to them. Rates of false-positive diagnosis decreased without any increase in rate of false-negative diagnosis." | 11% of pts without followup data were compared with pts with complete data and were found more likely to be women, have noncardiac ED diagnosis, less likely to have chest pain as chief symptom, one-half as likely to have ACI, & one-fourth as likely to be admitted. | Sensitivity & specificity could not be verified with limited data reported.
Davison 1990 ^3^ 91093810 | Country: USA Mean age: 56.3-65.4 Enrolled: 235 Evaluated: 232 ~50% male Race: ND | >30 yr, Chief complaint of chest, jaw, or left arm pain, Changed pattern of angina pectoris | Pain attributable to trauma or associated with noncardiac radiographic abnormalities | Protocol with data collection form including each clinical factors from decision aids of Goldman (1982), Pozen (1984), & Brush (1985). | ACI 29.7% AMI 20.7% (48/232) UA 9.1% (21/232) | ED residents had no knowledge of study purpose or given predictions of instrument. ND on final diagnosis. | NA | "…the final diagnosis at discharge to be used as the diagnostic 'gold standards' in the manners of Goldman and Pozen." | NA | "None of the decision aids could reduce unnecessary admissions without seriously increasing the rate of inappropriate discharges." | 3 admitted patients excluded for incomplete data & 5 discharged patients lost to followup but no death certificates found, assumed no MI or complications & included in analysis. | Data inconsistencies on number of patients enrolled & analyzed. Sensitivity/specificity data could not be verified with limited data reported. SROC given for ACI, but used 9 different cutoffs dividing normal from abnormal, not intended by ACI design.
Selker 1991 91304088 | Country: USA Mean age: 62 Enrolled: 2,320 Evaluated: 2,320 Test - 1,288 Control - 1,032 56% male Race: ND | Men >30 yr, Women >40 yr, Chief symptom of chest pain, shortness of breath, upper abdominal pain, dizziness (based on IMIR criteria), Hx CAD allowed | ND | Logistic regression-based ACI-TIPI based on 7 clinical variables from 3,453 patients at 6 various ED sites. The same sites were used to test the instrument as a probability scale & performance in probability risk stratification. | Overall - AMI 17.6% (409/2,320) UA 16.6% (384/2,320) | Physician reviewers blinded to study purpose and components of predictive instrument. | NA | WHO and NY Heart Association criteria for ACI: clinical presentation, ECG and cardiac enzyme results. ACI defined as AMI, new onset angina, and unstable angina. | NA | "The TIPI is accurate and reliable, and should be useful for real-time CCU triage decisionmaking and also for quality assurance and cost-containment efforts. This dual function may enhance cooperation between clinicians, institutions, payors, and review agencies." | 89% followup rate with 48-hour ECGs & cardiac enzymes for both admitted and nonadmitted patients. | ROC area was 0.88. For ACI pts, mean TIPI probability was 59%, for non-ACI pts, 21% (p=0.0001), regardless of triage decision. For the low-probability group of the 4 risk groups, 1.6% had ACI (0.7% AMI); the high-probability group, 81.6% had ACI (53.3% AMI). TIPI designed for optional retrospective use eliminating 2 clinical hx variables that are not always available in records, and adding age, sex, & presence of ECG Q waves.

dx-diagnosis; hx-history; IMIR-Imminent Myocardial Infarction Rotterdam; ND-no data; pt(s)-patient(s); sens-sensitivity; spec-specificity.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Study also used to evaluate Goldman predictive instrument. See Table 17a.

4 Interpretation of reference test results blinded to experimental test results and clinical information.

5 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 16b. Clinical impact studies evaluating ACI predictive instrument and ACI time-insensitive predictive instrument to manage acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Prevalence of disease | Study design/comparisons | Diagnostic protocol | Diagnostic criteria for ACI | Outcomes | Study conclusions | Limitations/comments
Pozen 1980 80107707 | Country: USA Mean age: Test - 55 Control - 58 Enrolled: 856 Evaluated: Test - 401 Control - 455 Test: 61% male Control: 55% male Race: Test - 49% White Control - 55% White | Men >30 yr, Women >40 yr, 1 of 9 IMIR criteria: Chest pain, Breathing difficulty, Upper abdominal pain and/or nausea, Fainting and/or dizziness, Palpitations, Pedal edema, Unexplained tiredness and/or weakness, Unexplained irritability, Pain in arms, shoulders, neck, or throat, Hx CAD allowed | ND | ACI - Test month 16.5% (66/401) Control month 17.4% (79/455) | Controlled clinical trial - alternating months/Number of CCU admissions during experimental months were compared with number of CCU admissions during control months. | Predictive instrument used on alternate months for 10-month study as a supplemental diagnostic aid for ED physicians, who were given autonomy whether to incorporate instrument's probability of ACI in decisionmaking. | Retrospective review of serial ECGs & cardiac enzymes. Additional clinical information was evaluated for admitted patients. ACI includes AMI, unstable preexisting angina (stable 3-month angina hx), or new onset angina (symptoms of 1^st^ time angina pectoris). | CCU admissions decreased from 26% during the control months to 14% during the experimental months (p<0.001). Inappropriate ED discharge rate of 3% did not change. Overall diagnostic accuracy increased from 81.8% to 90.7%. | "The mathematical instrument studies, which accurately predict acute ischemic heart disease using clinical data routinely collected in emergency rooms, has been shown to be successful in reducing physician's overadmission rates for patients with suspected acute ischemic heart disease while still maintaining a low false-negative discharge rate." | ND
Pozen 1984 84191327 | Country: USA Mean age: 62 Enrolled: 2,320 Evaluated: Test - 1,288 Control - 1,032 56% male Race: ND | Men >30 yr, Women >40 yr, Chief symptom of chest pain, left arm or jaw pain, shortness of breath, or changed pattern of angina pectoris | ND | Overall ACI - Test "32%" Control "29%" | Controlled clinical trial - time series/Number of CCU admissions during experimental months were compared with number of CCU admissions during control months. | Predictive instrument implemented at (1) 1^st^ 3 sites, 11-month study of test month alternating with control month; (2) 2^nd^ 3 sites, time series design of 6-month test period followed by 5-month control period. It was used as supplemental aid for ED physicians, who were given autonomy whether to incorporate instrument's probability of ACI in decisionmaking. | WHO criteria for MI: clinical hx, ECG and cardiac enzyme test results. Unstable preexisting angina: included stable 3-month hx of angina with increased frequency or severity. New onset angina: 1^st^ time symptoms & documented ECG changes in ST-T waves during pain, positive exercise stress test, or positive coronary arteriogram. | CCU admission rates dropped for pts without ACI from 24% during the control period to 17% (p=0.003) during the test period, correspondingly, ED discharge rates increased from 44% to 51%. For pts with ACI, there was no difference in triage outcomes between the two periods. | "Among study patients with a final diagnosis of "not acute ischemia," the number of CCU admissions decreased 30 per cent, without any increase in missed diagnoses of ischemia. The proportion of CCU admissions that represented patients without acute ischemia dropped from 44 to 33 per cent. Widespread use of this predictive instrument could reduce the number of CCU admissions in this country by more than 250,000 per year." | Results could not be verified with limited data given.
Corey 1987 87282178 | Country: USA Mean age: ND Enrolled: 58 Evaluated: 56 Test - ND Control - ND % male ND Race: ND | Men >30 yr, Women >40 yr, Chief symptom of chest pain, shortness of breath, or changed pattern of angina pectoris, Criteria same as Pozen (1984) | ND | ND | Randomized controlled trial/False accuracy rate compared between experiment and control group for admitted pts. | ED physicians computed predictive instrument risk. Autonomy was given whether to incorporate instrument's probability of ACI in decisionmaking. Data variables also completed for controls, but risk was not calculated. | ND | 100% pt followup at 1 to 5 months, no outcome data reported. | "The predictive instrument retained predictive accuracy in the new setting with good correlation between predicted and actual risk of acute cardiac ischemia (r=0.925)." | Data given could not be verified.
Sarasin 1994 94284912 | Country: Switzerland Mean age: 64 Enrolled: 529 Test - 294 Control - 325 Evaluated: 418 63.7% male Race: ND | > 18 yr, Chief symptom of chest pain, left arm or jaw pain, shortness of breath, or changed pattern of angina pectoris, Hx CAD allowed | ND | Overall - ACI 59.0% AMI 31.9% (169/529) UA 27.0% (143/529) Evaluated - ACI 69.4% AMI 37.3 (156/418) UA 32.1% (134/418) | Controlled clinical trial - alternating months/ED LOS, speed of triage, & impact on physicians of different training levels. | ACI-TIPI used on alternate months for 7-month study. During the 4 test months, a computerized probability was automatically printed out on ECG, with which the ED physicians had discretion to incorporate or ignore in triage decision. | WHO & NY Heart Association ACI criteria: clinical presentation, ECG & elevated CK-MB tests. ACI defined as AMI, new onset angina pectoris including 1^st^ time symptoms & documented ECG changes in ST-T waves during pain, positive exercise stress test, or positive coronary arteriogram, and unstable angina pectoris including stable 3-month hx of angina with increased frequency or severity. | For novice MDs evaluating pts with ACI using ACI-TIPI, LOS from presentation to triage and ED discharge decreased by 0.7 hour (19%, p=0.007). | "For ED patients with acute cardiac ischemia evaluated by novice clinicians, the ACI-TIPI substantially speeded ED decision making and triage." | 111 patients who stayed overnight at the ED were excluded from ED LOS analysis. Incomplete data ED LOS was 5%, and final diagnosis & followup was 4%. Swiss patients may see their primary physicians before ED referral, therefore the relatively higher ACI rate.
Selker 1998 99043207 | Country: USA Mean age: Cases - 59 Controls - 59 Enrolled: ND Evaluated: 10,689 Cases - 4738 Controls - 5951 Cases: 51% male Controls: 52% male Race: | (1) >30 yr, or >18 yr if reported or suspected of recent cocaine use (2) Chief symptom of chest, left arm, jaw, or epigastric pain or discomfort; shortness of breath; dizziness; palpitations; or other symptoms suggestive of acute ischemia | ND | "AMI 8%" "UA 15%" | Controlled clinical trial - alternating months/Number of CCU admissions during experimental months were compared with number of CCU admissions during control months stratified by low- versus high-capacity CCUs compared with telemetry units. | ACI-TIPI used on alternate months for 7-month study as supplemental diagnostic aid for ED physicians, who were given autonomy whether to incorporate instrument's probability of ACI in decisionmaking. | Initial & 30-day followup data using WHO criteria, including clinical features, ECG, CK-MB test results. | For non-ACI pts at high-capacity CCUs relative to low-capacity telemetry units, CCU admissions decreased 15% to 12%, 16% change (95% CI, −30% to 0%), & ED discharge increased, 49% to 52%, 6% change (CI, 0% to 14%); overall p=0.09. With unsupervised residents, CCU & telemetry unit admissions decreased, 14% to 10%, −32% change (CI, −55% to 3%) & 39% to 31%, −20% (CI, −34% to −2%), respectively, & ED discharge increased, 45% to 56%, 25% change (CI, 8% to 45%); overall p=0.008. 96% rate of admission unchanged for ACI pts at sites with high-capacity CCUs or telemetry units. | "Use of ACI-TIPI was associated with reduced hospitalization among emergency department patients without acute cardiac ischemia. This result varied as expected according to the CCU & cardiac telemetry unit capacities & physician supervision at individual hospitals. Appropriate admission for UA & AMI was not affected." | Results could not be verified with limited data given. Followup rate for data collection was 99% for final diagnosis. Low CCU capacity influences physicians to selectively reduce CCU admissions for patients without ischemia. There were no rural hospitals included or were there EDs without onsite physicians.
  | Case | Control
  Blk | 32% | 33%
  Hisp | 5% | 5%
  Wht | 63% | 61%

Blk-Black; Hisp-Hispanic; hx-history; IMIR-Imminent Myocardial Infarction Rotterdam; LOS-length of stay; MD-medical doctor; ND-no data; pt(s)-patient(s); Wht-White.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

Evidence Table 17a. Diagnostic performance studies evaluating Goldman predictive instrument for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^4^ | Experimental test results blinding ^5^ | Reference criteria for ACI | Diagnostic criteria for AMI: sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Goldman 1982 82272128 | Country: USA Mean age: ND Enrolled: 357 Evaluated: 357 % male ND Race: ND | ED patients: >25 yr, Chief complaint of anterior, precordial, or left-lateral chest pain with no obvious local trauma or chest-film abnormalities, Admitted patients: Chief complaint of chest pain | ND | Predictive model based recursive partitioning using 9 clinical, hx, & ECG variables. If probability of MI is at least 1 in 15, patient is classified positive for AMI. | AMI 15.4% (55/357) | Final diagnosis made without knowledge of instrument's prediction. | NA | AMI-one of following: SGOT > normal & > twice admission value, CK-MB fraction >5% CK total, or LDH 1 > isoenzyme 2 with no hemolytic anemia or renal infarction; ECG showing new pathologic Q wave; Scintiscan showing focal uptake of Tc-99m stannous pyrophosphate in cardiac area if serum enzyme peaked before hospitalization & no hx of MI or valvular calcification. ACI without MI-2 conditions: (1) Angina diagnosis by senior clinician, followup hx, or positive exercise test or coronary arteriogram; (2) Chest pain symptoms are either new or worse than any previous chronic anginal syndrome | Sens-90.9% Spec-69.9% Model integrated with physician decision for pts: Sens-89.1% Spec-77.2% | "Although our computer protocol performed well in external validation testing at a second hospital, substantially more testing will be required before it can be applied confidently to clinical practice." | ND | Followup in 48-72 hrs for enzymes & ECG tests was achieved for 85% of nonadmitted pts.
Goldman 1988 88174885 | Country: USA Mean age: 56 Enrolled: 4,898 Evaluated: 4,770 48.2% male Race: ND | >30 yr | Obvious local trauma or chest-film abnormalities, Cardiac arrest in ED | 2^nd^ generation predictive model based recursive partitioning using 9 clinical & 2 ECG variables. If probability of MI is at least 1 in 15, patient is classified positive for AMI. | ACI 26.6% AMI 12.1% (576/4,770) ACI without AMI 14.5% (694/4,770) | Data collection staff & ED physicians blinded to structure of protocol. | NA | AMI-one of following: Typical evolution of serum enzyme levels, CK-MB fraction >5% CK total, or LDH 1 > isoenzyme 2 with no hemolytic anemia or renal infarction; ECG with new pathologic Q wave >0.04 sec in duration & >25% decrease in amplitude in following R wave; Scintiscan showing focal uptake of Tc-99m stannous pyrophosphate in cardiac area if serum enzyme peaked before hospitalization & no hx of MI or valvular calcification. ACI without MI-2 conditions: (1) Angina diagnosis by senior clinician, followup hx, or positive exercise test or coronary arteriogram; (2) Chest pain symptoms are either new or worse than any previous chronic anginal syndrome | Sens-88.0% Spec-74.2% | "Although this protocol should not be used to override careful clinical judgment in individual cases, the computer protocol for the most part yields accurate estimates of the probability of myocardial infarction. Decisions about admission to the coronary care unit based on the protocol would have been as effective as those actually made by the unaided physicians who cared for the patients, and less costly." | 128 patients enrolled not included in analysis because of inadequate followup for final diagnosis, but in addition, 595 patients were not included because of incomplete forms or insufficient clinical data to complete assignment into subgrouping. | Improved upon model designed & validated in Goldman et al., 1982, this model considered separately patients with & without hx of cardiac ischemia.
Davison 1990 ^3^ 91093810 | Country: USA Mean age: Admitted 56.3 Discharged 65.4 Enrolled: 235 Evaluated: 232 ~50% male Race: ND | >30 yr, Chief complaint of chest, jaw, or left arm pain, Changed pattern of angina pectoris | Pain attributable to trauma or associated with noncardiac radiographic abnormalities | Protocol with data collection form including each clinical factors from decision aids of Goldman (1982), Pozen (1984), & Brush (1985). | ACI 29.7% AMI 20.7% (48/232) UA 9.1% (21/232) | ED residents had no knowledge of study purpose or given predictions of instrument. ND on final diagnosis. | NA | "…the final diagnosis at discharge to be used as the diagnostic 'gold standards' in the manners of Goldman and Pozen." | ND | "None of the decision aids could reduce unnecessary admissions without seriously increasing the rate of inappropriate discharges." | 3 admitted patients excluded for incomplete data & 5 discharged patients lost to followup but no death certificates found, assumed no MI or complications & included in analysis. | Data inconsistencies on number of patients enrolled & analyzed. Sensitivity/specificity data not given, but SROC provided.

hx-history; ND-no data; pt(s)-patient(s); sens-sensitivity; SGOT-serum glutamic-oxaloacetic transaminase; spec-specificity.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Study also used to evaluate ACI predictive instrument. See Table 16a.

4 Interpretation of reference test results blinded to experimental test results and clinical information.

5 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 17b. Clinical impact studies evaluating Goldman predictive instrument to manage acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Prevalence of disease | Study design/comparisons | Diagnostic protocol | Diagnostic criteria for ACI | Outcomes | Study conclusions | Limitations/comments
Lee 1995 95160388 | Country: USA Mean age: 56 Enrolled: 1,921 Evaluated: 1,921 Intervention 997 Control 924 48.4% male Race: 59% White | 30 yr, Chest pain unexplained by local trauma or chest radiograph | ND | Total AMI 6.6% (126/1,921) Intervention 6.9% (64/924) Control 6.2% (62/997) | Time series (six 14-week cycles: 5 week-intervention & 5-week control period separated by 2-week washout)/ Intervention versus control groups | Modified Goldman predictive instrument used during the intervention period; risk estimates & triage recommendations made by flowsheets & stickers to physicians in ED & first 3 mornings for hospitalized pts. | AMI: (1) CK-MB isoenzyme > than trace amounts or >5% total CK with typical increase & decrease; or (2) typical increase & decrease of total CK with peak value > twice upper limit of normal; or (3) LDH isoenzyme 1 level > LDH isoenzyme 2 level with no hemolysis or renal infarction. MI for pts with acute ST-segment elevation (receiving reperfusion tx with intravenous meds or primary angioplasty): 100% occlusion of infarction-related artery by catheterization, or CK-MB isoenzyme level >2.5% of elevated total CK. | Of the intervention group, 50.5% (467/924) were hospitalized with 10% (92/924) admitted to the CCU. Correspondingly, the control group had 52.2% (520/997) hospitalized with 9.5% admitted. Low-risk patients, 1,160 <7% for AMI, had 1.6% CCU admission with no differences between the two groups. | "The use of information alone -- without direct human contact -- did not affect management of patients with acute chest pain at this hospital. Although this low-intensity intervention might be more effective for other conditions and in other settings, our data support the use of other strategies to affect physician decision making." | Insufficient data for AMI prediction by algorithm; 78 in the control & 79 in the intervention groups. Physicians' discretion to assign hospitalized pts to coronary care, intermediate care, or coronary observation units adjacent to ED. Triage recommendations added to study protocol after 1^st^ intervention cycle at physicians' request.

hx-history; meds-medications; ND-no data; pt(s)-patient(s); tx-treatment.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

Evidence Table 18a. Diagnostic performance studies evaluating algorithm protocols for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Reference criteria for ACI | Diagnostic criteria for AMI/ACI: sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Lee 1991 91194729 | Country: USA Mean age: 62 Enrolled: 2,684 Evaluated: 2,684 57.6% male Race: ND | >30 yr, Anterior, precordial, or left-sided chest pain unexplained by trauma or radiograph abnormalities, Hx CAD allowed, All patients admitted | ND | 12-hour protocol to "rule out myocardial infarction" for low risk (<7%) by Goldman algorithm including at least 2 sets of cardiac-enzyme tests for CK & CK-MB. | ACI 58.2% AMI 30.0% (806/2,684) UA 28.1% (755/2,684) Low-risk pts-ACI 34.6% AMI 7.0% (67/957) UA 27.6% (264/957) | NA | NA | AMI: (1) CK-MB isoenzyme > than trace amounts or >5% total CK with typical increase & decrease; or (2) typical increase & decrease of total CK with peak value > twice upper limit of normal; or (3) LDH isoenzyme 1 level > LDH isoenzyme 2 level with no hemolysis or renal infarction. UA: chest pain symptoms are either new or worse than any previous chronic anginal syndrome and angina diagnosis by senior clinician. | NA | "Emergency room clinical data can be used to identify a large subgroup of patients for whom a 12-hour period of observation is normally sufficient to exclude acute myocardial infarction. Patient-specific evaluation and treatment can then proceed without the restrictions imposed by 'rule out' protocols for myocardial infarction." | ND | 771 of 957 low-risk pts did not have abnormal enzyme levels or recurrent ischemic chest pain & would have been transferred out to lower level care for further testing. 4 of 771 pts (0.5%) had AMI.
Gibler 1995 95100634 | Country: USA Avg age: 45.0 Enrolled: 1,010 Evaluated: 1,010 50.7% male Race: 59.7% Black 38.7% White 0.6% Asian 1.0% Other | >25 yr, or <25 yr with recent cocaine or sympathomimetic amine drug use, Chest pain unexplained radiograph | ECG diagnostic for ACI, SBP <90 mmHg, Hx CAD, Persistent or recurring chest pain suggesting unstable angina | 9-hour Heart ER Program based on: serial CK-MB at 0, 3, 6, & 9 hrs; SECG at 20-sec interval for 9 hrs; at hr 9, hx & physical exam by cardiologist; 2-D echocardiography at rest; & graded exercise (maximal Bruce protocol) test. If exercise test is negative, pt is discharged & given 24-48 hr followup instructions. | ACI 4.3% AMI 1.2% (12/1,010) Angina/UA 3.1% (31/1,010) | NA | NA | ND | Serial CK-MB: levels >7 ng/mL (ICON-QSR monoclonal antibody method) or 6 ng/mL (Stratus fluorometric enzyme immunoassay method) with relative index >5% (CK-MB/total CK). SECG Δ: ST-segment increase or decrease >0.1 mV in 2 contiguous leads or >0.2 mV in 1 lead. Echocardiogram: segmental wall motion, valvular/pericardial effusions abnormalities, or global myocardial dysfunction. Graded stress test: horizontal or downsloping ST-segment depression >1 mm baseline ECG & chest discomfort. | "The Heart ER program provides an effective method for evaluating low- to moderate-risk patients with possible acute ischemic coronary syndrome in the ED setting." | 28 released against medical advice before completion of Heart ER protocol. | Retrospective review of consecutive patients. One patient with negative evaluation returned to the ED 3 days later with AMI. 113 patients had cocaine use, of whom 10 were admitted by SECG detection, 3 had chest pain suggesting unstable angina, 2 had elevated CK-MB levels, & 1 had stroke.
  | Sens | Spec
  Serial CK-MB-AMI | 100% 12/12 | 98.3% 981/998
  Serial ECG-ACI | 21.2% 11/52 | 99.4% 952/958
  Echocardiography-ACI | 47.4% 9/19 | 99.0% 873/882
  Exercise stress-ACI | 28.6% 4/14 | 99.4% 772/777
Zalenski 1997a 97307161 | Country: USA Mean age: 46.6 Enrolled: 359 Evaluated: 317 53.5% male Race: 66.2% Black 12.0% Hispanic 7.6% White 6.6% Asian 7.6% Other | >30 yr at 1^st^ yr enrollment, >20 yr at 2^nd^ yr enrollment, Low-risk AMI pts defined by Goldman algorithm | Confirmed diagnosis of heart disease by: Cardiac testing, ECG Q waves, Probable or definite angina, Cardiac complications Safety risks: Atrial fibrillation, Frequent premature ventricular contractions, Inability to exercise, Concurrent noncardiac diagnosis requiring admission Pain <30 sec or >72 hrs in 1^st^ yr enrollment | 12-hour protocol based on: serial CK-MB at 0, 4, 8, & 12 hrs; SECG at 0, 6, & 12 hrs; clinical assessments at 0, 6, & 12 hrs; and exercise test (modified submaximal Bruce protocol). | ACI 9.5% (30/317) AMI 2.8% (9/317) UA 6.6% (21/317) | Reading of all ECGs for AMI blinded to test protocol. Serial CK-MB & clinical diagnosis results not blinded. | ED physicians' recording of test results in real time, blinded to reference diagnosis. | AMI-1 of following: (1) Q-wave evolution 40 ms wide in 2 leads & >1/4 height of R wave (2) elevated CK >130 U/L & CK-MB/CK index >2.5 (3) elevated LDH with isoenzymes 1 to 2 of 0.75 or more without hemolysis or renal infarction UA: Negative for AMI & positive angiogram, positive thallium or stress echocardiogram, resting ECG with new ST elevation or depression, cardiogenic shock, pump failure, ventricular tachycardia or fibrillation, heart block, or cardiac arrest. Senior or attending physician's diagnosis. Positive exercise test insufficient for UA. | ACI: Sens-90.0% Spec-50.5% | "A chest pain diagnostic protocol achieved high sensitivity and improved specificity over the standard emergency department workup. There were no adverse advents associated with early ExECG." | 31 patients had incomplete enzyme determinations or ECGs. 3 pts withdrew and 8 admitted for noncardiac reasons. | All 317 patients were admitted for final diagnoses. Pain onset 43.5% <24 hr, 16.6%=24-48 hr, 39.9% >48 hr.

2-D-two dimensional; ER-emergency room; hx-history; ms-millisecond; mV-millivolt; NA-not applicable; ND-no data; pt(s)-patient(s); SBP-systolic blood pressure; SECG-serial electrocardiography; sens-sensitivity; spec-specificity; δ-change.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 18b. Clinical impact studies evaluating algorithm protocols to manage acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Prevalence of disease | Study design/comparisons | Diagnostic protocol | Diagnostic criteria for ACI | Outcomes | Study conclusions | Limitations/comments
Gomez 1996 96286085 | Country: USA Mean age: Test 50 Control 53 Enrolled: 100 Evaluated: 97 61% male Race: ND | >30 yr, Chest pain or related symptoms unexplained by trauma or radiograph & determined by physician suggestive of ischemia requiring admission to rule out ACI, ECG absence of acute ischemic changes, Low-risk pts (<7%) defined by Goldman algorithm | <30 yr, >7% probability of AMI, ECG diagnostic of ACI, Sustained/nonsustained ventricular tachycardia, or frequent ventricular ectopic activity or supraventricular tachycardia requiring intravenous meds, 2° or 3° heart block or new BBB, Intravenous nitroglycerin, SBP >220 mmHg or DBP >120 mmHg despite tx, Congestive heart failure or other conditions requiring intravenous meds or intensive monitoring. | ACI 6.0% AMI 2.0% (2/100) UA 4.0% (4/100) | RCT/ED-based rapid rule-out protocol versus routine hospital care for LOS & charges. | Patients assigned to CPU. Serial enzyme testing at 0, 3, 6, & 9 hr; serial ECG with continuous ST-segment monitoring and if both tests were negative, symptom-limited graded exercise test. Pts unable to perform/complete test or if unequivocal/uninterpretable, had dobutamine stress echocardiography. If negative, pts discharged. | ND | LOS, by intention to treat analysis of 100 pts, or by pts with ACI ruled out, was shorter by factor of ~2 (median 12.1 vs 22.3 hr, p=0.0001; 11.9 vs 22.8, p=0.0001) for the test vs the control group. Hospital charges by intention to treat analysis were median $895 vs $1,488, p=0.0001 for the test vs control groups; by pts with ACI ruled out, median $893 vs $1,349, p=0.0001, respectively. ACI diagnosis for 6 pts not adequately powered, 1 for test & 5 for control groups. No missed diagnosis or mortality at 30-day followup. | "In low risk patients who present to the emergency department with chest pain, the rapid protocol ruled out myocardial infarction and unstable angina more quickly and cost-effectively than did routine hospital care." | 5 patients left against medical advice. Initial serum test results frequently available before randomization but not required per protocol. 30-day followup, 98%; 2 pts lost to followup. Protocol violation of 3 pts; 1 at admission had ECG for ACI & 2 in control group not admitted but discharged from ED. Event rate too low to show difference between control & rapid protocol.
Mikhail 1997 97152155 | Country: USA Mean age: 53 Enrolled: 502 Evaluated: 497 54% male Race: ND | Hx CAD allowed | ECG diagnostic for AMI, Diagnostic CK-MB with increased total CK, Continued chest pain suggestive of ischemia, Unstable atrial or ventricular rhythm, Tx of IV nitroglycerin or heparin, Concurrent congestive heart failure or hx dilated cardiomyopathy, Comorbidities requiring nursing care beyond CPC care, High probability of AMI | ACI 8.8% (44/502) AMI 2.0% (10/502) | Cohort-prospective/NA | Patients assigned to CPU which includes mandatory stress test except for end-stage heart disease. Rule out protocol include-4-hr myoglobin or 6- or 8-hr CK-MB, LDH, continuous ST-segment monitoring. Stress test options include: standard graded (modified Bruce protocol), stress echocardiography, dobutamine echocardiography, & thallium stress testing. | WHO criteria for AMI: CK-MB >8.5 ng/mL with relative index >8% (CK-MB/total CK) or, Myoglobin >90 ng/mL or double initial level | 67, 13.3%, admitted from CPU, of whom 44 had ACI. 32 of 67 admitted because of positive stress results. Of the 32, 24 had ACI. 14-day followup for 477, 95.0%. 410 of 435 discharged had followup on day 3, day 14, or both, at which no AMI, death, or tx intervention reported. No deaths or AMI at 5-month followup for negative diagnostic evaluation population. 374, 86.0%, were followed for 150 days, including 2 deaths & an additional AMI. | "Mandatory stress testing is safe, cost-effective, and valuable diagnostic and prognostic tool in CPC patients." | 5 patients left against medical advice. Stress testing available daily except for dobutamine & thallium stress tests, available on weekdays. 2 pts with known CAD & LTF, 1 had cardiac arrest 2 wk after CPU discharge, & 1 had AMI 6 days after discharge. 1, with end-stage heart disease, admitted for rule-out protocol only, had cardiac arrest.

BBB-bundle branch block; CPC-chest pain center; DBP-diastolic blood pressure; hx-history; LOS-length of stay; LTF-?; meds-medications; NA-not applicable; ND-no data; pt(s)-patient(s); RCT-randomized control trial; SBP-systolic blood pressure; tx-treatment.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

Evidence Table 19a. Diagnostic performance studies evaluating computer-based decision aids for the diagnoses of acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Diagnostic protocol | Prevalence of disease | Reference test results blinding ^3^ | Experimental test results blinding ^4^ | Reference criteria for AMI/ACI | Diagnostic criteria for AMI/ACI: sensitivity/specificity | Study conclusions | Potential verification bias | Limitations/comments
Tierney 1985 85229518 | Country: USA Mean age: AMI-55.0 Non-AMI-61.3 Enrolled: 655 Evaluated: 540 % male ND Race: ND | Men >30 yr, Women >40 yr, Hx CAD allowed | Prisoners, Recent hx chest trauma, smoke inhalation, or corrosive ingestion | Predictive model based on 4 dichotomous variables derived from logistic regression method. Data inputted from physician-completed questionnaire, consisting of patient hx and physical & ECG findings. | AMI 11.5% (62/540) | ER physicians' decision to admit or discharge prior to model outcome. | Investigator blind to ER or followup data | AMI: Elevated CK total & CK-MB isoenzyme fraction >4% of total, or LDH isoenzyme 1 > LDH isoenzyme 2 for patients without evidence of renal infarction or hemolysis. If no isoenzyme data, pathologic Q waves on serial ECG for admitted or released patients on followup. | 2 or more predictors: Sens - "81%" Spec - "86%" | "Our model is designed as a diagnostic aid for identifying patients at high risks for myocardial infarction, and therefore it should never be substituted for clinical judgement when the physician suspects infarction…[but] suggest that physicians reassess and consider admitting patients deemed at risk by the model or index whom they might otherwise have discharged from the ER…The model will more often support a physician's low suspicion of infraction." | 115 lost to followup & omitted from analysis. | Data from entire population used to calculate sensitivity & specificity including subset of 284 used to derive model. Sensitivity & specificity could not be verified with data reported.
Baxt 1991 92060377 | Country: USA Mean age: 52 Enrolled: 355 Evaluated: 331 58.0% male Race: ND | >18 yr | ND | Artificial neural network applying nonlinear statistics to recognize patterns from inputted data from physician-completed questionnaire, consisting of patient hx and physical & ECG findings. | AMI 10.6% (35/331) | Followup data for final diagnosis was entered into database with knowledge of initial data entry. | Initial data entry made before final diagnoses data entered | AMI: One of following: Characteristic evolution of serum enzyme levels, including CK CK-MB fraction >5% CK total or LDH level > isoenzyme 2 level in absence of hemolysis or renal infarction, ECG results of pathologic Q-wave development & >25% decrease R-wave amplitude compared with ED ECG, Scintiscan with focal uptake of Tc-99m stannous pyrophosphate in cardiac area. | Sens - 97.2% Spec - 96.3% | "An artificial neural network…may be a valuable aid to the clinical diagnosis of myocardial infarction; however, this possibility must be confirmed through prospective testing on a larger patient sample." | 24 lost to followup & omitted from analysis. | ND
Dilger 1992 93109076 | Country: Federal Republic of Germany Mean age: 59 Enrolled: 122 Evaluated: 122 67.2% male Race: ND | Patients suspected for AMI, CAD allowed | >75 yr, Symptoms >20 hrs, Uncertain onset of ischemic symptoms, Permanent pacemaker therapy, Major surgery or thoracic trauma <4 weeks, Final stage of disease, Acute cerebrovascular disease, Pregnancy | Predictive model based on 6 predictors derived from multiple logistic regression. Data from physician completed questionnaire, consisting of patient hx, and physical & ECG findings. | AMI 32.8% (40/122) | Reviewer of final diagnosis blinded to predicted result of model. | NA | AMI: "Standardized anamnestic, electrocardiographic, and enzymatic infarction criteria." | Sens - "89%" Spec - "86%" | Model's specificity increased & sensitivity not increased compared with an experienced physician. "Therefore, predictive models… should [not] serve as the only basis for diagnosis of AMI. [But] may prove useful in supporting the evaluation of risks, as a consequence of clinical judgement." | ND | Sensitivity & specificity could not be verified with limited data reported.
Jonsbu 1993 93231147 | Country: Norway Mean age: ND Enrolled: 1,252 Evaluated: 1,252 % male ND Race: ND | ND | ND | Decision support system using Bayes' formula to estimate probabilities & identify strong predictors of AMI and those in need of CCU observation. | AMI 41.7% (522/1,252) | Final ECG & diagnosis blinded to DSP. | ND | AMI: ECG findings of injury/necrosis, existing or new Q waves and/or AST & CK levels > upper normal limit. | Sens - "98.3%" Sens - "58.9%" | "DSP is only a chest pain program…results demonstrate that the view that the case history is an unreliable diagnostic parameter among patients with acute chest pain may be incorrect, and may arise from incomplete collection and analysis of all information comprised in the case history." | ND | Sensitivity & specificity could not be verified. Outcome data for 918 patients reported (Aase, Jonsbu, Liestol, et al., 1993) used to derive & validate DSP 'but virtually identical results' to study's 1,252 patients.
Baxt 1996 96129893 | Country: USA Mean age: ~53.1 Enrolled: 1,100 Evaluated: 1,070 72.9% male Race: ND | Patients >18 yr | ND | Artificial neural network applying nonlinear statistics to recognize patterns from inputted data of 20 clinical variables including hx & risk factors and physical & ECG findings. | AMI 7.0% (75/1,070) | ER physicians were blinded to network's results. Final diagnosis made blinded to ER physician & network results. | Initial data entry was check blinded to final diagnosis. Data entry for followup data blinded to initial data entry. | AMI: One of following within 3 days of admission: Characteristic CK levels & CK-MB fraction >5% of CK total, or ECG results of new pathologic Q-wave development & >25% decrease R-wave amplitude compared with ED ECG Discharged patients followed for 3 weeks. | AMI: Sens - 96.0% Spec - 96.0% | "The application of non-linear neural computational analysis via an artificial neural network to the clinical diagnosis of myocardial infarction appears to have significant potential." | 30 patients, diagnosed as negative by network, were lost to followup. | Network not basing diagnosis on ECG Δ as 33 of 75 AMI patients had no characteristic ECG findings.
Grijseels 1996 96289681 | Country: Netherlands Mean age: 65.6 Enrolled: 1,020 Evaluated: 977 53.1% male Race: ND | Hx CAD allowed | ND | Decision rule based on clinical indicators (hx & risk factors and physical & ECG findings) data to determine admission status for prehospital triage by GP. | ACI 47.8% AMI 29.9% (292/977) UA 17.9% (175/977) | ND | NA | AMI: hx, ECG, & enzyme criteria. UA: angina hx with increasing frequency & severity or new onset angina with ST-T changes at rest, abnormal stress test, or abnormal coronary angiogram. | ACI: Sens - 91.4% Spec - 36.7% | "This study demonstrates that a pre-hospital decision rule can be used as a simple and accurate means to identify patients without acute cardiac pathology and with a low risk of complications." | No data on 43 patients not included in final analyses. | Final diagnosis gathered from hospital medical records or GP.
Kennedy 1997 97187221 | Country: UK Center 1-Mean age: ND Enrolled: ND Evaluated: 200 % male ND Race: ND Center 2-Mean age: 64.5 Enrolled: 97 Evaluated: 91 58.2% male Race: ND | Center 1: Nontraumatic chest pain Center 2: Symptoms <4 hrs | Center 1: ND Center 2: ECG diagnostic for AMI | ANN using clinical indicators (hx & risk factors and physical & ECG findings) to derive binary inputs. | Center 1: AMI 33.8% (98/290) (200 validation data sets plus 90 data sets used in training of ANN) Center 2: AMI 23.1% (21/91) | Center 1: Final diagnosis by reviewers blinded to ANN results. Center 2: ND | ND | Two of following judged positive for AMI: Clinical hx ECG Biochemical markers including CK, CK-MB, & LDH assays | AMI: Center 1: Sens - "91.2%", Spec - "90.2%" Center 2: Sens - "52.4%", Spec - "80.0%" | "The data…confirm that artificial neural networks are capable of analyzing clinical data from patients with acute chest pain. The algorithm described performed well on data from a group of patients which were difficult to diagnose…" | Center 2: 6 patients omitted from analysis - followup clinical data unavailable for 2, & incomplete for 2, blood sampling incomplete for 2. | Sensitivity & specificity could not be verified for Center 1 or Center 2 with data reported.

ANN-artificial neural network; AST-aspartate aminotransferase; ER-emergency room; GP-general practitioner; hx-history; NA-not applicable; ND-no data; sens-sensitivity; spec-specificity; Δ-change.

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.

3 Interpretation of reference test results blinded to experimental test results and clinical information.

4 Interpretation of experimental test results blinded to reference test results and clinical information.

Evidence Table 19b. Clinical impact studies evaluating computer-based decision aids to manage acute cardiac ischemia in the emergency department

Study, year, identifier ^1^ | Location, population | Inclusion criteria ^2^ | Exclusion criteria | Prevalence of disease | Study design/comparisons | Diagnostic protocol | Diagnostic criteria for ACI | Outcomes | Study conclusions | Limitations/comments
Grijseels 1996 96289681 | Country: Netherlands Mean age: 65.6 Enrolled: 1,020 Evaluated: 977 53.1% male Race: ND | Hx CAD allowed | ND | ACI 47.8% AMI 29.9% (292/977) UA 17.9% (175/977) | Cohort - prospective NA | Decision rule based on data from questionnaire & computerized 12-lead ECG was used by GP to help determine admission status. | AMI: hx, ECG, & enzyme criteria. UA: angina hx with increasing frequency & severity or new onset angina with ST-T changes at rest, abnormal stress test, or abnormal coronary angiogram. | 427 of 750 (56.9%) recommended by decision rule for hospitalization had ACI. Of the 227 not recommended for hospitalization, GP admitted 128, of whom 32 had ACI (25%). Ultimately 8 pts with ACI were missed. There were 25 deaths total. GP decided not to admit 19 pts against the decision rule, 3 with AMI, because of social circumstances. | "Pre-hospital triage by the general practitioner was facilitated using a standardized questionnaire and pre-hospital electrocardiography, and resulted in a reduction in the number of patients admitted to the Coronary Care Unit, and proved to be safe." | ND

GP-general practitioner; hx-history; NA-not applicable; ND-no data; pt(s)-patient(s).

1 MEDLINE or unique identifying number assigned by EPC.

2 All presenting with chest pain or discomfort.