# References

Aase O, Jonsbu J, Liestol K, et al Decision support by computer analysis of selected case history variables in the emergency room among patients with acute chest pain Eur Heart J 1993 Apr 14(4):433 40 8472704
Apple FS, Voss E, Lund L, et al Cardiac troponin, CK-MB and myoglobin for the early detection of acute myocardial infarction and monitoring of reperfusion following thrombolytic therapy Clin Chim Acta 1995 Jun 15 237(1-2):59 66
Arntz HR, Stern R, Linderer T, et al Efficiency of a physician-operated mobile intensive care unit for prehospital thrombolysis in acute myocardial infarction Am J Cardiol 1992 Aug 15 70(4):417 20
Aufderheide TP, Haselow WC, Hendley GE, et al Feasibility of prehospital r-TPA therapy in chest pain patients Ann Emerg Med 1992c Apr 21(4):379 83 1554174
Aufderheide TP, Hendley GE, Thakur RK, et al The diagnostic impact of prehospital 12-lead electrocardiography Ann Emerg Med 1990 Nov 19(11):1280 7 2240725
Aufderheide TP, Hendley GE, Woo J, et al A prospective evaluation of prehospital 12-lead ECG application in chest pain patients J Electrocardiol 1992b 24Suppl:8 13 1552273
Aufderheide TP, Keelan MH, Hendley GE, et al Milwaukee Prehospital Chest Pain Project -- phase I: Feasibility and accuracy of prehospital thrombolytic candidate selection Am J Cardiol 1992a Apr 15 69(12):991 6
Aufderheide TP, Rowlandson I, Lawrence SW, et al Test of the acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) for prehospital use Ann Emerg Med 1996 Feb 27(2):193 8 8629751
Banerjee S, Rhoden WE Fast-tracking of myocardial infarction by paramedics J R Coll Physicians Lond 1998 Jan-Feb 32(1):36 8 9507439
Barbash GI, Roth A, Hod H, et al Improved survival but not left ventricular function with early and prehospital treatment with tissue plasminogen activator in acute myocardial infarction Am J Cardiol 1990 Aug 1 66(3):261 6
Baxt WG Use of an artificial neural network for the diagnosis of myocardial infarction Ann Intern Med 1991 Dec 1 115(11):843 8 1952470
Baxt WG, Skora J Prospective validation of artificial neural network trained to identify acute myocardial infarction Lancet 1996 Jan 6 347(8993):12 5
BEPS Collaborative Group Prehospital thrombolysis in acute myocardial infarction: The Belgian eminase prehospital study (BEPS) Eur Heart J 1991 Sep 12(9):965 7 1936009
Bertini G, Rostagno C, Taddei T, et al Evaluation of a mobile coronary care unit protocol in patients with acute onset chest pain J Emerg Med 1991 9Suppl 1:57 63 1955684
Bossaert LL, Demey HE, Colemont LJ, et al Prehospital thrombolytic treatment of acute myocardial infarction with anisoylated plasminogen streptokinase activator complex Crit Care Med 1988 Sep 16(9):823 30 3042284
Bouten MJ, Simoons ML, Hartman JA, et al Prehospital thrombolysis with alteplase (rt-PA) in acute myocardial infarction Eur Heart J 1992 Jul 13(7):925 31 1644083
Brogan GX Jr, Bock JL, McCuskey CF, et al Evaluation of cardiac STATus CK-MB/myoglobin device for rapidly ruling out acute myocardial infarction Clin Lab Med 1997 Dec 17(4):655 68 9439877
Brogan GX Jr, Friedman S, McCuskey C, et al Evaluation of a new rapid quantitative immunoassay for serum myoglobin versus CK-MB for ruling out acute myocardial infarction in the emergency department Ann Emerg Med 1994 Oct 24(4):665 71 8092593
Brogan GX Jr, Vuori J, Friedman S, et al Improved specificity of myoglobin plus carbonic anhydrase assay versus that of creatine kinase-MB for early diagnosis of acute myocardial infarction Ann Emerg Med 1996 Jan 27(1):22 8 8572443
Brouwer MA, Martin JS, Maynard C, et al Influence of early prehospital thrombolysis on mortality and event-free survival (the Myocardial Infarction Triage and Intervention [MITI] Randomized Trial). MITI Project Investigators Am J Cardiol 1996 Sep 1 78(5):497 502
Brown JL Jr An eight-month evaluation of prehospital 12-lead electrocardiogram monitoring in Baltimore County Md Med J 1997Suppl:64 6
Brush JE, Brand DA, Acampora D, et al Use of the initial electrocardiogram to predict in-hospital complications of acute myocardial infarction N Engl J Med 1985 May 2 312(18):1137 41
Canto JG, Rogers WJ, Bowlby LJ, et al The prehospital electrocardiogram in acute myocardial infarction: is its full potential being realized? National Registry of Myocardial Infarction 2 Investigators J Am Coll Cardiol 1997 Mar 1 29(3):498 505
Castaigne AD, Herve C, Duval-Moulin AM, et al Prehospital use of APSAC: results of a placebo-controlled study Am J Cardiol 1989 Jul 5 64(2):30A 33A; discussion:41A-2A
Castaldo AM, Ercolini P, Forino F, et al Plasma myoglobin in the early diagnosis of acute myocardial infarction Eur J Clin Chem Clin Biochem 1994 May 32(5):349 53 8086517
Clark HD, Wells GA, Huet C, et al. Assessing the quality of randomized trials: reliability of the Jadad Scale. Controlled Clin Trials. 1999;20:448-52. [pmid: 10503804].
Collins DR, Wright DJ, Rinsler MG, et al Early diagnosis of acute myocardial infarction with use of a rapid immunochemical assay of creatine kinase MB isoenzyme Clin Chem 1993 Aug 39(8):1725 8 8353963
Corey GA, Merenstein JH Applying the acute ischemic heart disease predictive instrument J Fam Pract 1987 Aug 25(2):127 33 3612036
Dalzell GW, Purvis J, Adgey AA The initial electrocardiogram in patients seen by a mobile coronary care unit Q J Med 1991 Mar 78(287):227 33 2047517
Davis CP, Barrett K, Torre P, et al Serial myoglobin levels for patients with possible myocardial infarction Acad Emerg Med 1996 Jun 3(6):590 7 8727630
Davison G, Suchman AL, Goldstein BJ Reducing unnecessary coronary care unit admissions: a comparison of three decision aids J Gen Intern Med 1990 Nov-Dec 5(6):474 9 2266427
D'Costa M, Fleming E, Patterson MC Cardiac troponin I for the diagnosis of acute myocardial infarction in the emergency department Am J Clin Pathol 1997 Nov 108(5):550 5 9353094
de Winter RJ, Koster RW, Sturk A, et al Value of myoglobin, troponin T, and CK-MBmass in ruling out an acute myocardial infarction in the emergency room Circulation 1995 Dec 15 92(12):3401 7
Dilger J, Pietsch-Breitfeld B, Stein W, et al Simple computer-assisted diagnosis of acute myocardial infarction in patients with acute thoracic pain Methods Inf Med 1992 Nov 31(4):263 7 1470037
DRG Guidebook. Reston, VA: David Schultz, Publisher; 1999.
Eisenberg JM, Horowitz LN, Busch R, et al Diagnosis of acute myocardial infarction in the emergency room: a prospective assessment of clinical decision making and the usefulness of immediate cardiac enzyme determination J Community Health 1979 Spring 4(3):190 8 457924
EMIP Group European Myocardial Infarction Project Group. Prehospital thrombolytic therapy in patients with suspected acute myocardial infarction N Engl J Med 1993 Aug 5 329(6):383 9
Fesmire FM, Percy RF, Bardoner JB, et al Serial creatinine kinase (CK) MB testing during the emergency department evaluation of chest pain: utility of a 2-hour delta CK-MB of +1. 6ng/ml Am Heart J 1998 Aug 136(2):237 44 9704684
Fine DG, Weiss AT, Sapoznikov D, et al Importance of early initiation of intravenous streptokinase therapy for acute myocardial infarction Am J Cardiol 1986 Sep 1 58(6):411 7
Fineberg HV, Scadden D, Goldman L Care of patients with a low probability of acute myocardial infarction. Cost effectiveness of alternatives to coronary-care-unit admission N Engl J Med 1984 May 17 310(20):1301 7
Foster DB, Dufendach JH, Barkdoll CM, et al Prehospital recognition of AMI using independent nurse/paramedic 12-lead ECG evaluation: impact on in-hospital times to thrombolysis in a rural community hospital Am J Emerg Med 1994 Jan 12(1):25 31 8285967
Garber AM, Solomon NA Cost-effectiveness of alternative test strategies for the diagnosis of coronary artery disease Ann Intern Med 1999 May 4 130(9):719 28
Gerhardt W, Waldenstrom J, Horder M, et al Creatine kinase and creatine kinase B-subunit activity in serum in cases of suspected myocardial infarction Clin Chem 1982 Feb 28(2):277 83 7055948
Gibler WB, Gibler CD, Weinshenker E, et al Myoglobin as an early indicator of acute myocardial infarction Ann Emerg Med 1987 Aug 16(8):851 6 3619163
Gibler WB, Kereiakes DJ, Dean EN, et al Prehospital diagnosis and treatment of acute myocardial infarction: a north-south perspective. The Cincinnati Heart Project and the Nashville Prehospital TPA Trial Am Heart J 1991 Jan 121(1 Pt 1):1 11 1898678
Gibler WB, Lewis LM, Erb RE, et al Early detection of acute myocardial infarction in patients presenting with chest pain and nondiagnostic ECGs: serial CK-MB sampling in the emergency department. [Published erratum appears in Ann Emerg Med 1991 Apr;20(4):420] Ann Emerg Med 1990 Dec 19(12):1359 66 2240745
Gibler WB, Runyon JP, Levy RC, et al A rapid diagnostic and treatment center for patients with chest pain in the emergency department Ann Emerg Med 1995 Jan 25(1):1 8 7802357
Gibler WB, Young GP, Hedges JR, et al Acute myocardial infarction in chest pain patients with nondiagnostic ECGs: serial CK-MB sampling in the emergency department. The Emergency Medicine Cardiac Research Group Ann Emerg Med 1992 May 21(5):504 12 1570904
Gilkeson G, Stone MJ, Waterman M, et al Detection of myoglobin by radioimmmunoassay in human sera: its usefulness and limitations as an emergency room screening test for acute myocardial infarction Am Heart J 1978 Jan 95(1):70 7 619592
Gillum RF, Fortman SP, Prineas RJ, et al. International diagnostic criteria for acute myocardial infarction and stroke. Am Heart J. 1984;108:150-8. [pmid: 6731265].
Giovas P, Papadoyannis D, Thomakos D, et al Transmission of electrocardiograms from a moving ambulance J Telemed Telecare 1998 4(Suppl 1):5 7 9640717
Goldman L, Cook EF, Brand DA, et al A computer protocol to predict myocardial infarction in emergency department patients with chest pain N Engl J Med 1988 Mar 31 318(13):797 803
Goldman L, Weinberg M, Weisberg M, et al A computer-derived protocol to aid in the diagnosis of emergency room patients with acute chest pain N Engl J Med 1982 Sep 2 307(10):588 96
Gomez MA, Anderson JL, Karagounis LA, et al An emergency department-based protocol for rapidly ruling out myocardial ischemia reduces hospital time and expense: results of a randomized study (ROMIO) J Am Coll Cardiol 1996 Jul 28(1):25 33 8752791
Gornall DA, Roth SN Serial myoglobin quantitation in the early assessment of myocardial damage: a clinical study Clin Biochem 1996 Aug 29(4):379 84 8828969
Gottlieb SO. The prognostic importance of asymptomatic ischemic episodes in patients with unstable angina pectoris. Herz. 1987;12:336-40. [pmid: 3679066].
Gottlieb SO, Weisfeldt ML, Ouyang P, et al. Silent ischemia predicts infarction and death during 2 year follow-up of unstable angina. J Am Coll Cardiol. 1987;10:756-60. [pmid: 3655143].
Feasibility, safety, and efficacy of domiciliary thrombolysis by general practitioners: Grampian Region Early Anistreplase Trial (GREAT) BMJ 1992 Sep 5 305(6853):548 53
Green GB, Beaudreau RW, Chan DW, et al Use of troponin T and creatine kinase-MB subunit levels for risk stratification of emergency department patients with possible myocardial ischemia Ann Emerg Med 1998 Jan 31(1):19 29 9437337
Grijseels EW, Deckers JW, Hoes AW, et al Implementation of a pre-hospital decision rule in general practice. Triage of patients with suspected myocardial infarction Eur Heart J 1996 Jan 17(1):89 95 8682136
Grim PS, Feldman T, Childers RW Evaluation of patients for the need of thrombolytic therapy in the prehospital setting Ann Emerg Med 1989 May 18(5):483 8 2719359
Grim P, Feldman T, Martin M, et al Cellular telephone transmission of 12-lead electrocardiograms from ambulance to hospital Am J Cardiol 1987 Sep 15 60(8):715 20
Gust R, Gust A, Bottiger BW, et al Bedside troponin T testing is not useful for early out-of-hospital diagnosis of myocardial infarction Acta Anaesthesiol Scand 1998 Apr 42(4):414 7 9563859
Hamm CW, Goldmann BU, Heeschen C, et al Emergency room triage of patients with acute chest pain by means of rapid testing for cardiac troponin T or troponin I N Engl J Med 1997 Dec 4 337(23):1648 53
Hamm CW, Ravkilde J, Gerhardt W, et al The prognostic value of serum tropinin T in unstable angina N Engl J Med 1992 Jul 16 327(3):146 50
Hedges JR, Gibler WB, Young GP, et al Multicenter study of creatine kinase-MB use: effect on chest pain clinical decision making Acad Emerg Med 1996 Jan 3(1):7 15 8749961
Hedges JR, Rouan GW, Toltzis R, et al Use of cardiac enzymes identifies patients with acute myocardial infarction otherwise unrecognized in the emergency department Ann Emerg Med 1987 Mar 16(3):248 52 3813158
Hedges JR, Young GP, Henkel GF, et al Early CK-MB elevations predict ischemic events in stable chest pain patients Acad Emerg Med 1994 Jan-Feb 1(1):9 16 7621159
Hedges JR, Young GP, Henkel GF, et al Serial ECGs are less accurate than serial CK-MB results for emergency department diagnosis of myocardial infarction Ann Emerg Med 1992 Dec 21(12):1445 50 1443839
Hetland O, Dickstein K Cardiac markers in the early hours of acute myocardial infarction: clinical performance of creatine kinase, creatine kinase MB isoenzyme (activity and mass concentration), creatine kinase MM and MB subform ratios, myoglobin and cardiac troponin T Scand J Clin Lab Invest 1996 Dec 56(8):701 13 9034351
Hilton TC, Fulmer H, Abuan T, et al Ninety-day follow-up of patients in the emergency department with chest pain who undergo initial single-photon emission computed tomographic perfusion scintigraphy with technetium 99m-labeled sestamibi J Nucl Cardiol 1996 Jul-Aug 3(4):308 11 8799249
Hilton TC, Thompson RC, Williams HJ, et al Technetium-99m sestamibi myocardial perfusion imaging in the emergency room evaluation of chest pain J Am Coll Cardiol 1994 Apr 23(5):1016 22 8144763
Hingorani AD, O'Hanlon S, Halloran SP, et al Evaluation of a paired creatine kinase test for the diagnosis of acute myocardial infarction in patients with a non-diagnostic electrocardiogram Accid Emerg Med 1997 May 14(3):134 8
Hoekstra JW, Hedges JR, Gibler WB, et al Emergency department CK-MB: A predictor of ischemic complications. National cooperative CK-MB project group Acad Emerg Med 1994 Jan-Feb 1(1):17 27 7621148
Hollander JE, Muttreja MR, Dalesandro MR, et al Risk stratification of emergency department patients with acute coronary syndromes using P-selectin J Am Coll Cardiol 1999 Jul 34(1):95 105 10399997
Holvoet P, Collen D, Van de Werf F Malondialdehyde-modified LDL as a marker of acute coronary syndromes JAMA 1999 May 12 281(18):1718 21
Horowitz RS, Morganroth J, Parrotto C, et al Immediate diagnosis of acute myocardial infarction by two-dimensional echocardiography Circulation 1982 Feb 65(2):323 9 7053890
Ioannidis JP, Lau J Can quality of clinical trials and meta-analyses be quantified? Lancet 1998 Aug 22 352(9128):590 1
Irwig L, MacAskill P, Glasziou, et al. Meta-analytic methods for diagnostic test accuracy. J Clin Epidemiol. 1995;48:119-30. [pmid: 7853038].
Irwig L, Tosteson ANA, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnosis tests. Ann Intern Med. 1994;120:667-76. [pmid: 8135452].
Jonsbu J, Aase O, Rollag A, et al Prospective evaluation of an EDB-based diagnostic program to be used in patients admitted to hospital with acute chest pain Eur Heart J 1993 Apr 14(4):441 6 8472705
Juni R, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282:1054-60. [pmid: 10493204].
Justis DL, Hession WT Accuracy of 22-lead ECG analysis for diagnosis of acute myocardial infarction and coronary artery disease in the emergency department: a comparison with 12-lead ECG Ann Emerg Med 1992 Jan 21(1):1 9 1539875
Karagounis L, Ipsen SK, Jessop MR, et al Impact of field-transmitted electrocardiography on time to in-hospital thrombolytic therapy in acute myocardial infarction Am J Cardiol 1990 Oct 1 66(10):786 91
Katz IA, Irwig L, Vinen JD, et al Biochemical markers of acute myocardial infarction: strategies for improving their clinical usefulness Ann Clin Biochem 1998 May 35(Pt 3):393 9 9635105
Kennedy RL, Harrison RF, Burton AM, et al An artificial neural network system for diagnosis of acute myocardial infarction (AMI) in the accident and emergency department: evaluation and comparison with serum myoglobin measurements Comput Methods Programs Biomed 1997 Feb 52(2):93 103 9034674
Kereiakes DJ, Gibler WB, Martin LH, et al Relative importance of emergency medical system transport and the prehospital electrocardiogram on reducing hospital time delay to therapy for acute myocardial infarction: a preliminary report from the Cincinnati Heart Project Am Heart J 1992 Apr 123(4 Pt 1):835 40 1549989
Kereiakes DJ, Weaver WD, Anderson JL, et al Time delays in the diagnosis and treatment of acute myocardial infarction: a tale of eight cities. Report from the Pre-hospital Study Group and the Cincinnati Heart Project Am Heart J 1990 Oct 120(4):773 80 2220531
Kerns JR, Shaub TF, Fontanarosa PB Emergency cardiac stress testing in the evaluation of emergency department patients with atypical chest pain Ann Emerg Med 1993 May 22(5):794 8 8470835
Kirk JD, Turnipseed S, Lewis WR, et al Evaluation of chest pain in low-risk patients presenting to the emergency department: the role of immediate exercise testing Ann Emerg Med 1998 Jul 32(1):1 7 9656941
Kontos MC, Anderson FP, Hanbury CM, et al Use of the combination of myoglobin and CK-MB mass for the rapid diagnosis of acute myocardial infarction Am J Emerg Med 1997a Jan 15(1):14 9 9002562
Kontos MC, Anderson FP, Schmidt KA, et al Early diagnosis of acute myocardial infarction in patients without ST-segment elevation Am J Cardiol 1999a Jan 15 83(2):155 8
Kontos MC, Arrowood JA, Jesse RL, et al Comparison between 2-dimensional echocardiography and myocardial perfusion imaging in the emergency department in patients with possible myocardial ischemia Am Heart J 1998 Oct 136(4 Pt 1):724 33 9778078
Kontos MC, Jesse RL, Anderson FP, et al Comparison of myocardial perfusion imaging and cardiac troponin I in patients admitted to the emergency department with chest pain Circulation 1999b Apr 27 99(16):2073 8
Kontos MC, Jesse RL, Schmidt KL, et al Value of acute rest sestamibi perfusion imaging for evaluation of patients admitted to the emergency department with chest pain Journal of the American College of Cardiology 1997b Oct 30(4):976 82 9316527
Koren G, Weiss AT, Hasin Y, et al Prevention of myocardial damage in acute myocardial ischemia by early treatment with intravenous streptokinase N Engl J Med 1985 Nov 28 313(22):1384 9
Krauss KR, Hutter AM Jr, DeSanctis RW Acute coronary insufficiency. Course and follow-up Arch Intern Med 1972 May 129(5):808 13 5025901
Kudenchuk PJ, Ho MT, Weaver WD, et al Accuracy of computer-interpreted electrocardiography in selecting patients for thrombolytic therapy. MITI Project Investigators J Am Coll Cardiol 1991 Jun 17(7):1486 91 2033180
Kudenchuk PJ, Maynard C, Cobb LA, et al Utility of the prehospital electrocardiogram in diagnosing acute coronary syndromes: the Myocardial Infarction Triage and Intervention (MITI) Project J Am Coll Cardiol 1998 Jul 32(1):17 27 9669244
Laird NM, Mosteller F. Some statistical methods for combining experimental results. Int J Tech Assess Health Care. 1990;6:5-30.
Laurino JP, Bender EW, Kessimian N, et al Comparative sensitivities and specificities of the mass measurements of CK-MB2, CK-MB, and myoglobin for diagnosing acute myocardial infarction Clin Chem 1996 Sep 42(9):1454 9 8787704
Laurino JP, Pelletier TE, Eadry R, et al Thrombus Precursor Protein and the measurement of thrombosis in patients with acute chest pain syndrome Ann Clin Lab Sci 1997 Sep-Oct 27(5):338 45 9303172
Lee TH, Juarez G, Cook EF, et al Ruling out acute myocardial infarction. A prospective multicenter validation of a 12-hour strategy for patients at low risk N Engl J Med 1991 May 2 324(18):1239 46
Lee TH, Pearson SD, Johnson PA, et al Failure of information as an intervention to modify clinical management. A time-series trial in patients with acute chest pain Ann Intern Med 1995 Mar 15 122(6):434 7
Lee TH, Weisberg MC, Cook EF, et al Evaluation of creatine kinase and creatine kinase-MB for diagnosing myocardial infarction. Clinical impact in the emergency room Arch Intern Med 1987 Jan 147(1):115 21 3800513
Levitt MA, Promes SB, Bullock S, et al Combined cardiac marker approach with adjunct two-dimensional echocardiography to diagnose acute myocardial infarction in the emergency department Ann Emerg Med 1996 Jan 27(1):1 7 8572434
Lewis WR, Amsterdam EA, Turnipseed S, et al Immediate exercise testing of low risk patients with known coronary artery disease presenting to the emergency department with chest pain J Am Coll Cardiol 1999 Jun 33(7):1843 7 10362183
Lijmer JG, Mol B, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-6. [pmid: 10493205].
Linderer T, Schroder R, Arntz R, et al Prehospital thrombolysis: beneficial effects of very early treatment on infarct size and left ventricular function J Am Coll Cardiol 1993 Nov 1 22(5):1304 10
Lohr KN, Carey TS. Assessing "Best Evidence": Issues in grading the quality of studies for systematic reviews. Joint Commission J Qual Improvement. 1999;25:470-9.
Mach F, Lovis C, Chevrolet JC, et al Rapid bedside whole blood cardiospecific troponin T immunoassay for the diagnosis of acute myocardial infarction Am J Cardiol 1995 Apr 15 75(12):842 5
Mair J, Artner-Dworzak E, Dienstl A, et al Early detection of acute myocardial infarction by measurement of mass concentration of creatine kinase-MB Am J Cardiol 1991b Dec 15 68(17):1545 50
Mair J, Artner-Dworzak E, Lechleitner P, et al Cardiac troponin T in diagnosis of acute myocardial infarction Clin Chem 1991a Jun 37(6):845 52 2049849
Mair J, Artner-Dworzak E, Lechleitner P, et al Early diagnosis of acute myocardial infarction by a newly developed rapid immunoturbidimetric assay for myoglobin Br Heart J 1992 Nov 68(5):462 8 1467029 1025188
Mair J, Genser N, Morandell D, et al Cardiac troponin I in the diagnosis of myocardial injury and infarction Clin Chim Acta 1996 Feb 9 245(1):19 38
Mair J, Wohlfarter T, Koller A, et al Serum cardiac troponin T after extraordinary endurance exercise Lancet 1992 Oct 24 340(8826):
Marin MM, Teichman SL Use of rapid serial sampling of creatine kinase MB for very early detection of myocardial infarction in patients with acute chest pain Am Heart J 1992 Feb 123(2):354 61 1736570
Maynard C, Beshansky JR, Griffith JL, et al Influence of sex on the use of cardiac procedures in patients presenting to the emergency department. A prospective multicenter study Circulation 1996 Nov 1 94(9 Suppl):II93 II98
McAleer B, Ruane B, Burke E, et al Prehospital thrombolysis in a rural community: short and long-term survival Cardiovasc Drugs Ther 1992 Aug 6(4):369 72 1520646
McNeill AJ, Cunningham SR, Flannery DJ, et al A double blind placebo controlled study of early and late administration of recombinant tissue plasminogen activator in acute myocardial infarction Br Heart J 1989 Apr 61(4):316 21 2496740 1216669
Mikhail MG, Smith FA, Gray M, et al Cost-effectiveness of mandatory stress testing in chest pain center patients Ann Emerg Med 1997 Jan 29(1):88 98 8998087
Millar-Craig MW, Joy AV, Adamowicz M, et al Reduction in treatment delay by paramedic ECG diagnosis of myocardial infarction with direct CCU admission Heart 1997 Nov 78(5):456 61 9415003 1892296
Mohler ER 3d, Ryan T, Segar DS, et al Comparison of digital with videotape echocardiography in patients with chest pain in the emergency department J Am Soc Echocardiogr 1996 Jul-Aug 9(4):501 6 8827633
Mohler ER 3d, Ryan T, Segar DS, et al. Clinical utility of troponin T levels and echocardiography in the emergency department. Am Heart J. 1998 Feb;135 (2 Pt 1):253-60.
Montague C, Kircher T Myoglobin in the early evaluation of acute chest pain Am J Clin Pathol 1995 Oct 104(4):472 6 7572801
Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12:1293-316. [pmid: 8210827].
Mulcahy R, Conroy R, Katz R, et al. Does intensive medical therapy influence the outcome in unstable angina?. Clin Cardiol. 1990;13:687-9. [pmid: 1979527].
Mulrow CD, Linn WD, Gual MK, et al. Assessing quality of a diagnostic test evaluation. J Gen Intern Med. 1989;4:288-95. [pmid: 2760697].
National Cooperative Study Group Unstable angina pectoris: National Cooperative Study Group to Compare Medical and Surgical Therapy. IV. Results in patients with left descending coronary artery disease Am J Cardiol 1981 Sep 48(3):517 24 6973924
Ohman EM, Casey C, Bengtson JR, et al Early detection of acute myocardial infarction: additional diagnostic information from serum concentrations of myoglobin in patients without ST elevation Br Heart J 1990 Jun 63(6):335 8 2375893 1024516
Otto LA, Aufderheide TP Evaluation of ST segment elevation criteria for the prehospital electrocardiographic diagnosis of acute myocardial infarction Ann Emerg Med 1994 Jan 23(1):17 24 8273952
Patterson RE, Eng C, Horowitz SF, et al Bayesian comparison of cost-effectiveness of different clinical approaches to diagnose coronary artery disease J Am Coll Cardiol 1984 Aug 4(2):278 89 6429224
Peels CH, Visser CA, Kupper AJ, et al Usefulness of two-dimensional echocardiography for immediate detection of myocardial ischemia in the emergency room Am J Cardiol 1990 Mar 15 65(11):687 91
16th ed. West Allis, WI: Yale Wasserman Medical Publishers; 1999.
Pope JH, Aufderheide TP, Ruthazer R, et al Missed diagnoses of acute cardiac ischemia in the emergency department N Engl J Med 2000 April 20 342(16):1163 70
Pope JH, Ruthazer R, Beshansky JR, et al. Clinical features of emergency department patients presenting with symptoms suggestive of acute cardiac ischemia: a multicenter study. J Thromb Thrombolysis. 1998;6:63-74. [pmid: 10751787].
Poretsky L, Leibowitz IH, Friedman SA The diagnosis of myocardial infarction by computer-derived protocol in a municipal hospital Angiology 1985 Mar 36(3):165 70 3896039
Pozen MW, D'Agostino RB, Mitchell JB, et al. The usefulness of a predictive instrument to reduce inappropriate admissions to the coronary care unit. Ann Intern Med. 1980 Feb;92 (2 Pt 1):238-42.
Pozen MW, D'Agostino RB, Selker HP, et al A predictive instrument to improve coronary-care-unit admission practices in acute ischemic heart disease. A prospective multicenter clinical trial New Engl J Med 1984 May 17 310(20):1273 8
Puleo PR, Meyer D, Wathen C, et al Use of a rapid assay of subforms of creatine kinase-MB to diagnose or rule out acute myocardial infarction N Engl J Med 1994 Sep 1 331(9):561 6
Rawles JM Halving of mortality at 1 year by domiciliary thrombolysis in the Grampian Region Early Anistreplase Trial (GREAT) J Am Coll Cardiol 1994 Jan 23(1):1 5 8277066
Rawles JM Quantification of the benefit of earlier thrombolytic therapy: Five-year results of the Grampian Region Early Anistreplase Trial (GREAT) J Am Coll Cardiol 1997 Nov 1 30(5):1181 6 9350912
Roberts KB, Califf RM, Harrell FE Jr, et al. The prognosis for patients with new-onset angina who have undergone cardiac catheterization. Circulation. 1983;68:970-8. [pmid: 6616798].
Roth A, Barbash GI, Hod H, et al Should thrombolytic therapy be administered in the mobile intensive care unit in patients with evolving myocardial infarction? A pilot study J Am Coll Cardiol 1990 Apr 15(5):932 6 2107239
Roxin LE, Cullhed I, Groth T, et al The value of serum myoglobin determinations in the early diagnosis of acute myocardial infarction Acta Med Scand 1984 215(5):417 25 6741606
Rozenman Y, Gotsman M, Weiss T, et al Very early thrombolysis in acute myocardial infarction -- a light at the end of the tunnel Isr J Med Sci 1994 Jan 30(1):99 107 8138401
Rozenman Y, Gotsman MS, Weiss AT, et al Early intravenous thrombolysis in acute myocardial infarction: the Jerusalem experience Int J Cardiol 1995 Aug 49(Suppl):S21 S28 7591313
Sabia P, Afrookteh A, Touchstone DA, et al Value of regional wall motion abnormality in the emergency room diagnosis of acute myocardial infarction. A prospective study using two-dimensional echocardiography Circulation 1991 Sep 84(3 Suppl):I85 I92
Sarasin FP, Reymond JM, Griffith JL, et al Impact of the acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) on the speed of triage decision making for emergency department patients presenting with chest pain: a controlled clinical trial J Gen Intern Med 1994 Apr 9(4):187 94 8014723
Sasaki H, Charuzi Y, Beeder C, et al Utility of echocardiography for the early assessment of patients with nondiagnostic chest pain Am Heart J 1986 Sep 112(3):494 7 3751862
Sayre MR, Kaufmann KH, Chen IW, et al Measurement of cardiac troponin T is an effective method for predicting complications among emergency department patients with chest pain Ann Emerg Med 1998 May 31(5):539 49 9581136
Schofer J, Buttner J, Geng G, et al Prehospital thrombolysis in acute myocardial infarction Am J Cardiol 1990 Dec 15 66(20):1429 33
Selker HP, Beshansky JR, Griffith JL, et al Use of the acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) to assist with triage of patients with chest pain or other symptoms suggestive of acute cardiac ischemia. A multicenter controlled clinical trial Ann Intern Med 1998 Dec 1 129(11):845 55
Selker HP, Griffith JL, D'Agostino RB A tool for judging coronary care unit admission appropriateness, valid for both real-time and retrospective use. A time-insensitive predictive instrument (TIPI) for acute cardiac ischemia: a multicenter study [published erratum appears in Med Care 1992 Feb;30(2):188] Med Care 1991 Jul 29(7):610 27 2072767
Selker HP, Zalenski RJ, Antman EM, et al An evaluation of technologies for identifying acute cardiac ischemia in the emergency department: a report from a National Heart Attack Alert Program Working Group Ann Emerg Med 1997 Jan 29(1):13 87 8998086
Spadafore JC, Lieber JG, Vasilenko P Variance cardiography for emergency department evaluation of chest pain patients Acad Emerg Med 1996 Apr 3(4):326 32 8881541
Stewart RE, Dickinson CZ, Weissman IA, et al Clinical outcome of patients evaluated with emergency centre myocardial perfusion SPET for unexplained chest pain Nucl Med Commun 1996 Jun 17(6):459 62 8822742
Stuart RJ Jr, Ellestad MH National survey of exercise stress testing facilities Chest 1980 Jan 77(1):94 7 7351157
Tatum JL, Jesse RL, Kontos MC, et al Comprehensive strategy for the evaluation and triage of the chest pain patient Ann Emerg Med 1997 Jan 29(1):116 25 8998090
Thomson SP, Gibbons RJ, Smars PA, et al Incremental value of the leukocyte differential and the rapid creatine kinase-MB isoenzyme for the early diagnosis of myocardial infarction Ann Intern Med 1995 Mar 1 122(5):335 41
Tierney WM, Roth BJ, Psaty B, et al Predictors of myocardial infarction in emergency room patients Crit Care Med 1985 Jul 13(7):526 31 4006491
Trippi JA, Kopp G, Lee KS, et al The feasibility of dobutamine stress echocardiography in the emergency department with telemedicine interpretation J Am Soc Echocardiogr 1996 Mar-Apr 9(2):113 6 8849606
Trippi JA, Lee KS, Kopp G, et al Dobutamine stress tele-echocardiography for evaluation of emergency department patients with chest pain J Am Coll Cardiol 1997 Sep 30(3):627 32 9283518
Tsakonis JS, Shesser R, Rosenthal R, et al Safety of immediate treadmill testing in selected emergency department patients with chest pain: a preliminary report Am J Emerg Med 1991 Nov 9(6):557 9 1930398
Tucker JF, Collins RA, Anderson AJ, et al Early diagnostic efficiency of cardiac troponin I and troponin T for acute myocardial infarction Acad Emerg Med 1997 Jan 4(1):13 21 9110006
Tucker JF, Collins RA, Anderson AJ, et al Value of serial myoglobin levels in the early diagnosis of patients admitted for acute myocardial infarction Ann Emerg Med 1994 Oct 24(4):704 8 8092598
Varetto T, Cantalupi D, Altieri A, et al Emergency room technetium-99m sestamibi imaging to rule out acute myocardial ischemic events in patients with nondiagnostic electrocardiograms J Am Coll Cardiol 1993 Dec 22(7):1804 8 8245332
Viskin S, Heller K, Gheva D, et al The importance of creatine kinase determination in identifying acute myocardial infarction among patients complaining of chest pain in an emergency room Cardiology 1987 74(2):100 10 3568048
Weaver WD, Cerqueira M, Hallstrom AP, et al Prehospital-initiated vs hospital-initiated thrombolytic therapy. The Myocardial Infarction Triage and Intervention Trial JAMA 1993 Sep 8 270(10):1211 6
Weaver WD, Eisenberg MS, Martin JS, et al Myocardial Infarction Triage and Intervention Project -- phase I: patient characteristics and feasibility of prehospital initiation of thrombolytic therapy J Am Coll Cardiol 1990 Apr 15(5):925 31 2312978
Weiss AT, Fine DG, Applebaum D, et al Prehospital coronary thrombolysis. A new strategy in acute myocardial infarction Chest 1987 Jul 92(1):124 8 3595223
Weiss AT, Leitersdorf I, Gotsman MS, et al Prevention of congestive heart failure by early, prehospital thrombolysis in acute myocardial infarction: a long-term follow-up study Int J Cardiol 1998 May 29 65(Suppl 1):S43 S48
Weissman IA, Dickinson CZ, Dworkin HJ, et al Cost-effectiveness of myocardial perfusion imaging with SPECT in the emergency department evaluation of patients with unexplained chest pain Radiology 1996 May 199(2):353 7 8668777
Wuerz RC, Meador SA Evaluation of a prehospital chest pain protocol Ann Emerg Med 1995 Nov 26(5):595 7 7486368
Young GP, Gibler WB, Hedges JR, et al Serial creatine kinase-MB results are a sensitive indicator of acute myocardial infarction in chest pain patients with nondiagnostic electrocardiograms: the second Emergency Medicine Cardiac Research Group Study Acad Emerg Med 1997 Sep 4(9):869 77 9305428
Young GP, Green TR The role of single ECG, creatinine kinase, and CKMB in diagnosing patients with acute chest pain Am J Emerg Med 1993 Sep 11(5):444 9 8363679
Zalenski RJ, Cooke D, Rydman R, et al Assessing the diagnostic value of an ECG containing leads V4R, V8, and V9: the 15-lead ECG Ann Emerg Med 1993 May 22(5):786 93 8470834
Zalenski RJ, McCarren M, Roberts R, et al An evaluation of a chest pain diagnostic protocol to exclude acute cardiac ischemia in the emergency department Arch Intern Med 1997a May 26 157(10):1085 91
Zalenski RJ, Roberts R, Das K, et al Admission avoidance for chest pain patients Acad Emerg Med 1994 1(2):
Zalenski RJ, Rydman RJ, Sloan EP, et al Value of posterior and right ventricular leads in comparison to the standard 12-lead electrocardiogram in evaluation of ST-segment elevation in suspected acute myocardial infarction Am J Cardiol 1997b Jun 15 79(12):1579 85