# Future Research

Many of the recommendations made here were also made in the 1997 Working Group report. Despite some progress in refining these technologies, the overall research effort in this area needs to be stimulated by proposing a research agenda to address these issues and by making research support available to complete the agenda.

Identifying patients with ACI in the ED is a complex problem. There is a diversity of patient populations, settings, availability of technologies, and timing of patients' presentation to the ED. Also, ACI is a clinical syndrome for which no one test may be the "best." All of these factors affect the selection of diagnostic technologies in these patients. Based on the review of the literature, we need additional research in the areas discussed in the sections that follow.

## Diagnostic Performance Studies

Although more than 45 relevant studies have been published since 1994 on this topic, many of the diagnostic technologies for ACI remain underevaluated. The number of studies that have evaluated the diagnostic performance of echocardiography, sestamibi myocardial perfusion imaging, and exercise stress ECG remains small and more studies are needed. Although there are many studies of single presentation measurement of biomarkers (CK, CK-MB, myoglobin, or troponin T), the number of studies of serial measurements remains small. The few studies of serial (2 to 4 hours) myoglobin show promise of having high sensitivity and specificity for AMI; this finding should be verified. Studies of newer biomarkers such as P-selectin and fatty acid binding proteins are needed.

## Combinations of Diagnostic Technologies

To date, most studies have evaluated a single technology. For example, single measurements of a biomarker at presentation to the ED, in general, have good specificity but limited sensitivity to detect AMI. Several of the current biomarkers (e.g., CK-MB, myoglobin, troponin I, or troponin T), when measured repeatedly over the course of several hours, can achieve excellent sensitivity for AMI while maintaining high specificity. But the several hours it takes to reach the correct diagnosis would delay the administering of reperfusion therapy for some of the patients and thus lessen the potential clinical benefit of this treatment. Even with improved accuracy for AMI when serial measurements are taken, currently available biomarkers do not identify most of the patients with UAP.

Given the morbidity and mortality associated with ACI, a diagnostic test or test combination with very high sensitivity and specificity is required. Also, since UAP may be a continuum of conditions, test combinations that optimize the strengths of the constituent tests may prove valuable. Research is needed to determine whether combinations of multiple tests, such as a panel of biomarkers, or of multiple modalities, such as ECG with serial CK-MB measurements, perform better than the component tests alone.

## Clinical Impact Studies

The 1997 Working Group report also noted the lack of health services research on the clinical impact of these technologies. Attention has clearly been focused on diagnostic accuracy, especially for AMI. It is clearly important to have technologies with high sensitivity and specificity values to diagnose ACI in order to minimize missed ACI and avoid unnecessary hospitalization. Good test performance, however, does not automatically translate to appropriate utilization of the technology or desired clinical outcome. Therefore, in addition to high sensitivity and specificity, a diagnostic technology must also demonstrate desired clinical impact during routine use in the ED setting. Clinical impact studies need to assess the clinical implications of the actual use of the technologies and the economic implications of both correct and incorrect diagnoses. The high cost of some of these diagnostic technologies, especially when applied to selected low risk subpopulations, mandates that cost-effectiveness analyses should be part of the clinical impact studies.

ACI-TIPI was demonstrated in a large multicenter clinical trial to have high accuracy of identifying patients with ACI and reduce unnecessary hospitalizations. This finding needs to be repeated at other ED settings and by other investigators.

## Multiple but Standardized Research Variables

The heterogeneity of inclusion and exclusion criteria, tests, outcome measures, and circumstances of testing found in the literature makes synthesizing the research results difficult. Reducing this heterogeneity by implementing a set of standard research variables would greatly assist in comparing studies. Such standard variables should accurately reflect the most common circumstances in which these technologies are used in the ED.

The characteristics of patients enrolled in studies need to be clearly defined. This is critical to ensure internal validity and to allow for study comparisons and data analyses and in attempting to apply the results to clinical practice. In our research, we found there was little correlation between the prevalence of ACI/AMI and the definitions of the study population. Studies with similarly defined populations often reported a wide range of ACI or AMI prevalence, and differently defined populations often have similar overlapping ranges of prevalence of ACI/AMI. Since the prevalence of the ACI/AMI outcomes is the most objective measure of the study's population similarity, the lack of correlation between the criteria and the prevalence raises the question of whether the inclusion criteria used in current studies are sufficiently refined to assist the interpretation of the results.

Standardization of research variables would also aid in identifying the best strategies for detection of patients with AMI and UAP. Because of the numerous possible combinations of technologies, it may not be possible to conduct all the clinical trials to assess the clinical impact of combination strategies. By standardizing protocols (of how diagnostic technologies are used), registries of patient data can be developed to provide complementary evidence of how best to diagnose patients with either AMI or UAP.

## Higher Quality Studies and Better Reporting

The methodological quality of diagnostic test evaluation studies in general is lower than that of the randomized controlled trials used to assess efficacy of therapeutic interventions. This is also the case among the studies we examined. The AMI outcome is more often clearly defined than UAP. Some authors reported procedural diagnoses, such as angioplasty, or diagnoses based on invasive or noninvasive procedures, such as significant coronary artery disease, based on angiography or imaging rather than a symptom-defined diagnosis of UAP (using Braunwald's criteria, for example). Even though the procedural diagnoses could be reported, it would be desirable if studies would report UAP as clinically defined (or agreed on) to ensure consistency across studies.

Our literature review was complicated by several instances of multiple publications of overlapping data and sometimes of the same data. To avoid the bias resulting from overcounting, we had to eliminate some studies from our analyses. Several studies by the same group of authors published in adjacent years appeared to be based on the same data, but we were informed they were indeed independent studies when the investigators were contacted. To avoid under- or overusing published data, authors need to alert readers when there is overlapping of patient data in their reports.

Another major problem that we frequently encountered is the lack of clarity and accuracy of the reporting of data. Diagnostic studies are not consistently reported in a uniform manner, thus making it difficult to identify and verify relevant pieces of data needed for evidence synthesis. In addition, some studies reported data that contradicted their summary results, and some studies reported different values for the same outcomes in different locations in the report. There is much room for improvement in the conduct and reporting of diagnostic test evaluation studies. A document similar to the CONSORT statement that was published to improve the reporting of randomized controlled trials would be very useful to improve the reporting of diagnostic test evaluation studies.