# Appendix C: Acronyms

ACI: acute cardiac ischemia

ACI-TIPI: Acute Cardiac Ischemia Time-Insensitive Predictive Instrument

AHCPR: Agency for Health Care Policy and Research

AHRQ: Agency for Healthcare Research and Quality

AMI: acute myocardial infarction

AST: aspartate aminotransferase

CABG: coronary artery bypass graft

CAD: cardiac arterial disease

CCU: cardiac care unit

CE: cost-effectiveness

CI: confidence interval

CK: creatine kinase

CPOU: chest pain observation unit

CPU: chest pain unit

DRG: diagnosis-related group

ECG: electrocardiograph(y)

ED: emergency department

EMIP: European Myocardial Infarction Project

EMS: emergency medical service

EPC: Evidence-based Center

GREAT: Grampian Region Early Anistreplase Trial

IV: intravenous

LDH: lactate dehydrogenase

LDL: lipoprotein

MDA: malondialdehyde

MI: myocardial infarction

MITI: Myocardial Infarction Triage and Intervention

NHAAP: National Heart Attack Alert Program

NHLBI: National Heart, Lung, and Blood Institute

NIH: National Institutes of Health

NRSA: National Research Service Award

PFR: Physicians=Fee Reference

ROC: receiver operating characteristics

SD: standard deviation

SROC: summary receiver operating characteristics

Tc: technetium

UA: unstable angina

UAP: unstable angina pectoris

WHO: World Health Organization