# Appendix B: Acknowledgments

## New England Medical Center EPC Project Staff

- EPC/Project Director
- Joseph Lau, MD

- Assistant Project Director
- John Ioannidis, MD

- Primary Technical Expert
- Deeb Salem, MD

- Decision Analysis Consultant
- John B. Wong, MD

- NRSA Research Fellows
- Ethan Balk, MD, MPH; Catherine Milch, MD

- Project Manager
- Deirdre DeVine, M Litt

- Statistician
- Norma Terrin, PhD

- Research Associate
- Priscilla Chew, MPH

- Technical Writer
- Thomas A. Lang, MA

- Library Assistant
- David Liu, BA

## NHAAP Technology Working Group Technical Experts

- Harry Selker, MD, MSPH
- Co-chair, NHAAP TWG
- Division of Clinical Care Research
- New England Medical Center
- Boston, Massachusetts

- Robert Zalenski, MD
- Co-chair, NHAAP TWG
- Emergency Medicine and Internal Medicine
- Wayne State University
- Detroit, Michigan

- Tom Aufderheide, MD
- Department of Emergency Medicine
- Medical College of Wisconsin
- Milwaukee, Wisconsin

- Michael Hagen, MD, FAAFP
- Department of Family Practice
- University of Kentucky
- Lexington, Kentucky

- Robert McNutt, MD
- Department of Medicine
- Cook County Hospital
- Chicago, Illinois

- Joseph Ornato, MD
- Department of Emergency Medicine
- Medical College of Virginia
- Virginia Commonwealth University
- Richmond, Virginia

## Peer Reviewers

The partner organization, NHAAP, for the evidence report nominated individuals to participate in the peer review of the evidence report. Additional individuals with appropriate methodologic and clinical expertise were identified by the EPC. Review of the evidence report by these individuals does not represent endorsement of the report. We are grateful to the peer reviewers for generously offering their time and knowledge.

### NHAAP Coordinating Committee-Science Base Subcommittee

- Costas T. Lambrew, MD
- Division of Cardiology
- Maine Medical Center
- Portland, Maine

### NHAAP Coordinating Committee

- James M. Atkins, MD, FACC
- Emergency Medicine Education
- University of Texas Southwestern Medical Center
- Dallas, Texas
- Representing: American College of Cardiology

- Gottlieb Friesinger, MD
- Division of Cardiology
- Vanderbilt University Medical Center
- Nashville, Tennessee
- Representing: American College of Physicians

- Lee Green, MD, MPH
- Department of Family Practice
- University of Michigan
- Ann Arbor, Michigan
- Representing: American Academy of Family Physicians

### External Reviewers

- Harold Sox, MD
- Department of Medicine
- Dartmouth Hitchcock Medical Center
- Lebanon, New Hampshire