# Appendix A: Data Abstraction Forms

## Diagnostic Tests for ACI in the Emergency Department Initial Article Screen Form

Instructions: Circle or fill-in where appropriate. Only one answer except: * - multiple answers possible, [image] - answer only if required

Date of Screen: _________________

Author: _____________________________________________________________ UI: _________________

Journal: _____________________________________________________________ Volume _____Year _______

Data Extractor:PC JPI JL _____

1. | Acute Cardiac Ischemia (meets inclusion criteria)? | | | Yes | No | Unclear | (Stop if No)
2. | Excluded (by exclusion criteria)? | | eXcluded | nOt Excluded | (Stop if Excluded)
4. | Article Type: | Patient Outcome Study | reView | Other_______________
*3. | Study Question:
| Diagnosis | Clinical Impact | DA/CEA | Other__________________ | | | (Stop if Other)
[image]5. | If Clinical Impact study-Study Type: RCT | Prosp Cohort | reTrosp Cohort | Case-control | | | Case-Series
[image]6. | If Diagnosis study: | | Comparative Study | | Other ____________________________________
*7. | Setting:
| PreHospital | ED | CP Eval Unit | CCU | Hospital(not CCU) | No Data | Other_____________________
*8a. Technology Type:; 1. Standard ECG; 2. Continuous/Serial 12-lead ECG; 3. Prehospital ECG; 4. Nonstandard ECG: # leads ______; 5. ECG stress test; 6. Echocardiogram; 7. Creatine Kinase; 8. Myoglobin; 9. Troponin-T and troponin-I; 10. Sestamibi; 11. Computer-based decision aids; 12. Original ACI predictive instrument; 13. TIPI; 14. Goldman chest pain protocol; 15. Other_____________________________ | | | | * 8b. Compared with:; 1. Standard ECG; 2. Continuous/Serial 12-lead ECG; 3. Prehospital ECG; 4. Nonstandard ECG: # leads ______; 5. ECG stress test; 6. Echocardiogram; 7. Creatine Kinase; 8. Myoglobin; 9. Troponin-T and troponin-I; 10. Sestamibi; 11. Computer-based decision aids; 12. Original ACI predictive instrument; 13. TIPI; 14. Goldman chest pain protocol; 15. Other_____________________________
9. | Treatment Study: Intervention: _____________________________

## Diagnostic Tests for ACI in the Emergency Department

Instructions: Circle or fill-in where appropriate. Only one answer except where indicated by an*

Reviewer: EB PC JI CM _________
  Key: n.A.-not applicable n.D.-not described *-one or more answers TEST-test under investigation
Review date: ____/_____/____
UI:____________________
First author:_______________________

### Study Characteristic

Number of Study Arms:_____

*Country: US UK Can Eur Asia Other _____________n.D.

Number of Centers: _______ n.D.

*Hospital type(s):

Urban | Suburban | Rural
Community | Tertiary
Other_____________________

*Funding source:

Government Pharmaceutical pRivate Unfunded n.D.

*Study Setting:

Pre-Hospital/pre-ED | ED | CP Eval Unit
CCU | Hospital (Not CCU) | n.D.
oTher_____________________________________

### Study Patients Characteristics

*Age Group (Overall recruitment)

Adult(18-65) Elderly (>65) Other ________________

Mean Age: ______

Age Range: _____ - _____

% Male: _____

Race:

Dates of Study: _____________________________________

*Comments: _______________________________________ __________________________________________________ __________________________________________________

### Verification of Acute Cardiac Ischemia

*Inclusion criteria presenting:

Signs/Symptoms:

Chest pain

_________________________________

_________________________________

_________________________________

_________________________________

_________________________________

_________________________________

Past history of ACI allowed? | Yes | No | n.D.
Past history of AMI allowed? | Yes | No | n.D.
Past history of known CAD allowed? | Yes | No | n.D.
Other inclusion criteria: _________________________________ _____________________________________________ _____________________________________________

*What were protocol's exclusion criteria:

ECG Diagnosis of AMI

Other: _______________________________________ _____________________________________________ _____________________________________________ _____________________________________________

*Comments: _______________________________________ __________________________________________________ __________________________________________________

## DIAGNOSIS Tests/Characteristics

Changes in protocol during study: _______________________ ___________________________________________________ ___________________________________________________ __________________________________________________ | Comments on diagnostic methods: ____________________ ________________________________________________ ________________________________________________ ________________________________________________

ROC data reported? Y es No

AUC: _________

Subgroup data available: Y es No

If YES, list subgroups:

___________________ ___________________ ___________________ ___________________ ___________________ | ___________________ ___________________ ___________________ ___________________ ___________________

Total number of patients per group: Reference Group: _________ TEST Group: _________ | Number of withdrawals by group: Reference Group: _________ TEST Group: _________

Reason for withdrawal: Reference Group: ___________________________________________________________________________ TEST Group: _______________________________________________________________________________

Codes for Diagnostic Tests:

A Standard ECG

B Continuous/Serial 12-lead ECG

C Pre-hospital ECG

D Non-standard ECG: # leads __________________

E ECG stress test

F Echocardiogram

G Creatine Kinase

H Myoglobin

I Troponin-T and/or Troponin-I

J Sestamibi

K Computer-based decision aids

L Original ACI predictive instrument

M TIPI

N Goldman chest pain protocol

O Other: _______________________

## Test Results

Use above codes to fill in 2 x 2 table. Use multiple tables for multiple TEST cut-off values, if applicable.

Test for (Circle one): AMI ACI | Reference Test Positive | Reference Test Negative
TEST Positive | (TP) | (FP)
TEST Negative | (FN) | (TN)

Comment: _________________________________ _____________________________________________ _____________________________________________ _____________________________________________

Test for (Circle one): AMI ACI | Reference Test Positive | Reference Test Negative
TEST Positive | (TP) | (FP)
TEST Negative | (FN) | (TN)

Comment: _________________________________ _____________________________________________ _____________________________________________ _____________________________________________

Test for (Circle one): AMI ACI | Reference Test Positive | Reference Test Negative
TEST Positive | (TP) | (FP)
TEST Negative | (FN) | (TN)

Comment: _________________________________ _____________________________________________ _____________________________________________ _____________________________________________

Test for (Circle one): AMI ACI | Reference Test Positive | Reference Test Negative
TEST Positive | (TP) | (FP)
TEST Negative | (FN) | (TN)

Comment: _________________________________ _____________________________________________ _____________________________________________ _____________________________________________

Test for (Circle one): AMI ACI | Reference Test Positive | Reference Test Negative
TEST Positive | (TP) | (FP)
TEST Negative | (FN) | (TN)

Comment: _________________________________ _____________________________________________ _____________________________________________ _____________________________________________

Test for (Circle one): AMI ACI | Reference Test Positive | Reference Test Negative
TEST Positive | (TP) | (FP)
TEST Negative | (FN) | (TN)

Comment: _________________________________ _____________________________________________ _____________________________________________ _____________________________________________

### Quality Assessment of Evaluations of Diagnostic Test Performance for ACI/AMI

Reviewer: EB PC JI CM ________ Review date: ______________ UI:____________________

First author:_______________________ Title:____________________________________________

Journal: ________________________________________________________________ Year: ________

Test | | Yes | | | | No
1. | Were the technicalities of the TEST adequately described? | 4 | 3 | 2 | 1 | 0
2. | Were the TEST criteria of normality defined (positive/negative)? | 4 | 3 | 2 | 1 | 0
Description of TEST ____________________________________________________________________
Definition of TEST [image]: ___________________________________________________________________
Reference Standard
3. | Was the Reference Standard stated? | Y | | | | N
4. | Description of Reference Stnd? ________________________________________________________
| Definition of Reference Stnd [image]: ________________________________________________________
| (Was the appropriate Reference Standard used? | 4 | 3 | 2 | 1 | 0
5. | Were the Reference Standard criteria of normality defined? | 4 | 3 | 2 | 1 | 0
Study Population
6. | Was the study population appropriate for evaluating ED use? | 4 | 3 | 2 | 1 | 0
7. | Were individuals with and without disease included in the evaluation? | 4 | 3 | 2 | 1 | 0
8. | Were the inclusion/exclusion criteria stated? | 4 | 3 | 2 | 1 | 0
9. | Was the patient selection process described? | 4 | 3 | 2 | 1 | 0
10. | Was a wide spectrum of diseased patients included? | 4 | 3 | 2 | 1 | 0
11. | Were the characteristics of the patients described? | 4 | 3 | 2 | 1 | 0
12. | Was the source of the patients described? | 4 | 3 | 2 | 1 | 0
13. | Were positive and negative test results verified equally? | 4 | 3 | 2 | 1 | 0
14. | If not, was there random sampling of individuals with negative tests for verification? | 4 | 3 | 2 | 1 | 0
Performance of tests and Interpretation of test results
15. | Were tests being directly compared (TEST vs. Reference Standard)? | Y | | | | N
16. | Was the TEST repeated blindly and randomly? | Y | | | | N
17. | If appropriate, was order of tests (TEST/Ref. Standard) randomized? | Y | | | | N | n.a.
18. | Regarding the interpretation of the TEST:
| a. Was the interpreter blinded to the results of the Reference Standard? | Y | | | | N
| b. Was the interpreter blinded to clinical information? | Y | | | | N
| c. Was blinded interpretation of TEST performed in duplicate? | Y | | | | N
19. | Regarding the interpretation of Reference Standard:
| a. Was the interpreter blinded to the result of the TEST? | Y | | | | N
| b. Was the interpreter blinded to clinical information? | Y | | | | N
| c. Was blinded interpretation of Ref. Standard performed in duplicate? | Y | | | | N
Statistical Analysis and Reporting
20. | Were the data reported in sufficient detail so that the reported results may be replicated (and meta-analysis performed)? | 4 | 3 | 2 | 1 | 0
21. | Adequate description of patients excluded from all analyses (drop-outs, protocol non-compliance, etc)? | 4 | 3 | 2 | 1 | 0
22. | Were the sensitivity and specificity of the TEST reported? | Y | | | | N
23. | Was the TEST precision (confidence interval, SE) reported? | Y | | | | N
24. | If appropriate, were different criteria used to establish an ROC curve? | Y | | | | N
Comments:

### Quality Assessment of RCTs on Clinical Impact of Diagnostic Test on care for ACI/AMI

Reviewer: EB PC JI CM _____________ Review date: ___________________

First author: ____________________________ Title:___________________________________________

Journal: ________________________________ Year:__________ UI:___________________________

Study Population | | Yes | | | | No
1. | Was the study population appropriate for evaluating the ED use? | 4 | 3 | 2 | 1 | 0
2. | Were individuals with and without disease included in the evaluation? | 4 | 3 | 2 | 1 | 0
3. | Were the inclusion/exclusion criteria stated? | 4 | 3 | 2 | 1 | 0
4. | Was the patient selection process adequately described? | 4 | 3 | 2 | 1 | 0
5. | Was a wide spectrum of diseased patients included? | 4 | 3 | 2 | 1 | 0
6. | Were the characteristics of the patients adeqiately described? | 4 | 3 | 2 | 1 | 0
7. | Adequate description of eligible but not enrolled patients? | 4 | 3 | 2 | 1 | 0
Randomization
8. | Method of the randomization? Central Envelope Other Unknown
9. | Adequate blinding of randomization? | 4 | 3 | 2 | 1 | 0
10. | Was randomization achieved (balanced groups)? | 4 | 3 | 2 | 1 | 0
Tests compared
11. | Were the tests being compared adequately described? | 4 | 3 | 2 | 1 | 0
12. | a. Could the test assignment be blinded to the patient? | 4 | 3 | 2 | 1 | 0
| b. If blindable, were the test assignments blinded? | 4 | 3 | 2 | 1 | 0
13. | a. Could the test assignment be blinded to the observer? | 4 | 3 | 2 | 1 | 0
| b. If blindable, were the test assignments blinded? | 4 | 3 | 2 | 1 | 0
14. | Did both tests receive the same clinical information in interpretation the results? | 4 | 3 | 2 | 1 | 0
15. | If test assignments were unblinded, were patients treated equivalently for the same test diagnosis? | 4 | 3 | 2 | 1 | 0
16. | Was a test for differences in treatment pattern between test group performed? | 4 | 3 | 2 | 1 | 0
Outcomes
17. | Were all relevant outcomes reported? | 4 | 3 | 2 | 1 | 0
18. | Were the outcome measures clearly defined? | 4 | 3 | 2 | 1 | 0
19. | Was the observer blinded to the interim results? | 4 | 3 | 2 | 1 | 0
Statistical Analysis and Reporting
20. | Was there a priori estimation of sample size? | Y | | | | N
21. | Was the analysis based on intention-to-treat? | Y | | | | N
22. | Was there adequate reporting of compliance? | 4 | 3 | 2 | 1 | 0
23. | Was a stopping rule defined? | Y | | | | N
24. | Were statistical analyses appropriate? | 4 | 3 | 2 | | 0
25. | Were exact P values or confidence intervals reported? | Y | | | | N
26. | Were post hoc power calculations or confidence intervals reported for non-significant results? | Y | | | | N
27. | Were the data reported in sufficient details so that the results may be replicated (and meta-analysis performed)? | 4 | 3 | 2 | 1 | 0
28. | Adequate description of patients excluded from all analyses (drop-outs, protocol non-compliance, etc)? | 4 | 3 | 2 | 1 | 0
Comments: _______________________________________________________________________________ _________________________________________________________________________________________