# Appendixes

Appendix A: Data Abstraction Forms

Appendix B: Acknowledgments

Appendix C: Acronyms