# Evidence Tables

* See the "Glossary of Abbreviations" (following the Appendices) for abbreviations used in the Evidence Tables.

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
213 Walter, Hofman, Vaughan, 1988 Know Your Body curriculum | Setting: school (children from 2 demographically diverse areas selected as eligible study pop) Gender:M, F Age: 4th-8th grade (at base) Race: W, B, O Risk: general Low-income sites included (site 1) Some analyses separate by gender and race | RCT 37 schools in 2 demographically dissimilar areas were randomly assigned to either intv or con; in intv schools, all children in grades 4-8 received intv | Participation rate (schools): 100% (total) Participation rate (students) Site 1 (low-income) Intv grp: 70.1% Con grp: 64.6% Site 2 (mid/upper SES) Intv grp: 92.1% Con grp: 74.9% Baseline sample sizeSite 1 (low-income) Intv grp: 14 schools; 1115 students Con grp: 8 schools; 448 students Site 2 (mid/upper SES) Intv grp: 8 schools; 447 students Con grp: 7 schools; 464 students F/U sample size: NR Retention rate: NR Comparison of drop-outs: no sig diffs in risk factors at baseline were evident b/w subjects retained and subjects lost to f/u | Intv grp Intv components: "Know Your Body" curriculum used, involving skill training, modeling, goal-setting, reinforcement; nutr component; exercise component; smoking component; all components taught in classrooms Intv delivery: regular classroom teachers (received training) Special features: NR Nutr message: reduce total fat, sat fat, chol, sodium; increase complex carb and fiber; increase p:s ratio Con grp Intv components: no intv (state-mandated general health ed curriculum) Theoretical perspective: Health Belief Model; Social Learning Theory; Cognitive Development Theory | classroom component taught 2 hrs/wk throughout school yr; tot duration of intv: 5 yrs Maintenance: NR | 5 yrs from base* *although the study included 4 f/u data collection pts, this article only presents the overall "rate of change per yr" over a 5 yr period | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Walter, Hofman, Vaughan, 1988 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: polyunsat fat Instrument: 24-hr dietary interviews by dietitians* Statististics: school was unit of analysis; intv effect determined by comparing average chng over the 5 yr period b/w intv and con grps within each site; the changes for indiv subjects within schools were calculated by linear reg and averaged (to obtain an estimate of mean chng for each school); net effect of intv estimated by diffs in chng b/w the 2 grps of schools *dietary interviews were only conducted at base and final f/u, and were estimated from independent, randomly selected subsamples of consenting subjects | Total fat (mean and sd) Significance of effects: net mean reduction for site 1 n.s. (data NR) net mean reduction for site 2: -3.6% (95%CI: -7.1 to -0.1) (sig effect) Significance of effects: net mean reduction for site 1: -2.1% (95% CI: -4.7 to +0.5) (n.s.) net mean reduction for site 2 n.s. (data NR) Intention to treat: NR *diet analyses based on random subsamples | NR | Variables: TC (mg/dl) Instrument: nonfasting plasma TC measured using Auto-Analyzer II at f/u1 and computer-directed analyzer with use of enzymatic methods at all other f/u periods Statistics: school was unit of analysis; intv effect determined by comparing average chng over the 5 yr period b/w intv and con grps within each site; the changes for indiv subjects within schools were calculated by linear reg and averaged (to obtain an estimate of mean chng for each school); net effect of intv estimated by diffs in chng b/w the 2 grps of schools | TC Baseline (school means and sd) F (rate of chng per yr and sd) Significance of effects: p for diffs b/w grps at base NR diff b/w rate of chng for intv and con grp for site 1: -1.0 (95% CI: -2.3 to +0.3) diff b/w rate of chng for intv and con grp for site 2: -1.7 (-2.7 to -0.7) "sig intv effect" Intention to treat: NR | health knowledge: sig intv effect | 63
  Site 1 (low-income schools)
  | Base | F/U
  Intv grp: | 35.1 (3.8) | 34.0 (3.1)
  [n] | [n = 92 students*] | [n = 124 students*]
  Con grp: | 34.4 (3.9) | 35.2 (4.1)
  [n] | [n = 35 students*] | [n = 52 students*]
  Site 2 (mid/upper SES schools)
  | Base | F/U
  Intv grp: | 32.8 (2.1) | 31.3 (3.0)
  [n] | [n = 78 students*] | [n = 112 students*]
  Con grp: | 32.9 (3.9) | 35.0 (3.2)
  [n] | [n = 30 students*] | [n = 70 students*]
  Sat fat (mean and sd)
  Site 1 (low-income schools)
  | Base | F/U
  Intv grp: | 13.7 (1.8) | 11.9 (1.9)
  [n] | [n = 92 students*] | [n = 124 students*]
  Con grp: | 12.6 (1.6) | 12.9 (1.5)
  [n] | [n = 35 students*] | [n = 52 students*]
  Site 2 (mid/upper SES schools)
  Base | F/U
  Intv grp: | 12.3 (1.8) | 10.7 (2.0)
  [n] | [n = 78 students*] | [n = 112 students*]
  Con grp: | 12.7 (2.3) | 13.0 (1.2)
  [n] | [n = 30 students*] | [n = 70 students*]
  Site 1 (low-income schools)
  Intv grp (n = 8 schools): | 173.5 (4.5)
  Con grp (n = 7 schools): | 169.5 (5.2)
  Site 2 (mid/upper SES schools)
  Intv grp (n = 14 schools): | 169.4 (4.9)
  Con grp (n = 8 schools): | 166.3 (4.7)
  Site 1 (low-income schools)
  Intv grp (n = 8 schools): | -2.6 (1.5)
  Con grp (n = 7 schools): | -1.6 (1.8)
  Site 2 (mid/upper SES schools)
  Intv grp (n = 14 schools): | -2.1 (1.0)
  Con grp (n = 8 schools): | -0.4 (0.7)

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
073 Parcel, Simons-Morton, O'Hara, 1989 Go For Health | Setting: school (schools recruited from one school district; presumably all students participated) Gender: M,F Age: 3rd and 4th graders Race: W,B,H,A,N Risk: General | Study design unclear Two of the 4 elementary schools in one school district assigned to intv and 2 to con; (presumably all K-4th graders participated in intv) | Participation rate (schools): NR Participation rate (students): NR Baseline sample size Intv grp: 2 schools; 213 students (n used in dietary analyses) Con grp: 2 schools; 194 students (n used in dietary analyses) F/U 1 sample size Intv grp: 2 schools; 205 students (n used in dietary analyses) Con grp: 2 schools; 147 students (n used in dietary analyses) F/U 2 sample size Intv grp: 2 schools; 239 students (n used in dietary analyses) Con grp: 2 schools; 159 students (n used in dietary analyses): Retention rate (schools): 100% Retention rate (students): n/a (cross-sectional surveys of students conducted annually) Comparison of drop-outs: n/a (analyses not longitudinal) | Intv Grp Intv components: classroom health ed (including modeling, demonstrations, self-monitoring); PE modification; modification of school lunches Intv delivery: PE teachers, food service staff, 3rd and 4th grade classroom teachers Special features: goal setting; food-related activities Nutr message: school lunches modified to decrease fat (to < 30% energy), sat fat (to < 10% energy), and sodium ( 600mg); nutr message of classroom component: decrease fat and sodium Con Grp Intv components: no intv Theoretical perspective: Social Learning Theory; Organizational Change Model | PE component: 2 semester long units (6-8 wks each) Classroom component: 6 modules (3 for 3rd grade and 3 for 4th grade) -each module consisted of a 30-min activity at the beginning of the wk, then 5-10 min activities conducted the remaining days of the wk -two eating modules taught in continuous 4 wk time blocks, one in the fall and one in the spring) -one 6-wk physical activity module (taught at 3 separate times during the school year); cafeteria component NR Tot duration of intv: 2 yrs Maintenance: NR | F/U 1: 1 yr after base F/U 2: 2 yrs after base | Variables: F&V (% of F&V selected in relation to all foods selected) Instrument: questionnaire consisting of 89 food choices (based on Baranowski, Dworkin, Henske, 1986) Statistics: multifactorial ANOVA (with tx condition, time, and time*tx interaction as effects); analyses done with both student and school as unit of analysis | F&V (mean and sd) Significance of effects: p for time*tx interaction with student as unit of analysis n.s. p for time*tx interaction with school as unit of analysis n.s. p for time*school within tx interaction (individual school effects) <0.01 (improvements in both intv and con schools) Intention to treat: n/a
  | Base | F/U 1
  Intv grp: | 21.38 (8.49) | 23.07 (8.18)
  [n] | [n = 213] | [n = 205]
  Con grp: | 22.06 (7.98) | 23.92 (7.76)
  [n] | [n = 194] | [n = 147]
  | F/U 2
  Intv grp: | 23.26 (8.37)
  [n] | [n = 239]
  Con grp: | 22.15 (8.50)
  [n] | [n = 159]

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Parcel, Simons-Morton, O'Hara, 1989 | NR | NR | NR | NR | NR | Diet behavioral capability:sig intv effect Diet self-efficacy: sig intv effect Diet behavioral expectations: sig intv effect | 45

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
078 Simons-Morton, Parcel, Baranowski, 1991 Go For Health | Setting: school (schools recruited from one school district; presumably all students participated) Gender: M,F Age: 3rd and 4th graders Race:W,B,H,A,N Risk: General | Study design unclear Two of the 4 elementary schools in one school district assigned to intv and 2 to con; (presumably all K-4th graders participated in intv) | Participation rate (schools): NR Participation rate (students): NR Baseline sample size Intv grp: 2 schools; n of students NR Con grp: 2 schools; n of students NR F/U 1 sample size Intv grp: 2 schools; n of students NR Con grp: 2 schools; n of students NR F/U 2 sample size Intv grp: 2 schools; n of students NR Con grp: 2 schools; n of students NR Retention rate (schools): 100% Retention rate (students): n/a (cross-sectional surveys of students conducted annually) Comparison of drop-outs: n/a (analyses not longitudinal) | Intv Grp* Intv components: classroom health ed; vigorous PE; modification of school lunches Intv delivery: PE specialists, food service staff, 3rd and 4th grade classroom teachers Special features: NR Nutr message: school lunches modified to lower-fat, lower-sodium lunches; nutr message of classroom component NR Con Grp Intv components: no intv *some analyses presented individually for the 2 intv schools and 2 con schools Theoretical perspective: Social Learning Theory | 6 classroom health ed modules; 5 (6-8 wk) PE units; duration of cafeteria modifications NR; total duration of intv: 2 yrs Maintenance: NR | F/U 1: presumably 1 yr after base F/U 2: presumably 2 yrs after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Simons-Morton, Parcel, Baranowski, 1991 | Variables: total fat (g) in school lunches total fat consumed by students (g) sat fat consumed by students (g) Other variables analyzed: total fat from students' tray lunches total fat from students' bag lunches sat fat from students' tray lunches sat fat from students' bag lunches Instrument: fat in school lunches (n = 12 meals/school) determined by recipe analyses (based on interviews with each cook), analyzed by NCC fat consumed by students determined by 24-hr recall (F/U 2 only) Statistics: means and 95% CIs calculated | Total fat in school lunches (mean and 95% CI) *base values for con schools estimated by averaging the values of the 2 intv schools Significance of effects: p values NR (CIs for intv and con schools do not overlap at either f/u period) Total fat consumed by students (mean and 95% CI) Significance of effects: p values NR (CIs for intv and con grp overlap at f/u 2) Sat fat consumed by students (mean and 95% CI) Significance of effects: p values NR (CIs for intv and con grp overlap at f/u 2) Intention to treat: n/a (cross-sectional waves of data) | Calcium: n.s. | NR | NR | NR | 40
  | Base* | F/U 1
  Intv school 1: | 50.8 (48.1;53.5) | 35.4 (33.4;37.4)
  Intv school 2: | 46.1 (43.6;48.5) | 35.5 (33.5;37.5)
  Con school 1: | 48.4 (46.0;50.9) | 46.9 (43.4;50.3)
  Con school 2: | 48.4 (46.0;50.9) | 47.8 (44.9;50.6)
  | F/U 2
  Intv school 1: | 34.0 (32.0;35.9)
  Intv school 2: | 34.5 (32.1;37.0)
  Con school 1: | 39.5 (37.8;41.3)
  Con school 2: | 42.3 (40.6;43.9)
  | Base | F/U 1 | F/U 2
  Intv grp (n = 67): | NR | NR | 78.6 (70.0;87.2)
  Con grp (n = 68): | NR | NR | 90.0 (80.8;99.1)
  | Base | F/U 1 | F/U 2
  Intv grp (n = 67): | NR | NR | 28.5 (25.0;32.0)
  Con grp (n = 68): | NR | NR | 33.9 (30.3;37.6)

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
005 Resnicow, Cohn, Reinhardt, 1992 Know Your Body curriculum | Setting: School (all 1st-4th grade students recruited from selected schools) Gender: M,F Age: 1st-4th graders Race: B,H,W,A Risk: General Low income pop Results presented separately for "longitudinal cohort" and "post-test only cohort" | non-random assign. of schools 5 elem. schools assigned to intv or con condition by the district; 3 received the intv and 2 were con sites; all 1st-4th grade students were eligible to participate | Participation rate (schools): NR Participation rate (students): 87% (total) Baseline sample size (schools) Intv grp: 3 Con grp: 2 Baseline sample size (students): 2973 (total) F/U sample size (schools) Intv grp: 3 Con grp: 2 F/U sample size (students): 1209 (total) Retention rate (students): 41% (total) Comparison of drop-outs: drop-outs were sig older and less likely to be female or Hispanic | Intv Grp* Intv components: classroom curriculum, cafeteria modifications, peer leader training, food tasting, poster and essay contests, aerobics Intv delivery: regular classroom teacher Special features: NR Nutr message: increase fiber, decrease fat Con Grp Intv components: usual health and science curricula Theoretical perspective: Social Learning Theory; Health Belief Model; PRECEDE Model *results presented for 3 categories of intv exposure (dose-response, based on ratings of teacher implementation): low, moderate, and high | curriculum used once a wk for 30-45 mins during entire school year; program implemented for ~ 2.5 yrs Maintenance: NR | ~ 2.5 yrs from base | Variables: Fruit intake (index score) Veg intake (index score) Instrument: non-quantitative FFQ (36 items), measured on a 5-pt scale (high values = greater intake) Statistics: diffs in means b/w grps assessed using MANCOVA; trends in means across intv grps assessed using linear reg (dose response relationship b/w curriculum exposure and student outcomes), adjusting for demographic covariates | Fruit Intake (mean; sd/se NR) * Significance of effects: Low exposure intv grp sig diff from con grp at base (p<.05; higher fruit intake in con grp); no sig diffs b/w grps at f/u Veg intake (mean; sd/se NR)
  | Base | F/U
  Intv grp - low (n = 557): | 3.41 | 3.13
  Intv grp - mod (n = 184): | 3.43 | 3.15
  Intv grp - high (n = 98): | 3.43 | 3.24
  Con grp (n = 370): | 3.59 | 3.25
  | Base | FIU
  Intv grp - low (n = 557): | 2.83 | 2.68
  Intv grp - mod (n = 184): | 2.78 | 2.53
  Intv grp - high (n = 98): | 2.62 | 2.63
  Con grp (n = 370): | 2.92 | 2.58
  Significance of effects: No sig diffs b/w grps at base or f/u Intention to treat: NR *The full article also presents results for "post-test only cohort" (no baseline values)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Resnicow, Cohn, Reinhardt, 1992 | NR | NR | "Heart healthy foods" (low-fat milk, whole wheat bread, cereal with fiber, broiled fish, popcorn w/o butter): n.s. Dairy intake: n.s. | Variables: TC (mg/dl) Instrument: non-fasting finger stick samples analyzed by enzymatic method, using NCEP guidelines Statistics: diffs in means b/w grps assessed using MANCOVA; trends in means across intv grps assessed using linear reg (dose response relationship b/w curriculum exposure and student outcomes), adjusting for demographic covariates and base values | TC (mean; sd/se NR)* | Health Knowledge: n.s. (effect favored con grp) | 53
  | Base | F/U
  Intv grp - low (n = 557): | 171.6 | 165.0
  Intv grp - mod (n = 184): | 168.6 | 165.0
  Intv grp - high (n = 98): | 165.3 | 157.4
  Con grp (n = 370): | 165.9 | 168.5
  Significance of effects: Low exposure intv grp sig diff from con grp (p<.05) at base; High exposure intv grp sig diff from all other grps at f/u, p< 05 Intention to treat: NR *The full article also presents results for "post-test only cohort" (no baseline values)

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
326 Domel, Baranowski, Davis, 1993 Gimme 5 curriculum | Setting: school (2 elementary schools selected; all 4th-5th graders participated) Gender: M,F Age: 4th-5th graders Race: W,B Risk: general | RCT 2 similar elementary schools interested in participation were randomly assigned to intv or con grp; all 4th-5th graders in intv school received intv | Participation rate (schools): NR Participation rate (students): NR Baseline sample size Intv grp: 1 school; 214 students Con grp: 1 school; 132 students F/U sample size Intv grp: 1 school; 195 students (n used in analyses) Con grp: 1 school; 106 students (n used in analyses) Retention rate (students) Intv grp: 91% Con grp: 80% Comparison of drop-outs: NR | Intv grp Intv components: community advisory committee formed; lessons targeting F&V asking and preparation skills; inclusion of F&V on school lunch menu; recipe preparation; taste-testing; goal setting; self-monitoring; problem solving; use of goal buddies; wkly newsletter sent home to parents; F&V festival Intv delivery: classroom teacher Special features: family component; social support; food-related activities Nutr message: increase F&V Con grp Intv components: teachers conducted classes as usual Theoretical perspective: social Cognitive Theory | 18 sessions (designed to be taught 3 times/wk); total duration of intv: 6 wks Maintenance: NR | within 2 wks following intv (6 wks after base) | Variables: F&V (servings/d) Fruit (servings/d) Veg (servings/d) Other variables analyzed: juices legumes Instrument: food diaries (mean n of days: 6.59-6.81) Statistics: ANOVA test for grp differences, with dep var the diff in servings (f/u - base) | F&V (mean and sd) Significance of effects: p for diff b/w chng in intv and con grp: .913 Fruit (mean and sd) Significance of effects: p for diff b/w chng in intv and con grp: .001 Veg (mean and sd) Significance of effects: p for diff b/w chng in intv and con grp: .018 (effect favored con grp) Intention to treat: NR
  | Base | F/U
  Intv grp (n = 195): | 2.66 (1.25) | 2.95 (1.21)
  Con grp (n = 106): | 2.05 (1.04) | 2.35 (1.32)
  | Diff
  Intv grp (n = 195): | .29 (1.23)
  Con grp (n = 106): | .30 (.99)
  | Base | F/U | Diff
  Intv grp (n = 195): | .60(.53) | .90(.58) | .30(.61)
  Con grp (n =106): | .42(.42) | .48(.54) | .06(.50)
  | Base | F/U | Diff
  Intv grp (n = 195): | 1.55(.75) | 1.55(.70) | -.00(.70)
  Con grp (n = 106): | 1.16(.65) | 1.36(.67) | .20(.68)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Domel, Baranowski, Davis, 1993 | NR | NR | NR | NR | NR | Fruit preferences: sig intv effect F&V snack preferences: sig intv effect Veg preferences: n.s. F&V knowledge: sig intv effect | 65

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
135, 136, 169, 334, 337 Luepker, Perry, McKinlay, 1996 Lytle, Stone, Nichaman, 1996 Osganian, Ebzery, Montgomery, 1996 Perry, Lytle, Feldman, 1998 Nader, Stone, Lytle, 1999 CATCH | Setting: school (schools recruited based on distance from study centers, ethnic diversity, agreement to participating in study) Gender: M,FAge: 3rd graders (at base); mean age 8.76 yrs Race: W,B,H,O Risk: general some results presented separately by ethnicity, gender, and study site | RCT 96 public schools from 12 districts were randomized to intv or con; all 3rd graders invited to participate | Participation rate (schools): NR Participation rate (students): 60% Baseline sample size (schools) Intv grp: 56 Con grp: 40 Baseline sample size (students): 5106 (total) F/U 1 sample size (schools) Intv grp: 56 Con grp: 40 F/U 1 sample size (students): 1229 (total) F/U 2 sample size (schools) Intv grp: 56 Con grp: 40 F/U 2 sample size (students): 4019 (total) F/U 3 sample size (schools) Intv grp: 56 Con grp: 40 F/U 3 sample size (students): 3714 (total) Retention rate (schools): 100%* Retention rate (students): 79%* (total) Comparison of drop-outs: African-Am students and students in California were more likely to have dropped out *Retention rates based on final f/u period | Intv grp Intv components: classroom curricula (including lessons in psychosocial factors, skills development, tobacco prevention), school cafeteria food service modification (involving training of food service personnel), PE component (including training of PE staff) home programs* (including activity packets requiring adult participation, family fun night) Intv delivery: school food service staff, PE teachers, classroom teachers Special features: family component*; food-related activities Nutr message: decrease total fat (to 30% energy), sat fat (10% energy), and sodium; increase F&V Con grp Intv components: usual health curricula, PE, and food service programs *although the grp that received the family-based home program could be classified as a 2nd intv grp, this article presents the results for both intv grps combined Theoretical perspective: NR | food service changes and PE enhancement lasted for 3 school yrs; classroom component included 15 lessons during 5 wks in grade 3, 24 lessons during 12 wks in grade 4, and 16 lessons during 8 wks in grade 5 (lessons averaged 30-40 mins); 4 session tobacco use curriculum in grade 5; 47 total nutrition lessons; home component included 19 activity packets over the 3 yr period Maintenance: NR | F/U 1: 1.5 yrs after base F/U 2: 2.5 yrs after base F/U 3: 5 yrs after base (results only reported for dietary fat outcomes) | Variables: F&V (servings/d) Fruit (servings/d) Veg (servings/d) Instrument: 1 24-hr dietary recall, analyzed with NDS * Statistics: analyzed by mixed-model regression procedures with tx grp as independent var and base values as covariate *based on a subsample of 1186 students | F&V (mean and se) Significance of effects: p for diffs b\w grps at f/u 2 n.s. Fruit (mean and se) Vegetable (mean and se)
  California
  | Base | F/U1 | F/U 2
  Intv grp (n NR*): | NR | NR | 4.19 (0.28)
  Con grp (n NR*): | NR | NR | 4.34 (0.33)
  *total n = 249
  Louisiana
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 3.46 (0.29)
  Con grp (n NR*): | NR | NR | 4.00 (0.35)
  *total n = 293
  Significance of effects:
  p for diffs b/w grps at f/u 2 n.s.
  Minnesota
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 3.98 (0.28)
  Con grp (n NR*): | NR | NR | 4.30 (0.37)
  *total n = 339
  Significance of effects:
  p for diffs b\w grps at f/u 2 n.s.
  Texas
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 5.05 (0.27)
  Con grp (n NR*): | NR | NR | 3.76 (0.36)
  *total n = 305
  Significance of effects:
  p for diffs b/w grps at f/u 2 <0.006
  California
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 2.31 (0.25)
  Con grp (n NR*): | NR | NR | 2.52 (0.29)
  *total n = 249
  Significance of effects:
  p for diffs b\w grps at f/u 2 n.s.
  Louisiana
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 1.71 (0.25)
  Con grp (n NR*): | NR | NR | 2.07 (0.31)
  *total n = 293
  Significance of effects:
  p for diffs b\w grps at f/u 2 n.s.
  Minnesota
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 2.12 (0.24)
  Con grp (n NR*): | NR | NR | 2.37 (0.32)
  *total n = 339
  Significance of effects:
  p for diffs b\w grps at f/u 2 n.s.
  Texas
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 2.85 (0.24)
  Con grp (n NR*): | NR | NR | 1.85 (0.31)
  *total n = 305
  Significance of effects:
  p for diffs b\w grps at f/u 2 <0.02
  California
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 1.81 (0.16)
  Con grp (n NR*): | NR | NR | 1.78 (0.19)
  *total n = 249
  Significance of effects:
  p for diffs b\w grps at f/u 2 n.s.
  Louisiana
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 1.77 (0.16)
  Con grp (n NR*): | NR | NR | 1.94 (0.19)
  *total n = 293
  Significance of effects:
  p for diffs b\w grps at f/u 2 n.s.
  Minnesota
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 1.81 (0.15)
  Con grp (n NR*): | NR | NR | 1.91 (0.20)
  *total n = 339
  Significance of effects:
  p for diffs b\w grps at f/u 2 n.s.
  Texas
  | Base | F/U 1 | F/U 2
  Intv grp (n NR*): | NR | NR | 2.18 (0.15)
  Con grp (n NR*): | NR | NR | 1.92 (0.20)
  *total n = 305
  Significance of effects:
  p for diffs b\w grps at f/u 2 n.s.

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Luepker, Perry, McKinlay, 1996 Lytle, Stone, Nichaman, 1996 Osganian, Ebzery, Montgomery, 1996 Perry, Lytle, Feldman, 1998 Nader, Stone, Lytle, 1999 | Variables: total fat intake of students (% energy) sat fat intake of students (% energy) total fat in school meals (% energy) Other variables analyzed: sat fat in school meals (% energy) tot fat in school meals (g) polyunsat fat intake of students monounsat fat intake of students Instrument:(school level outcomes): recipes, menus, and vendor product info collected for 5 consecutive days from food service personnel and records of student participation in school meals (analyzed using NDS) (individual level outcomes): 1 24-hr dietary recall, analyzed with NDS * Statistics: school level measures analyzed by repeated measures ANCOVA (with tx grp as independent var) indiv-level measures analyzed by mixed-model ANCOVA with tx grp as independent var and base values as covariate (as well as other demographic vars) *recall only conducted on a random subsample of 30 students per school at base and f/u | Total fat intake among students (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for diff in chng (f/u 2) b/w grps: 0.001 p for diff in chng b/w grps (f/u 3): 0.01 Sat fat intake among students (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for diffs in chng (f/u 2) b/w grps <0.005 p for diffs in chng (f/u 3) b/w grps: 0.02 Intention to treat: NR Total fat in school meals (mean and se) Significance of effects: p for diff in chng b/w grps <0.001 p for diff in chng b/w grps <0.001 | Fiber: n.s. Calcium: n.s. | Variables: TC (mmol/L) Instrument: nonfasting venipuncture samples drawn; analyzed using CDC Lipid Standardization Program guidelines Statistics: mixed-model ANCOVA with tx grp as independent var and base values as covariate (as well as other demographic vars) | TC (mean and se) | Dietary knowledge: sig intv effect Dietary intention: sig intv effect Perceived social reinforcement for healthful eating: sig intv effect Diet self-efficacy: sig intv effect (only at f/u 1) | 80
  | Base | F/U 1
  Intv grp (n = 709 students): | 32.7(0.3) | NR
  Con grp (n = 473 students): | 32.6(0.3) | NR
  | F/U 2 | Chng
  Intv grp (n = 709 students): | 30.3(0.3) | -2.3(0.3)
  Con grp (n = 473 students): | 32.2(0.3) | -0.5(0.5)
  | F/U 3
  Intv grp (n NR): | 30.6 (0.3)
  Con grp (n NR): | 31.6 (0.3)
  | Base | F/U 1
  Intv grp (n = 709): | 12.8 (3.6) | NR
  Con grp (n = 473): | 12.5 (3.3) | NR
  | F/U 2 | Chng
  Intv grp (n = 709): | 11.4 (3.5) | -1.2 (0.2)
  Con grp (n = 473): | 12.1 (3.5) | -0.3 (0.2)
  | F/U 3
  Intv grp (n NR): | 11.3 (0.1)
  Con grp (n NR): | 11.8 (0.2)
  | Base | F/U 1
  Intv grp (n = 56 schools): | 38.7(0.4) | 32.5 (0.4)
  Con grp (n = 40 schools): | 38.9(0.5) | 36.2 (0.5)
  | F/U 2
  Intv grp (n = 56 schools): | 31.9 (0.4)
  Con grp (n = 40 schools): | 36.2 (0.5)
  | Base | F/U 1
  Intv grp (n = 2311): | 4.39 (0.01) | NR
  Con grp (n = 1625): | 4.41 (0.02) | NR
  | F/U 2 | Chng
  Intv grp (n = 2311): | 4.36 (0.01) | -0.03 (0.02)
  Con grp (n = 1625): | 4.38 (0.02) | -0.02 (0.02)
  Significance of effects: p for diff in chng b/w grps = 0.68 Intention to treat: analyzed using intention to treat principle

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
037 Baxter, Milner, Hawkins, 1997 Action Heart | Setting: Community and school (children attending schools within selected communities exposed to intv) Gender: M,F Age: 11-14 yrs Race: NR Risk: general Country: UK some analyses separate by gender or by age | Non-equivalent comparison grp design ("prospective comparative study") 2 communities chosen for intv and 1 for con; schools (and other community settings) within selected communities participated in various aspects of intv (intv not standardized across schools); children in schools exposed to intv | Wave 1 Participation rate (schools): NR Wave 1 Participation rate (students): 45-90% (total) Wave 2 Participation rate (schools): NR Wave 2 Participation rate (students): 83-94% (total) Wave 1 sample size (schools): NR Wave 1 sample size (students) Intv grp: 1910 Con grp: 372 Wave 2 sample size (schools): NR Wave 2 sample size Intv grp: 2404 Con grp: 476 Retention rate: n/a (cross-sectional waves of data) Comparison of drop-outs: n/a (cross-sectional waves of data) | Intv grp Intv components: "My Body" project materials provided to schools (anti-smoking); peer-led health educ used in some schools (peers ran "health days" at schools); healthy eating days; no-smoking policies; Action Heart Club; promotional materials available to schools; staff training Intv delivery: school staff; health visitors; school nurses; peers Special features: NR Nutr message: NR (general CVD health intv including "healthy eating") Con grp Intv components: NR Theoretical perspective: NR | Not clear (presumably 3 yrs) Maintenance comp: NR | 3 yrs after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Baxter, Milner, Hawkins, 1997 | Variables: -- low-fat spread consumption (presumably % using low-fat spread) -- milk consumption (presumably % using low-fat milk) instrument: NR (used "validated questions from other youth surveys" for various health outcomes) Statistics: -- calculated changes over the 3 yr period for the cohort of children age 11 at wave 1 (statistics and sig NR) -- analyzed cross-sectional changes over the 3 yr period b/w intv and con grps (used logistic reg to compare the diff in the % engaging in the behavior b/w wave 1 and wave 2 in intv schools with the diff b/w wave 1 and wave 2 in the con school) | Low-fat spread Significance of effects: NR Significance of effects: NR Significance of effects: p for diff b/w intv and con schools in chng rates b/w wave 1 and wave 2 = 0.3 Significance of effects: p for diff b/w intv and con schools in chng rates b/w wave 1 and wave 2 = 0.3 Low-fat milk Significance of effects: NR Significance of effects: p for diff b/w intv and con schools in changing use of low fat milk b/w wave 1 and wave 2 = 0.9 Significance of effects: p for diff b/w intv and con schools in changing use of low fat milk b/w wave 1 and wave 2 = 0.9 Intention to treat: n/a | Wholemeal bread consumption: sig intv effect | NR | NR | NR | 25
  Cohort aged 11 at wave 1 (boys) (%; se NR)
  | Wave 1 | Wave 2 | Diff
  Intv grp: | 50% | 57% | +7%
  [n] | [n = 221] | [n = 250]
  Con grp: | 44% | 61% | +17%
  [n] | [n = 118] | [n = 115]
  Cohort aged 11 at wave 1 (girls) (%; se NR)
  | Wave 1 | Wave 2 | Diff
  Intv grp: | 51% | 64% | +13%
  [n] | [n = 257] | [n = 289]
  Con grp: | 46% | 54% | +8%
  [n] | [n = 129] | [n = 125]
  Diffs b/w 11 yr olds at wave 1 and wave 2 (ratio of odds at wave 2 to odds in wave 1)
  Intv grp (n NR): | 1.01
  Con grp (n NR): | 1.24
  Diffs b/w 14 yr olds at wave 1 and wave 2 (ratio of odds at wave 2 to odds in wave 1)
  Intv grp (n NR): | 0.94
  Con grp (n NR): | 1.07
  Cohort age 11 at wave 1 (boys) (%; se NR)
  | Wave 1 | Wave 2 | Diff
  Intv grp: | 53% | 68% | +15%
  [n] | [n = 223] | [n = 249]
  Con grp: | 59% | 71% | +12%
  [n] | [n = 119] | [n = 115]
  Significance of effects: NR
  Cohort age 11 at wave 1 (girls) (%; se NR)
  | Wave 1 | Wave 2 | Diff
  Intv grp: | 49% | 71% | +22%
  [n] | [n = 254] | [n = 286]
  Con grp: | 54% | 71% | +17%
  [n] | [n = 125] | [n = 125]
  Diffs b/w 11 yr olds at wave 1 and wave 2 (ratio of odds at wave 2 to odds in wave 1)
  Intv grp (n NR): | 2.01
  Con grp (n NR): | 2.28
  Diffs b/w 14 yr olds at wave 1 and wave 2 (ratio of odds at wave 2 to odds in wave 1)
  Intv grp (n NR): | 1.94
  Con grp (n NR): | 1.15

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
100 Harrell, Gansky, McMurray, 1998 CHIC (Cardiovascular Health in Children) | Setting: school (all 3rd and 4th graders of selected schools were screened for CVD risk and participated) Gender: M,F Age: 8-11 yrs Race: B,W,O Risk: CVD risk Analyses presented at the school level and individual level | RCT 18 schools randomly selected from 33 schools that agreed to participate; 3 school clusters randomly selected within each of 3 geographic regions and randomized to one of two intv grps or a con grp; all 3rd and 4th grade students screened for ability to participate (high CVD risk) | Participation Rate (schools): NR Participation Rate (students): 60.4% (total) Baseline sample size (schools): 18 (total) Baseline sample size (students) Intv grp 1: 164 (sample size for analyses) Intv grp 2: 108 (sample size for analyses) Con grp: 150 (sample size for analyses) F/U sample size (schools): 18 (total) F/U sample size (students) Intv grp 1: 164 (sample size for analyses) Intv grp 2: 108 (sample size for analyses) Con grp: 150 (sample size for analyses) Retention rate: NR Comparison of drop-outs: NR | Intv Grps (2 grps) Intv components individualized risk based intv given to high CVD risk children (intv grp 1) -included physical activity classes, nutr classes, conducted in small grps of 5-8 students classroom-based intv given to all students (intv grp 2)* -included AHA program kits stressing heart healthy foods, exercise, smoking; physical activity program Intv delivery: PE teachers (both intv grps), regular classroom teachers (intv grp 2 only), registered nurses (intv grp 1 only) Special features: small group (Intv grp 1 only) Nutr message: "heart healthy foods" (Intv grp 2 only; NR for Intv grp 1) Con grp Intv components: regular health and PE classes, parents provided with testing results Theoretical perspective: NR *results for intv grp 2 are based on only a subset of children with same high CVD risk factors as intv grp 1 | Instruction provided twice a wk for 8 wks; PE taught 3 times/wk (duration of PE component NR); total intv duration: 8 wks Maintenance: NR | F/U data collected within 2 wks after intv (~ 8-10 wks from baseline) | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Harrell, Gansky, McMurray, 1998 | Variables: Fat intake (high-fat diet score) Instruments: short list of high and low fat foods; students indicated how often they ate each food (not much, some, or a lot) Statistics: school-level data analyzed using survey data reg (SDR); this assessed the overall intv effects for diffs b/w any of the 3 grps, then each of the intv grps was comp with con, and the 2 intv grps were compared with each other student-level data analyzed using separate MANOVA examining changes in outcomes, adjusted for study design (region and locale within region) | Fat intake Student-level analyses (mean and se) Significance of effects: p for diffs b/w intv grps and con grp n.s. p for diff b/w intv grp 1 and 2: 0.598 School-level analyses (survey data reg results) Diffs in means b/w 2 intv grps and con grp Intv grp 1 vs. con grp: -1.41 Intv grp 2 vs. con grp: -0.59 Significance of effects: p for overall intv effect: 0.089 p for step down comparison b/w 2 intv grps: 0.375 Intention to treat: NR | NR | Variables:TC (mg/dL) Instrument: nonfasting; measured with Reflotron, using internal and external quality control procedures Statistics: school-level data analyzed using survey data reg (SDR); student-level data analyses using separate MANOVA, adjusted for study design (region and locale within region) | TC Student-level analyses (mean and se) Significance of effects: p for diffs b/w intv grps and con grp <0.05 p for diffs b/w intv grps 1 and 2: 0.915 School-level analyses (survey data reg results) Diffs in means b/w 2 intv grps and con grp Intv grp 1 vs. Con grp: -7.88 Intv grp 2 vs. Con grp: -8.91 Significance of effects: p for overall intv effect: 0.017 p for step down comparison b/w 2 intv grps: 0.868 Intention to treat: NR | Nutr. knowledge: sig intv effect | 55
  | Base | F/U | Chng
  Intv grp 1 (n NR): | NR | NR | -4.10 (0.73)
  Intv grp 2 (n NR): | NR | NR | -5.02 (0.89)
  Con grp (n NR): | NR | NR | -3.20 (0.66)
  | Base | F/U
  Intv grp 1 (n = 164): | 178.9 (2.5) | NR
  Intv grp 2 (n = 108): | 181.6 (3.2) | NR
  Con grp (n = 150): | 178.4 (2.6) | NR
  | Chng
  Intv grp 1 (n NR): | -10.07 (1.77)
  Intv grp 2 (n NR): | -11.68 (2.39)
  Con grp (n NR): | -2.35 (1.87)

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
325 Resnicow, Davis, Smith, 1998 TeachWell | Setting: school/worksite (schools recruited from 1 district; all 3rd-5th grade students and teachers participated) Gender: M,F Age: range NR; mean age of teachers: 41 yrs; mean age of students: 8.7 yrs Race: W,B Risk: general results presented separately for teachers and students | RCT Schools recruited from 1 district and pair matched (on n of students, SES, and student turnover rate), then randomly assigned to intv or con grp | Participation rate (schools): ~72% (total) Participation rate (teachers): 74% (total) Participation rate (students): 66% (total) Baseline sample size (schools) Intv grp: 16 Con grp: 16 Baseline sample size (teachers): 233 (total) Baseline sample size (students): 1780 (total) F/U 1 sample size (teachers): 268 (total) F/U 1 sample size (students): 966 (total) F/U 2 sample size (teachers): 257 (total) F/U 2 sample size (students): NR Retention rate (teachers): 41% (for cohort sample) Retention rate (students): 54% Comparison of drop-outs: teacher drop-outs significantly younger than subjects who provided data at f/u; no sig diffs b/w student drop-outs and non-drop-outs | Intv grp Intv components: Gimme-5 curriculum (classroom lessons); teacher wellness program (including printed ed materials; interactive health workshops; exercise program; wellness counselors available to teachers) Intv delivery: wellness counselors (for teachers only); classroom teachers (for students only) Special features: NR Nutr message: increase F&V Con grp Intv components: students received Gimme-5 curriculum; no wellness training for teachers Theoretical perspective: Social Learning Theory; Organizational Change Theory | Gimme-5 curriculum included 12 sessions (designed to be delivered twice a wk over 6 wks) (in both grades 4 and 5) with 3 activities per session; tot duration of intv: 6 wks; teacher wellness program included 36 health workshops in yr 1 (1 per wk) lasting around 30 mins, and 18 workshops in yr 2; also included exercise program (2-3 times/wk) Maintenance: NR | F/U 1: 1 yr after base F/U 2: 2 yrs after base | Variables: F&V (servings/d) Fruit (servings/d) Veg (servings/d) Instrument: teachers completed 7-d food record (including 5 wk days and 2 wkend days) students completed 7-d food diary Statistics: mixed-model repeated measures ANOVA, adjusting for the effects of the clustering of measurements within schools; model included fixed-effect terms for tx grp, ethnicity, and gender and random-effect terms for school and individual; primary test of intv effect was grp*time interaction; analyses conducted for a "cohort" sample (subjects with data at all 3 time periods) and the "full" sample (subjects with data at any time point) | F&V (Grp*time F) Teachers - Cohort sample (n = 96) F = 1.0 Teachers - Full sample (n = 439) F = 3.19 Students -Cohort sample (n = 966) F = 0.39 Students - Full sample (n = 3052) F = 0.45 Significance of effects: p for F for teacher cohort sample n.s. p for F for teacher full sample <0.05 p for F for student cohort sample n.s. p for F for student full sample n.s. Fruit (Grp*time F) Teachers - Cohort sample (n = 96) F = 0.96 Teachers - Full sample (n = 439) F = 3.43 Students - Cohort sample (n = 966) F = 0.03 Students - Full sample (n = 3052) F = 0.07 Significance of effects: p for F for teacher cohort sample n.s. p for F for teacher full sample <0.05 p for F for student cohort sample n.s. p for F for student full sample n.s. Veg (Grp*time F) Teachers - Cohort sample (n = 96) F = 0.42 Teachers - Full sample (n = 439) F = 0.35 Students - Cohort sample (n = 966) F = 1.11 Students - Full sample (n = 3052) F = 0.33 Significance of effects: p for F for teacher cohort sample n.s. p for F for teacher full sample n.s. p for F for student cohort sample n.s. p for F for student full sample n.s. Intention to treat: NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Resnicow, Davis, Smith, 1998 | Variables: high-fat practices (score) low-fat practices (score; teachers only) Instrument: teachers completed 7-d food record (including 5 wk days and 2 wkend days) Statistics: mixed-model repeated measures ANOVA, adjusting for the effects of the clustering of measurements within schools; model included fixed-effect terms for tx grp, ethnicity, and gender and random-effect terms for school and individual; primary test of intv effect was grp*time interaction; analyses conducted for a "cohort" sample (subjects with data at all 3 time periods) and the "full" sample (subjects with data at any time point) | High-fat practices (Grp*time F) Teachers - Cohort sample (n = 96) F = 1.2 Teachers - Full sample (n = 439) F = 1.99 Significance of effects: p for F for teacher cohort sample n.s. p for F for teacher full sample n.s. Low fat practices (Grp*time F) Teachers - Cohort sample (n = 96) F = 0.24 Teachers - Full sample (n = 439) F = 0.95 Significance of effects: p for F for teacher cohort sample n.s. p for F for teacher full sample n.s. Intention to treat: NR | NR | NR | NR | Teacher F&V preferences: n.s Teacher negative F&V outcome expectations: n.s Teacher positive F&V outcome expectations: sig intv effect Teacher F&V selection efficacy: n.s. Teacher low-fat food relapse efficacy: n.s. Teacher social support for low-fat eating: n.s. Teacher negative support for low-fat eating: n.s. Student F&V knowledge: n.s. Student F&V preferences: n.s. (chng favored con grp) Student snack F&V preferences: sig intv effect Student F&V selection efficacy breakfast and lunch: n.s. Student F&V selection efficacy snack: n.s. Student F&V shopping efficacy: sig intv effect | 58

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
333 Nicklas, Johnson, Myers, 1998 Gimme 5 | Setting: School (schools recruited from New Orleans school system; within intv schools, an intv cohort was identified) Gender: M, F Age: 9th graders (at base) Race: W, B, H, O Risk: general | Randomized, paired design 12 schools matched on gender, race, school enrollment, and geographic location randomly assigned to intv or con conditions | Participation rate (schools): 86% Participation rate (students): 95% Baseline sample size (schools): 12 Baseline sample size (students): 2213 F/U 1 sample size (schools): 12 F/U 1 sample size (students): 2065 F/U 2 sample size (schools): 12 F/U 2 sample size (students): 1967 F/U 3 sample size (schools): 12 F/U 3 sample size (students): 1911 Retention rate (schools): 100% Retention rate (students): 93% Comparison of drop-outs: cohort participation at f/u did not differ by tx condition, gender, or ethnicity | Intv grp Intv components: classroom activities; media campaign; school meal modification; parental involvement Intv delivery: Gimme 5 health educator; trained school personnel; regular classroom teachers; food service staff Special features: family component, interactive activities involving food Nutr components: increase F&V Con grp Intv components: no intv Theoretical perspective: PRECEDE Model | Five 55-minute workshops; parental newsletter sent once a semester (duration of newsletter NR); duration of other components NR; total duration of intv: 3 yrs Maintenance component: NR | F/U 1: 1 yr from base F/U 2: 2 yrs from base F/U 3: 3 yrs from base | Variables: F&V (servings/d) Instrument: self-reported number of F&V usually consumed on a daily basis Statistics: repeated measures ANOVA (school pair as unit of analysis) | F&V (means; sd/se NR) Significance of effects: p for grp*time interaction at f/u 1 <0.001 p for grp*time interaction at f/u 2 <0.05 p for grp*time interaction at f/u 3 n.s. p for linear increase in intv grp from base to f/u 2 <0.001 p for linear increase in con grp from base to f/u 2 n.s. p for diffs b/w grps at f/u 3 n.s.
  | Base | F/U1 | F/U2 | F/U3
  Intv grp (n NR): | 2.63 | NR | 3.00 | NR
  Con grp (n NR): | NR | NR | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Nicklas, Johnson, Myers, 1998 | NR | NR | NR | NR | NR | Stage of change related to F&V intake: sig intv effect F&V knowledge: sig intv effect F&V attitudes: n.s. | 70

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
335 Perry, Bishop, Taylor, 1998 5-a-Day Power Plus | Setting: school (20 elementary schools in the St. Paul school district were recruited and agreed to participate; primary cohort was 4th grade students) Gender: M,F Age: 4th-5th grade children Race: W,B,H,A,N, O Risk: general Some results presented separately by ethnicity | Randomized community trial 20 recruited schools were matched (by school size, student ethnic makeup; % participating in free lunch program); randomization occurred within pairs (10 schools assigned to intv; 10 to con) | Participation rate (schools): NR Participation rate (students): 92% Baseline sample size (schools): 20 Baseline sample size (students): 1612 F/U sample size (schools): 20 F/U sample size (students): 441* Retention rate (schools): 100 Retention rate (students): NR Comparison of drop-outs: NR *sample size for subsample of students completing dietary measurement only | Intv grp Intv components: curricula; parental involvement/education; school food service changes; industry involvement and support (i.e., provided F&V and educational materials, gave presentations); training for teachers and food service staff; snack packs brought home Intv delivery: trained classroom teachers; school food service staff; industry partners Special features: family component; food-related activities Nutr message: increase F&V Con grp Intv components: NR Theoretical perspective: Social Learning Theory | 16 40-45 minute classroom sessions implemented twice a wk for 8 wks (occurred once each school yr); 5 parental information packets sent out; food service component lasted for 2 semesters; total duration of intv: 7 mos Maintenance component: NR | 1 yr after base | Variables: F&V (servings/d, using recall) fruit (servings/d, using recall) veg (servings/d, using recall) Other variables analyzed: F&V (servings/1000 kcal, recall method) fruit (servings/1000 kcal, recall method) veg (servings/1000kcal, recall method) F&V (servings/d, using cafeteria observation) fruit (servings/d, using cafeteria observation) veg (servings/d, using cafeteria observation) F&V (servings/1000 kcal, using cafeteria observation) fruit (servings/1000 kcal, using cafeteria observation) veg (servings/1000kcal, using cafeteria observation) Instrument: 24-hr recall* (# of recalls NR), analyzed using Nutritional Coding Center software student lunchroom observations (1 day), analyzed using Nutritional Coding Center software Statistics: mixed-model regression (adjusted for base value and demographic covariates); school included as a random effect nested within conditions *24-hr recall conducted on a subsample of students | F&V (means; sd/se NR) Significance of effects: p for diff b/w grps at f/u (0.58; 95% CI: -0.15 to 1.31): 0.14 Fruit (means; sd/se NR) Significance of effects: p for diff b/w grps at f/u (0.62; 95% CI: 0.10 to 1.14): 0.02 Veg (means; sd/se NR) Significance of effects: p for diff b/w grps at f/u (-0.02; 95% CI: -0.43 to 0.48): 0.92
  | Base | F/U
  Intv grp (n NR*): | NR | 5.24
  Con grp (n NR*): *total n = 407 | NR | 4.66
  | Base | F/U
  Intv grp (n NR*): | NR | 2.75
  Con grp (n NR*): *total n = 407 | NR | 2.13
  | Base | F/U
  Intv grp (n NR*): | NR | 2.50
  Con grp (n NR*): *total n = 407 | NR | 2.52

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Perry, Bishop, Taylor, 1998 | Variables: total fat (% energy) sat fat (% energy) Instrument: 24-hr recall* (# of recalls NR), analyzed using Nutritional Coding Center software student lunchroom observations (1 day), analyzed using Nutritional Coding Center software Statistics: mixed-model regression (adjusted for base value and demographic covariates); school included as a random effect nested within conditions *24-hr recall conducted on a subsample of students | Total fat (means; sd/se NR) Significance of effects: p for diff b/w grps at f/u (-1.81; 95% CI: -3.25 to -0.37): 0.02 Sat fat (means; sd/se NR) Significance of effects: p for diff b/w grps at f/u (-0.59; 95% CI: -0.20 to 1.38): 0.13 | calcium: sig intv effect fiber: n.s. | NR | NR | F&V asking: sig intv effect F&V knowledge: sig intv effect F&V norms (teacher): sig intv effect F&V norms (friends): n.s. F&V norms (school food service staff): n.s. F&V preference: n.s. F&V family consumption: n.s. | 68
  | Base | F/U
  Intv grp (n NR): | NR | 30.02
  Con grp (n NR): | NR | 31.82
  | Base | F/U
  Intv grp (n NR): | NR | 11.72
  Con grp (n NR): | NR | 12.31

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
327 Baranowski, Davis, Resnicow, 2000 Gimme 5 | Setting: school (metropolitan and suburban schools recruited; all 4th graders received intv) Gender: M,F Age: 4th and 5th graders Race: W,B Risk: general | RCT 16 schools matched within school district on size, SES, and student turnover were randomly assigned within pairs to intv or con grp | Participation rate (schools): NR Participation rate (students): NR Baseline sample size (schools): 16 (total) Baseline sample size (students): 1732 (total) F/U 1 sample size (schools): NR F/U 1 sample size (students): 1864 (total) F/U 2 sample size (schools): NR F/U 2 sample size (students): 1946 (total) Retention rate (schools): NR Retention rate (students): 68% Comparison of drop-outs: drop-outs reported higher "asking" behaviors than non-dropouts; no other sig diffs | Intv grp Intv components: classroom curriculum, newsletters brought home for parents, videotapes sent to parents, point-of-purchase ed (at grocery stores); involved role-playing to develop skills; taste tests; goal-setting; problem solving; meal/snack preparation Intv delivery: classroom teacher Special features: family component Nutr message: increase veg intake (4th grade curriculum); increase fruit/juice (5th grade curriculum) Con grp Intv components: NR Theoretical perspective: Social Cognitive Theory | 12 sessions (lasting 45-55 mins each); videotapes sent to parents at 2-wk intervals; wkly home assignments; total duration of intv: 6 wks Maintenance: NR | F/U 1: 1 yr after base F/U 2: 2 yrs after base | Variables: F&V (servings/d) fruit (servings/d) veg (servings/d) Other variables analyzed: F&V wkday lunch F&V all other times Instrument: 7-d food records Statistics: mixed-model repeated-measures ANOVA (fixed effect terms for time, tx grp, grp*time interaction; random effect terms for school nested in tx condition and indiv nested in school) *analyses based on cohort model of students (subjects who remained in the same school throughout the 3 yrs and had available data at all 3 time points) (n = 1172) | F&V (mean and se) Significance of effects: p for grp*time interaction term: 0.038 Fruit (mean and se) Significance of effects: p for grp*time interaction term n.s Veg (mean and se) Significance of effects: p for grp*time interaction term: 0.004 Intention to treat: NR
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 2.3(0.1) | 2.3(0.1) | 2.3(0.1)
  Con grp (n NR): | 2.4(0.1) | 2.1(0.1) | 2.1(0.1)
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 1.2(0.1) | 1.1(0.1) | 1.1(0.1)
  Con grp (n NR): | 1.2(0.1) | 1.1(0.1) | 1.0(0.1)
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 1.1(0.1) | 1.2(0.1) | 1.1(0.1)
  Con grp (n NR): | 1.2(0.1) | 1.0(0.1) | 1.1(0.1)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Baranowski, Davis, Resnicow, 2000 | NR | NR | NR | NR | NR | F&V knowledge: sig intv effect F&V preferences: n.s. F&V self-efficacy (eating): n.s. F&V self-efficacy (asking and shopping): n.s. Positive F&V outcome expectations: n.s. Negative F&V outcome expectations: n.s. Social norms for F&V: n.s. F&V asking behavior: sig intv effect | 65

Evidence Table 1. Interventions to modify dietary behavior: School settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
328 Reynolds, Franklin, Binkley, 2000 High 5 | Setting: school (schools within 3 school districts recruited; all 4th grade students participated) Gender: M,F Age: 4th graders (students); mean age of parents: 37 yrs Race: W,B,O Risk: general Analyses separate by race, gender, parent marital status, parental education, SES | RCT 28 elementary schools paired within 3 school districts (based on ethnicity and SES), with one school in each pair randomly assigned to an intv grp or con grp; all 4th graders in intv schools invited to participate in intv | Participation rate (schools): NR Participation rate (families): 69% (total) Baseline sample size (families): 1698 (total) F/U sample size: NR Retention rate: 89% (students - total); 87% (parents - total) Comparison of drop-outs: drop-outs had higher fruit and tot F&V intake than subjects who remained in the study | Intv Grp Intv components: classroom component (involving lessons, problem-solving, taste testing); food service component (involving promotion of F&Vs); parent component (involving homework assignments, brochures, interactive lessons with child) Intv delivery: "curriculum coordinators" employed by the project, regular classroom teachers assisted with lessons; food service managers and workers Special features: family component Nutr message: increase F&V Con grp Intv components: delayed intv Theoretical perspective: Social Cognitive Theory | Classroom component: 14 bi-wkly lessons (delivered 3 consecutive days/wk, with lessons lasting from 30-45 mins each); parent component: 7 homework assignments, 7 wkly interactive lessons with child; food service component: intv delivered in the fall and winter (total duration presumably ~ 6 mos) Maintenance: 3 short "booster" sessions delivered the year after the intv | F/U 1: 1 yr after base F/U 2: 2 yrs after base | Variables: F&V servings/d fruit servings/d veg servings/d Other variables analyzed: F&V (students) (according to 5 a Day guidelines) fruit (students) (according to 5 a Day guidelines) veg (students) (according to 5 a Day guidelines) F&V (students) (cafeteria observation) fruit (students) (cafeteria observation) veg (students) (cafeteria observation) Instrument: 1 24-hr recall (either face-to-face or telephone) (students) FFQ (Health Habits and History Questionnaire; n of items NR) (parents) Statistics: schools were unit of analysis; modeling using mixed models procedure; main effect of tx diffs across time conducted using ANCOVA (adjusting for base values) | F&V (mean and 95% CI) Students Parents Significance of effects: p for diffs b/w grps at base (students) <0.59 p for diffs b/w grps at f/u 1 (students) <0.0001 p for diffs b/w grps at f/u 2 (students) <0.0001 p for diffs b/w grps at base (parents) <0.69 p for diffs b/w grps at f/u 1 (parents) <0.0366 p for diffs b/w grps at f/u 2 (parents) <0.09 Fruit (mean and 95% CI) Students Parents Significance of effects: p for diffs b/w grps at base (students)<0.14 p for diffs b/w grps at f/u 1 (students)<0.0001 p for diffs b/w grps at f/u 2 (students)<0.0001 p for diffs b/w grps at base (parents)<0.71 p for diffs b/w grps at f/u 1 (parents)<0.11 p for diffs b/w grps at f/u 2 (parents)<0.77 Veg (mean and 95% CI) Students Parents Significance of effects: p for diffs b/w grps at base (students)<0.89 p for diffs b/w grps at f/u 1 (students)<0.0001 p for diffs b/w grps at f/u 2 (students)<0.009 p for diffs b/w grps at base (parents)<0.84 p for diffs b/w grps at f/u 1 (parents)<0.0359 p for diffs b/w grps at f/u 2 (parents)<0.09 Intention to treat: NR
  | Base
  Intv grp (n NR): | 2.61 (2.36; 2.86)
  Con grp (n NR): | 2.51 (2.27; 2.77)
  | F/U 1
  Intv grp (n NR): | 3.96 (3.51; 4.44)
  Con grp (n NR): | 2.28 (1.92; 2.66)
  | F/U 2
  Intv grp (n NR): | 3.20 (2.89; 3.52)
  Con grp (n NR): | 2.21 (1.94; 2.49)
  | Base
  Intv grp (n NR): | 3.83 (3.60; 4.07)
  Con grp (n NR): | 3.77 (3.53; 4.02)
  | F/U 1
  Intv grp (n NR): | 4.23 (4.03; 4.43)
  Con grp (n NR): | 3.94 (3.75; 4.12)
  | F/U 2
  Intv grp (n NR): | 4.52 (4.28; 4.77)
  Con grp (n NR): | 4.24 (4.00; 4.48)
  | Base
  Intv grp (n NR): | 1.00 (0.86; 1.14)
  Con grp (n NR): | 0.85 (0.72; 0.99)
  | F/U 1
  Intv grp (n NR): | 1.71 (1.45; 1.99)
  Con grp (n NR): | 0.83 (0.63; 1.04)
  | F/U 2
  Intv grp (n NR): | 1.21 (1.01; 1.41)
  Con grp (n NR): | 0.65 (0.50; 0.82)
  | Base
  Intv grp (n NR): | 1.65 (1.48; 1.82)
  Con grp (n NR): | 1.60 (1.43; 1.78)
  | F/U 1
  Intv grp (n NR): | 1.75 (1.62; 1.87)
  Con grp (n NR): | 1.61 (1.49; 1.73)
  | F/U 2
  Intv grp (n NR): | 1.94 (1.75; 2.14)
  Con grp (n NR): | 1.90 (1.70; 2.11)
  | Base
  Intv grp (n NR): | 1.32 (1.17; 1.48)
  Con grp (n NR): | 1.33 (1.18; 1.49)
  | F/U 1
  Intv grp (n NR): | 1.84 (1.61; 2.09)
  Con grp (n NR): | 1.15 (0.95; 1.35)
  | F/U 2
  Intv grp (n NR): | 1.60 (1.42; 1.79)
  Con grp (n NR): | 1.25 (1.08; 1.43)
  | Base
  Intv grp (n NR): | 2.05 (1.89; 2.23)
  Con grp (n NR): | 2.03 (1.86; 2.20)
  | F/U 1
  Intv grp (n NR): | 2.38 (2.26; 2.49)
  Con grp (n NR): | 2.21 (2.10; 2.32)
  | F/U 2
  Intv grp (n NR): | 2.43 (2.58; 2.61)
  Con grp (n NR): | 2.22 (2.04; 2.39)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Reynolds, Franklin, Binkley, 2000 | Variables: total fat (% energy) sat fat (% energy) Instrument: 1 24-hr recall (either face-to-face or telephone) (students only) Statistics: schools were unit of analysis; modeling using mixed models procedure; main effect of tx diffs across time conducted using ANCOVA (adjusting for base values)
Total fat (mean and 95% CI) Students Significance of effects: p for diffs b/w grps at base (students) <0.86 p for diffs b/w grps at f/u 1 (students) <0.003 p for diffs b/w grps at f/u 2 (students) <0.0402 Sat fat (mean and 95% CI) Students Significance of effects: p for diffs b/w grps at base (students) <0.96 p for diffs b/w grps at f/u 1 (students) <0.009 p for diffs b/w grps at f/u 2 (students) <0.0249 Intention to treat: NR | Fiber: sig intv effect (students) | NR | NR | Cognitive outcome expectancy (students only): sig intv effect Physical outcome expectancy (students only): sig intv effect Health benefits outcome expectancy (parents only): n.s. Negative outcome expectancy: sig intv effect for students and parents F&V self-efficacy : sig intv effect for students; n.s. for parents Knowledge of 5 a Day: sig intv effect for students and parents F&V asking skills (students only): sig intv effect | 75
  | Base
  Intv grp (n NR): | 34.27 (33.29; 35.25)
  Con grp (n NR): | 34.15 (33.15; 35.14)
  | F/U 1
  Intv grp (n NR): | 30.93 (29.84; 32.02)
  Con grp (n NR): | 33.37 (32.26; 34.49)
  | F/U 2
  Intv grp (n NR): | 31.56 (30.45; 32.66)
  Con grp (n NR): | 33.23 (32.08; 34.37)
  | Base
  Intv grp (n NR): | 12.53 (12.13; 12.93)
  Con grp (n NR): | 12.54 (12.13; 12.95)
  | F/U 1
  Intv grp (n NR): | 11.07 (10.60; 11.54)
  Con grp (n NR): | 12.00 (11.51; 12.49)
  | F/U 2
  Intv grp (n NR): | 11.49 (11.04; 11.94)
  Con grp (n NR): | 12.24 (11.77; 12.71)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
110 Hjermann, Byre, Holme, 1981 | Setting: healthcare (recruited from all Oslo men meeting selection criteria) Gender: M Age: 40-49 yrs Race: NR Risk: CVD Country: Norway Some analyses separate by highest and lowest quintile of chol-lowering, or smoking status | RCT subjects randomly assigned to intv or con grp | Participation rate: 97% (total) Baseline sample size Intv grp: 604 Con grp: 628 F/U sample size 1187(total; but dietary data presented for only 46 subjects) Retention rate: 96% (total sample) Comparison of drop-outs: NR | Intv Grp Intv components: indiv dietary counseling, spouse group discussion, clinical exams, smoking cessation Intv delivery: physician, dietitian Special features: family component (meetings with wives) Nutr message: (tailored to dietary assessment results) decrease sat fat, energy, sugars, margarine, and alcohol Con Grp Intv components: no intv (diet record and annual exams) Theoretical perspective: NR | 30-min dietary counseling, duration of other components NR Maintenance: NR | 5 yrs after baseline (but data presented in article are at 4 yrs) | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Hjermann, Byre, Holme, 1981 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: polyunsat fat Instrument: "diet interview" Statistics: diffs b/w grps determined by a t-test accounting for unequal variances in grps | Total fat (mean; sd/se NR) Significance of effects: p for diff b/w grps at f/u <.01 Sat fat (mean; sd/se NR) Significance of effects: p for diff b/w grps at f/u <.01 Intention to treat: NR *based on a subsample of "good dietary responders" | Crude fiber: sig intv effect | Variables: TC (mg/dL) Instrument: fasting Statistics: diffs b/w grps determined by a t-test accounting for unequal variances in grps | TC (mean and se) Significance of effects: p (for diff b/w means at base) NR p (for diff b/w means at f/u) < 01 *based on a subsample of "good dietary responders" | NR | 60
  | Base | F/U
  Intv grp (n = 23*): | NR | 27.9
  Con grp (n = 23): | NR | 44.1
  | Base | F/U
  Intv grp (n = 23*): | NR | 8.2
  Con grp (n = 23): | NR | 18.3
  | Base | F/U
  Intv grp (n = 23*): | 327.7 (6.41) | 263.2 (6.11)
  Con grp (n = 23): | 328.0 (5.65) | 341.2 (6.70)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
329 Gorder, Dolecek, Coleman, 1986 Multiple Risk Factor Intervention Trial (MRFIT) | Setting: healthcare (recruited from general public, organizations, universities, etc.) Gender: M Age: 35-57 yrs Race: W,B Risk: CVD | RCT subjects randomly assigned to intv or con grp, stratified by clinic | Participation rate: 99.8% (total) Baseline sample size Intv grp: 6428 Con grp: 6438 F/U sample size Intv grp: 6273 Con grp: 6271 Retention rate Intv grp: 98% Con grp: 97% Comparison of drop-outs: NR | Intv Grp Intv components: group and indiv counseling; health info to modified risk factors (obesity, smoking, bp, chol); behavior change skills; nutr ed programs Intv delivery: nutritionist, nurse, physician, behavioral scientist, health counselor Special features: NR Nutr message: <25-35% energy from fat, <5-8% from sat fat, 10% energy from polyunsat fat, <100-300 mg/d chol Con grp Intv components: usual medial care without recommendations for tx Theoretical perspective: NR | 10 grp sessions (duration NR); indiv session every 4 mos; additional grp and indiv sessions (# and duration NR); >6 visits to MRFIT centers by participants (duration NR); total duration of intv NR Maintenance: NR | F/U 1: 6 yrs* *annual follow-ups not reported separately | Variables:: fruit (% energy) veg (% energy) Instrument: 24-hr dietary recall using MRFIT food grouping and NHLBI nutr data system Statistics: NR | Fruit (mean; sd/se NR) Significance of effects: p for diff chng b/w grps (2.0) <0.001 Veg (mean; sd/se NR) Significance of effects: p for diff chng b/w grps (1.0) <0.001 *baseline means only presented for intv and con grps combined
  | Base | F/U
  Intv grp (n = 6273): | 4.2* | 7.2
  Con grp (n = 6271): | 4.2* | 5.2
  | Base | F/U
  Intv grp (n = 6273): | 3.0* | 4.3
  Con grp (n = 6271): | 3.0* | 3.4

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Gorder, Dolecek, Coleman, 1986 | Variables: total fat (% energy) sat fat (% energy) high fat meat (%energy) Other variables analyzed: monounsat fat polyunsat fat fats, oils (sat) high fat dietary high fat baked goods Instrument: 24-hr dietary recall using MRFIT food grouping and NHLBI nutr data system Statistics: NR | Total fat (mean; sd/se NR) Significance of effects: p for diffs in chng grps (-4.2) <0.001 Sat fat (mean; sd/se NR) Significance of effects: p for diffs in chng grps (-3.5) <0.001 High fat meat (mean; sd/se NR) Significance of effects: p for diffs in chng b/w grps (-3.5) <0.001 *the mean at baseline reflects intv and con grps combined Intention to treat: NR | Fiber: sig intv effect | Variables: TC (mg/dL) LDL-C (mg/dL) Instrument: blood samples taken (subjects only fasted for base TC values); serum chol and plasma LDL-C measured by Lipid Research Clinics methodology Statistics: student t-test | TC (mean; sd/se NR) Significance of effects: NR LDL-C (mean; sd/se NR) Significance of effects: NR Intention to treat: NR | NR | 55
  | Base | F/U
  Intv grp (n = 6273*): | 38.2* | 33.8
  Con grp (n = 6271): | 38.2 | 38.0
  | Base | F/U
  Intv grp (n = 6273*): | 14.3* | 10.4
  Con grp (n = 6271): | 14.3* | 13.9
  | Base | F/U
  Intv grp (n = 6273*): | 13.6* | 10.4
  Con grp (n = 6271): | 13.6* | 13.9
  | Base | F/U | Chng
  Intv grp: | 253.8 | 235.5 | 18.3
  [n] | [n = 6428] | [n = 5754]
  Con grp: | 253.5 | 240.3 | 13.2
  [n] | [n = 6438] | [n = 5639]
  | Base | F/U | Chng
  Intv grp: | 159.8 | 148.7 | 11.1
  [n] | [n = 6428] | [n = 5754]
  Con grp: | 160.3 | 152.9 | 7.4
  [n] | [n = 6438] | [n = 5639]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
128 Lee-Han, Cousins, Beaton, 1988 Breast Dysplasia Intervention Trial | Setting: healthcare (subjects screened for cancer risk and recruited from hospital) Gender: F Age:> 30 yrs Race: NR Risk: Cancer Country: Canada | RCT subjects randomly allocated to intv or con grp | Participation rate Intv grp: 59% Con grp: 51% Baseline sample size Intv grp: 37 Con grp: 33 F/U 1 sample size: NR F/U 2 sample size Intv grp: 29 Con grp: 28 Retention rate* Intv grp: 78% Con grp: 85% Comparison of drop-outs: NR *retention rate refers to final f/u period | Intv grp Intv components: indiv counseling; dietary assessment; written info on foods, recipes, eating out, etc. Intv delivery: research dietitian Special features: NR Nutr message: decrease total fat intake (to 15% energy) and maintain this change for 12 mos Con grp Intv components: general advice about maintaining a healthy diet according to Canada's Food Guide (not counseled to change composition of diet) Theoretical perspective: NR | 1 session of dietary assessment and advice; monthly visits to dietitian for 12 mos; phone access to study personnel as needed Maintenance: NR | F/U 1: 6 mos after base F/U 2: 12 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Lee-Han, Cousins, Beaton, 1988 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: polyunsat fat monounsat fat p:s ratio Instrument: 4-d food record (including 2 wkdays and 2 wkend days) Statistics: student t-tests, paired sample t-tests | Total fat (mean and se) Significance of effects: p for chng from base to f/u for intv grp <0.001 p for diff b/w grps at f/u 2 <0.00)1 Sat fat (mean and se) Significance of effects: NR Intention to treat: NR | NR | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: fasting venous blood sample drawn; lipids measured by Lipid Research Clinics Laboratory (Univ of Toronto) by standardized Lipid Research Clinic Method; TC measured by Technicon Autoanalyzer II; LDL-C assayed and calculated indirectly Statistics: student t-tests, paired sample t-tests | TC (mean; sd/se NR) Significance of effects: p for chng from base to f/u 1 for intv grp <0.01 p for chng from base to f/u 1 for con grp <0.05 (increase in TC) p for chng from f/u 1 to f/u 2 for intv grp n.s. LDL-C (mean; sd/se NR) Significance of effects: p for chng from base to f/u 1 for intv grp n.s. p for chng from f/u 1 to f/u 2 for intv grp <0.05 (sig increase in LDL-C) Intention to treat: NR | NR | 46
  | Base | F/U 1
  Intv grp (n NR): | 36.42 (1.34) | 23.49 (1.09)
  Con grp (n NR): | 35.73(1.16) | 34.35 (1.19)
  | F/U 2
  Intv grp (n NR): | 25.83 (1.64)
  Con grp (n NR): | 35.88 (1.38)
  | Base | F/U 1
  Intv grp (n NR): | 14.14 (0.62) | 8.61 (0.47)
  Con grp (n NR): | 13.92 (0.72) | 13.77 (0.60)
  | F/U 2
  Intv grp (n NR): | 9.50 (0.77)
  Con grp (n NR): | 13.98 (0.74)
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 4.82 | 4.47 | 4.65
  Con grp (n NR): | 4.54 | 4.74 | NR
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 2.63 | 2.49 | NR
  Con grp (n NR): | NR | NR | NR

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
049 Burr, Fehily, Gilbert, 1989 DART | Setting: healthcare (pts recovering from MI referred by physicians and recruited for study) Gender: M Age: 39-69 yrs Race: NR Risk: CVD | RCT with factorial design Subjects were randomly allocated to receive or not receive advice on 3 dietary factors (fat intake, fish intake, fiber intake), resulting in 8 total conditions | Participation rate: NR Baseline sample size Intv grp: 1018 Con grp: 1015 F/U 1 sample size Intv grp: NR (~ 947 used in analyses) Con grp: NR (~ 953 used in analyses) F/U 2 sample size Intv grp: NR (~ 869 used in analyses) Con grp: NR (~ 896 used in analyses) Retention rate: NR Comparison of drop-outs: NR | Intv grp* Intv components: dietary advice; diet sheet; smoking cessation advice (if necessary); weight reducing advice (if necessary) Intv delivery: dietitian Special features: family component Nutr message: reduce total fat to 30% energy and increase p:s ratio to 1.0 (very detailed suggestions provided to subjects) Con grp Intv components: non-fat-related dietary advice (for subjects in 1 of the 3 intv grps not receiving fat advice); no specific advice (subjects told to eat a balanced diet) *although the actual trial contained a total of 8 grps (fat advice, fish advice, fiber advice, fat+fish advice, fat+fiber advice, fish+fiber advice, fat+fish+fiber advice, no advice), this article presents results for all grps receiving fat advice compared with all grps not receiving fat advice. Thus, the con grp includes subjects receiving non-fat-related dietary advice and subjects receiving no advice Theoretical perspective: NR | Duration NR (presumably 1 short "advice" session and fact sheet) Maintenance: dietitians visited and telephoned subjects regularly to reinforce advice | F/U 1: 6 mos after completion of intv F/U 2: 2 yrs after completion of intv | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Burr, Fehily, Gilbert, 1989 | Variables: total fat (% energy) Other variables analyzed: p:s ratio Instrument: NR ("detailed dietary questionnaire") Statistics: NR | Total fat (mean and sd) Significance of effects: NR Intention to treat: NR *dietary data not collected at baseline | NR | Variables: TC (mmol/L) Instrument: blood sample taken (fasting vs. non NR) Statistics: NR | TC (mean and sd) Significance of effects: p for diff b/w means at f/u 1 <0.001 Intention to treat: NR | NR | 48
  | Base* | F/U 1 | F/U 2
  Intv grp: | NR | 32.1 (6.0) | 32.3 (5.9)
  [n] | | [n = 937] | [n = 869]
  Con grp: | NR | 35.3 (5.9) | 35.0 (5.8)
  [n] | | [n = 942] | [n = 876]
  | Base | F/U 1 | F/U 2
  Intv grp: | 6.47 (1.24) | 6.31 (1.14) | 6.29 (1.13)
  [n] | [n = 982] | [n = 924] | [n = 855]
  Con grp: | 6.47 (1.23) | 6.57 (1.16) | 6.55 (1.10)
  [n] | [n = 978] | [n = 931] | [n = 860]

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
311 Glasgow, Toobert, Mitchell, 1989 | Setting: healthcare (outpatients recruited from physicians) Gender: M,F Age: 42-75 Race: NR Risk: type 2 diabetes | RCT pts stratified by sex, mode of therapy, and physician; then randomly assigned to 1 of 2 intv grps or a con grp | Participation rate: NR Baseline sample size Intv grps 1 and 2: 56 Con grp: 22 F/U 1 sample size Intv grps 1 and 2: 56 Con grp: 18 F/U 2 sample size: NR Retention rate Intv grp 1: 100% Intv grp 2: 100% Con grp: 82% Comparison of drop-outs: NR | Intv grps (2 grps) Intv components: nutr ed (in group meetings) only (intv grp1) nutr ed (in group meetings) plus social learning intv (individualized goal setting, feedback, training in problem solving; relapse prevention) (intv grp 2) Intv delivery: NR Special features: small group Nutr message: decrease energy (by 500-800 kcals) intake and fat intake (to 30% energy), increase fiber (by 10-20 g/d) Con grp Intv components: wait-list Theoretical Perspective: Social Learning Theory | Wkly meetings for 5 wks (duration of meetings: 1.5-2 hrs) Maintenance: NR | F/U 1: not clear (presumably 5 wks after base) F/U 2: 2 mos (presumably from base) | NR | NR | Glasgow, Toobert, Mitchell, 1989 | Variables: Total fat (% energy) Instrument: 3-d food record (2 wkdays, 1 wkend day) Statistics: within grp changes; ANCOVA (covarying pretest scores) | Total fat (mean and sd) Significance of effects: p for chng from base to f/u 1 for intv grp 2 <0.01 p for chng from base to f/u 2 for intv grp 2 <0.01 the combined intv conditions not sig diff from con grp Intention to treat: NR | Fiber: sig intv effect (changes n.s. for intv grps 1 and 2, but the combined intv grps were superior to con grp) | NR | NR | NR | 38
  | Base | F/U 1
  Intv grp 1 (n = 20): | 36.2 (8.0) | 35.6 (8.2)
  Intv grp 2 (n = 23): | 40.6 (7.0) | 35.7 (9.5)
  Con grp (n = 16): | 38.5 (9.7) | 35.3 (10.4)
  | F/U 2
  Intv grp 1 (n = 20): | 38.1 (9.4)
  Intv grp 2 (n = 23): | 36.8 (6.7)
  Con grp (n = 16): | 39.2 (9.0)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
035 Baron, Gleason, Crowe, 1990 | Setting: healthcare (recruited from general practice) Gender: M,F Age: 25-60 yrs Race: NR Risk: general Country: U.K. Analyses separate for males and females | RCT subjects randomly assigned to intv or con grp | Participation rate: 84% (total) Baseline sample size: Intv grp: 187 Con grp: 181 F/U 1 sample size Intv grp: 183 Con grp: 180 F/U 2 sample size Intv grp: 180 Con grp: 178 F/U 3 sample size Intv grp: 167 Con grp: 168 Retention rate Intv grp: 98% Con grp: 99% Comparison of drop-outs: NR | Intv Grp Intv components: self-administered health questionnaire, general health info, recipes provided Intv delivery: nurse Special features: NR Nutr message: decrease total fat, increase p:s ratio, increase fiber Con Grp Intv components: no dietary advice, nurse f/u visit at 1 and 3 mos Theoretical perspective: NR | Duration of indiv or small grp sessions: around 30 mins; n of sessions NR; duration of total intv: 3 mo Maintenance: NR | F/U 1: 1 mo after base F/U 2: 3 mos after base F/U 3: 1 yr after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Baron, Gleason, Crowe, 1990 | Variables: % of subjects using sat fat for frying % of subjects using sat fat for spreading Other variables: % of subjects using polyunsat fat for spreading self-reported decrease of fat self-reported increase of polyunsat fat Instrument: "simple FFQ" (n items NR) Statistics: t-tests | Sat fat for frying (%; se NR) Men Significance of effects: p (diff b/w grps) at base n.s p (diff b/w grps) at f/u1, f/u2, and f/u3 <.05 Women Significance of effects: p (diff b/w grps) at base. n.s p (diff b/w grps) at f/u1, f/u2, and f/u3 <.05 Sat fat for spreading (%; se NR) Men Significance of effects: p (diff b/w grps) at base, f/u1, f/u2, and f/u3 <.05 Women Significance of effects: p (diff b/w grps) at base n.s p (diff b/w grps) at f/u1, f/u2, and f/u3 <.05 Intention to treat: NR | Total fiber: n.s. | Variables: TC (mM) LDL-C (mM) Instrument: fasting blood sample; chol concentration determined by Liebermann-Burchardt reaction Statistics: t-tests | TC (mean and se) Men Significance of effects: p (diff b/w grps) at base, f/u 1, f/u 2, and f/u 3 n.s. Women Significance of effects: p (diff b/w grps) at base, f/u 1, f/u 2, and f/u 3 n.s. LDL-C (mean and se) Men Significance of effects: p (diff b/w grps) at base, f/u 1 and f/u 3 n.s. p (diff b/w grps) at f/u 2 <.05 LDL-C Women Significance of effects: p (diff b/w tx grps) at base, f/u 1, f/u 2, and f/u 3 n.s. Intention to treat: NR | NR | 61
  | Base | F/U1 | F/U2 | F/U3
  Intv grp: | 26% | 4% | 3% | 9%
  [n] | [97] | [95] | [93] | [77]
  Con grp: | 23% | 17% | 19% | 26%
  [n] | [92] | [92] | [91] | [85]
  | Base | F/U1 | F/U2 | F/U3
  Intv grp: | 20% | 7% | 5% | 7%
  [n] | [90] | [88] | [87] | [83]
  Con grp: | 19% | 26% | 25% | 14%
  [n] | [89] | [88] | [87] | [79]
  | Base | F/U1 | F/U2 | F/U3
  Intv grp: | 41% | 5% | 3% | 6%
  [n] | [97] | [95] | [93] | [83]
  Con grp: | 24% | 28% | 24% | 23%
  [n] | [92] | [92] | [91] | [87]
  | Base | F/U1 | F/U2 | F/U3
  Intv grp: | 31% | 5% | 0% | 2%
  [n] | [90] | [88] | [87] | [83]
  Con grp: | 36% | 34% | 43% | 37%
  [n] | [89] | [88] | [87] | [81]
  | Base | F/U 1
  Intv grp: | 4.92 (0.08) | 4.70 (0.08)
  [n] | [n = 97] | [n = 95]
  Con grp: | 4.81 (0.08) | 4.72 (0.08)
  [n] | [n = 92] | [n = 92]
  | F/U 2 | F/U 3
  Intv grp: | 4.73 (0.08) | 4.52 (0.08)
  [n] | [n = 93] | [n = 85]
  Con grp: | 4.92 (0.09) | 4.50 (0.08)
  [n] | [n = 91] | [n = 86]
  | Base | F/U 1
  Intv grp: | 4.79 (0.09) | 4.65 (0.09)
  [n] | [n = 89] | [n = 88]
  Con grp: | 4.88 (0.10) | 4.87 (0.10)
  [n] | [n = 89] | [n = 87]
  | F/U 2 | F/U 3
  Intv grp: | 4.73 (0.10) | 4.80 (0.11)
  [n] | [n = 87] | [n = 82]
  Con grp: | 4.75 (0.11) | 4.84 (0.11)
  [n] | [n = 87] | [n = 80]
  | Base | F/U 1
  Intv grp: | 2.96 (0.08) | 2.73 (0.07)
  [n] | [n = 85] | [n = 81]
  Con grp: | 2.87 (0.09) | 2.77 (0.09)
  [n] | [n = 80] | [n = 82]
  | F/U 2 | F/U 3
  Intv grp: | 2.57 (0.08) | 2.36 (0.07)
  [n] | [n = 89] | [n = 83]
  Con grp: | 2.83 (0.08) | 2.31 (0.08)
  [n] | [n = 81] | [n = 85]
  | Base | F/U 1
  Intv grp: | 2.90 (0.09) | 2.77 (0.09)
  [n] | [n = 84] | [n = 85]
  Con grp: | 2.76 (0.10) | 2.81 (0.09)
  [n] | [n = 87] | [n = 84]
  | F/U 2 | F/U 3
  Intv grp: | 2.70 (0.09) | 2.71 (0.09)
  [n] | [n = 77] | [n = 81]
  Con grp: | 2.79 (0.11) | 2.73 (0.10)
  [n] | [n = 81] | [n = 79]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
303 Bloomfield, Calder, Chisholm, 1990 | Setting: healthcare (pts recruited from pediatric diabetic clinic) Gender: M,F Age: <13 yrs Race: NR Risk: type 1 diabetes Country: U.K. | randomized crossover trial subjects allocated to receive either the intv or con conditions for 1 year, then conditions were switched | Participation rate: 52% (total) Baseline sample size Intv grp 1: 24 Intv gtp 2: 24 F/U 1 sample size: NR F/U 2 sample size: NR Retention rate: 100% (presumably) Comparison of drop-outs: NR | Intv grps (2 intv grps) Intv components: "diabetic club" involving informal ed, prepared lunch, semi-structured discussion groups, separate sessions for parents and children, cooking, story-telling, computer-based teaching, videos, indiv discussion with pediatrician intv grp 1 received the intv during yr 1, and routine clinic visits during yr 2 intv grp 2 received routine clinic visits during yr 1, and the intv during yr 2 Intv delivery: dietitian, pediatrician (if needed) Special features: small groups, family component Nutr message: NR Con grp (no true con grp; intv grp 2 serves as con grp for f/u 1 and intv grp 1 serves as con grp for f/u 2) Theoretical perspective: NR | 10 sessions (3.5 hrs each) for 1 yr Maintenance: NR | F/U 1: 1 yr after base F/U 2: 2 yrs after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Bloomfield, Calder, Chisholm, 1990 | Variables: total fat (% energy) Instrument: modification of 7-d weighed food record Statistics: Armitage and Hills methods for 2-period crossover trials were used (using Wilcoxon rank sums tests) | Total fat (mean and sd) *at f/u 1, intv grp 2 serves as con grp; at f/u 2, intv grp 1 serves as con grp Significance of effects: p for sig of intv <0.05 95% confidence limits for intv: -1.38 to 0.04 Intention to treat: NR | Fiber: n.s. | NR | NR | Diabetes knowledge: n.s. | 48
  | Base | F/U 1*
  Intv grp 1 (n NR): | 39.5 (3.8) | 39.1 (3.2)
  Intv grp 2 (n NR): | 40.0 (4.6) | 40.0 (4.2)
  | F/U 2*
  Intv grp 1 (n NR): | 39.9 (2.8)
  Intv grp 2 (n nR): | 37.8 (5.2)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
306 Campbell, Barth, Gosper, 1990 | Setting: healthcare (subjects screened and recruited by physicians) Gender: M,F Age: range NR; mean 58-59 yrs Race: NR Risk: type 2 diabetes Country: Australia | RCT subjects randomly allocated to 1of 2 intv grps | Participation rate: NR Baseline sample size: 70 (total) F/U 1 sample size: 62 (total) F/U 2 sample size: NR F/U 3 sample size: NR Retention rate: 89% (total) Comparison of drop-outs: NR | Intv grps (2 intv grps) Intv components: conventional program about diabetes, diet, excercise, and podiatry (intv grp 1) intensive program including dietary and podiatry components; application of cognitive motivational theory (visualize adverse effects, diet demonstrated by dietitian; pts devise diet plans, pts set goals and develop coping strategies) (intv grp 2) Intv delivery: NR (intv grp 1); MD, dietitian, psychologist (intv grp 2) Special features: NR Nutr message: decrease total fat and sat fat, increase complex carb and fiber (intv grp 1); decrease all fats and increase legumes (intv grp 2) Con grp (no con grp) Theoretical perspective: Motivational Theory | (Intv grp 1) 3 days (diet section was 5 hrs in length; total duration NR) (Intv grp 2) 11 wks (diet section was 13.5 hrs; total duration: 22 hrs) | F/U 1: 1 mo after base F/U 2: 3 mos after base F/U 3: 6 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Campbell, Barth, Gosper, 1990 | Variables: total fat (% energy) sat fat (g) Other variables analyzed: polyunsat fat p:s ratio Instrument: 4-d food records Statistics: ANCOVA with repeated measures design (baseline values as covariate); when sig interaction effects were evident, further ANCOVAs ascertained sig grp diffs; within grp changes over time assessed with one way ANOVA with repeated measures followed by multiple t-tests | Total fat (mean and sd) Significance of effects: p for diff b/w grps at base: 0.097 p for chng for intv grp 1 <0.001 p for chng for intv grp 2 <0.0001 p for diff b/w grps in chng: 0.004 Sat fat (mean and sd) Significance of effects: p for diffs b/w grps at base: 064 p for chng for intv grp 1 <0.001 p for chng for intv grp 2 <0.0001 p for diffs b/w grps in chng: 0.001 Intention to treat: NR | Fiber: sig intv effect | Variables: TC (mM) Instrument: fasting blood samples; TC measured by automated enzymatic method Statistics: ANCOVA with repeated measures design (baseline values as covariate); when sig interaction effects were evident, further ANCOVAs ascertained sig grp diffs; within grp changes over time assessed with one way ANOVA with repeated measures followed by multiple t-tests | TC (mean and sd) Significance of effects: p for diff b/w grps at base < 0.01 p for chng for intv grp 1: 0.42 p for chng for intv grp 2: 0.0001 p for diff b/w grps in chng: 0.007 Intention to treat: NR | NR | 56
  | Base | F/U1 | F/U2 | F/U3
  Intv grp 1 (n = 24): | 42(5) | 35(7) | NR | 37(9)
  Intv grp 2 (n = 26): | 45(5) | 29(8) | NR | 33(7)
  | Base | F/U1 | F/U2 | F/U3
  Intv grp 1 (n = 24): | 35(11) | 27(15) | NR | 28(15)
  Intv grp 2 (n = 26): | 41(18 | 21(8) | NR | 20(7)
  | Base | F/U 1
  Intv grp 1 (n = 28): | 6.5 (1.1) | 6.5 (1.4)
  Intv grp 2 (n = 29): | 7.4 (1.2) | 6.6 (1.1)
  | F/U 2 | F/U 3
  Intv grp 1 (n = 28): | 6.3 (1.2) | 6.5 (1.0)
  Intv grp 2 (n = 29): | 6.8 (1.1) | 6.6 (1.0)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
113 Insull, Henderson, Prentice, 1990 WHT | Setting: healthcare (pts pre-screened and recruited from registry in a med care facility) Gender: F Age: 45-69 Race: NR Risk: cancer | RCT subjects randomized 3:2 to intv or con grps by age stratification | Participation rate: 55% Baseline sample size Intv grp: 184 Con grp: 119 F/U 1 sample size Intv grp: 179 Con grp: 113 F/U 2 sample size Intv grp: 173 Con grp: 114 F/U 3 sample size Intv grp: 163 Con grp: 101 Retention rate* Intv grp: 89% Con grp: 85% Comparison of drop-outs: NR *retention rate refers to final f/u point | Intv grp Intv components: group counseling sessions, indiv counseling sessions, self-help materials; individualized dietary plan; self-monitor fat intake; educational tools Intv delivery: nutritionist Special features: small group Nutr message: decrease total fat (to 20% of energy), increase carb, maintain optimum use of vitamins and minerals Con grp Intv components: no dietary advice Theoretical perspective: NR | small group counseling wkly for 8 sessions, biwkly for 4 sessions, and monthly thereafter; indiv counseling at 12 wks, 12 mos, and 24 mos; total duration of intv: 24 mos Maintenance: NR | F/U 1: 6 mos post-randomization F/U 2: 12 mos post-randomization F/U 3: 24 mos post-randomization | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Insull, Henderson, Prentice, 1990 | Variables: total fat (% energy) total fat (g) sat fat (g) Other variables analyzed: monounsat fat polyunsat fat p:s ratio m:s ratio Instrument: 4-d food record Statistics: paired-sample t-test comp base vs/ f/u 1 values for intv and con grps | Total fat (% energy; mean and se) Significance of effects: p for diff b/w base and f/u 1 for intv grp <.0001 p for diff b/w base and f/u 1 for con grp n.s. p for diffs b/w grps at f/u 3 <.0001 Total fat (g; mean; sd/se NR) Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u 2 and f/u 3 sig Sat fat (g; mean; sd/se NR) Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u 2 and f/u 3 sig Intention to treat: NR | Calcium: sig. NR | Variables: TC (mmol/L) Instrument: plasma chol determinations made by local laboratories at base and f/u 1; f/u 2 and f/u 3 determinations carried out under the direction of the Nutr Coordinating Unit at Tufts Univ (TC measured at base and f/u 1 only for intv grp; measured at f/u 2 and f/u 3 for tot sample) Statistics: t-tests | TC (mean and se) Significance of effects: p for diffs b/w grps at base n.s. p for chng from base to f/u 1 for intv grp <0.002 p for diffs b/w grps at f/u 2 and f/u 3 < .01 Intention to treat: NR | NR | 65
  | Base | F/U 1
  Intv grp: | 39.1 (0.45) | 20.9 (0.44)
  [n] | [n = 184] | [n = 179]
  Con grp: | 39.0 (0.62) | 38.1 (0.72)
  [n] | [n = 119] | [n = 113]
  | F/U 2 | F/U 3
  Intv grp: | 21.6 (0.51) | 22.6 (0.55)
  [n] | [n = 173] | [n = 163]
  Con grp: | 37.3 (0.71) | 36.8 (0.79)
  [n] | [n = 114] | [n = 101]
  | Base | F/U 1 | F/U 2 | F/U 3
  Intv grp: | 75.8 | NR | 31.3 | 34.2
  [n] | [184] | | [127] | [163]
  Con grp: | 74.5 | NR | 66.2 | 66.7
  [n] | [119] | | [114] | [101]
  | Base | F/U 1 | F/U 2 | F/U 3
  Intv grp: | 26.9 | NR | 10.2 | 11.0
  [n] | [184] | | [127] | [163]
  Con grp: | 26.1 | NR | 23.2 | 22.4
  [n] | [119] | | [114] | [101]
  | Base | F/U 1 | Chng (F/U 1)
  Intv grp: | 5.74 | NR | -0.178 (0.057)
  Con grp: | NR | NR | NR
  | F/U 2 | F/U 3
  Intv grp: | 5.374 (0.072) | 5.451 (0.067)
  [n] | [n = 166] | [n = 157]
  Con grp: | 5.681 (0.098) | 5.772 (0.098)
  [n] | [n = 104] | [n = 101]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
164, 111, 007 Nordevang, Ikkala, Callmer,1990 Holm, Nordevang, Ikkala, 1990 Nordevang, Callmer, Marmur, 1992 | Setting: healthcare (recruited from post-operative pts) Gender: F Age: 50-65 yrs Race: NR Risk: Cancer Country: Sweden Some results presented by level of education | RCT subjects randomly assigned to intv or con grp | Participation rate:NR Baseline sample size Intv grp: 121 Con grp: 119 F/U sample size Intv grp: 63 Con grp: 106 Retention rate Intv grp: 52% Con grp: 89% Comparison of drop-outs:NR | Intv Grp Intv components: indiv dietary counseling, group meetings, low fat cooking courses; regular cancer treatment Intv delivery: dietitian Special features: social support, family component, food-related activities Nutr message: decrease dietary fat (to 20-25% of energy), increase carb Con Grp Intv components: no dietary advice; regular adjuvant postoperative treatment Theoretical perspective:NR | Counseling 4-6 times for first 2 mos, then every 3rd month; group meetings every 6-8 wks; total duration of intv: 2 yrs Maintenance: NR | 2 yrs from base | Variables: Fruit (g per 10 MJ) Veg (g per 10 MJ) Instrument: diet history interview, with nutrients coded from Swedish National Food Admin Database Statistics: diffs b/w intv and con grp compared using students' t-tests and ANOVA | Fruit (mean and sd) Significance of effects: no sig diffs b/w grps at base p for chng at f/u in intv grp <.01 p for chng at f/u in con grp <.01 p for diff in chng b/w grps <.01 Veg (mean and sd) Significance of effects: no sig diffs b/w grps at base p for chng at f/u in intv grp <.01 p for chng at f/u in con grp <.01 p for diff in chng b/w grps n.s. Intention to treat:NR
  | Base | F/U
  Chng
  Intv grp: | 179 (126) | NR +86
  [n] | [n = 121] | [n = 63]
  Con grp: | 165 (102) | NR +56
  [n] | [n = 119] | [n=106]
  | Base | F/U
  Chng
  Intv grp: | 174 (85) | NR +66
  [n] | [n = 121] | [n = 63]
  Con grp: | 192 (104) | NR +35
  [n] | [n = 119] | [n = 106]

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Nordevang, Ikkala, Callmer, 1990 | Variables: total fat (% energy) sat fat (% energy) beef >11% fat (g per 10 MJ) Other variables analyzed: monunsat fat polyunsat fat pork >11% fat (g per 10 MJ) butter (g per 10 MJ) sausages >11% fat cakes, biscuits margarine Instrument: diet history interview, with nutrients coded from Swedish National Food Admin. Database Statistics:diffs b/w intv and con grp compared using t-tests | Total fat (mean and range) Significance of effects: p (diff b/w grps at base) n.s. p (change in intv grp at f/u) <.01 p (change in con grp at f/u) <.01 p (diffs in chng b/w grps) <.01 Sat fat (mean and range) Significance of effects: p (diff b/w grps at base.) n.s. p (chng in intv grp at f/u) <.01 p (chng in con grp at f/u) <.01 p (diffs in chng b/w grps) <.01 Beef (mean and sd) Significance of effects: no sig diffs b/w grps at base p for chng at f/u in intv grp n.s . p for chng at f/u in con grp n.s. p for diff in chng b/w grps <.05 Intention to treat: NR | Fiber: sig intv effect Calcium: sig intv effect Cereals: sig intv effect Bread: sig intv effect Milk products: sig intv effect Rice, pasta: n.s. | NR | NR | NR | 48
  | Base | F/U
  Intv grp: | 36.9 (23.8-50.7) | NR
  [n] | [n = 121]
  Con grp: | 37.2 (20.6-62.4) | NR
  [n] | [n = 119]
  | Chng
  Intv grp (n = 63): | -12.9
  Con grp (n = 106): | -3.1
  | Base | F/U
  Intv grp: | 16.6 (9.3-25.5) | NR
  [n] | [n = 121]
  Con grp: | 16.9 (7.4-32.4) | NR
  [n] | [n = 119]
  | Chng
  Intv grp (n = 63): | -6.8
  Con grp (n = 106): | -1.9
  | Base | F/U | Chng
  Intv grp: | 13 (11) | NR | +2
  [n] | [n = 121] | | [n = 63]
  Con grp: | 13 (12) | NR | -2
  [n] | [n = 119] | | [n = 106]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
167 Ornish, Brown, Scherwitz, 1990 Lifestyle Heart Trial | Setting: healthcare (subjects recruited from hospital) Gender: M,F Age: 35-75 Race: NR Risk: CVD | RCT subjects randomly assigned to intv or con grps | Participation rate Intv grp: 53% Con grp: 42% Baseline sample size Intv grp: 28 Con grp: 20 F/U Intv grp: 22 Con grp: 19 Retention rate Intv grp: 79% Con grp: 95% Comparison of drop-outs: NR | Intv Grp Intv components: retreat; group meetings; smoking cessation; exercise classes; stress management Intv delivery: clinical psychologists Special features: support groups, small groups Nutr message: eat low fat (<10% energy) vegetarian diet Con Grp Intv components: no intv (consume usual diet); usual care Theoretical perspective: NR | 1-wk-long residential retreat; then 2 4-hr grp meetings per wk for at least 1 yr Maintenance: NR | 12 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Ornish, Brown, Scherwitz, 1990 | Variables: total fat (% energy) total fat (g) Instrument: 3-d food record, analyzed by CBORD diet analyzer Statistics: Repeated measures ANOVA | Total fat (% energy; mean and sd) Significance of effects: no sig diffs b/w grps at base p (presumably for diffs at f/u) <.0001 Total fat (g; mean and sd) Significance of effects: no sig diffs b/w grps at base p (presumably for diffs at f/u) <.0001 Intention to treat: NR | NR | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: fasting blood sample; TC measured by "Astra" enzymic assays; LDL calculated as TC - HDL plus 0.16 tg Statistics: Repeated measures ANOVA | TC (mean and sd) Significance of effects: no sig diffs b/w grps at base p (presumably for diffs at f/u): 0.0192 LDL-C ( mean and sd) Significance of effects: no sig diffs b/w grps at base p (presumably for diffs at f/u): 0.0072 Intention to treat: NR | NR | 60
  | Base | F/U
  Intv grp (n = 20-22): | 31.5 (7.6) | 6.8 (3.5)
  Con grp (n = 17-19): | 30.1 (10.7) | 29.5 (8.6)
  | Base | F/U
  Intv grp (n = 20-22): | 67.4 (18.6) | 14.0 (8.6)
  Con grp (n = 17-19): | 58.2 (25.9) | 55.2 (21.1)
  | Base | F/U
  Intv grp (n = 20-22): | 5.88 (1.29) | 4.45 (1.15)
  Con grp (n = 17-19): | 6.34 (1.02) | 6.00 (1.55)
  | | Base | F/U
  Intv grp | (n = 20-22): | 3.92 (1.25) | 2.46 (1.55)
  Con grp | (n = 17-19): | 4.32 (0.77) | 4.07 (1.17)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
099 Hanefeld, Fischer, Schmechel, 1991 Diabetes Intervention Study | Setting: healthcare (newly diagnosed type 2 diabetes pts recruited through screening) Gender: M, FAge: 30-55 yrsRace: NRRisk: type 2 diabetes Country: Germany | RCT pts randomly allocated to 1 of 2 intv grps or con grp | Participation rate:NR Baseline sample size Intv grp 1: 382 Intv grp 2: 379 Con grp: 378 F/U sample size Intv grp 1: 328 Intv grp 2: 334 Con grp: 346 Retention rate Intv grp 1: 85.9% Intv grp 2: 88.1% Con grp: 91.5% Comparison of drop-outs: NR | Intv grps (2 intv grps) Intv components: health ed included: recommendations to reduce overweight, recommendations to increase exercise, anti-smoking ed, antihypertensive drugs (if necessary); group sessions; individual discussions; written materials health ed plus placebo (intv grp 1) health ed plus clofibric acid (intv grp 2) Intv delivery: trained diabetologists Special features: NR Nutr message: reduce total fat to <35% energy, p:s ratio of 1.0, daily chol intake <300 mg, increase fiber and complex carb Con grp Intv component: regular clinical checkups; traditional diet prescribed following Medical Council for Diabetes Research recommendations Theoretical perspective: NR | Grp teachings of diet, smoking, exercise, hypertension given at beginning of yr 1, 2, 3, 4; indiv discussion on diet and exercise given spring of yr 1, 2, 3, 4; visits every 3 mos for 5 yrs to clinic for consultation Maintenance: NR | 5 yrs from base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Hanefeld, Fischer, Schmechel, 1991 | Variables: total fat (g) Other variables analyzed: p:s fat ratio Instrument: NR ("special questionnaires") Statistics: two-sided t-tests | Total fat (mean and sd) Significance of effects: p for diffs b/w grps n.s. Intention to treat: NR | NR | Variables: TC (mM) Instrument: fasting venous blood sample drawn Statistics: two-sided t-tests | TC (mean and sd) Significance of effects: p for diffs bw grps at base n.s. p for chng in intv grp 1 <0.01 (TC increased) p for chng in intv grp 2 <0.01 (TC increased) p for chng in con grp <0.01 (TC increased) p for diff b/w intv grp 1 and con grp at f/u n.s. p for diff b/w intv grp 2 and con grp at f/u n.s. Intention to treat: NR | NR | 55
  | Base | F/U
  Intv grp 1 (n NR): | NR | 107 (31)
  Intv grp 2 (n NR): | NR | 104 (30)
  Con grp (n NR): | NR | 107 (34)
  | Base | F/U
  Intv grp 1 (n NR): | 5.71 (1.20) | 6.06 (1.40)
  Intv grp 2 (n NR): | 5.62 (1.37) | 5.96 (1.41)
  Con grp (n NR): | 5.75 (1.23) | 6.22 (1.59)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
163 Nikolaus, Schlierf, Vogel, 1991 | Setting: healthcare (pts undergoing coronary angiography screened and recruited) Gender: M Age: NR Race: NR Risk: CVD Country: Germany | RCT eligible pts randomized into intv or con grp | Participation rate: NR Baseline sample size Intv grp: 18 Con grp: 27 F/U sample size Intv grp: 18 Con grp: 27 Retention rate Intv grp: 100% (presumably) Con grp: 100% (presumably) Comparison of drop-outs: NR | Intv grp Intv components: intensive dietary counseling; supervised individualized exercise; beta-blockers administered according to need Intv delivery: NR Special features: NR Nutr message: consume a diet low in fat (20% energy) and chol (<200 mg/d), consume 15% energy from protein, 65% energy from carb, reduce energy intake (for overweight subjects) Con grp Intv components: admitted to metabolic ward for 1 wk for measurement, seen at clinic at 3-mo intervals; cared for by family physicians Theoretical perspective: NR | Dietary counseling component: NR (presumably during the 3-wk hospitalization period); exercise component: 5-15 mins 6 times/d, then twice/d for 20 mins each, grp exercise sessions of 60 mins 1-2 times/wk; pts seen at clinic at 3-mo intervals; total duration of intv: 12 mos Maintenance: NR | 1 yr after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Nikolaus, Schlierf, Vogel, 1991 | Variables: total fat (g) sat fat (g) Other variables analyzed: unsat fat Instrument: 24-hr recall (1 recall every 3 mos. for intv grp; 1 recall every 6 mos. for con grp) Statistics: non-parametric testing was conducted (Mann-Whitney U test, Wilcoxon signed-rank test, Fisher's exact test); within grp parameters compared at base and f/u b/w grps at both time periods | Total fat (median and sd) Significance of effects: p for diffs b/w intv and con grp at base: 0.16 p for chng in intv grp: 0.0004 p for chng in con grp: 0.10 p for diffs b/w intv and con grp at f/u: 0.01 Sat fat (median and sd) Significance of effects: p for diffs b/w intv and con grp at base: 0.38 p for chng in intv grp: 0.0006 p for chng in con grp: 0.27 p for diff b/w intv and con grp: 0.0007 Intention to treat: NR | NR | Variables: TC (mg%) LDL-C (mg%) Instrument: NR ("determined according to established methods") Statistics: non-parametric testing was conducted (Mann-Whitney U test, Wilcoxon signed-rank test, Fisher's exact test); within grp parameters compared at base and f/u b/w grps at both time periods | TC (median and sd) Significance of effects: p for diffs b/w intv and con grp at base: n.s. p for chng in intv grp: 0.22 p for chng in con grp: 0.33 p for diffs b/w intv and con grp at f/u: n.s. LDL-C (median and sd) Significance of effects: p for diffs b/w intv and con grp at base: n.s. p for chng in intv grp: 0.91 for chng in con grp: 0.63 p for diffs b/w intv and con grp at f/u: n.s. | NR | 31
  | Base | F/U
  Intv grp (n = 18): | 111.7 (44.4) | 52.0 (23.9)
  Con grp (n = 28): | 91.5 (42.5) | 77.5 (33.6)
  | Base | F/U
  Intv grp (n = 18): | 42.5 (20.4) | 14.3 (8.1)
  Con grp (n = 28): | 35.7 (20.2) | 29.9 (16.0)
  | Base | F/U
  Intv grp (n = 18): | 242.8 (41.1) | 230.2 (29.6)
  Con grp (n = 27): | 237.7 (41.9) | 234.3 (37.5)
  | Base | F/U
  Intv grp (n = 18): | 164.3 (31.7) | 165.9 (25.5)
  Con grp (n = 27): | 163.7 (36.3) | 166.7 (31.1)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
041 Beresford, Farmer, Feingold, 1992 | Setting: healthcare (subjects recruited from their physicians) Gender: M,F Age: adults >18 Race: NR Risk:general Some analyses presented separately for subjects responsible for their own meal preparation | RCT 2 primary care clinics randomized their clinic days into intv or con designations (allocation balanced in 10-d blocks) | Participation rate Intv grp: 72% Con grp: 71% Baseline sample size Intv grp: 120 Con grp: 122 F/U sample size Intv grp: 93 Con grp: 98 Retention rate Intv grp: 78% Con grp: 80% Comparison of drop-outs: subjects lost to f/u were more likely to be Black and less educated | Intv Grp Intv components: self-help written materials (including checklist, sample food record, menus, etc.) presented by nurse; telephone call; pt visited MD as scheduled Intv delivery: RN Special features: NR Nutr message: decrease fat, increase fiber Con Grp Intv components: visited MD as scheduled Theoretical perspective: NR | Presentation of materials lasted 5 mins; 1 telephone call 10 days later Maintenance: NR | 3 mos after initial contact | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Beresford, Farmer, Feingold, 1992 | Variables: total fat (g) trim fat when eat meat(n reporting "always" or "frequently") eat poultry w/ skin (n reporting "rarely" or "never") Other variables analyzed: Use low fat milk for cooking and drinking Instrument: Semiquantitative FFQ (Willett, et al 1985); behavioral questionnaire designed to detect changes in food choices Statistics: ANCOVA (with f/u value as dep var and base value as covariate); multiple reg, adjusted for demographic covariates (grp diffs for chng were calculated) | Total fat (mean; sd/se NR) Significance of effects: no sig diffs b/w grps adj diff (95% CI) b/w grps for chng: -3.8 (-9.4, 1.9) Trim fat when eat meat (n reporting "always" or "frequently") ,BR> Significance of effects: no sig diffs b/w grps at f/u diff (95% CI) b/w grps at f/u: 8 (-4, 20) Eat poultry w/ skin (n reporting "rarely" or "never") Significance of effects: no sig diffs b/w grps at f/u diff (95% CI) b/w grps at f/u: 5 (-6, 23) Intention to treat:NR | Whole grain breakfast choices: n.s. Whole grain breads/crackers: sig intv effect | NR | NR | NR | 53
  | Base | F/U
  Intv grp (n = 93): | 66 | NR
  Con grp (n = 98): | 67 | NR
  | Base | F/U
  Intv grp (n = 91): | NR | 74
  Con grp (n = 96): | NR | 70
  | Base | F/U
  Intv grp (n = 89): | NR | 44
  Con grp (n = 94): | NR | 42

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
310 Glasgow, Toobert, Hampson, 1992 "Sixty Something..." | Setting: healthcare (pts recruited from diabetes practices, advertisements) Gender: M,F Age: >60 yrs Race: NR Risk: type 2 diabetes | RCT subjects "blocked" on type of diabetes med and randomly assigned to "immediate" or "delayed" intv | Participation rate: NR Baseline sample size Intv grp 1: 52 Intv grp 2: 50 F/U sample size Intv grp 1: 52 Intv grp 2: 49 Retention rate Intv grp 1: 100% Intv grp 2: 98% Comparison of drop-outs:NR | Intv components: meetings; focus on self-care; individualized plans; problem-solving; group discussion; worsheets; blood glucose monitoring; exercise sessions -intv grp 1 received intv immediately (before f/u 1 and f/u 2 data collection) -intv grp 2 received intv after f/u 1 data collection but before f/u 2 data collection Intv delivery: psychologists, RD, ACSM certified exercise leaders, other educators Special features: small group, goal setting Nutr message: reduce energy intake, fats; increase fiber Con grp (no con grp) intv grp 2 serves as a con grp for f/u 1; no true con grp for f/u 2 Theoretical perspective: Social Learning Theory | 10 sessions total; met wkly for 8 wks, then 2 meetings held at 2-wk intervals; total duration of intv: 3 mos Maintenance: NR | F/U 1: 3 mos after base F/U 2: 6 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Glasgow, Toobert, Hampson, 1992 | Variables: total fat (% energy) Instruments*:diet history portion of the Block/NCI Health Habits and History Questionnaire (analyzed by NCI software) 3-d food record (2 wkdays and 1 wkend day) (analyzed by Food Processor II Nutr and Dietary Analysis System) Statistics: paired-comparison t-tests (to evaluate chng over time within each grp), with ANCOVA (to compare tx conditions), controlling for base value *results presented separately for each dietary instrument | Total fat (mean and sd) Results of Block/NCI questionnaire Significance of effects: p for diffs b/w grps at base n.s. chng from base to f/u 1 for intv grp 1 "sig" chng from base to f/u 1 for intv grp 2 n.s. sig b/w tx condition diff on ANCOVA at f/u 1 chng from f/u 1 to f/u 2 for intv grp1 n.s. chng from f/u 1 to f/u 2 for intv grp 2 sig Results of 3-d food records Significance of effects: p for diffs b/w grps at base n.s. chng from base to f/u 1 for intv grp 1 "sig" chng from base to f/u 1 for intv grp 2 n.s. sig b/w tx condition diff on ANCOVA at f/u 1 chng from f/u 1 to f/u 2 for intv grp 1 sig chng from f/u 1 to f/u 2 for intv grp 2 sig Intention to treat: NR | Fiber: n.s. | NR | NR | Diet self-efficacy (diabetes-specific): n.s. | 61
  | Base | F/U 1
  Intv grp 1 (n NR): | 39.5 (8.9) | 35.9 (7.6)
  Intv grp 2 (n NR): | 41.4 (8.5) | 41.7 (8.0)
  | F/U 2
  Int grp 1 (n NR): | 37.0 (8.3)
  Intv grp 2 (n NR): | 36.4 (7.5)
  | Base | F/U 1
  Intv grp 1 (n NR): | 33.2 (7.2) | 29.0 (6.7)
  Intv grp 2 (n NR): | 34.5 (8.1) | 33.6 (6.0)
  | F/U 2
  Int grp 1 (n NR): | 29.6 (8.5)
  Intv grp 2 (n NR): | 29.2 (6.1)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
056 Kristal, White, Shattuck, 1992 WHT | Setting: healthcare (random sample of WHT subjects was selected) Gender: F Age: 45-69 yrs Race: W Risk: Cancer | RCT subjects selected at random for intv and con grp from 1,600 eligible WHT participants at 3 clinical sites | Participation rate: NR Baseline sample size Intv grp: 525 Con grp: 525 F/U sample size: Intv grp: 448 Con grp: 456 Retention rate Intv grp: 85% Con grp: 88% Comparison of drop-outs: NR | Intv Grp Intv components: group intv sessions, nutr info and behaviors necessary to adopt a low fat eating pattern Intv delivery: nutritionist Special features: NR Nutr message: reduce fat intake to < 20% energy, increase carb intake, maintain adequate intakes of minerals and vitamins Con Grp Intv components: encouraged to follow usual diet Theoretical perspective: NR | Total duration of intv: 18 months Maintenance: NR | an average of 1 year after completion of intv | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Kristal, White, Shattuck, 1992 | Variables: total fat (g) summary scale of fat-related dietary habits (higher scores - less favorable fat beh) avoid fat as flavoring subscale (higher scores - less favorable fat beh) Other variables analyzed: modification subscale replacement subscale avoid meat subscale all individual fat-related dietary habits (26 items) individual low fat intv tools (10 items) (complete data NR for): total fat (% energy) added fat from cooking/table fats fat from dairy fat from red meat fat from poultry/fish fat from other food groups Instrument: semi-quantitative FFQ (Willett FFQ and NCI/Block FFQ) Statistics: paired t-tests to test change in dietary outcomes; two-sample t-tests to test diffs b/w intv and con grps at f/u | Total fat (mean; sd/se NR) Significance of effects: p for chng in intv grp <0.0002 p for chng in con grp < 0.001 Summary fat-related dietary habits scale (mean; sd/se NR) Significance of effects: p for chng in intv grp <.0001 p for diff b/w intv and con grp at f/u <.0001 Avoid fat as flavoring subscale of fat-related dietary habits scale (mean; sd/se NR) Significance of effects: p for chng in intv grp <.0001 p for diff b/w intv and con grp at f/u <.0001 | NR | NR | NR | Sig intv effect for practice of all 10 low-fat intv tools, including: -count fat grams -budget fat over wk -restrict restaurant foods to those low in fat -restrict foods at friends' to those low in fat -use low-fat cookbooks -read articles on low-fat meals -read food labels -eat low-fat dinner -eat low-fat lunch -eat low-fat breakfast Note: Another article (# 085) considering behavioral and experiential predictors of long-term maintenance of the WHT diet found: -feelings of food deprivation: sig effect -time and money costs: sig effect -feeling of wellness: n.s. -development of distaste: n.s. -inconvenience: n.s. -inconvenience for family: n.s. | 51
  | During study | F/U
  Intv grp (n = 448?): | 37.8 | 41.0
  Con grp (n = 456?): | 65.0 | 57.5
  Chng
  Intv grp (n = 448?): | +3.2
  Con grp (n = 456?): | -7.5
  | During study | F/U
  Intv grp (n = 448?): | 1.77 | 1.95
  Con grp (n = 456?): | NR | 2.36
  | "During study" | F/U
  Intv grp (n = 448?): | 1.77 | 2.01
  Con grp (n = 456?): | NR | 2.59

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
214 White, Shattuck, Kristal, 1992 WHT | Setting: healthcare (subjects recruited from 1650 eligible WHT participants) Gender: F Age: 45-69 Race: 97% W Risk: cancer Analyses presented separately for "Vanguard phase" and '"full scale phase" | RCT participants were randomly assigned to intv or con grp by computerized randomization | Participation rate: NR Baseline sample size Intv grp: 525 Con grp: 525 F/U sample size Intv grp: 448 Con grp: 460 Retention rate Intv grp: 85% Con grp: 88% Comparison of drop-outs: non-responders were less likely to report diet maintenance, but the sig of diffs was NR | Intv Grp Intv components: ed and counseling sessions in small groups; subjects monitored fat intake with fat gram counter; behavior skills taught Intv delivery: nutritionist Special features: small groups, goal setting Nutr message: decrease fat to 20% energy Con Grp Intv components: encouraged to follow customary diet Theoretical perspective: NR | (Vanguard phase): met wkly for 8 sessions, every other wk for 8 sessions, monthly for 12 sessions, and every other mo thereafter, during the ~ 3 yrs of intv (Full-Scale phase): 6 wkly sessions, followed by monthly sessions, during the ~1 year of intv Maintenance: NR | ~ 1 yr after completion of intv | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
White, Shattuck, Kristal, 1992 | Variables:total fat (% energy) total fat (g) sat fat (g) Other variables analyzed: polyunsat fat monounsat fat Instrument: semi-quantitative 100-item FFQ (modified Block/NCI) Statistics: diffs b/w intv and con grps determined using student t-test | Total fat (% energy; mean and sd) Significance of effects p for diff b/w grps at base: .158 p for diff b/w grps at f/u: .001 Total fat (g; mean and sd) Significance of effects p for diff b/w grps at f/u = .001 Sat fat (g; mean and sd) Baseline: NR F/U Intv grp (n = 448): 12.3 (6.1) Con grp (n = 457): 17.1 (9.6) Significance of effects p for diff b/w grps at f/u = .001 Intention to treat: NR | Fiber: sig intv effect Calcium: n.s. | Variables: TC (mmol/L) Instrument: blood drawn (fasting NR) and analyzed at Northwest Lipid Research Center Statistics: diffs b/w intv and con grps determined using student t-test | TC (mean and sd) Significance of effects p for diff b/w grps at f/u: 0.279 Intention to treat: NR | Note: Another article (# 085) considering behavioral and experiential predictors of long-term maintenance of the WHT diet found: -feelings of food deprivation: sig effect -time and money costs: sig effect -feeling of wellness: n.s. -development of distaste: n.s. -inconvenience: n.s. -inconvenience for family: n.s. | 69
  | Base | F/U
  Intv grp: | 40.0 | 27.7 (8.4)
  [n] | [n = 446] | [n = 448]
  Con grp: | 39.2 | 35.1 (8.6)
  [n] | [n = 137] | [n = 457]
  | Base | F/U
  Intv grp (n = 448): | NR | 36.9 (17.7)
  Con grp (n = 457): | NR | 51.4 (27.7)
  | Base | F/U
  Intv grp (n = 202): | NR | 5.53 (0.96)
  Con grp (n = 211): | NR | 5.63 (1.03)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
054 Chlebowski, Blackburn, Buzzard, 1993 WINS (Women's Intervention Nutrition Study) | Setting: healthcare (pts recruited from oncologists) Gender: F Age: >50 yrs Race: NR Risk: Cancer | RCT Subjects randomized into intv or con grp | Participation rate: 96% (total) Baseline sample size:Intv grp: 143 Con grp: 147 F/U sample size: Intv grp: 96 Con grp: 100 Retention rate: Intv grp: 67% Con grp: 68% Comparison of drop-outs: NR | Intv Grp Intv components: individualized instruction, establishing fat intake goals, monitoring progress through tools (fat counter, guide, score booklet); adjuvant cancer treatment Intv delivery: RD Special features: NR Nutr message: decrease fat (<20% of total energy) Con Grp Intv components: minimal nutr counseling, adjuvant cancer treatment Theoretical perspective: Social Learning Theory | 4 biwkly nutr visits of 1 hr in length (more visits if deemed necessary); then, monthly visits through 8 mos, bimonthly visits through 12 mos, and quarterly visits until 24 mos Maintenance: NR | 6 mos after baseline | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Chlebowski, Blackburn, Buzzard, 1993 | Variables: total fat (%energy) total fat (g) sat fat (% energy) Other variables analyzed:monounsat fats polyunsat fats Instrument: 4-d food record analyzed using Nutr Coordinating Center system Statistics: compared diffs b/w grps at f/u | Total fat (% energy; mean and sd) Significance of effects: p for diff in chng b/w grps <0.001 Total fat (g; mean and sd) Significance of effects: p for diff in chng b/w grps < 0.001 Sat fat (% energy; mean and sd) Significance of effects: p for diff in chng b/w grps <0.001 Intention to treat: NR | Fiber: n.s. | Variables: TC (mg/dL) Instrument: fasting blood sample, enzymatic assay used to determine TC levels Statistics: diff in chng b/w grps from baseline to f/u | TC (mean and sd) Significance of effects: p (for diff in change) n.s. Intention to treat: NR | NR | 68
  | Base | F/U
  Intv grp (n = 96): | 33.4 (6.0) | 20.5 (6.2)
  Con grp (n = 100): | 34.3 (5.6) | 32.1 (7.3)
  | Base | F/U
  Intv grp (n = 96): | 66 (23) | 33 (14)
  Con grp (n = 100): | 66 (20) | 56 (20)
  | Base | F/U
  Intv grp (n = 96): | 11.3 (4.5) | 6.8 (3.0)
  Con grp (n = 100): | 11.4 (4.2) | 10.2 (4.3)
  | Base | F/U | Chng
  Intv grp (n = 143): | 214 (39) | NR | - .02
  Con grp (n = 147): | 209 (38) | NR | 5.53

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
098 Haber, Lacy, 1993 | Setting: healthcare (subjects recruited from a geriatric clinic) Gender: M,F Age: 55-94 yrs Race: NR (91% W) Risk: experiencing "any health problem" | RCT subjects screened and and randomly assigned to intv or con grp | Participation rate: NR Baseline sample size Intv grp: 32 Con grp: 32 F/U sample size Intv grp: 29 Con grp: 28 Retention rate: 89% (total) Comparison of drop-outs: NR | Intv grp Intv components: lectures, demonstrations of health behavior, instructional materials about nutr, exercise, stress management, medication usage, and healthy heart; peer support group (health behavior contracts); wellness prescription by physician Intv delivery: multidisciplinary team of health professionals; physicians; student nurses Special features: social support Nutr message: reduce fat, salt, and sweets; increase fiber Con grp Intv components: same lectures, demonstrations of health behavior, instructional materials about nutr, exercise, stress management, med usage, and healthy heart as intv grp, but no peer support grp or wellness prescription Theoretical perspective: Andragogy Theory | 10 wkly lectures plus 30-min support grp after each lecture; tot duration of intv: 10 wks Maintenance: NR | 10 wks after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Haber, Lacy, 1993 | Variables: "fats" (n of subjects limiting fats "all the time," "most of the time," "sometimes," or "never") Instrument: adapted from Geriatric Health Risk Appraisal instrument; includes the adoption of concrete, definite, and ongoing changes in the reduction of fats; respondents provide names of food products, amt consumed, and freq of eating; (n of items NR) Statistics: stratified sample by base values, then cross-tabulated eating beh chng by tx condition; used Mantel-Haenzel OR as a summary measure of tx effect, net of pre-test diff | Fats (n adopting chng at f/u; no other statistics reported) Subjects who limited fats "all the time" at base Subjects who limited fats "most of the time" at base Subjects who limited fats "sometimes" at base Subjects who "never" limited fats at base Significance of effects: OR and 90% CI for intv grp vs. con grp at f/u: 2.12 (0.757; 5.64); p = 0.14 | Fiber: sig intv effect | NR | NR | NR | 40
  | Base | F/U
  Intv grp (n = 29): | n/a | 3
  Con grp (n = 28): | n/a | 2
  | Base | F/U
  Intv grp (n = 29): | n/a | 8
  Con grp (n = 28): | n/a | 6
  | Base | F/U
  Intv grp (n = 29): | n/a | 5
  Con grp (n = 28): | n/a | 2
  | Base | F/U
  Intv grp (n = 29): | n/a | 1
  Con grp (n = 28): | n/a | 0

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
316 Laitinen, Ahola, Sarkkinen, 1993 | Setting: healthcare (newly diagnosed type 2 diabetes pts referred by physicians) Gender: M,F Age: 40-64 yrs Race: NR Risk: type 2 diabetes Country: Finland some analyses separate by gender | RCT all pts recruited for participation received basic diabetes ed for 3 mos, then were randomly separated into intv or con grps | Participation rate: NR Baseline sample size Intv grp: 40 Con grp: 46 F/U sample size Intv grp: 40 Con grp: 46 Retention rate Intv grp: 100% (presumably) Con grp: 100% (presumably) Comparison of drop-outs: NR | Intv grp Intv components: received the basic diabetes ed for 3 mos (before group assignment); 6 visits to outpatient clinic; individual dietary ed (set short-term goals); set goals for weight reduction; group session on food preparation Intv delivery: clinical nutritionist, MD, nurse Special features: NR Nutr message: restrict total fat (< 30% energy), sat fat (<10% energy), chol, increase intake of unrefined carbs Con grp Intv components: received the basic diabetes ed for 3 mos (before grp assignment); advised to increase exercise; advised by nurse to restrict intake of energy, fat, and chol; advised to increase unsat fat and unrefined carbs; received usual ed at health centers; 2 visits to outpatient clinic Theoretical perspective: NR | 3 mos of basic education before randomization; duration of diet ed NR; total duration of intv: 12 mos Maintenance: NR | 12 mos after randomization | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Laitinen, Ahola, Sarkkinen, 1993 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: monounsat fat polyunsat fat Instrument: 3-d food records Statistics: paired t-test | Total fat (mean and sd) Significance of effects: p for chng in intv grp n.s. p for chng in con grp n.s. Sat fat (mean and sd) Significance of effects: p for chng in intv grp <0.05 p for chng in con grp n.s. Intention to treat: NR | Fiber: n.s. | Variables: TC (mmol/L) Instrument: fasting blood samples; chol measured by enzymatic methods Statistics: multivariate analysis of variance for a repeated measures design | TC (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for intv effect n.s. Intention to treat: NR | NR | 43
  | Base | F/U
  Intv grp (n = 38): | 35 (7) | 34 (9)
  Con grp (n = 46): | 35 (7) | 37 (7)
  | Base | F/U
  Intv grp (n = 38): | 15 (4) | 13 (5)
  Con grp (n = 46): | 15 (4) | 15 (4)
  | Base | F/U 1
  Intv grp (n = 40): | 6.1 (1.2) | 6.0 (1.0)
  Con grp (n = 46): | 6.3 (1.0) | 6.4 (1.0)
  Chng (mean and 95% CI) | Intv grp (n = 40): -0.1 (-0.3; +0.1) | Con grp (n = 46): +0.1 (-0.2; +0.4)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
059 Cupples, McKnight, 1994 | Setting: healthcare (pts recruited from 18 general practices) Gender: M,F Age: <75 yrs Race: NR Risk: CVD Country: Northern Ireland | RCT subjects identified from GPs and randomly assigned to intv or con grp | Participation rate: NR Baseline sample size Intv grp: 342 Con grp: 346 F/U sample size Intv grp: 317 Con grp: 300 Retention rate Intv grp: 93% Con grp: 87% Comparison of drop-outs: NR | Intv grp Intv components: personal health ed (advice about CVD risk factors) Intv delivery: "trained health visitor" Special features: NR Nutr message: NR Con grp Intv components: no intv Theoretical perspective: NR | Health ed given every 4 mos; total duration of intv NR Maintenance: NR | 2 yrs after base | Variables: green veg (n of subjects classified as "improved," "deteriorated," or "no chng") Instrument: FFQ Statistics: chi-square analysis | Veg (n of subjects classified as "improved," "deteriorated," or "no chng" in eating habits b/w base and f/u; sd/se NR) Significance of effects: p for chi-square: 0.002 Intention to treat: NR
  | "improved" | "no chng"Intv grp (n = 317): | 139 | 146
  Con grp (n = 300): | 113 | 122
  | "deteriorated" | Intv grp (n = 317): | 32
  Con grp (n = 300): | 65

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Cupples, McKnight, 1994 | Variables: sat fat (n of subjects classified as "improved," "deteriorated," or "no chng") fried food (n of subjects classified as "improved," "deteriorated," or "no chng") biscuits/sweets (n of subjects classified as "improved," "deteriorated," or "no chng") Instrument: NR ("questionnaire to determine intake of various foods") Statistics: chi-square analysis | Sat fat (n of subjects classified as "improved," "deteriorated," or "no change" in eating habits b/w base and f/u; sd/se NR) Significance of effects: p for chi-square: 0.013 Fried food (n of subjects classified as "improved," "deteriorated," or "no change" in eating habits b/w base and f/u; sd/se NR) Significance of effects: p for chi-square: 0.045 Biscuits/sweets (n of subjects classified as "improved," "deteriorated," or "no change" in eating habits b/w base and f/u; sd/se NR) Significance of effects: p for chi-square: 0.0001 Intention to treat:NR | Fiber: sig intv effect | Variables:TC (mmol/L) Instrument: blood sample taken (fasting status NR) Statistics: ANOVA | TC (mean; sd/se NR) Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u n.s. p for chng in intv grp: 0.003 p for chng in con grp: 0.439 p for diffs in chng b/w grps: 0.06 | NR | 60
  | "improved" | "no chng"
  Intv grp (n = 317): | 33 | 250
  Con grp (n = 300): | 25 | 220
  | "deteriorated"
  Intv grp (n = 317): | 34
  Con grp (n = 300): | 55
  | "improved" | "no chng"
  Intv grp (n = 317): | 85 | 168
  Con grp (n = 300): | 79 | 127
  | "deteriorated"
  Intv grp (n = 317): | 64
  Con grp (n = 300): | 94
  | "improved" | "no chng"
  Intv grp (n = 317): | 116 | 134
  Con grp (n = 300): | 79 | 128
  | "Deteriorated"
  Intv grp (n = 317): | 67
  Con grp (n = 300): | 103
  | Base | F/U
  Intv grp (n = 313): | 6.20 | 6.05
  Con grp (n = 285): | 6.12 | 6.08
  | Chng(95%CI) | % reduction
  Intv grp (n = 313): | 0.15(0.05;0.25) | 2.4
  Con grp (n = 285): | 0.03 (-0.91;0.97) | 0.5

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
066 DeBusk, Miller, Superko, 1994 | Setting: healthcare (MI hospital pts recruited) Gender: M,F Age: range NR; mean <70 yrs Race: NR (76-78% W) Risk: CVD | RCT subjects randomly assigned to intv or con grp | Participation rate: 65%(total) Baseline sample size Intv grp: 293 Con grp: 292 F/U 3 sample size* Intv grp: ~ 260 Con grp: ~ 265 F/U 5 sample size* Intv grp: ~ 248 Con grp:~ 258 Retention rate** Intv grp: 88.7% Con grp: 90.8% Comparison of drop-outs: NR *sample sizes NR for f/u 1, 2, and 4 **retention rates indicate retention at f/u 3 | Intv grp Intv component: usual care (see "on grp" below) plus nurse telephone contacts, mailed computer-generated progress reports, physical activity prescription, lipid-lowering therapy (if needed), smoking cessation counseling, computer-based system providing nutr counseling, nutr workbook Intv delivery: nurse, physician; nutritionist Special features: goal setting Nutr message: used National Chol Ed Program Step 2 diet (low in chol and sat fat) Con grp Intv components: usual medical care (physician counseling on smoking cessation; nutr counseling on dietary change; physician-managed lipid lowering drug therapy; group exercise rehabilitation available) Theoretical perspective: Social Learning Theory | Maximum of 14 nurse-initiated phone contacts, 8 patient visits to laboratory, and 4 patient visits to nurse case manager; intv involved ~ 9 hrs per pt during the first yr (smoking cessation: 2 hrs; dietary management: 1.5 hrs; drug therapy: 2.5 hrs; exercise training: 1 hr; liaison with primary care physician and other hospital personnel: 1 hr; consultation with staff: 1 hr); total duration of intv NR Maintenance: NR | F/U 1: 6 wks after base F/U 2: 11 wks after base F/U 3: 26 wks after base F/U 4: 36 wks after base F/U 5: 52 wks after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
DeBusk, Miller, Superko, 1994 | Variables: Chol and Sat Fat Index Instrument: FFQ (n items NR) scored using the Chol and Sat Fat Index developed by Connor et al. (1989) -- calculations based on wkly food intakes. Statistics: NR | Chol and Sat Fat Index (mean and sd) Significance of effects: p for chng from base to f/u 1 for intv grp <0.001 p for chng from base to f/u 3 for con grp <0.001 Intention to treat: "analysis based on intention to treat" (all available data for each participant used) | NR | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: blood samples taken (fasting status NR); LDL-C measured by Friedewald method for indirect beta quantitation of lipoproteins; plasma samples collected according to Lipid Research Clinics methodology Statistics: NR | TC (mean and sd) Significance of effects: p for chng from base to f/u 1 for intv grp:0.002 p for chng from base to f/u 1 for con grp: 0.002 p for diff in chng b/w intv and con grp <0.001 LDL-C (mean and sd) Significance of effects: p for diff in chng b/w intv and con grp <0.001 Intention to treat: "analysis based on intention to treat" (all available data for each participant used) | NR | 59
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 322(206) | 121(90) | 125(77)
  Con grp (n NR): | 307(255) | NR | NR
  | F/U 3 | F/U 4 | F/U 5
  Intv grp (n NR): | 123(87) | 117(72) | 124(84)
  Con grp (n NR): | 149(95) | NR | 140(83)
  | Base | F/U 1 | F/U 2
  Intv grp: | 5.33(1.37) | 5.60(1.09) | NR
  [n] | [n NR] | [n = 268]
  Con grp: | 5.05(1.46) | 5.50(1.35) | NR
  [n] | [n NR] | [n = 49]
  | F/U 3 | F/U 4 | F/U 5
  Intv grp: | 4.85(0.94) | NR | 4.78(0.83)
  [n] | [n = 253] | | [n = 243]
  Con grp: | 5.45(0.99) | NR | 5.41(1.05)
  [n] | [n = 248] | | [n = 244]
  | Slope | (95% CI)
  Intv grp (n = 269): | -0.64 | (-0.79; -0.50)
  Con grp (n = 257): | -0.09 | (-0.25; 0.07)
  | Base | F/U 1 | F/U 2
  Intv grp: | NR | 3.63(0.98) | NR
  [n] | [n NR] | [n = 254]
  Con grp: | NR | 3.52(0.81) | NR
  [n] | [n NR] | [n = 47]
  | F/U 3 | F/U 4 | F/U 5
  Intv grp: | 2.85(0.83) | NR | 2.77(0.69)
  [n] | [n = 252] | | [n = 243]
  Con grp: | 3.49(0.90) | NR | 3.41(0.90)
  [n] | [n = 248] | | [n = 244]
  | Slope (95% CI)
  Intv grp (n = 269): | -0.65 (-0.79; -0.50)
  Con grp (n = 257): | -0.14 (0.29; 0.00)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
108 Heller, Walker, Boyle, 1994 | Setting: healthcare (siblings and offspring of heart attack victims registered in MONICA project recruited) Gender: M,F Age: 18-70 yrs Race: NR Risk: CVD (family members had CVD) Country: Wales | RCT Adult offspring or siblings of heart attack victims were identified and allocated to 1 of 2 intv grps or a con grp (offspring/sibs of heart attack victims who were participating in a secondary study were assigned to the tx cond of the "victim"; offspring/sibs of victims not participating in the secondary study were randomly assigned to 1 of the 3 conditions) | Participation rate: 36% (total) Baseline sample size Intv grp 1: 109 Intv grp 2: 120 Con grp: 113 F/U sample size Intv grp 1: 64 Intv grp 2: 85 Con grp: 87 Retention rate Intv grp 1: 59% Intv grp 2: 71% Con grp: 77% Comparison of drop-outs: drop-outs more likely to be younger, smokers, and offspring (rather than siblings of heart attack victims) | Intv grps (2 intv grps) Intv component: mailed ed materials (including a quiz, behavior contract, newsletter, NHF booklet) (intv grp 1) advised to make contact with GP, info letter and form for GP to complete (intv grp 2) Intv delivery: n/a for intv grp 1 (mailed materials only); GP (intv grp 2) Special features: family component Nutr message: decrease fat (intv grp 1); NR for intv grp 2 Con grp Intv components: no intv Theoretical perspective: NR | 4 mail "contacts" at intervals of 2-4 wks over 6 mos (intv grp 1); n/a for intv grp 2 (referred to GP for advice) Maintenance comp: NR | 6 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Heller, Walker, Boyle, 1994 | Variables: fat score (logged) Instrument: short questionnaire assessment of dietary fat intake Statistics*: ANCOVA (for baseline diffs, with tx grp and sex as factors, and age as a covariate); repeated measures ANOVA (for chngs in fat from base to f/u) with family as unit of analysis; Wald chi-square statistic (to test for diffs in chngs among the 3 study grps) *2 outliers excluded from con grp for base comparisons; values more than 2 sd's from mean excluded in analysis of chng (n = 3) | Fat score (mean and 95% CI; sd/se NR) Significance of effects: p for Wald chi-square test <0.001 chng in intv grp 1 sig diff from chng in intv grp 2 and con grp Intention to treat: NR | NR | Variables: TC (mmol/L) Instrument: subjects asked to have a blood chol measurement at a lab, and have the lab send results to study team Statistics*: ANCOVA (for baseline diffs, with tx grp and sex as factors, and age as a covariate); repeated measures ANOVA (for chngs in TC from base to f/u) with family as unit of analysis; Wald chi-square statistic (to test for diffs in chngs among the 3 study grps) *TC values more than 3 sd's from mean were excluded for base comparisons (n = 6) and analyses of chng scores (n = 2) | TC (mean and 95% CI; sd/se NR) Significance of effects: p for Wald Chi-square test = 0.73 chng n.s. for any of the 3 grps Intention to treat: NR | NR | 43
  | Base F/U | Chng
  Intv grp 1 (n = 63): NR | NR | -29.3(-41.8;-16.8)
  Intv grp 2 (n = 83): NR | NR | 1.4(-9.5;12.2)
  Con grp (n = 86): NR | NR | 10.2(-0.5;20.8)
  | Base | F/U | Chng
  Intv grp 1 (n = 34): NR | NR | -0.1 (-0.3; 0.1)
  Intv grp 2 (n = 34): NR | NR | -0.2 (-0.4;0.05)
  Con grp (n = 37): NR | NR | -0.1 (-0.3; 0.1)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
143 McKeown-Eyssen, Bright-See, Bruce, et al., 1994 | Setting: healthcare (recruited for polypectomy at hospitals) Gender: M,F Age: <85 yrs Race: NR Risk: cancer Country: Canada Analyses separate for males and females | RCT subjects randomly assigned to intv or con grps | Participation rate: 87% (total) Baseline sample size: Intv grp: 99 Con grp: 102 F/U 1 sample size: Intv grp: 78 Con grp: 87 F/U 2 sample size: Intv grp: 54 Con grp: 68 Retention rate: Intv grp: 79% Con grp: 85% Comparison of drop-outs: NR | Intv Grp Intv components: dietary counseling, pre-packaged high fiber snack Intv delivery: nutritionist Special features: NR Nutr message: consume <50 g of fat or 20% of calories from fat and > 50 g of dietary fiber Con Grp Intv components: follow normal Western diet, dietary counseling, pre-packaged low fiber snack Theoretical perspective: NR | Counseling once a mo for 12 mos Maintenance: NR | F/U 1: 12 mos from base F/U 2: 24 mos from base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
McKeown-Eyssen, Bright-See, Bruce,1994 | Variables total fat (%energy) total fat (g) Instrument: 4-d food record, analyzed using CANDAT nutr calculation system Statistics: NR | Total fat (% energy; mean and sd) Significance of effects: p (diff at base) n.s. p (diff at f/u 1) <.01 p (diff at f/u 2) <.01 Significance of effects: p (diff at base) n.s. p (diff at f/u 1) <.01 p (diff at f/u 2) <.01 Total fat (g; mean and sd) Significance of effects: p (diff at base) n.s. p (diff at f/u 1) <.01 p (diff at f/u 2) <.01 Significance of effects: p (diff at base) n.s. p (diff at f/u 1) <.01 p (diff at f/u 2) <.01 Intention to treat: dietary outcomes NR | Fiber: sig intv effect Calcium: sig intv effect (in men only) | TC measured from fasting blood samples using standardized methods | TC measured, but statistics NR | NR | 55
  Men
  | Base | F/U 1 | F/U 2
  Intv grp: | 33.1 (7.3) | 22.9 (5.9) | 24.3 (5.2)
  [n] | [n = 39] | [n = 38] | [n = 34]
  Con grp: | 34.3 (6.1) | 32.2 (6.3) | 31.6 (5.9)
  [n] | [n = 44] | [n = 41] | [n = 37]
  Women
  | Base | F/U 1 | F/U 2
  Intv grp: | 35.1 (5.8) | 22.6 (7.9) | 24.4(8.2)
  [n] | [n = 26] | [n = 23] | [n = 20]
  Con grp: | 32.8(7.4) | 32.2(5.7) | 31.3(6.5)
  [n] | [n = 33] | [n = 30] | [n = 31]
  Men
  | Base | F/U 1 | F/U 2
  Intv grp: | 94.6(32.0) | 53.0(19.4) | 57.9(19.4)
  [n] | [n = 39] | [n = 38] | [n = 34]
  Con grp: | 85.1(26.7) | 80.0(37.3) | 81.2(27.0)
  [n] | [n = 44] | [n = 41] | [n = 37]
  Women
  | Base | F/U 1 | F/U 2
  Intv grp: | 69.5(25.7) | 37.1(15.9) | 38.9(14.7)
  [n] | [n = 26] | [n = 23] | [n = 20]
  Con grp: | 60.4(23.4) | 61.7(19.3) | 60.3(26.2)
  [n] | [n = 33] | [n = 30] | [n = 31]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
178 Rankinen, Rauramaa, Vaisanen, 1994 | Setting: healthcare (subjects recruited and screened from representative pop) Gender: M Age: 51-53 yrs Race: NR Risk: General Country: Finland | RCT Subjects screened and randomly allocated to 1 of 5 intv grps or a con grp | Participation rate: NR Baseline sample size: Intv grp 1: 19 Intv grp 2: 19 Con grp: 18(other non-diet intv grps: n = 55) F/U sample size: Intv grp 1: 19 Intv grp 2: 19 Con grp: 18 (other non-diet intv grps: n = 55) Retention rate: 93% (total) Comparison of drop-outs: NR | Intv Grp (2 intv grps)* Intv components: nutr advice only (intv grp 1) -subjects given nutr message below and provided with rapeseed oil and margarine nutr advice and exercise (int grp 2) -subjects given nutr message below and provided with rapeseed oil and margarine -exercise training 4 times/wk Intv delivery: NR Special features: NR Nutr message: decrease sat fat, increase unsat fat, increase fruit, veg, whole grain Con Grp Intv components: NR Theoretical perspective: NR *the study included 5 intv grps, but 3 of the intv grps received only an exercise intv (no dietary intv), and are not presented in this report | Duration of nutr counseling: NR; exercise training: 4 times/wk for around 50 mins (presumably for 6 mos); tot duration of intv; 6 mos Maintenance: NR | 6 mos from base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Rankinen, Rauramaa, Vaisanen, 1994 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: monounsat fat polyunsat fat Instrument: 7-d food records analyzed using UNIDAP Statistics: ANCOVA to test diffs b/w grps | Total fat (mean and 95% CI; sd/se NR) Sat fat (mean and 95% CI) | NR | NR | NR | NR | 38
  | Base | F/U | Chng
  Intv grp 1: | 36.0(33.7;38.4) | NR | 0.7(-2.2;3.5)
  [n] | [n = 19] | | [n = 19]
  Intv grp 2: | 36.9(34.1;39.6) | NR | -4.1(-6.1;-2.0)
  [n] | [n = 19] | | [n = 19]
  Con grp: | 35.8(33.1;38.6) | NR | 0.4(-1.9;2.6)
  [n] | [n = 18] | | [n = 18]
  Significance of effects: p for diffs b/w grps at base n.s.
  | Base | F/U | Chng
  Intv grp 1: | 16.2(14.6;17.7) | NR | -2.2(-3.9;-0.5)
  [n] | [n = 19] | | [n = 19]
  Intv grp 2: | 15.7(14.1;17.3) | NR | -3.0(-3.9;-2.2)
  [n] | [n = 19] | | [n = 19]
  Con grp: | 15.3(13.6;17.0) | NR | -0.1(-1.5;1.3)
  [n] | [n = 18] | | [n = 18]
  Significance of effects: p for diffs b/w grps at base n.s. Intention to treat: NR

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
076, 083 Shannon, Tershakovec, Martel, 1994 Tershakovec, Shannon, Achterberg, 1998 Children's Health Project | Setting: healthcare/home (subjects identified through chol screening program in pediatric clinics) Gender: M,F Age: 4-10 yrs Race: B,W,O Risk: CVD and general | RCT "at risk" children randomized (using a permuted blocks within strata design, stratifying on age and gender) to intv grp 1, intv grp 2, or con grp 1; "not at risk" children were assigned to con grp 2 using sequential tx assignment adjusting for age, sex, practice, and season | Participation rate: 97% (total) Baseline sample size Intv grp 1: 88 Intv grp 2: 86 Con grp 1: 87 Con grp 2: 81 F/U 1 sample size Intv grp 1: 75 Intv grp 2: 78 Con grp 1: 78 Con grp 2: 76 F/U 2 sample size Intv grp 1: 65 Intv grp 2: 73 Con grp 1: 76 Con grp 2: 75 F/U 3 sample size Intv grp 1: 66 Intv grp 2: 73 Con grp 1: 78 Con grp 2: 75 Retention rate: Intv grp 1: 85% Intv grp 2: 91% Con grp 1: 90% Con grp 2: 94% Comparison of drop-outs: NR | Intv Grps (2 intv grps) Intv components: home-based, parent-child autotutorial (PCAT) including talking book lessons and f/u games; manual for parents (intv grp 1) dietary counseling with RD; take home print materials (intv grp 2) Intv delivery: self-administered (intv grp 1); RD (intv grp 2) Special features: family component Nutr message: "heart healthy eating" Con Grps (2 con grps) Intv components: no dietary education until completion of the study con grp 1 was "at risk" con grp 2 was not at risk Theoretical perspective: Social Cognitive Theory | (Intv grp 1) PCAT program included 10 lessons (and f/u games) (intv grp 2) dietary counseling program involved 1 45-60 min counseling session (and take home materials) total duration of intv: NR Maintenance: NR | F/U 1: 3 mos after base F/U 2:6 mos after base F/U 3:12 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Shannon, Tershakovec, Martel, 1994 Tershakovec, Shannon, Achterberg, 1998 | Variables: total fat (g)* sat fat (g)** Instrument: 3 24-hr recalls (2 wk days, 1 wkend day) (parent interviewed for 4-7-yr-olds and assisted 8-10-yr-olds); data analyzed by NDS Statistics: linear model including tx grp as b/w subject factor and time as within subject factor; for f/u 1-3, analyses based on mixed-effects linear model and adjusted for mistimed visits, age, and gender; preplanned contrasts with Bonferroni correction *means reported for f/u 1 only (but the significance of effects reported for f/u 1-3) **means reported for f/u 1 only | Total fat (mean and se) Significance of effects: p for diff in chng b/w intv grp 1 and con grp 2 at f/u 1 <.05 p for diff in chng b/w intv grp 2 and con grp 1 at f/u 1 p<.05 sig within grp diff from base to f/u 1 for intv grp 2 (p<.05) chng from base to f/u 1 sig diff b/w intv grp 2 and con grp 1 (p<.05) sig within grp diff from base to f/u 2 for intv grp 1 (p<.05) chng from base to f/u 2 sig diff b/w intv grp 1 and con grp 1 (p<.05) sig within grp diff from base to f/u 2 for intv grp 2 (p<.05) chng from base to f/u 2 sig diff b/w intv grp 2 and con grp 1 (p<.05) sig within grp diff from base to f/u 3 for intv grp 1 (p<.05) chng from base to f/u 3 sig diff b/w intv grp 1 and con grp 1 (p<.05) sig within grp diff from base to f/u 3 for intv grp 2 (p<.05) chng from base to f/u 3 sig diff b/w intv grp 2 and con grp 1 (p<.05) Sat fat (mean and se) Significance of effects: p for diff in chng b/w intv grp 1 and con grp 1 at f/u 1 p<.05 p for diff in chng b/w intv grp 2 and con grp at f/u 1 p<.05 Intention to treat: available data from all subjects were used in the analyses | NR | Variables: LDL-C (mmol/L)* Instrument: fasting venous blood samples drawn from antecubital vein; TC measured using Kodak Ectachem Clinical Chemistry Slides; LDL-C calculated using Friedewald equation Statistics: linear model including tx grp as b/w subject factor and time as within subject factor; for f/u 1-3, analyses based on mixed-effects linear model and adjusted for mistimed visits, age, and gender; preplanned contrasts with Bonferroni correction *mean values only reported for f/u 1 (but the significance of changes at f/u 1-3 is reported) | LDL-C (mean and se) Significance of effects: no sig diffs b/w grps at f/u 1* sig within grp diff from base to f/u 1 for intv grp 1 (p<.05) sig within grp diff from base to f/u 2 for intv grp 1, intv grp 2, and con grp 2 (p<0.05) sig within grp diff from base to f/u 3 for intv grp 1, intv grp 2, and con grp 2 (p<0.05) *when expressed as mg/dL, the change in LDL-C from base to f/u was sig diff for intv grp 1 and con grp 1 Intention to treat: available data from all subjects were used in analyses | Dietary knowlege: sig intv effect (greatest increase in intv grp 1) | 66
  | Base | F/U1 | Chng
  Intv grp 1 (n NR): | 51.1(1.5) | 46.6(1.8) | -4.5(2.3)
  Intv grp 2 (n NR): | 52.1(1.5) | 47.3(1.6) | -4.8(2.2)
  Con grp 1 (n NR): | 56.2(1.5) | 60.2(1.6) | 4.0(2.2)
  Con grp 2 (n NR): | 58.1(1.8) | 59.5(1.9) | 1.4(2.6)
  | Base | F/U 1 | Chng
  Intv grp 1 (n NR): | 19.4(0.6) | 17.2(0.7) | -2.2(0.9)
  Intv grp 2 (n NR): | 19.8(0.6) | 17.2(0.6) | -2.6(0.8)
  Con grp 1 (n NR): | 21.1(0.6) | 22.7(0.6) | 1.6(0.8)
  Con grp 2 (n NR): | 22.7(0.7) | 22.9(0.7) | 0.2(1.0)
  | Base | F/U 1
  Intv grp 1 (n NR): | 3.26 (0.03) | 3.00 (0.04)
  Intv grp 2 (n NR): | 3.30 (0.03) | 2.19 (0.03)
  Con grp 1 (n NR): | 3.34 (0.03) | 3.26 (0.04)
  Con grp 2 (n NR): | NR | NR
  | Chng
  Intv grp 1 (n NR): | -0.26 (0.05)
  Intv grp 2 (n NR): | -0.11 (0.05)
  Con grp 1 (n NR): | -0.09 (0.05)
  Con grp 2 (n NR): | NR

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
132 Lindholm, Ekbom, Dash, 1995 Cost Effectiveness of Lipid Lowering (CELL) | Setting: healthcare (recruited from pt files and advertisements in local press) Gender: M,F Age: 30-59 yrs Race: NR Risk: CVD Country: Sweden | RCT randomization performed separately by center (32 health centers participated) and sex; subjects allocated equally to intv or con | Participation rate: NR Baseline sample size Intv grp: 339 Con grp: 342 F/U 1 sample size Intv grp: 312 Con grp: 325 F/U 2 sample size Intv grp: 306 Con grp: 320 Retention rate Intv grp: 92% Con grp: 95% Comparison of drop-outs: NR | Intv Grp Intv components: introduction and pamphlet by doctor; group sessions; videos; group discussion; practical instruction; advised to exercise, stop smoking, and lose weight (if necessary) Intv delivery: trained health professional (nurse or MD) Special features: small group Nutr message: reduce fat Con Grp Intv components: usual healthcare advice; pamphlet Theoretical perspective: NR | 6 sessions (total); 1st 3 sessions (90 mins each) held at monthly intervals; 4th session (lasted all day); 5th session (held 12 mos after start of intv; lasted 90 mins); 6th sessions (held 3-6 mos later; lasted 90 mins); tot intv duration: 18 mos Maintenance: NR | F/U 1: 12 mos from base F/U 2: 18 mos from base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Lindholm, Ekbom, Dash, 1995 | Variables: fat intake score (1 pt per gram of fat) Instrument: NR Statistics: calculated mean changes b/w each of 6 sessions (and mean chng from session 1 to 6) | Fat intake (mean and se) Significance of effects: text reported "a gradual decrease (p<.001) in the amount of fat consumed...as the study progressed" | Fiber: sig intv effect | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: fasting lipid profile analysis; standardized to ref preparations provided by CDC; LDL calculated by Friedewald et al, (1972) formula. Statistics: calculated mean diff b/w grps in changes from base to f/u 2 | TC (mean and se) Significance of effects: p for mean diff in chng at f/u 2 b/w grps (-0.15; 95% CI: -0.26 to -0.04) n.s. LDL-C (means NR) Significance of effects: mean diff (95% CI) in chng (at f/u 2) b/w grps: -0.10 (-0.21 to 0.01) Intention to treat: NR | NR | 65
  | Chng (sess 1-2) | Chng (sess 2-3) | Chng (sess 3-4)
  Intv grp: | -9.91(1.84) | -3.90(1.22) | -0.41(1.21)
  [n] | [n = 259] | [n = 260] | [n = 253]
  Con grp: | NR | NR | NR
  | Chng (sess 4-5) | Chng (sess 5-6) | Chng (sess 1-6)
  Intv grp: | -0.45(1.21) | 0.06(1.21) | -14.97(2.12)
  [n] | [n = 233] | [n = 211] | [n = 202]
  Con grp: | NR | NR | NR
  | Base | F/U1 | F/U 2
  Intv grp (n = 339): | 6.82 (0.56) | NR | NR
  Con grp (n = 342): | 6.82 (0.65) | NR | NR
  | Base | F/U1 | F/U 2
  Intv grp (n = 339): | 5.00 (0.63) | NR | NR
  Con grp (n = 342): | 5.02 (0.70) | NR | NR

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
181, 062, 015, 065 Renaud, de Lorgeril, Delaye, 1995 De Lorgeril, Renaud, Mamelle, 1994 De Lorgeril, Salen, Martin, 1998 De Lorgeril, Salen, Martin, 1999 Lyon Diet Heart Study | Setting: healthcare (recruited from hospital) Gender: M,F (91% M) Age: <70 yrs (mean age 53) Race: NR Risk: CVD Country: France | RCT patients randomly assigned to intv or con grp | Participation rate: 96% (total) Baseline sample size Intv grp: 289 Con grp: 295 F/U sample size Intv grp: 227 (n used in analyses) Con grp: 218 (n used in analyses) Retention rate Intv grp: 76-78% Con grp: 65-74% Comparison of drop-outs: NR ("characteristics of pts who withdrew were similar to those of the whole group") | Intv Grp Intv components: nutr counseling Intv delivery: cardiologist, dietitian Special features: NR Nutr message: follow Mediterranean-type diet ("6 dietary commandments": more bread, more veg and legumes, more fish, less meat, no day without fruit, no more butter and cream); a canola oil-based margarine supplied to subjects; rapeseed oil encouraged; moderate alcohol consumption allowed Con grp Intv components: no dietary counseling other than usual patient care by hosp dietitian or physician Theoretical perspective: NR | 1-hr instruction (dietary counseling); further counseling at each subsequent visit (presumably 2 mo later, then annually for 5 yrs) Maintenance: NR | 1-4 yrs* from base (mean f/u: 27 mos) *some results presented by indiv f/u periods: f/u 1: 2 mos f/u 2: 12 mos f/u 3: 24 mos f/u 4: 36 mos | Variables: fruit (g/d) veg (g/d) Instrument: 24-hr recall and FFQ* (no other details reported) Statistics: diffs b/w grps during f/u evaluated by unpaired students' t-tests *dietary info not collected for con grp for 1st 4 yrs | Fruit (mean and se) Significance of effects: f/u 1, f/u 2, f/u 3, and f/u 4 sig diff from base (p<.001) p for diff b/w grps at "all f/u": 0.007 Veg (mean and se) Significance of effects: p for diffs b/w grps at "all f/u": 0.07 Intention to treat: "all analyses performed according to intention to treat"
  | Base | F/U 1 | F/U 2
  Intv grp: | 193 (11) | 247 (12) | 251 (13)
  [n] | [n = 289] | [n = 268] | [n = 276]
  Con grp: | NR | NR | NR
  | F/U 3 | F/U 4 | All F/U(1-4yrs)
  Intg grp: | 256 (13) | 237 (15) | 251 (12)
  [n] | [n = 186] | [n = 121] | [n = 251]
  Con grp: | NR | NR | 203 (12)
  [n] | | | [n = 192]
  | Base | F/U 1 | F/U 2
  Intv grp: | 381 (15) | 368 (16) | 373 (14)
  [n] | [n = 289] | [n = 268] | [n = 276]
  Con grp: | NR | NR | NR
  | F/U 3 | F/U 4 | All F/U(1-4yrs)
  Intg grp: | 399 (17) | 392 (24) | 316 (10)
  [n] | [n = 186] | [n = 121] | [n = 219]
  Con grp: | NR | NR | 288
  [n] | | | [n = 192]

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Renaud, de Lorgeril, Delaye, 1995 De Lorgeril, Renaud, Mamelle, 1994 De Lorgeril, Salen, Martin, 1998 De Lorgeril, Salen, Martin, 1999 | Variables: total fat (% energy) sat fat (% energy) intake of butter/cream (g/d) Other variables analyzed: p:s ratio other fats intake of margarine intake of oil Instrument*: 24-hr recall and FFQ (no other details reported) Statistics: diffs b/w grps during f/u evaluated by unpaired students' t-tests *dietary info not collected for con grp for 1st 4 yrs | Total fat (mean and se) Significance of effects: pfor diffs b/w grps at "all f/u (1-4 yrs)" <.01 Sat fat (mean and se) Significance of effects: p for diffs b/w grps at "all f/u (1-4 yrs)" <.001 Butter/cream (mean and se) Significance of effects: f/u 1, f/u 2, f/u 3, and f/u 4 sig diff from base (p<.001) no other effects reported Intention to treat: "all analyses performed according to intention to treat" | Bread: sig intv effect Cereals: n.s. | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: evaluated in plasma; extracted and methylated by boron-fluoride-methanol reagent Statistics: diffs b/w grps evaluated by unpaired student t-tests | TC (mean and se) Significance of effects: p for diffs b/w grps n.s. LDL-C (mean and se) Significance of effects: p for diffs b/w grps n.s. Intention to treat: NR | NR | 45
  | Base | F/U 1 | F/U 2
  Intv grp: | 31.1 (0.5) | 28.8 (0.5) | 29.2 (0.5)
  [n] | [n = 258] | [n = 265] | [n = 245]
  Con grp: | NR | NR | NR
  | F/U 3 | F/U 4 | all f/u (1-4 yrs)
  Intg grp: | 30.5 (0.6) | 30.0 (0.7) | 30.6 (0.5)
  [n] | [n = 142] | [n = 112] | [n = 227]
  Con grp: | NR | NR | 33.1 (0.6)
  [n] | | | [n = 218]
  | Base | F/U 1 | F/U 2
  Intv grp: | 10.6 (0.3) | 7.3 (0.2) | 7.7 (0.2)
  [n] | [n = 258] | [n = 265] | [n = 245]
  Con grp: | NR | NR | NR
  | F/U 3 | F/U 4 | all f/u (1-4 yrs)
  Intg grp: | 8.1 (0.3) | 7.5 (0.3) | 8.3 (0.2)
  [n] | [n = 142] | [n = 112] | [n = 227]
  Con grp: | NR | NR | 11.8 (0.3)
  [n] | | | [n = 218]
  | Base | F/U 1 | F/U 2
  Intv grp: | 13 (1) | 1.7 (0.4) | 2.0 (0.4)
  [n] | [n = 289] | [n = 268] | [n = 276]
  Con grp: | NR | NR | NR
  | F/U 3 | F/U 4
  Intg grp: | 2.2 (0.5) | 2.2 (0.6)
  [n] | [n = 186] | [n = 121]
  Con grp: | NR | NR
  | Base | F/U 1
  Intv grp: | 6.50 (.08) | 6.30 (.08)
  [n] | [n = 289] | [n = 278]
  Con grp: | 6.47 (.07) | 6.41 (.07)
  [n] | [n = 295] | [n = 280]
  | F/U 2 | F/U 3
  Intv grp: | 6.16 (.07) | 6.17 (.09)
  [n] | [n = 239] | [n = 171]
  Con grp: | 6.11 (.07) | 6.16 (.10)
  [n] | [n = 241] | [n = 168]
  | Base | F/U 1
  Intv grp: | 4.52 (.07) | 4.32 (.07)
  [n] | [n = 289] | [n = 278]
  Con grp: | 4.54 (.06) | 4.31 (.11)
  [n] | [n = 295] | [n = 280]
  | F/U 2 | F/U 3
  Intv grp: | 4.20 (.06) | 4.18 (.08)
  [n] | [n = 239] | [n = 171]
  Con grp: | 4.16 (.07) | 4.11 (.09)
  [n] | [n = 241] | [n = 168]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
197 Simkin-Silverman, Wing, Hansen, 1995 WHLP | Setting: healthcare (subjects recruited from a random sample of registered voters) Gender: F Age: 44-50 Race: W,O Risk: general | RCT subjects randomly assigned to intv or con grp | Participation rate: 84% (total) Baseline sample size: 535 (total) F/U sample size Intv grp: 267 Con grp: 253 Retention rate: 97% (total) Comparison of drop-outs: NR | Intv Grp Intv components: group sessions, self-monitoring fat intake, behavior strategies (problem solving, goal setting, assertiveness training, cognitive techniques); weight loss; exercise Intv delivery: trained nutritional and behavioral interventionists Special features: NR Nutr message: decrease total fat (to 25% energy), sat fat (to 7% energy), total chol (to 100 mg/d) Con Grp Intv component: no intv Theoretical perspective: NR | Intensive phase: 15 grp meetings held -wkly for 10 wks, then biwkly for 10 wks Maintenance phase: 3 monthly grp meetings; then 3 bimonthly meetings; then grp, mail, or phone contact every 2-3 mos; soc and educ gatherings 2-3 times/yr Total duration of intv: 5 yrs | 6 mos after randomization | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Simkin-Silverman, Wing, Hansen, 1995 | Variables: total fat (% energy)sat fat (% energy) Instrument: FFQ (Block); analyzed using DIETSYS Statistics: 2-way repeated measured ANOVA to test diffs b/w grps (with time as within factor) | Total fat (mean and 95% CI; sd/se NR) Significance of effects: no sig diffs at base p for grp*time interaction <0.001 Sat fat (mean and 95% CI; sd/se NR) Significance of effects: no sig diffs at base p for grp*time interaction <0.001 Intention to treat:NR | Calcium: n.s. | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: fasting blood samples; TC measured by Heinz Nutr Lab. (certified by CDC); LDL-C estimated with Friedewald equation Statistics: 2-way repeated measured ANOVA to test diffs b/w grps (with time as within factor) | TC (mean and 95% CI; sd/se NR) Significance of effects: no sig diffs at base p for grp*time interaction <0.001 LDL-C (mean and 95% CI) Significance of effects: no sig diffs at base p for grp*time interaction <0.001 Intention to treat: NR | NR | 78
  | Base | F/U
  Intv grp (n = 216): | 36.1 (35.0 to 37.1) | NR
  Con grp (n = 204): | 35.5 (34.4 to 36.6) | NR
  | Chng
  Intv grp (n = 216): | -11.1 (-12.2 to -10.0)
  Con grp (n = 204): | -1.0 (-1.7 to -0.28)
  | Base | F/U
  Intv grp (n = 216): | 12.3 (11.9 to 12.7) | NR
  Con grp (n = 204): | 11.8 (11.4 to 12.3) | NR
  | Chng
  Intv grp (n = 216): | -4.3 (-4.7 to -3.9)
  Con grp (n = 204): | -0.4 (-0.70 to -0.10)
  | Base | F/U
  Intv grp (n = 253): | 4.89 (4.82 to 4.98) | NR
  Con grp (n = 267): | 4.91 (4.84 to 4.99) | NR
  | Chng
  Intv grp (n = 253): | -0.34 (-0.41 to -0.26)
  Con grp (n = 267): | 0.03 (-0.04 to 0.01)
  | Base | F/U
  Intv grp (n = 253): | 2.96 (2.89 to 3.03) | NR
  Con grp (n = 267): | 3.01 (2.94 to 3.07) | NR
  | Chng
  Intv grp (n = 253): | -0.280 (-0.34 to -0.21)
  Con grp (n = 267): | -0.002 (-0.062 to 0.059)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
019 Aish, 1996 | Setting: healthcare (MI patients recruited from hospital) Gender: M,F Age: range NR; mean 59 yrs (men), 65 yrs (women) Race:NR Risk:CVD Country: Canada some analyses presented separately by gender | RCT Subjects randomly assigned to intv or con grp | Participation rate:NR Baseline sample size Intv grp: 52 Con grp: 52 F/U sample size Intv grp: 52 Con grp: 52 Retention rate: 100% Comparison of drop-outs:n/a (retention 100%) | Intv Grp Intv components: nursing intervention home visits; taught healthy self-care behavior related to diet; diet records; telephone contact Intv delivery: nurse Special features:NR Nutr message: heart healthy diet with reduced fat and increased fiber Con Grp Intv components: given info on heart healthy diet Theoretical perspective: Orlem's Self-Care Deficit Theory of Nursing | 1 initial home visit; 3 f/u telephone calls; total duration of intv: 6 wks Maintenance: NR | 7 wks after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Aish, 1996 | Variables: tot fat (% energy) sat fat (% energy) fat-related behaviors (score) Instrument: 3-d diet record analyzed by West Diet Analysis program; Food Habits Questionnaire (used to measure fat behaviors) Statistics: t-tests; ANCOVA (controlling for time 1 measures - only for fat-related behaviors); MANOVA | Total fat (mean and sd) Significance of effects: p for diffs in means b/w grps < 0.01 p for tx group effect (MANOVA): 0.000 Sat fat (mean and sd) Significance of effects: p for diffs in means b/w grps < 0.01 p for tx group effect (MANOVA): 0.002 Fat-related behaviors (mean and sd) Significance of effects: p for diffs in means b/w grps < 0.05 p for diffs b/w grps (ANCOVA) < 0.05 p for tx group effect (MANOVA): 303 p for tx group*time interaction (MANOVA): 0.047 | NR | NR | NR | Eating habits confidence: n.s. Social support for healthy eating: n.s. | 45
  | Base | F/U
  Intv grp (n = 52): | NR | 26.40 (5.60)
  Con grp (n = 52): | NR | 32.38 (6.33)
  | Base | F/U
  Intv grp (n = 52): | NR | 8.82 (2.86)
  Con grp (n = 52): | NR | 11.08 (3.58)
  | Base | F/U
  Intv grp (n = 52): | NR | 2.15 (0.45)
  Con grp (n = 52): | NR | 2.29 (0.35)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
046 Boyd, Martin, Beaton,1996 | Setting: healthcare (recruited from Breast Diag Clinic) Gender: F Age: 30-65 yrs Race: NR Risk: Cancer Country: Canada | RCT subjects randomly assigned to intv or con grp | Participation rate: NR Baseline sample size: 295 (total) F/U sample size Intv grp: 76 Con grp: 81 Retention rate: 53% (total) Comparison of drop-outs: no sig. diffs | Intv Grp Intv components: individualized dietary counseling, self-help materials, tested low fat recipes Intv delivery: dietitian Special features: NR Nutr message: decrease fat (to 15% of energy), increase carbohydrates Con Grp Intv components: no dietary counseling Theoretical perspective: NR | Once a mo for 12 mos Maintenance: NR | 7-8 yrs after intv | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Boyd, Martin, Beaton, 1996 | Variables: total fat (% energy) total fat (g) sat fat (g) Other variables analyzed: linoleic acid oleic acid Instrument: semi-quantitative 100 item FFQ (Health Habits and History) Statistics: diffs b/w intv and con grps measured by t-tests | Total fat (%energy; mean and sd) Significance of effects: p (for diff b/w grps at F/U): 0.0007 Total fat (g; mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p (for diff b/w grps at F/U): 0.0006 Sat fat (g; mean and sd) Significance of effects: p (for diff b/w grps): 0.0005 Intention to treat: NR | Calcium: n.s. Fiber: n.s. | Variables: TC (mmol/L) Instrument: non-fasting fresh serum sample measured by Technicon RA1000 and Technicon enzymatic reagents Statistics: diffs b/w intv and con grps measured by t-tests | TC (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p (for diff b/w grps at f/u): 0.13 Intention to treat: NR | NR | 65
  | Base | F/U
  Intv grp (n = 76): | 36.9 (6.7) | 31.7 (7.3)
  Con grp (n = 80): | 36.9 (6.3) | 35.3 (5.6)
  | Base | F/U
  Intv grp (n = 76): | NR | 52.0 (21.0)
  Con grp (n = 81): | NR | 62.6 (20.1)
  | Base | F/U
  Intv grp (n = 76): | NR | 17.2 (7.4)
  Con grp (n = 81): | NR | 21.5 (8.1)
  | Base | F/U
  Intv grp (n = 54): | 4.95(1.04) | 5.14 (0.84)
  Con grp (n = 61): | 4.89 (1.01) | 5.38 (0.81)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
309, 308 Glasgow, Toobert, Hampson, 1996 Glasgow, La Chance, Toobert, 1997 | Setting: healthcare (pts recruited from their primary care clinics) Gender: M,F Age: >40 yrs Race: NR Risk: Type 2 diabetes | RCT pts randomized within physician practice to intv or con cond | Participation rate: 57-66% (total) Baseline sample size Intv grp: 108 Con grp: 98 F/U sample size Intv grp: ~ 93 Con grp: ~ 83 Retention rate Intv grp: 88% Con grp: 89% Comparison of drop-outs:NR | Intv Grp Intv components: touchscreen computer-assisted assessment (providing immediate feedback on barriers to dietary self-management); feedback form for physicians; counseling (personalized dietary intv goals, problem solving); take-home or interactive videos Intv delivery: self-guided (computer and video components); "intv staff member" (counseling component) Special features: individually tailored Nutr message: decrease fat (particularly sat fat) Con Grp Intv components: usual care Theoretical perspective: NR | Duration of computer session 5-10 mins; counseling session: 20 mins; total staff contact time (not including video): 1 hr Maintenance: f/u phone calls at around 1 and 3 wks after intv; take-home videos (or return to clinic for video session): 30 mins; written maintenance info sent home; entire maintenance component repeated at 3 mo f/u visit; final phone call at 6 mos; diabetes book provided to subjects at 9 mos | F/U 1: 3 mos after base F/U 2: 12 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Glasgow, Toobert, Hampson, 1996 Glasgow, La Chance, Toobert, 1997 | Variables: total fat (% energy) sat fat (% energy) fat-related dietary habits Instrument: 4-d food records (1 wkend day) scored using Univ of Minnesota NDS Kristal Food Habits Questionnaire (20 items measuring 4 dimensions of fat-related dietary habits) Stastics: MANCOVA (to evaluate intv effects for dietary behavior in general); ANOVAS (if MANCOVA sig, to identify specific vars on which there was differential chng) comparing intv and con f/u scores, covarying out the effect of base scores | Total fat (mean; sd/se NR) Significance of effects: no sig diffs b/w grps at base p for MANCOVA (chng in overall dietary behavior) at f/u 1: 0.022 p for ANCOVA model (comp intv and con f/u scores) at f/u 1: 0.008 p for MANCOVA (chng in overall dietary behavior) at f/u 2: 0.008 p for ANCOVA model (comp intv and con f/u scores) at f/u 2: 0.023 Sat fat (mean; sd/se NR) Significance of effects: no sig diffs b/w grps at base p for MANCOVA (chng in overall dietary behavior) at f/u 1: 0.022 p for ANCOVA model (comp intv and con f/u scores) at f/u 1: 0.007 p for MANCOVA (chng in overall dietary behavior) at f/u 2: 0.008 p for ANCOVA model (comp intv and con f/u scores) at f/u 2: 0.003 Fat-related habits (mean; sd/se NR) Significance of effects: no sig diffs b/w grps at base p for MANCOVA (chng in overall dietary behavior) at f/u 1: 0.022 p for ANCOVA model (comp intv and con f/u scores) at f/u 1 <0.001 p for MANCOVA (chng in overall dietary behavior) at f/u 2: 0.008 p for ANCOVA model (comp intv and con f/u scores) at f/u 2: 0.007 Intention to treat: NR | NR | Variables: TC (units NR) Instrument: blood samples analyzed (fasting status NR) Statistics: MANCOVA (to evaluate intv effects for physiological outcomes in general); ANOVAS (if MANCOVA sig, to identify specific vars on which there was differential chng) comparing intv and con f/u scores, covarying out the effect of base scores | TC (mean; sd/se NR) (tot sample size: 173) Significance of effects: no sig diffs b/w grps at base p for MANCOVA (chng in physiologic outcomes overall) at f/u 1: 0.001 p for ANCOVA model (comp intv and con f/u scores) at f/u 1 <0.001 p for MANCOVA (chng in physiologic outcomes overall) at f/u 2: 0.04 p for ANCOVA model (comp intv and con f/u scores) at f/u 2: 0.002 Intention to treat: NR | NR | 72
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 34.0 | 29.4 | 30.5
  Con grp (n NR): | 33.6 | 32.0 | 32.0
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 11.3 | 9.8 | 9.7
  Con grp (n NR): | 10.9 | 10.7 | 10.7
  | Base | F/U 1 | F/U 2
  Intv grp (n NR): | 2.27 | 2.06 | 2.06
  Con grp (n NR): | 2.18 | 2.15 | 2.17
  | Base | F/U 1 | F/U 2
  Intv grp: | 216 | 207 | 208
  Con grp: | 223 | 231 | 226

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
097 Grimm, Flack, Grandits, 1996 TOMHS | Setting: healthcare (pts recruited from community screenings) Gender: M,F Age: 45-69 yrs Race: NR Risk: CVD Some results presented by weight change categories | RCT 4 clinical centers assigned subjects to receive lifestyle management plus 1 of 6 active drugs or placebo conditions (randomization strata were clinical center and antihypertensive medication use at initial screen) | Participation rate: NR Baseline sample size Intv grp 1: 234 Intv grp 2: 136 Intv grp 3: 132 Intv grp 4: 134 Intv grp 5: 131 Intv grp 6: 135 F/U 1-4 sample size: NR Retention rate: NR Comparison of drop-outs:NR | Intv Grps (6 intv grps) Intv components: all grps received intensive nutritional-hygienic intervention aimed at weight loss with an energy intake and fat-modified diet, reduced sodium and alcohol, and increased phys act -intv plus placebo (intv grp 1) -intv plus diuretic (intv grp 2) -intv plus b-blocker (intv grp 3) -intv plus a 1 antagonist (intv grp 4) -intv plus calcium antagonist (intv grp 5) -intv plus ACE inhibitor (intv grp 6) Intv delivery: NR Special features: NR Nutr message: decrease energy intake, fat intake, sodium, and alcohol Con Grp (no con grp) Theoretical perspective: NR | Duration of nutr counseling NR; tot duration of intv NR Maintenance: NR | F/U 1: 12 mos after base F/U 2: 24 mos after base F/U 3: 36 mos after base F/U 4: 48 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Grimm, Flack, Grandits, 1996 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: monounsat fat polyunsat fat Keys score Instrument: food records (2 days at baseline; 1 day at all f/u points) coded by Nutr Coding Center of Univ of Minnesota Statistics: combined all intv grps and reported mean change over the entire 4 yrs of f/u; statistics used to determine significance NR | Total fat (mean and se) *data presented for all intv grps combined (all intv grps received nutr intv); text states that there were no sig diffs among tx grps Significance of effects: "sig decrease in fat intake" (p values NR) Sat fat (mean and se) *data presented for all intv grps combined (all intv grps received nutr intv); text states that there were no sig diffs among tx grps Significance of effects: NR Intention to treat: NR | NR | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: measured after 12-hr fast; TC measured enzymatically; LDL estimated with Friedewald equation; measured at the Minnesota Core Lipid Res Clinics Lab Statistics: ANCOVA (with randomization strata and baseline values as covariates); tx comparisons made based on all 4 f/u values using a random effects model (with the average chng over the 4 yrs reported as a summary measure) | TC (mean and se) Significance of effects: p for chng among active grps at f/u 1 <.001 p for chng among active grps at f/u : .16 p for chng among active grps at f/u 3: 07 p for chng among active grps at f/u 4 <.002 p for average chng among active grps <.001 LDL-C (mean and se) Significance of effects: p for chng among active grps at f/u 1 <0.001 p for chng among active grps at f/u 2: 0.32 p for chng among active grps at f/u 3: 0.09 p for chng among active grps at f/u 4: 0.002 p for average chng among active grps: 0.004 Intention to treat: text indicated that "analyses were done based on intention to treat"; all participants who attended the annual visit and had lipid measurements were included | NR | 58
  | Base | F/U | Chng (all f/u pts)
  Intv grps* (n NR): | 36.4 | NR | -6.4 (0.3)
  | Base | F/U | Chng (all f/u pts)
  Intv grps* (n NR): | 12.7 | NR | -2.6 (0.1)
  | Base | Chng(f/u 1)
  Intv grp 1 (n NR): | 5.83 (0.97) | -0.13 (0.04)
  Intv grp 2 (n NR): | 5.94 (0.99) | 0.03 (0.06)
  Intv grp 3 (n NR): | 6.03 (1.05) | -0.33 (0.06)
  Intv grp 4 (n NR): | 5.92 (0.98) | -0.33 (0.06)
  Intv grp 5 (n NR): | 5.92 (1.06) | -0.19 (0.07)
  Intv grp 6 (n NR): | 5.84 (0.94) | -0.21 (0.06)
  | Chng(f/u 2) | Chng(f/u 3)
  Intv grp 1 (n NR): | -0.08 (0.05) | -0.18 (0.04)
  Intv grp 2 (n NR): | -0.06 (0.07) | -0.21 (0.07)
  Intv grp 3 (n NR): | -0.22 (0.08) | -0.37 (0.06)
  Intv grp 4 (n NR): | -0.29 (0.07) | -0.43 (0.06)
  Intv grp 5 (n NR): | -0.19 (0.08) | -0.24 (0.08)
  Intv grp 6 (n NR): | -0.13 (0.05) | -0.25 (0.07)
  | Chng(f/u 4) | Average Chng
  Intv grp 1 (n NR): | -0.15 (0.05) | -0.13 (0.03)
  Intv grp 2 (n NR): | -0.15 (0.07) | -0.12 (0.05)
  Intv grp 3 (n NR): | -0.30 (0.06) | -0.30 (0.05)
  Intv grp 4 (n NR): | -0.42 (0.07) | -0.36 (0.05)
  Intv grp 5 (n NR): | -0.10 (0.08) | -0.17 (0.06)
  Intv grp 6 (n NR): | -0.29 (0.06) | -0.21 (0.05)
  | Base | Chng(f/u 1)
  Intv grp 1 (n NR): | 4.05 (0.86) | -0.05 (0.04)
  Intv grp 2 (n NR): | 4.13 (0.89) | 0.05 (0.06)
  Intv grp 3 (n NR): | 4.21 (0.92) | -0.26 (0.06)
  Intv grp 4 (n NR): | 4.09 (0.91) | -0.21 (0.06)
  Intv grp 5 (n NR): | 4.14 (0.96) | -0.10 (0.06)
  Intv grp 6 (n NR): | 3.97 (0.87) | -0.11 (0.05)
  | Chng(f/u 2) | Chng(f/u 3)
  Intv grp 1 (n NR): | -0.05 (0.04) | -0.15 (0.04)
  Intv grp 2 (n NR): | -0.08 (0.07) | -0.19 (0.06)
  Intv grp 3 (n NR): | -0.21 (0.08) | -0.33 (0.06)
  Intv grp 4 (n NR): | -0.26 (0.07) | -0.37 (0.06)
  Intv grp 5 (n NR): | -0.15 (0.08) | -0.21 (0.07)
  Intv grp 6 (n NR): | -0.12 (0.05) | -0.17 (0.07)
  | Chng(f/u 4) | Average Chng
  Intv grp 1 (n NR): | -0.13 (0.04) | -0.09 (0.03)
  Intv grp 2 (n NR): | -0.13 (0.06) | -0.09 (0.05)
  Intv grp 3 (n NR): | -0.30 (0.06) | -0.27 (0.05)
  Intv grp 4 (n NR): | -0.34 (0.06) | -0.29 (0.05)
  Intv grp 5 (n NR): | -0.08 (0.07) | -0.13 (0.05)
  Intv grp 6 (n NR): | -0.25 (0.06) | -0.15 (0.05)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
300 Agurs-Collins, Kumanyika, Ten Have, 1997 | Setting: healthcare (subjects recruited through general clinics, diabetes clinics, comm outreach) Gender: M,F Age: 55-79 Race: B Risk: Type 2 diabetes | RCT subjects screened and randomized to intv or con grp | Participation rate: NR Baseline sample size Intv grp: 32 Con grp: 32 F/U 1 sample size Intv grp: 31 Con grp: 27 F/U 2 sample size Intv grp: 30 Con grp: 25 Retention rate Intv grp: 97% Con grp: 84% Comparison of drop-outs: NR | Intv Grp Intv components: group sessions (sharing, problem solving); indiv weight reduction diet; food and exercise diaries; goal setting; peer support; weight reduction and exercise classes Intv delivery: RD and exercise physiologist Special features: social support; family component; group sessions; ethnically specific Nutr message: adhere to a diet with 55-60% energy from carb; 12-20% from protein; <30% from fat Con Grp 1 class (related to methods of glycemic control); 2 mailings of nutr info Theoretical perspective: Social Action Theory | 12 wkly group sessions for first 3 mos (each session included 60 mins of nutr ed and 30 mins exercise); one indiv diet counseling session; 6 biwkly group sessions (90 mins in length) for next 3 mos; total duration of intv: 12 wks Maintenance: NR | F/U 1: 3 mos after base F/U 2: 6 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Agurs-Collins, Kumanyika, Ten Have, 1997 | Variables: total fat (% energy) sat fat (% energy) Instrument:: FFQ adapted by Eck, Klesges, Hanson, 1988, from Willet's semiquantitative FFQ Statistics: subtracted within grp change from base for con grp from the within grp change for intv grp, for f/u 1 and f/u 2; used unpaired student t-tests of within grp changes; used linear reg to assess intv minus con diffs, adjusting for diff combinations of covariates | Total fat (mean and sd) Significance of effects: net diff (within grp mean change in con grp from within grp mean chng in intv grp) for f/u 1: -0.06 (95% CI: -0.1; -0.02), p<.01 net diff (within grp mean change in con grp from within grp mean chng in intv grp) for f/u 2: -0.03 (95% CI: -0.7; 0.01), p n.s Sat fat (mean and sd) Significance of effects: net diff (within grp mean change in con grp from within grp mean chng in intv grp) for f/u 1: -0.02 (95% CI: -0.03; -0.002), p<.05 net diff (within grp mean change in con grp from within grp mean chng in intv grp) for f/u 2: -0.008 (95% CI: -0.02; 0.008), p n.s Intention to treat: NR | Fiber: n.s. | Variables: TC (mg/dL) LDL-C (mg/dL) Instrument: fasting blood sample; TC determined by enzymatic methods; LDL calculated by Frieldwald equation Statistics: subtracted within grp change from base for con grp from the within grp change for intv grp, for f/u 1 and f/u 2; used unpaired student t-tests of within grp changes; used linear reg to assess intv minus con diffs, adjusting for diff combinations of covariates | TC (mean and sd) Significance of effects: net diff (within grp mean change in con grp from within grp mean chng in intv grp) for f/u 1: -9.1 (95% CI: -33.0; 14.8), p n.s net diff (within grp mean change in con grp from within grp mean chng in intv grp) for f/u 2:-3.7 (95% CI: -25.7; 18.3), p n.s LDL-C (mean and sd) Significance of effects: net diff (within grp mean change in con grp from within grp mean chng in intv grp) for f/u 1:2.3 (95% CI: -12.0; 16.7), p n.s net diff (within grp mean change in con grp from within grp mean chng in intv grp) for f/u 2: -2.7 (95% CI: -23.7; 18.3), p n.s Intention to treat: NR | Nutr knowledge: sig intv effect (at f/u 1) | 68
  | Base | F/U 1 | F/U 2
  Intv grp: | 32 (7) | 26 (6) | 27 (5)
  [n] | [n = 32] | [n = 31] | [n = 30]
  Con grp: | 29 (7) | 29 (6) | 27 (6)
  [n] | [n = 32] | [n = 26] | [n = 25]
  | Chng (base to f/u1) | Chng (base to f/u2)
  Intg grp: | -0.06 | -0.05
  Con grp: | 0.0006 | -0.02
  | Base | F/U 1 | F/U 2
  Intv grp: | 10 (3) | 9 (2) | 9 (2)
  [n] | [n = 32] | [n = 31] | [n = 30]
  Con grp: | 9 (2) | 9 (2) | 8 (2)
  [n] | [n = 32] | [n = 26] | [n = 25]
  | Chng (base to f/u1) | Chng (base to f/u2)
  Intg grp: | -0.02 | -0.02
  Con grp: | - 0.003 | -0.01
  | Base | F/U 1
  Intv grp: | 250.1 (39.6) | 226.8 (35.9)
  [n] | [n = 32] | [n = 31]
  Con grp: | 238.3 (48.6) | 231.2 (39.2)
  [n] | [n = 32] | [n = 26]
  | F/U 2 | Chng(f/u1) | Chng(f/u2)
  Intv grp: | 232.9(44.9) | -21.2 | -14.3
  [n] | [n = 30]
  Con grp | 230.6 (34.1) | -12.2 | -10.7
  [n] | [n = 25]
  | Base | F/U 1
  Intv grp: | 171.9 (37.0) | 156.1 (32.8)
  [n] | [n = 31] | [n = 31]
  Con grp: | 156.0 (47.9) | 150.1 (27.8)
  [n] | [n = 31] | [n = 24]
  | F/U 2 | Chng (f/u1) | Chng f/u 2)
  Intv grp: | 162.4 (39.2) | -12.8 | -4.9
  [n] | [n = 29]
  Con grp: | 154.5 (30.7) | -15.1 | -2.2
  [n] | [n = 23]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
031 Bakx, Stafleu, van Staveren, 1997 Nijmegen Family Practice Monitoring Project | Setting: healthcare (recruited from family practice clinic) Gender: M,F Age: 20-50 yrs Race: NR Risk: CVD Country: The Netherlands Some analyses separate by chol levels and stage of change | RCT subjects randomly assigned to intv and con grp | Participation rate: 68.9% (total) Baseline sample size Intv grp: 840 Con grp: 497 F/U sample size Intv grp: 360 Con grp: 112 Retention rate Intv grp: 43% Con grp: 23% Comparison of drop-outs: NR | Intv Grp Intv components: health ed Intv delivery: trained practice nurse Special features: NR Nutr message: decrease sat fat, energy intake, sodium; increase polyunsat fat Con Grp Intv components: routine visits and "unsupported advice" by MD Theoretical perspective: NR | Sessions every 2 mos for 1 yr Maintenance: NR | 17 yrs after baseline | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Bakx, Safleu, van Staveren, 1997 | Variables: total fat (% energy) total fat (g) sat fat (g) Other variables analyzed: monounsat fat polyunsat fat Instrument: FFQ Statistics: comparison of means | Total fat (g; mean and se) Significance of effects: p (for diff at f/u) n.s. Total fat (% energy; mean and se) Significance of effects: p (for diff at f/u) n.s. Sat fat (g; mean and se) Significance of effects: p (for diff at f/u) n.s. Intention to treat: NR | NR | Variables: TC (mmol/L) Instrument: non-fasting serum concentration using quality control standards of the National Laboratory Foundation; enzymatic method used Statistics: comparison of means | TC (mean and se) Significance of effects: p (for diff b/w grps at base.) n.s. p (for diff b/w grps at f/u) n.s. | NR | 45
  | Base | F/U
  Intv grp (n = 360): | NR | 105.8 (42.5)
  Con grp (n = 112): | NR | 103.3 (37.1)
  | Base | F/U
  Intv grp (n = 360): | NR | 38.5 (6.9)
  Con grp (n = 112): | NR | 39.3 (7.8)
  | Base | F/U
  Intv grp (n = 360): | NR | 38.0 (15.4)
  Con grp (n = 112): | NR | 38.5 (13.5)
  | Baseline | F/U
  Intv grp (n = 360): | 6.3 (1.13) | 6.5 (1.10)
  Con grp (n = 112): | 6.1 (1.10) | 6.5 (1.30)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
231 Beresford, Curry, Kristal, 1997 Eating Patterns Study | Setting: healthcare (subjects recruited from pt list at selected primary care clinics) Gender: M,F Age: NR Race: W,O Risk: General Some results presented by stage of change or whether the subject reported complete/partial autonomy over meals | RCT 28 physician practices in 6 primary care clinics randomized equally to intv or con status; subjects recruited from physician lists | Participation rate Intv grp: 61% Con grp: 64% Baseline sample size Intv grp: 1010 Con grp: 1111 F/U 1 sample size Intv grp 1: 896 Con grp: 990 F/U 2 sample size Intv grp 1: 859 Con grp: 959 Retention rate (at f/u 2):86% (total) Comparison of drop-outs: participants who dropped out were younger, less likely to be white, and from lower-income families; also had slightly higher fat intake and lower fiber | Intv Grp Intv components: self-help booklet (including brief self-test, suggested changes, social norms; indiv goal-setting, self-assessment); motivational message by physician Intv delivery: physicians Special features: NR Nutr message: eat lower fat, high fiber diets Con Grp Intv components: no intervention; usual care Theoretical perspective: Social Learning Theory, Stages of Change | Booklet given to participants by physicians, with a brief introduction (less than 3 mins); reminder sent 2 wks later Maintenance: NR | F/U 1: 3 mos post-randomization F/U 2: 12 mos post-randomization | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Beresford, Curry, Kristal, 1997 | Variables: total fat (% energy) fat (g) fat score Instruments: 94-item FFQ (modified from Block); 41-item fat- and fiber-related behavioral questionnaire (modified from Kristal) assessing info on factors related to selecting low fat and high fiber diets (high values indicate greater fat/fiber intake) Statistics: mixed linear model (design effects were clinic, tx grp, and physician practice; covariates were baseline dietary intake, age, and gender) | Total fat (% energy; mean and se)* Significance of effects: diffs b/w grps at base n.s. intv effect at f/u 1: -1.04(-1.67, -0.41), p<.01 intv effect at f/u 2: -1.20 (-1.68;-0.73), p<.01 Total fat (g; mean and se)* Significance of effects: diffs b/w grps at base n.s. Fat score (mean and se)* Significance of effects: diffs b/w grps at base n.s. intv effect at f/u 1: -.046 (-.074;-.018), p<.01 intv effect at f/u 2: -.044 (-.073;-.016), p<.01 Intention to treat: NR *results also presented by stage of change and autonomy score | Fiber intake (g/1000 kcal): n.s. Fiber score: sig intv effect | Variables: TC (mg/dL) Instrument: blood collected using venipuncture (fasting status NR) Statistics: NR | Data NR, but text reports that "over the 12 mo f/u period, both grps decreased TC levels by a similar and small amount (~ 3.5 mg/dL) | Stage of change (in adopting a lowfat/highfiber diet) and autonomy in meal preparation measured, but diffs in these mediators b/w grps NR | 86
  | Base | F/U 1 | F/U 2
  Intv grp (n = 859): | 37.6 (0.3) | NR | NR
  Con grp (n = 959): | 37.5 (0.3) | NR | NR
  | Chng (95% CI) F/U 1 | Chng (95% CI) F/U 2
  Intv grp: | -1.52(-1.98;-1.06) | -1.54(-1.88;-1.19)
  [n] | [n = 896] | [n = 859]
  Con grp: | -0.48(-0.91;-0.05) | -0.34(-0.66;-0.01)
  [n] | [n = 990] | [n = 959]
  | Base | F/U 1 | F/U 2
  Intv grp (n = 859): | 71 (2) | NR | NR
  Con grp (n = 959): | 70 (2) | NR | NR
  | Base | F/U 1 | F/U 2
  Intv grp (n = 859): | 1.95 (0.006) | NR | NR
  Con grp (n = 959): | 1.95 (0.006) | NR | NR
  | Chng (95% CI) F/U 1 | Chng (95% CI) F/U 2
  Intv grp: | -.085(-.105;-.065) | -.084(-.105;-.063)
  [n] | [n = 896] | [n = 859]
  Con grp: | -.039(-.058;-.020) | -.040(-.059;-.020)
  [n] | [n = 990] | [n = 959]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
045 Boyd, Lockwood, Greenberg, 1997 Canadian Diet and Breast Cancer Study | Setting: healthcare (subjects screened for cancer risk and recruited from healthcare centers) Gender: F Age: 30-65 Race: NR Risk: cancer Country: Canada | RCT Subjects randomized to intv or con grp; randomization stratified according to center and balanced within each center | Participation rate: NR Baseline sample size Intv grp: ~ 122 Con grp: ~ 118 F/U sample size Intv grp: ~ 112 Con grp: ~ 104 Retention rate Intv grp: 83% Con grp: 91% Comparison of drop-outs: NR | Intv grp Intv components: indiv dietary counseling; subjects provided with dietetic scales, written guide, indiv diet prescription Intv delivery: dietitian Special features: NR Nutr message: decrease total fat (15% energy); increase carb Con grp Intv components: general dietary advice (not counseled to change intake of fat) Theoretical perspective: NR | Visited dietitian once a mo for 1st 12 mos, then once every 3 mos for 2nd yr; tot duration of intv: 2 yrs Maintenance: NR | 2 yrs after randomization | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Boyd, Lockwood, Greenberg, 1997 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: polyunsat fat monounsat fat Instrument: 3-d food record (including 2 wkdays and 1 wkend day); analyzed by NDS Statistics: t-tests | Total fat (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u <0.001 Sat fat (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u <0.001 Intention to treat: NR | Fiber: sig intv effect | NR | NR | NR | 58
  | Base | F/U
  Intv grp: | 34.0 (6.3) | 21.2 (6.0)
  [n] | [n = 112] | [n = 104]
  Con grp: | 34.3 (5.8) | 33.1 (6.7)
  [n] | [n = 104] | [n = 100]
  | Base | F/U
  Intv grp: | 12.4 (3.0) | 7.2 (2.5)
  [n] | [n = 112] | [n = 104]
  Con grp: | 12.3 (3.4) | 12.3 (3.4)
  [n] | [n = 104] | [n = 100]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
319 Dyson, Hammersley, Morris, 1997 Fasting Hyperglycaemia Study | Setting: healthcare (subjects recruited in "centers") Gender: M,F, Age: range NR; mean 50 yrs Race: NR Risk: type 2 diabetes Country: France, England | RCT subjects randomized to intv grp 1 (50%) or intv grp 2 (50%) in a factorial design with further allocation to sulfonylurea grp (50%) or con grp (50%), who received either placebo or no tablets | Participation rate: NR Baseline sample size Intv grp 1: 116 Intv grp 2: 111 F/U sample size Intv grp 1: 108 Intv grp 2: 93 Retention rate Intv grp 1: 93% Intv grp 2: 84% Comparison of drop-outs: drop-outs more likely to be in intv grp 1, and less likely to be male | Intv grps (2 grps) Intv components: written diet info; exercise advice; weight loss advice (if necessary) (intv grp 1) seen by dietitian; advised to change diet in line with British nutr recommendations; indiv energy requirements calculated; diet sheet provided; food diaries every 3 mos; weight loss advice (if necessary); exercise advice (intv grp 2) Intv delivery: physician (intv grp 1 only); dietitian (intv grp 2 only) Special features: NR Nutr message: limit total fat, increase intake of unrefined carb and fiber Con grp (no con grp) Theoretical perspective: NR | (Intv grp 1) advice given only once (initial visit) (Intv grp 2) advice given every 3 mos Total duration of intv NR Maintenance: NR | 1 yr (presumably post-randomization) | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Dyson, Hammersley, Morris, 1997 | Variables: total fat (% energy) Instrument: 3-d food diary (consecutive days: Sun-Tues), calculated using Dietplan 5 Statistics: paired t-test (comparison of diffs b/w grps); 2-sample t-test (mean changes over 1 yr) | Total fat (mean; sd/se NR) Significance of effects: no sig diffs b/w grps at base p for chng in intv grp 1 n.s. p for chng in intv grp 2 <0.001 p for comparison of net diffs b/w grps (-2.1): .04 Intention to treat: NR | Fiber: n.s. | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: NR Statistics: paired t-test (comparison of diffs b/w grps); 2-sample t-test (mean changes over 1 yr) | TC (mean; sd/se NR) Significance of effects: no sig diffs b/w grps at base p for chng in intv grp 1 <.001 p for chng in intv grp 2 <.01 p for comparison of net diffs b/w grps (0.0) n.s. LDL-C (mean; sd/se NR) Significance of effects: no sig diffs b/w grps at base p for chng in intv grp 1 <.001 p for chng in intv grp 2 <.01 p for comparison of net diffs b/w grps (0.1) n.s. Intention to treat: NR | NR | 59
  | Base | F/U | Chng (95%CI)
  Intv grp 1 (n = 100): | 37.2 | 35.8 | -1.4(-3.0;0.2)
  Intv grp 2 (n = 78): | 37.6 | 34.1 | -3.5(-5.3;-1.7)
  | Base | F/U | Chng (95%CI)
  Intv grp 1 (n = 104): | 4.9 | 4.7 | -0.2(-0.3;0.0)
  Intv grp 2 (n = 92): | 5.0 | 4.8 | -0.2(-0.3;-0.1)
  | Base | F/U | Chng (95%CI)
  Intv grp 1 (n = 104): | 3.2 | 3.0 | -0.2 (-0.3;-0.1)
  Intv grp 2 (n = 92): | 3.2 | 3.1 | -0.1 (-0.2;0.0)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
124 Kristal, Shattuck, Bowen, 1997 American Cancer Society Breast Cancer Dietary Intervention Project | Setting: healthcare (pts identified through local oncologists' offices and advertising) Gender: F Age: <75 (post-menopausal) Race: B,W,O Risk: Cancer | RCT subjects who had been treated for breast cancer were randomized to intv or con grp at 9 study sites | Participation rate: 94% (total) Baseline sample size: Intv grp: 73 Con grp: 71 F/U 1 sample size: Intv grp: 63 Con grp: 59 F/U 2 sample size: Intv grp: 62 Con grp: 53 F/U 3 sample size:Intv grp: 57 Con grp: 53 Retention rate* Intv grp: 77.0% Con grp: 74.6% Comparison of drop-outs: smokers more likely to drop out than non-smokers *retention rates refer to final f/u point | Intv Grp Intv components: indiv sessions, group sessions, interactive activities; self-assessment activities; reference materials; adjuvant cancer treatment Intv delivery: trained community volunteers (40% were RDs) Special features: group sessions, social support, goal setting Nutr message: decrease total fat (to 15% of energy) Con Grp Intv components: written materials on Am Cancer Soc guidelines (30% or less of tot energy from fat) Theoretical perspective: Social Learning Theory, Cognitive Behavior Therapy, Self Control Theory | 6 wkly indiv sessions (1 hr each), then monthly, 1-hr grp sessions (10 grp sessions), then a 7th indiv session at 6 mos; duration of total intv: 12 mos. Maintenance: NR | F/U 1: 3 mos after randomization F/U 2: 6 mos after randomization F/U 3: 12 mos after randomization | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Kristal, Shattuck, Bowen, 1997 | Variables: total fat (% energy) total fat (g) Instrument: 4-d food records (4 alternate days) Statistics: compared diffs in means b/w intv and con grp at base and each f/u period | Total fat (% energy; mean and sd) Significance of effects: p for diff b/w grps at base n.s. p for diffs b/w grps at f/u 1, f/u 2, and f/u 3 <.001 Total fat (g; mean and sd) Significance of effects: p for diff b/w grps at base n.s. p for diffs b/w grps at f/u 1 <.01 p for diffs b/w grps at f/u 2 and f/u 3 <.001 Intention to treat: NR | Calcium: sig intv effect (at 3 and 12 mos) | NR | NR | NR | 63
  | Base | F/U 1
  Intv grp: | 29.8 (6.4) | 19.9 (7.1)
  [n] | [n = 73] | [n = 63]
  Con grp: | 30.7 (7.8) | 26.5 (7.5)
  [n] | [n = 71] | [n = 59]
  | F/U 2 | F/U 3
  Intv grp: | 19.7 (6.8) | 20.0 (6.9)
  [n] | [n = 62] | [n = 57]
  Con grp: | 28.3 (7.7) | 28.0 (7.7)
  [n] | [n = 53] | [n = 53]
  | Base | F/U 1
  Intv grp: | 59.3 (22.5) | 33.9 (17.7)
  [n] | [n = 73] | [n = 63]
  Con grp: | 57.9 (21.7) | 44.3 (18.6)
  [n] | [n = 71] | [n = 59]
  | F/U 2 | F/U 3
  Intv grp: | 33.2 (27.4) | 33.8 (12.8)
  [n] | [n = 62] | [n = 57]
  Con grp: | 49.7 (19.9) | 47.7 (16.9)
  [n] | [n = 53] | [n = 53]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
183 Roderick, Ruddock, Hunt, 1997 | Setting: healthcare (subjects recruited opportunistically by GPs) Gender: M,F Age: 35-59 yrs Race: NR Risk: not clear Country: U.K. Some results presented separately by gender | RCT 8 general practices allocated within matched geographical pairs to intv or con grps; subjects recruited by GPs | Participation rate: 75% (total) Baseline sample size Intv grp: 473 Con grp: 483 F/U sample size Intv grp: 401 Con grp: 352 Retention rate Intv grp: 86% Con grp: 74% Comparison of drop-outs: non-responders more likely to be smokers and from manual groups than responders; no other diffs | Intv Grp Intv components: structured dietary advice; advice based on negotiated change principles; received standard health ed materials Intv delivery: trained nurses Special features: NR Nutr message: aimed for food substitution (foods were classified as "to eat plentifully," "in moderation," or "on special occasions only") Con Grp Intv components: standard health ed materials Theoretical perspective: NR | Initial counseling session (duration NR); f/u counseling at 4-6 wks; further f/u visits (at 3 and 6 mos) for pts with elevated chol, BMI, or other risk factors Maintenance: NR | 1 yr after base (median time for intv grp: 12.4 mos; con grp: 13.8 mos) | Variables: Fruit (portions/wk) Veg (portions/wk) Instrument: FFQ Statistics: outcomes analyzed at the level of the GP; mean change in intv and con sites reported, with 95% CI for diff within matched pairs | Fruit (mean; sd/se NR) Significance of effects: Mean diff within matched pairs b/w intv and con sites: 0.44 (range: -0.02 to 1.0) (95% CI: -0.24 to 1.11) Veg (mean; sd/se NR) Significance of effects: Mean diff within matched pairs b/w intv and con sites: 0.50 (range: -0.05 to 1.8) (95% CI: -0.9 to 1.9) Intention to treat: between practice changes analyzed on an intention-to-treat basis weighted for grp size (non-responders assumed not to have changed base measures)
  | Base | F/U | Chng
  Intv site (n NR): | NR | NR | 0.76
  Con site (n NR): | NR | NR | 0.28
  | Base | F/U | Chng
  Intv site (n NR): | NR | NR | 0.33
  Con site (n NR): | NR | NR | -0.25

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Roderick, Ruddock, Hunt, 1997 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: p:s ratio Instrument: FFQ Statistics: outcomes analyzed at the level of the GP; mean change in intv and con sites reported, with 95% CI for diff within matched pairs | Total fat (mean and sd) Significance of effects: mean diff within matched pairs b/w intv and con sites: -1.4 (range: -2.1 to -0.8) (95% CI: -2.2 to -0.7) Sat fat (mean and se) Significance of effects: mean diff within matched pairs b/w intv and con sites: -0.9 (range: -1.3 to -0.2) (95% CI: -1.5 to -0.2) Intention to treat: between practice changes analyzed on an intention-to-treat basis weighted for grp size (non-responders assumed not to have changed base measures) | Fiber: sig NR Wholemeal/brown bread: sig NR High-fiber cereal: sig NR | Variables: TC (mmol/L) Instrument: non-fasting blood sample analyzed using an enzymic method* Statistics: outcomes analyzed at the level of the GP; mean change in intv and con sites reported, with 95% CI for diff within matched pairs *pts with high chol at base completed fasting samples at f/u | TC (mean and sd) Significance of effects: mean diff within matched pairs b/w intv and con sites: -0.18 (range: -0.42 to 0.5) (95% CI: -0.52 to 0.16) Significance of effects: mean diff within matched pairs b/w intv and con sites: -0.25 (range: -0.40 to 0.04) (95% CI: -0.53 to 0.02) Intention to treat: between practice changes analyzed on an intention-to-treat basis weighted for grp size (non-responders assumed not to have changed base measures) | NR | 60
  | Base | F/U | Chng
  Intv grp: | 34.3 (6.3) | NR | -2.4
  [n] | [n = 473] | | [n NR]
  Con grp: | 34.2 (6.7) | NR | -0.9
  [n] | [n = 483] | | [n NR]
  | Base | F/U | Chng
  Intv grp: | 13.7 (3.6 ) | NR | -1.5
  [n] | [n = 473] | | [n NR]
  Con grp: | 14.0 (3.9) | NR | -0.6
  [n] | [n = 483] | | [n NR]
  Males
  | Base | F/U | Chng
  Intv grp: | 6.20 (1.17) | NR | -0.26
  [n] | [n = 227] | | [n NR]
  Con grp: | 6.29 (1.08) | NR | -0.05
  [n] | [n = 251] | | [n NR]
  Females
  | Base | F/U | Chng
  Intv grp: | 5.94 (1.07) | NR | -0.20
  [n] | [n = 246] | | [n NR]
  Con grp: | 5.95 (1.13) | NR | 0.04
  [n] | [n = 232] | | [n NR]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
198 Simon, Heilbrun, Boomer, 1997 | Setting: healthcare (subjects recruited from breast cancer prevention program, physicians, and media advertising) Gender: F Age: 18-67 yrs Race: W,B,H Risk: cancer | RCT women stratified by age and randomized into intv or con grps | Participation rate: 74% (total) Baseline sample size Intv grp: 98 Con grp: 96 F/U 1 sample size: Intv grp: 80 Con grp: 89 F/U 2 sample size: Intv grp: 74 Con grp: 85 F/U 3 sample size: Intv grp: 67 Con grp: 76 F/U 4 sample size Intv grp: 67 Con grp: 76 Retention rate Intv grp: 82% Con grp: 93% Comparison of drop-outs: sig tests NR | Intv Grp Intv components: nutr counseling (individualized low fat eating plan), goal setting, evaluation, feedback, participant self-monitoring; group meetings (with special nutr topics) Intv delivery: RD Special features: social support, group meetings Nutr message: reduce dietary fat intake (to 15% of energy) Con grp Intr components: no counseling; asked to maintain usual food intake; given a copy of USDA dietary guidelines Theoretical perspective: NR | Intensive one-on-one counseling biwkly for 3 mos; then monthly visits (in an indiv or group format); total duration of intv NR (but presumably 12-24 mos) Maintenance: NR | F/U 1: 3 mos after base F/U 2: 6 mos after base F/U 3: 9 mos after base F/U 4: 12 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Simon, Heilbrun, Boomer, 1997 | Variables: total fat (% energy) total fat (g) Instrument: 3-d food records (representative sampling of days) Statistics: NR | Total fat (% energy; mean and se) Significance of effects: NR Total fat (g; mean and se) Significance of effects: NR | Fiber: sig NR | NR | NR | NR | 56
  | Base | F/U 1 | F/U 2
  Intv grp: | 36.0 (0.7) | 19.0 (0.7) | 17.1 (0.5)
  [n] | [n = 93] | [n = 77] | [n = 68]
  Con grp: | 35.9 (0.7) | 34.7 (0.8) | 34.4 (0.9)
  [n] | [n = 91] | [n = 85] | [n = 82]
  | F/U 3 | F/U 4
  Intv grp: | 17.3 (0.6) | 18.0 (0.7)
  [n] | [n = 66] | [n = 65]
  Con grp: | 34.1 (0.9) | 33.8 (0.9)
  [n] | [n = 72] | [n = 68]
  | Base | F/U 1 | F/U 2
  Intv grp: | 78.2 (3.8) | 32.5 (1.2) | 29.8 (1.2)
  [n] | [n = 93] | [n = 77] | [n = 68]
  Con grp: | 67.9 (2.6) | 63.7 (2.5) | 60.3 (2.8)
  [n] | [n = 91] | [n = 85] | [n = 82]
  | F/U 3 | F/U 4
  Intv grp: | 31.5 (1.4) | 31.4 (1.4)
  [n] | [n = 66] | [n = 65]
  Con grp: | 59.2 (3.3) | 61.4 (3.4)
  [n] | [n = 72] | [n = 68]

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
030 Aubin, Godin, Vezina, 1998 | Setting: healthcare (recruited from hospital-based family med center) Gender: M,F Age: 18-65 Race: NR Risk: general Country: Canada | RCT subjects randomized to 1 of 2 intv grps | Participation rate: 80% (total) Baseline sample size Intv grp 1: 197 Intv grp 2: 222 F/U sample size: 391 (total) Retention rate: 93% (total) Comparison of drop-outs: NR | Intv Grp (2 grps) Intv components: brochure about low fat diet, info from physician, and: -intv grp 1 received results of screening before completing baseline questionnaire -intv grp 2 received results of screening after completing baseline questionnaire Intv delivery: MD, resident Special features: NR Nutr message: decrease fat Con Grp (no con grp) Theoretical perspective: Theory of Reasoned Action | Immediate (the nutr intv was the brochure), but a 3 mo delay was used before f/u results were obtained Maintenance: NR | 3 mos from baseline | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Aubin, Godin, Vezina, 1998 | Variables: total fat (g) Instrument: 13 item questionnaire (Block Fat screener) Statistics: ANOVA | Total fat (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for intv effect < 0.00001 Intention to treat: NR | NR | Variables: TC (mmol/L) LDL-C (mmol/L) Instrument: fasted blood samples Statistics: ANOVA | TC (mean and sd) Significance of effects: p for diff b/w grps at base n.s. LDL-C (mean and sd) Significance of effects: p for diff b/w grps at base n.s. Intention to treat: NR | Intention to adopt a low fat diet: sig intv effect | 78
  | Base | F/U
  Intv grp 1 (n = 197): | 49.6 (49.1) | NR
  Intv grp 2 (n = 222): | 47.5 (25.3) | NR
  | Base | F/U
  Intv grp 1 (n = 197): | 5.1 (1.2) | NR
  Intv grp 2 (n = 222): | 5.1 (1.1) | NR
  | Base | F/U
  Intv grp 1 (n = 197): | 3.0 (1.1) | NR
  Intv grp 2 (n = 222): | 3.1 (1.1) | NR

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
051 Campbell, Ritchie, Thain, 1998 | Setting: healthcare (pts recruited from general practices) Gender: M,F Age: range NR; mean 66.1 yrs Race: NR Risk: CVD Country: Scotland | RCT 19 practices recruited from a stratified random sample of all general practices in NE Scotland; high CVD risk pts identified and randomized to receive intv or con conditions | Participation rate (practices): 68% (total) Participation rate (patients): 71% (total) Baseline sample size Intv grp: 673 Con grp: 670 F/U sample size Intv grp: 593 Con grp:580 Retention rate Intv grp: 88% Con grp: 87% Comparison of drop-outs: non-responders more likely to be smokers | Intv grp Intv components: nurse-run clinics with review of symptoms, review of drug treatment, assessment of bp and lipids, assessment of behavior risk factors, and, if appropriate, negotiation of behavior change; patient feedback, goal planning, action plan Intv delivery: nurse Special features: NR Nutr message: NR Con grp Intv components: usual care from general practice Theoretical perspective: NR | Clinics ran for 1 yr (pts were invited to attend during first 3 mos, then f/u was encouraged, with timing every 2 to 6 mos; first visits lasted around 45 mins, and f/u visits around 20 mins) Maintenance: NR | 1 yr (presumably after baseline; immediately after intv) | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Campbell, Ritchie, Thain, 1998 | Variables: "low fat diet" (% of subjects achieving a DINE diet score < 30) Instrument: "DINE" (details NR) Statistics: logistic reg, adjusting for baseline performance, age, sex, and practice | Low fat diet (% and CI) Significance of effects: OR (95% CI) for intv grp membership: 1.47 (1.10 to 1.96), p: 0.009 Intention to treat: "all analyses conducted on an intention to treat basis" | NR | Variables: "Lipid management" (% managing lipids according to Grampian general practice lipid management guidelines: chol < 5.2 mmol/L or receiving attention by healthcare provider) Instrument: assessed with reference to British Hypertension Society guidelines Statistics: logistic reg, adjusting for baseline performance, age, sex, and practice | Lipid management (% and CI) Significance of effects: OR (95% CI) for intv grp membership: 3.19 (2.39 to 4.26), p <.001 Intention to treat: " all analyses conducted on an intention to treat basis" | NR | 46
  | Base | F/U | Diff (95%CI)
  Intv grp (n = 480): | 49.0 | 56.5 | 7.5 (2.4 to 12.6)
  Con grp (n = 465): | 48.6 48.6 | 0.0 (-4.6 to 4.6)
  | Base | F/U | Diff (95%CI)
  Intv grp (n = 593): | 12.0 | 41.1 | 29.2(25.1-33.3)
  Con grp (n = 580): | 13.8 | 21.6 | 7.8 (4.3 to 11.2)

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
166 Ornish, 1998 Multicenter Lifestyle Demonstration Project | Setting: healthcare (subjects with angiographically documented CVD recruited) Gender: M,F Age: range NR, mean 58 yrs Race: NR Risk: CVD | NR ("demonstration project") Intv grp pts selected and screened; matched con grp pts provided by Mutual of Omaha (matched for age, gender, and CVD risk factors) | Participation rate: NR Sample size (NR separately for base and f/u) Intv grp: 194 Con grp: 139 Retention rate: NR Comparison of drop-outs: NR | Intv Grp Intv components: exercise; stress management; meal, group support Intv delivery: cardiologists, RDs, exercise physiologists, psychologists, chefs, stress management specialists, RNs, administrative support personnel Special features: support groups Nutr message: eat low fat (<10% energy) whole-foods vegetarian diet high in complex carbs and low in simple sugars; low chol diet (< 10 mg/d) Con Grp Intv components: NR Theoretical perspective: NR | Met 3 times per wk (most sessions 4 hrs long) for 12 wks, then once per wk for the remaining 9 mos: tot duration of intv: 1 yr Maintenance: NR | F/U 1: 3 mos (presumably from base) F/U 2: 1 yr (presumably from base) F/U 3: 2 yrs (presumably from base) F/U 4: 3 yrs (presumably from base) | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Ornish, 1998 | Variables: total fat (% energy) Instrument: 3-d diet diary Statistics: NR | Total fat (mean; sd/se NR) Significance of effects: NR Intention to treat: NR | NR | Variables: TC (mg/dL) LDL-C (mg/dL) Instrument:: NR Statistics: NR | TC (mean; sd/se NR) Significance of effects: chng at f/u 1, 2, 3, and 4 for intv grp: p<.0001 LD-C (mean; sd/se NR) Significance of effects: chng at f/u 1, 2, 3, and 4 for intv grp: p<.0001 Intention to treat:: NR | NR | 35
  | Base | F/U 1 | F/U 2
  Intv grp (n = 194): | NR | 6.5 | 6.8
  Con grp (n = 139): | NR | NR | NR
  | F/U 3 | F/U 4
  Intv grp (n = 194): | 7.4 | 8.3
  Con grp (n = 139): | NR | NR
  | Base | F/U 1 | F/U 2
  Intv grp (n = 194): | 202.0 183.7 | 182.6
  Con grp (n = 139): | NR | NR | NR
  | F/U 3 | F/U 4
  Intv grp (n = 194): | 187.3 | 183.4
  Con grp (n = 139): | NR | NR
  | Base | F/U 1 | F/U 2
  Intv grp (n = 194): | 122.9 | 106.1 | 104.2
  Con grp (n = 139): | NR | NR | NR
  | F/U 3 | F/U 4
  Intv grp (n = 194): | 107.5 | 101.7
  Con grp (n = 139): | NR | NR

Evidence Table 2. Interventions to modify dietary behavior: Health care settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
225 Coates, Bowen, Kristal, 1999 WHT - Minority | Setting: healthcare (post-menopausal women recruited from Birmingham, Atlanta, and Miami) Gender: F Age: 50-79 yrs Race: B,H,W, N, A, O Risk: general Included low-income pops Results presented separately by ethnicity | RCT In each of the 3 sites, subjects were randomized to intv or con grp | Participation rate: 26% (total) Baseline sample size Intv grp: 1324 Con grp: 883 F/U 1 sample size Intv grp: 1071 Con grp: 649 F/U 2 sample size Intv grp: 698 Con grp: 443 F/U 3 sample size Intv grp: 285 Con grp: 194 Retention rate: ~ 75-85% (total) Comparison of drop-outs: NR | Intv grp Intv components: counseling sessions, individualized diet plan, set goals, behavior change strategies, monitored fat intake, role played Intv delivery: nutritionist Special features: ethnically specific, group sessions (social support) Nutr message: decrease fat to 20% energy, reduce sat fat and chol, increase F&V and grain Con grp Intv components: received Dietary Guidelines for Americans Theoretical perspective: NR | Group sessions met wkly for 6 wks, biwkly for 6 wks, monthly for 9 mos, and then quarterly (presumably for 2 yrs) Maintenance: NR | F/U 1: 6 mos after base F/U 2: 12 mos after base F/U 3: 18 mos after base | Variables: Fruit (servings/d) Veg (servings/d) Instrument: 100-item self-administered FFQ Statistics: mean diffs b/w intv and con grps determined by ANOVA | Fruit intake (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. mean diff b/w grps in chng (95% CI) at f/u 1: 0.37 (0.26 to 0.48) mean diffs b/w grps in chng (95% CI) at f/u 2: 0.42 (0.28 to 0.58) mean diffs b/w grps in chng (95% CI) at f/u 3: 0.53 (0.33 to 0.73) Veg intake Significance of effects: p for diffs b/w grps at base n.s. mean diff b/w grps in chng (95% CI) at f/u 1: 0.24 (0.13 to 0.35) mean diff b/w grps in chng (95% CI) at f/u 2: 0.31 (0.18 to 0.44) mean diff b/w grps in chng (95% CI) at f/u 3: 0.27 (0.07 to 0.47) Intention to treat: NR
  | Base | F/U
  Intv grp (n = 1,324): | 1.53 (1.13) | NR
  Con grp (n = 883): | 1.52 (1.09) | NR
  | Chng (f/u1) | Chng (f/u2) | Chng (f/u3)
  Intv grp (n NR): | .40 | .50 | .54
  Con grp (n NR): | .03 | .08 | .02
  | Base | F/U
  Intv grp (n = 1,324): | 1.62 (1.09) | NR
  Con grp (n = 883): | 1.65 (1.08) | NR
  | Chng (f/u 1) | Chng (f/u 2) | Chng (f/u 3)
  Intv grp (n NR): | .26 | .30 | .35
  Con grp (N NR): | .02 | - .01 | .08

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Coates, Bowen, Kristal, 1999 | Variables: total fat (% energy) total fat (g) sat fat (% energy) Other variables analyzed: sat fat (g) Instrument: 100-item self-administered FFQ Statistics: mean diffs b/w intv and con grps determined by ANOVA | Total fat (% energy; mean and sd) Significance of effects: p for diffs b/w grps at base n.s. mean diff in chng b/w grps (95% CI) at f/u1: -11.01 (-11.85 to -10.17) mean diff in chng b/w grps (95% CI) at f/u2: -11.30 (-12.35 to -10.25) mean diff in chng b/w grps (95% CI) at f/u3: -11.62 (-13.07 to -10.17) Total fat (g; mean and sd)) Significance of effects: p for diffs b/w grps at base n.s. mean diff in chng b/w grps (95% CI) at f/u 1: -31.9 (-36.0 to -27.9) mean diff in chng b/w grps (95% CI) at f/u 2: -28.1 (-32.6 to -23.7) mean diff in chng b/w grps (95% CI) at f/u 3: -27.8 (-34.8 to -20.8) Sat fat (% energy; mean and sd) Significance of effects: mean diff in chng b/w grps (95% CI) at f/u 1: -3.49 (-3.80 to -3.18) mean diff in chng b/w grps (95% CI) at f/u 2: -3.68 (-4.07 to -3.29) mean diff in chng b/w grps (95%CI) at f/u 3: -3.54 (-4.09 to -2.99) Intention to treat: NR | NR | Variables: TC (mg/dL) Instrument: fasting blood sample; plasma analyzed by standardized enzymatic assay Statistics: mean diffs b/w intv and con grps determined by ANOVA | TC (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u 3 n.s. Intention to treat: NR | NR | 70
  | Base | F/U
  Intv grp (n = 1,324): | 39.74 (7.11) | NR
  Con grp (n = 883): | 39.08 (7.04) | NR
  | Chng (f/u 1) | Chng (f/u 2) | Chng (f/u 3)
  Intv grp (n NR): | -13.34 | -14.34 | -14.17
  Con grp (N NR): | -2.33 | -3.05 | -2.54
  | Base | F/U
  Intv grp (n = 1,324): | 82.4 (47.3) | NR
  Con grp (n = 883): | 78.5 (44.2) | NR
  | Chng (f/u 1) | Chng (f/u 2) | Chng (f/u 3)
  Intv grp (n NR): | -43.5 | -43.4 | -43.4
  Con grp (N NR): | -11.6 | -15.3 | -15.5
  | Base | F/U
  Intv grp (n = 1,324): | 13.26 (2.84) | NR
  Con grp (n = 883): | 12.97 (2.82) | NR
  | Chng (f/u 1) | Chng (f/u 2) | Chng (f/u 3)
  Intv grp (n NR): | -4.21 | -4.54 | -4.40
  Con grp (N NR): | -0.71 | -0.86 | -0.87
  | Base | F/U
  Intv grp (n = 1324): | 219.0 (38.97) | NR
  Con grp (n = 883): | 218.8 (38.01) | NR
  | Chng F/U 1 | Chng F/U 2 | Chng F/U 3
  Intv grp (n NR): | -7.8 | -8.4 | -12.3
  Con grp (n NR): | -3.3 | -4.9 | -11.9

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
036 Bauer, Heller, Challah, 1985 U.K. Heart Disease Prevention Project | Setting: worksite Gender: M Age: 40-59 Race: NR Risk: general and CVD Country: U.K. | RCT 24 factories randomly allocated to an intv or con site; all workers in intv site invited to participate in intv, and a random 10% sample of workers in con site invited to participate; current study examines long-term results in 10 factories (5 intv and 5 con) chosen from original 24 factories | Participation rate (sites): NR Participation rate (subjects): 86% (total) Baseline sample size (sites) Intv grp: 12 worksites Con grp: 12 worksites Baseline sample size (subjects): NR F/U 1 sample size (sites): NR F/U 1 sample size (subjects) Intv grp: 2612 Con grp: 2932 F/U 2 sample size (sites) Intv grp: 5 worksites; 604 subjects Con grp: 5 worksites; 600 subjects Retention rate (sites): 42%* (total) Retention rate (subjects): 83** (total) Comparison of drop-outs: factories included in f/u 2 less likely to include smokers than factories not included; NR for subjects *retention rates refer to f/u 2, because the current study reports only data for f/u 2 **it is not clear that workers from the original study were re-sampled at f/u 2; the 83% may more accurately reflect a "response rate" for the f/u 2 survey | Intv Grp Intv components: general ed campaign using pamphlets, lectures, cooking demonstrations (for subjects' spouses), posters, and films; advice by mail and posters; personal advice by physician given to subset of high CVD risk subjects; smoking cessation, weight loss (in subjects >15% overweight), exercise, control hypertension Intv delivery: medical personnel at factories; physician (for CVD risk subset) Special features: NR Nutr message: reduce sat fat and chol, partial substitution by polyunsat fat Con Grp Intv components: NR Theoretical perspective: NR | Total duration of intv: 5-6 yrs Maintenance: NR | F/U 1: 5-6 yrs after base F/U 2: 12 yrs after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Bauer, Heller, Challah, 1985 | Variables*: fried foods (% usually frying foods) trim fat off meat (% usually trimming fat off meat) use skim milk (% using skim milk) Other variables analyzed: eggs <3 times/wk* sausages <3 times/wk* butter intake (data NR) Instrument: NR ("8 questions on diet") Statistics: chi-square *dietary intake not measured at base, and these items were not measured at f/u 1 | Fried foods (%; se/sd NR) Significance of effects: p for diffs b/w grps at f/u 2 <0.05 *variable not measured at base or f/u 1 Trim fat off meat (%; se/sd NR) Significance of effects: p for diffs b/w grps at f/u 2 <0.05 *variable not measured at base or f/u 1 Use skim milk (%; se/sd NR) Significance of effects: p for diffs b/w grps at f/u 2 <0.05 *variable not measured at base or f/u 1 Intention to treat: NR | Cheese: n.s. Milk: sig intv effect | NR | NR | NR | 43
  | Base* | F/U 1* | F/U 2
  Intv grp (n = 486): | NR | NR | 14%
  Con grp (n = 492): | NR | NR | 19%
  | Base* | F/U 1* | F/U 2
  Intv grp (n = 486): | NR | NR | 63%
  Con grp (n = 492): | NR | NR | 49%
  | Base* | F/U 1* | F/U 2
  Intv grp (n = 486): | NR | NR | 16%
  Con grp (n = 492): | NR | NR | 11%

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
200 Sorensen, Morris, Hunt, 1992 Treatwell | Setting: worksite (eligible worksites recruited from Massachusetts and Rhode Island; all employees in intv worksites were exposed to intv) Gender: M,F Age: 17-75 Race: NR Risk: general | RCT 16 eligible worksites identified, stratified by size and employee gender, and randomly assigned to intv or con condition; all employees in intv condition exposed to intv; employees randomly selected to participate in measurement | Participation rate (worksites): NR Participation rate (employees): 70% (total) Baseline sample size (worksites) Intv grp: 8 sites Con grp: 8 sites Baseline sample size (employees): 3076 (total) F/U sample size (worksites) Intv grp: 8 sites Con grp: 8 sites F/U sample size (employees): 2258 (total) Retention rate (worksites): 100%* Retention rate (employees): 74% (total) Comparison of drop-outs: non-responders less educated *although base and f/u data were collected from all 16 worksites, one intv worksite elected not to participate in the intv | Intv grp Intv components*: activities (kickoff event, chol screening, counseling and referral events, BBQ, parties, trade show); classes ("Eat Well" skill building class; "Wise Weight" weight management course; "Taking control" slide-tape presentation on cancer); goal setting; self-monitoring; ed materials; cafeteria modifications (offer low-fat, high-fiber options; point-of-choice food labeling); employee advisory board Intv delivery: nutritionists and dietitians; food service staff Special features: small group classes; family component (families of employees invited to participate in chol screenings and classes), food interactions Nutr message: decrease fat (to <30% energy); increase fiber (20-30 g/d) Con grp Intv components: no intv *the intv components were not standardized across worksites (although a core of 3 ed programs was offered at all intv sites); individual worksites tailored the intv Theoretical perspective: Community Organization Theory; Social Learning Theory; Diffusion of Innovation Theory; Adult Learning Theory | Classes ("Eat well": 7 sessions; "wise weights": 10 sessions; "Taking Control": 1 hr presentation); duration of other components NR; total duration of intv: 15 mos Maintenance: NR | 15 mos from base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Sorensen, Morris, Hunt, 1992 | Variables: total fat (% energy) Instrument: Willet 67-item semiquantitative FFQ Statistics: repeated measures ANOVA (employee effects nested within worksite effects) | Total fat (mean; sd/se NR) Significance of effects: p for tx*time interaction (F test =12.41) <0.01 Intention to treat: NR (only subjects with complete data at base and f/u included in analyses) | Fiber: n.s. | NR | NR | NR | 65
  | Base | F/U | Chng
  Intv grp [n NR]: | 34.3 | 32.6 | -1.70
  Con grp [n NR]: | 33.8 | 33.2 | -0.60
  [total n for analyses = 2011]

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
012 Hanlon, McEwen, Carey, 1995 | Setting: worksite (subjects recruited from large engineering factory) Gender: M,F Age: 20-65 yrs Race: NR Risk: General and CVD Country: Scotland | RCT subjects randomly selected from main intv site and randomly assigned to 1 of 4 intv grps or 1 internal con grp; another worksite served as an external con site | Participation rate Intv grp: 86% Con grp: 90% Baseline sample size Intv grp 1: 293 Intv grp 2: 297 Intv grp 3: 285 Intv grp 4: 263 Int con grp: 233 Ext con grp: 261 F/U sample size Intv grp 1: 247 Intv grp 2: 250 Intv grp 3: 241 Intv grp 4: 219 Int con grp: 200 Ext con grp: 246 Retention rate Intv grp: 84% Con grp: 94% Comparison of drop-outs NR | Intv Grps (4 intv groups)* Intv components: health ed package, interview, written info (intv grp 1) health ed package plus feedback on serum cholesterol (intv grp 2) health ed package plus feedback on CVD risk score (intv grp 3) health ed package plus feedback on serum cholesterol and CVD risk score (intv grp 4) Intv delivery: "counselors" Special features: NR Nutr message: NR Con Grp (2 con grps) Intv components: delayed intv (internal con grp) delayed intv (external con grp) Theoretical perspective: NR *results presented for intv grp 4 ("full health check") comp to internal con grp, and intv grp 4 comp to external con grp | Duration NR Maintenance: NR | 5 months after base | Variables: F&V (% of subjects who self-reported an increase) Instrument: NR Statistics: chi-square tests (comparing the n who made a positive change b/w grps) | F&V (%;sd/se NR) Comp b/w intv grp 4 and internal con grp Significance of effects: p for diffs b/w grps at base n.s. p for diff b/w grps at f/u (12.7) <.001 Comp b/w intv grp 4 and external con grp Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u (5.5): 0.12 Intention to treat: all results analyzed on the basis of intention to treat, with non-attenders deemed to have made no change
  | Base | F/U
  Intv Grp 4 (n = 263): | NR | 24.3%
  Intv Con Grp (n = 233): | NR | 11.6%
  | Base | F/U
  Intv Grp 4 (n = 263): | NR | 24.3%
  Ext Con Grp (n = 261): | NR | 18.8%

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Hanlon, McEwen, Carey, 1995 | Variables: fat (% of subjects who self-reported a decrease) Instrument: NR Statistics: chi-square tests (comparing the n who made a positive change b/w grps) | Fat (%;se/sd NR) Comp b/w intv grp 4 and internal con grp Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u (20.6) < 0.001 Comp b/w intv grp 4 and external con grp Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u (16.2) < 0.001 Intention to treat: all results analyzed on the basis of intention to treat, with non-attenders deemed to have made no change | Fiber: n.s. | Variables: TC (mmol/L) Instrument: NR Statistics: two sample t-tests | TC (mean and sd) Comp b/w intv grp 4 and internal con grp Significance of effects: p for diffs b/w grps at base n.s. p for diff in chng b/w grps at (0.13): 0.02 Comp b/w intv grp 4 and external con grp Significance of effects: p for diffs b/w grps at base n.s. p for diffs in chng b/w grps ( 0.17) <.001 Intention to treat: all results analyzed on the basis of intention to treat, with non-attenders deemed to have made no change | NR | 43
  | Base | F/U
  Intv grp 4 (n = 263): | NR | 30.0%
  Int con grp (n = 233): | NR | 9.4%
  | Base | F/U
  Intv grp 4 (n = 263): | NR | 30.0%
  Con grp (n = 261): | NR | 13.8%
  | Base | F/U | Chng
  Intv grp 4 (n NR): | 5.88(1.14) | NR | 0.16(.57)
  Int con grp (n NR): | 5.81(1.05) | NR | 0.03(.55)
  | Base | FIU
  Intv grp 4 (n = 263): | 5.88 (1.14) | NR
  Ext con grp (n = 261): | 5.66 (1.03) | NR
  | Chng
  Intv grp 4 (n = 263): | 0.16 (.57)
  Ext con grp (n = 261): | -0.01 (.59)

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
002 Sorensen, Thompson, Glanz, 1996 Working Well | Setting: Worksite (recruited through convenience sampling using different strategies) Gender: NR Age: NR Race: NR Risk: general Results presented separately for 4 categories of worksites Results presented separately by stage of change in Glanz, Patterson, Kristal, 1998 (# 013) | Randomized, matched pair design Worksites were stratified, matched into pairs, and randomly assigned within pairs to the intv or con grp; cross-sectional surveys of individuals conducted at base and f/u | Participation rate (worksites): NR Participation rate (individuals): Wave 1: 69% (total) Wave 2: 71% (total) Wave 1 sample size: 108 worksites; n of subjects NR Wave 2 sample size: 108 worksites; n of subjects NR Retention rate (worksites): 97% Retention rate (individuals): n/a (cross-sectional surveys at two time points) Comparison of drop-outs: NR | Intv grp Intv components: interactive activities, posters, brochures, self-assessment materials, campaigns and contests, classes, environmental changes (cafeteria, catering, and machine food choices improved); smoking cessation Intv delivery: NR Special features: NR Nutr message: increase F&V, increase fiber, decrease fat Con Grp Intv components: optional minimal intervention (posters, printed materials, survey results) Theoretical perspective: Stages of Change; Community Activation | 2 years Maintenance: NR | ~ 2.5 years after baseline | Variables: F&V (servings/d; log scale and back transformed) Instrument: 88-item semi-quantitative FFQ based on Block (1988); F&V servings calculated from 2 questions on the FFQ Statistics: mixed linear model (regarded as a weighted paired t-test); with worksite as the unit of analysis | F&V (mean; sd/se NR) Significance of effects: p for diff b/w grps at base n.s. p for diff b/w grps at f/u <.001 p for diff in chng b/w grps <.001
  | Base | F/U | Chng
  Intv grp (n = 108 sites): | 2.60 | 2.80 | .20
  Con grp (n = 108 sites): | 2.58 | 2.60 | .02

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Sorensen, Thompson, Glanz, 1996 | Variables: total fat (%energy) Instrument: 88-item semi-quantitative FFQ based on Block Statistics: mixed linear model (regarded as a weighted paired t-test); with worksite as the unit of analysis | Total fat (mean; sd/se NR) Significance of effects: p for diff b/w grps at base n.s. p for diff b/w grps at f/u n.s. p for diff in chng b/w grps: 0.03 | Fiber: n.s. | NR | NR | Results presented separately by stage of change in Glanz, Patterson, Kristal, 1998 (# 013) -- sig intv effect for stage of change | 70
  | Base | F/U | Chng
  Intv grp (n = 108 sites): | 36.71 | 34.64 | -2.07
  Con grp (n = 108 sites): | 36.70 | 35.00 | -1.70

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
182 Reynolds, Gillum, Hyman, 1997 | Setting: worksite (phone company employees recruited through advertisements at worksites) Gender: M,F Age: range NR; mean 41 yrs Race: W,H,B,A,N,O Risk: general Some results presented separately by chol level | RCT 4 worksites assigned to intv condition (with subjects randomly assigned to receive either "full intv" or "partial intv"), and 2 worksites assigned to control condition | Participation rate: NR Baseline sample size Intv grp 1: 236 Intv grp 2: 284 Con grp: 115 F/U 1 sample size: 452 (total) F/U 2 sample size: 412 (total) Retention rate: 71% (total) Comparison of drop-outs: NR | Intv Grps (2 intv grps) Intv components: received self-help booklet (Eat Right Kit) and told serum chol values (intv grp 1) received self-help booklet (Eat Right Kit) (intv grp 2) Intv delivery: n/a (self-help booklet, and chol results sent through mail) Special features: NR Nutr message: decrease sat fat and chol; increase complex carb Con Grp Intv components: no intv, but received the self-help booklet after final f/u Theoretical perspective: NR | Self-help kit designed to be completed in 13 wks ideally, but no duration data available Maintenance: NR | F/U 1: 3 mos after base F/U 2: 6 mos after base | Variables: "produce" (servings/wk) Instrument: 20-item FFQ Statistics: t-tests completed on difference scores (to assess whether chng occurring b/w measurements differed sig from 0); reg analyses (to compare the tx conditions at f/u 1 and f/u 2), controlling for baseline diet and demographic confounders | Produce (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for chng in intv grp 1 at f/u 2 n.s. p for chng in intv grp 2 at f/u 2 <0.001 p for chng in con grp at f/u 2 <0.0001 (con grp had largest increase in produce) Intention to treat: NR
  | Base | F/U1 | F/U2 | Chng
  Intv grp 1 (n NR): | 3.2(1.6) | NR | NR | 0.15
  Intv grp 2 (n NR): | 3.0(1.7) | NR | NR | 0.37
  Con grp (n NR): | 3.1(1.8) | NR | NR | 0.44

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Reynolds, Gillum, Hyman, 1997 | Variables: oils (n oil items used regularly) high fat meat (servings/wk) snacks (servings/wk) Instrument: 20-item FFQ; and list of 16 fats/oils used routinely Statistics: t-tests completed on difference scores (to assess whether chng occurring b/w measurements differed sig from 0); reg analyses (to compare the tx conditions at f/u 1 and f/u 2), controlling for baseline diet and demographic confounders | Oils (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for chng in intv grp 1 at f/u 2 <0.0001 p for chng in intv grp 2 at f/u 2 <0.001 p for chng in con grp at f/u 2 n.s. High fat meat (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for chng in intv grp 1 at f/u 2 <0.05 p for chng in intv grp 2 at f/u 2 <0.001 p for chng in con grp at f/u 2 n.s. Snacks (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for chng in intv grp 1 at f/u 2 <0.05 p for chng in intv grp 2 at f/u 2 <0.0001 p for chng in con grp at f/u 2 n.s. Intention to treat: NR | Low fat cheese: sig intv effect (for intv grp 2) Whole milk cheese: sig intv effect (for intv grp 1 and 2) | Variables: TC (mmol/L) Instrument: Reflotron Desktop Analyzers; quality control procedures of Boehringer Mannheim (1985); followed Statistics: t-tests completed on difference scores (within each condition to determine whether sig chng occurred b/w measurement waves); reg analyses (to compare the tx conditions at f/u 1 and f/u 2), controlling for baseline TC and demographic confounders | TC (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. sig reductions in all grps (including con) at f/u 1 and f/u 2 con grp had sig lower TC than intv grp 1 or intv grp 2 at f/u 1 (p<0.0001) p for diff b/w con grp and other intv grps at f/u 2: <0.08 p for one way ANOVA on chng scores (presumably for con grp comp to other grps) at f/u 1: <0.0001 p for one way ANOVA on chng scores (presumably for con grp comp to other grps) at f/u 2: <0.06 Intention to treat: NR | Perceived benefits of dietary chng: n.s. Perceived barriers to adopting a healthier diet: n.s. Intention to make dietary changes: n.s. Knowledge of dietary info: n.s. | 56
  | Base | F/U1 | F/U2 | Chng
  Intv grp 1 (n NR): | 2.3(1.1) | NR | NR | -0.58
  Intv grp 2 (n NR): | 2.5(1.1) | NR | NR | -0.35
  Con grp (n NR): | 2.3(1.0) | NR | NR | 0.02
  Base | F/U1 | F/U 2 | Chng
  Intv grp 1 (n NR): | 1.8(1.0) | NR | NR | -0.17
  Intv grp 2 (n NR): | 2.0(1.1) | NR | NR | -0.27
  Con grp (n NR): | 2.0(1.0) | NR | NR | -0.19
  | Base | F/U1 | F/U2 | Chng
  Intv grp 1 (n NR): | 1.7(0.9) | NR | NR | -0.15
  Intv grp 2 (n NR): | 1.9(0.9) | NR | NR | -0.20
  Con grp (n NR): | 1.8(1.1) | NR | NR | 0.09
  | Base | F/U1 | F/U 2
  Intv grp1: | 5.31(0.9) | 5.10 | 5.05
  [n] | | [n NR] | [n = 197] | [n = 195]
  Intv grp 2: | 5.26(0.9) | 5.09 | 5.05
  [n] | [n NR] | [n = 196] | [n = 195]
  Con grp: | 5.39(0.8) | 4.79 | 4.87
  [n] | [n NR] | [n = 185] | [n = 188]

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
204 Strychar, Champagne, Ghadirian, 1998 | Setting: workplace (employees from 6 hospitals recruited) Gender: M,F Age: NR (majority b/w 35-64) Race: NR Risk: general Country: Canada Some results presented separately by TC levels | RCT subjects systematically randomized into 1 of 2 intv grps | Participation rate: 69% (total) Baseline sample size: 500 (total) F/U sample size Intv grp 1: 216 Intv grp 2: 213< Retention rate: 86% (total) Comparison of drop-outs: NR | Intv Grp (2 intv grps) Intv components: both groups received nutr ed sessions; subjects' eating habits were evaluated; subjects signed behavior contract and received educational materials intv grp 1 was informed of current blood cholesterol level at baseline and f/u intv grp 2 was informed of current blood cholesterol level at f/u onlyIntv delivery: dietitian Special features: NR Nutr message: make dietary modifications based on individualized dietary evaluation (mostly involved decreasing high fat foods); decrease sat fat and total fat intake Con Grp (no con grp) Theoretical perspective: Social Learning Theory | 1 20-min ed session; mail reminder 6 wks later Maintenance: NR | 16-20 wks after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Strychar, Champagne, Ghadirian, 1998 | Variables: total fat (% energy) sat fat (% energy) Other variables analyzed: polyunsat fat monounsat fat p/s ratio Instrument: 24-hr recall (n of recalls NR), analyzed using CANDI Statistics: paired sample t-tests | Total fat (mean and 95% CI; sd/se NR) Significance of effects: chng from base to f/u sig for intv grp 1 but not intv grp 2 Sat fat (mean and 95% CI; sd/se NR) Significance of effects: p for diffs b/w grps at base n.s. p for chng for both intv grps <0.05 Intention to treat: NR | Fiber: n.s. | Variables: TC (mmol/L) Instrument: finger-stick sample (fasting status NR) analyzed using Boehringer Mannheim Reflotron; quality assurance monitored Statistics: paired sample t-tests to determine base and f/u diffs (Bonferroni method for multiple comp applied); multiple reg analysis, with diffs from base to f/u as dependent variable, and group status as independent variable (along with other independent variables) | TC (mean and 95% CI; sd/se NR)
  | Base | F/U
  Intv grp 1: | 33.5 (32.3;34.7) | 31.7 (30.5;33.0)
  [n] | [n = 216] | [n = 216]
  Intv grp 2: | 33.8 (32.6;34.9) | 32.9 (31.8;34.1)
  [n] | [n = 213] | [n = 213]
  | Chng
  Intv grp 1 (n = 216): | -1.8 (-3.4 to -0.2)
  Intv grp 2 (n = 213): | -0.8 (-2.3 to 0.6)
  | Base | | F/U
  Intv grp 1: | 12.0 (11.4;12.6) | 11.1 (10.5;11.7)
  [n] | [n = 216] | [n = 216]
  Intv grp 2: | 12.5 (11.9;13.1) | 11.5 (11.0;12.1)
  [n] | [n = 213] | [n = 213]
  | Chng
  Intv grp 1 (n = 216): | -0.9 (-1.7 to -0.1)
  Intv grp 2 (n = 213): | -0.9 (-1.6 to -0.2)
  | Base | F/U
  Intv grp 1: | 5.1 (5.0 to 5.2) | 4.8 (4.7 to 4.9)
  [n] | [n = 216] | [n = 216]
  Intv grp 2: | 5.4 (5.2 to 5.5) | 5.1 (5.0 to 5.2)
  [n] | [n = 213] | [n = 213]
  | Chng
  Intv grp 1 (n = 216): | -0.3 (-0.3 to -0.2)
  Intv grp 2 (n = 213): | -0.2 (-0.3 to -0.2)
Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u n.s. p for chng for both intv grps <0.001 Intention to treat: NR | | NR | 66

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
022 Anderson and Dusenbury, 1999 Worksite Cholesterol and Nutrition Intervention Project | Setting: worksite (recruitment of worksites NR: workers screened for dyslipidemia and recruited from selected worksites) Gender: M,F Age: 18-64 yrs Race: H,W Risk: CVD | quasi-experimental 8 worksites randomly assigned to intv or con conditions; employees within intv sites chose which of two intvs to receive | Participation rate (worksites): NR Participation rate (individuals): NR Baseline sample size (individuals) Intv grp 1: 64 Intv grp 2: 52 Con grp: 118 F/U 1 sample size (individuals) Intv grp 1: 50 Intv grp 2: 41 Con grp: 276 F/U 2 sample size (individuals) Intv grp 1: 35 Intv grp 2: 26 Con grp: 61 Retention rate (individuals) Intv grp 1: 78% Intv grp 2: 79% Con grp: 233% Comparison of drop-outs: NR | Intv Grps (2 grps) Intv components: group ed classes (intv grp 1) indiv self-help program (intv grp 2) both groups received info about risk factors (such as blood pressure, smoking, exercise, dietary guidelines) Intv delivery: NR Special features: NR Nutr message: foods to increase/decrease Con Grp Intv components: standard health messages delivered by nurse Theoretical perspective: NR | (intv grp 1) 4 classes (intv grp 2) 4 lessons (con grp) 1 20 min session duration of total intv NR Maintenance: NR | F/U 1: 6 mos after base F/U 2: 12 mos after base | Variables: F&V (servings/d) Instrument: 28 item FFQ modified from BRFSS Statistics: General Linear Model, sex and age adjusted for baseline and 12 mos; for the difference, sex, age, and base values were adjusted | F&V (mean; sd/se NR) Significance of effects: p (for diffs b/w grps) at base n.s. p (for means or % change b/w grps) at f/u 2 n.s.
  | Base | F/U1 | F/U2 | % chng
  Intv grp 1 (n = 35): | 2.2 | NR | 2.9 | 25.9%
  Intv grp 2 (n = 26): | 2.9 | NR | 2.4 | -11.3%
  Con grp (n = 61): | 2.4 | NR | 2.4 | 0%

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Anderson and Dusenbury, 1999 | Variables: total fat (g) Instrument: 28 item FFQ modified from Behavioral Risk Factor Surveillance System Statistics: General Linear Model, sex and age adjusted for baseline and 12 mos; for the difference, sex, age, and base values were adjusted | Total fat (mean; se/sd NR) Significance of effects: p for diff b/w con grp and intv grps 1 and 2 at base: 0.04 p for diffs b/w the 3 grps at f/u 2 n.s. | Fiber: n.s. | Variables: TC (mg/dL) Instrument: NCEP guidelines, used Boehringer Mannheim Reflotron testing equipment (fasting status NR) Statistics: GLM adjusted to age and sex and baseline measure (% diff) | TC (mean; se/sd NR) Significance of effects: p for diff b/w grps at base n.s. p for % change at f/u 1 and 2 n.s. | Individual attitudinal items: "less fat is important": sig. intv. effect "less fat decreases cholesterol": sig. intv. effect "F&V are healthy": n.s. "I will eat less fat": n.s. | 51
  Base | F/U1 | F/U2 | % chng
  Intv grp 1 (n = 35): | 45.1 | NR | 43.8 | 1.6%
  Intv grp 2 (n = 26): | 57.3 | NR | 42.0 | -17.3%
  Con grp (n = 61): | 37.8 | NR | 33.6 | -11.7%
  | Base | F/U 1 | F/U 2
  Intv grp 1: | 238.3 | 223.4 | 212.3
  [n] | [n = 61] | [n = 50] | [n = 35]
  Intv grp 2: | 228.7 | 222.1 | 216.7
  [n] | [n = 35] | [n = 41] | [n = 26]
  Con grp): | 242.0 | 221.9 | 213.1
  [n] | [n = 118] | [n = 76] | [n = 61]
  | % Chng (F/U1) | % Chng (F/U 2)
  Intv grp 1: | -5.7 | -7.9
  [n] | [n = 50] | [n = 35]
  Intv grp 2: | -3.6 | -3.9
  [n] | [n = 41] | [n = 26]
  Con grp: | -5.0 | -9.5
  [n] | [n = 76] | [n = 61]

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
324 Buller, Morrill, Taren, 1999 | Setting: worksite (labor and trades blue-collar employees from 10 public employers recruited) Gender: M,F Age: range NR; mean 41-43 yrs Race: W,H,N,B,O Risk: general low-income populations | RCT employees from 10 employers recruited; the unit of matching and randomization was the informal social network (cliques); one clique within each pair was randomly assigned to intv or con grp; pairs were rematched at interim survey; peer leaders within cliques identified and chosen to deliver intv | Participation rate (employees): 83% Participation rate (worksites): NR Baseline sample size: 2091 (total) Pre-intv sample size: Intv grp: 41 cliques; 373 employees Con grp: 41 cliques; 350 employees F/U 1 sample size: Intv grp: 41 cliques; 338 employees Con grp: 41 cliques; 326 employees F/U 2 sample size Intv grp: 41 cliques; 314 employees Con grp: 41 cliques; 285 employees Retention rate (cliques) Intv grp: 100% Con grp: 100% Retention rate (employees) Intv grp: 91% Con grp: 93% Comparison of drop-outs: NR | Intv grp Intv components: General Five a Day Program included workplace mail, cafeteria promotions, speakers; program activities; Five a Day Peer Ed Program included training peer educators (through role playing, group discussions, presentations), distributing printed materials; informal discussions; newsletter Intv delivery: peer educators; managers; guest speakers Special features: small groups, social networks, ethnically specific messages Nutr messages: increase F&V intake Con grp Intv components: received only General Five a Day Ed program (no peer ed) Theoretical perspective: theory to use paraprofessionals | Program activities every other month; total duration of General Five a Day Program: 18 mos; peer education program 9 mos (conducted during the last 9 mos of the general program); contact b/w peer educators and workers: 2 hrs/wk Maintenance: NR | F/U 1: 18 mos after base F/U 2: 24 mos after base | Variables: F&V servings/d (using recall) F&V servings/d (using FFQ) Other variables analyzed: fruit (recall) fruit (FFQ) veg (recall) veg (FFQ) juice (recall) juice (FFQ) Instrument: 1 24-hr dietary recall 7-item FFQ Statistics: analyses based on clique-level averages; linear reg was used, with the diff b/w changes from base to f/u b/w intv and con cliques as the dependent variable; intv effect determined by significance of alpha | F&V (recall method; mean and sd) Significance of effects: p for alpha intv effect (a=0.77) at f/u 1: 0.0001 p for alpha intv effect (a=0.41) at f/u 2: 0.034 F&V (FFQ method; mean and sd) Sig effect p for alpha intv effect (a = 0.46) at f/u1: 0.002 p for alpha intv effect (a = -0.04) at f/u 2: 0.743 Intention to treat: NR
  | Base | F/U 1
  Intv grp (n = 41 cliques): | 3.32(0.88) | 4.33(0.88)
  Con grp (n = 41 cliques): | 3.55(1.16) | 3.79(1.14)
  | F/U 2
  Intv grp (n = 41 cliques): | 3.81 (1.01)
  Con grp (n = 41 cliques): | 3.64 (1.48)
  | Base | F/U 1
  Intv grp (n = 41 cliques): | 2.80(0.64) | 3.74(0.85)
  Con grp (n = 41 cliques): | 3.00(0.73) | 3.48(1.17)
  | F/U 2
  Intv grp (n = 41 cliques): | 3.24 (0.64)
  Con grp (n = 41 cliques): | 3.47 (1.16)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Buller, Morrill, Taren, 1999 | NR | NR | NR | NR | NR | Knowledge of appropriate F&V servings: sig intv effect Confusion about what to eat: sig intv effect Beliefs that food is impt to health: sig intv effect Info about healthy eating available at work: sig intv effect Eating F&V impt to me: n.s. Hard to get F&V at work: n.s. Awareness of 5 a Day: sig intv effect | 83

Evidence Table 3. Interventions to modify dietary behavior: Worksite settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
001, 331 Tilley, Glanz, Kristal, 1999 Kristal, Glanz, Tilley, 2000 Next Step Trial | Setting: worksite (worksites recruited from all automotive sites in Canada meeting criteria; all workers within each site screened) Gender : M,F Age : range NR; mean 57 yrs Race : W,B,O Risk : cancer Country: Canada Analyses presented separately by employment status, age, and participation in intv | RCT 28 worksites randomized (13 to con, 15 to intv) based on geographic location, n of employees, and work type; all employees (including retired or layoff) offered screening | Participation rate (worksites): 93% (total) Participation rate (individuals): Intv grp: 61% Con grp: 55% Baseline sample size: Intv grp: 15 sites; 1578 individuals Con grp: 13 sites; 1899 individuals F/U 1 sample size: 2810 individuals (total) F/U 2 sample size: 2765 individuals (total) Retention rate (individuals): 57% (total) Comparison of drop-outs: responders were older, Caucasian, male, married, retired, and better educated | Intv Grp Intv components: nutr classes (based on National Center for Health Promotion program); focused on developing skills, setting goals; mailed self-help materials, personalized dietary feedback; cafeteria food choices Intv delivery: NR Special features: family component, social support Nutr message: decrease total fat intake, increase fiber, increase F&V Con Grp Intv components: no intv (offered the intv in the final year of study funding) Theoretical perspective : Health Belief Model, Social Learning Theory, Stages of Change, Social Support theory | 5 nutr classes in first yr; posters and personalized feedback in second yr; quarterly newsletter throughout intv; total duration of intv: 2 yrs Maintenance: NR | F/U 1: 1 yr post-randomizat. F/U 2: 2 yrs post-randomizat. | Variables: F&V (servings/d) Fruit (servings/d) Veg (servings/d) Instrument: FFQ modified from NCI Health Habits and History, completed through mail Statistics: diff b/w change in intv and con worksites determined by reg models, with dependent variable being change from base, independent variable being tx grp (intv vs con), and covariates that included base values, and demographic characteristics that differed b/w intv and con worksites | F&V (mean and se) Significance of effects: p for diffs b/w grps at base:0 70 intv effect (least squares means from reg model) for f/u 1: 0.21 (0.05), p: 0.001 intv effect (least squares means from reg model) for f/u 2: 0.10 (0.05), p: 0.08 Fruit (mean and se) Significance of effects: p for diffs b/w grps at base: 0.75 intv effect (least squares means from reg model) for f/u 1: .12 (0.04), p : 0.02 intv effect (least squares means from reg model) for f/u 2: .07 (0.05), p : 0.13 Veg (mean and se) Significance of effects: p for diffs b/w grps at base: 0.93 intv effect (least squares means from reg model) for f/u 1: 0.10 (0.03), p : 0.004 intv effect (least squares means from reg model) for f/u 2: 0.03 (0.02), p : 0.20 Intention to treat: used a modified intention to treat approach; conducted additional analyses with imputed values for missing cases and found identical results
  | Base | F/U1 | F/U 2
  Intv grp: | 3.35 (0.05) | 3.56 (0.04) | 3.62 (0.04)
  Con grp: | 3.38 (0.06) | 3.35 (0.05) | 3.52 (0.05)
  [total n] | [n = 2836] | [n = 2810] | [n = 2765]
  | Base | F/U1 | F/U 2
  Intv grp: | 1.62 (0.04) | 1.74 (0.04) | 1.80 (0.04)
  Con grp: | 1.64 (0.04) | 1.63 (0.03) | 1.73 (0.04)
  [total n] | [n = 2836] | [n = 2810] | [n = 2765]
  | Base | F/U1 | F/U 2
  Intv grp: | 1.73 (0.04) | 1.81 (0.02) | 1.81 (0.03)
  Con grp: | 1.74 (0.02) | 1.72 (0.02) | 1.79 (0.03)
  [total n] | [n = 2836] | [n = 2810] | [n = 2765]

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Tilley, Glanz, Kristal, 1999 Kristal, Glanz, Tilley, 2000 | Variables: total fat (% energy) Instrument: FFQ modified from NCI Health Habits and History, completed through mail Statistics: diff b/w change in intv and con worksites determined by reg models, with dependent variable being change from base, independent variable being tx grp (intv vs con), and covariates that included base values, and demographic characteristics that differed b/w intv and con worksites | Total fat (mean and se) Significance of effects: p for diffs b/w grps at base: 0.42 intv effect (least squares means from reg model) for f/u 1: -0.9 (0.3), p: 0.004 intv effect (least squares means from reg model) for f/u 2: -0.5 (0.4), p: 0.19 Intention to treat: used a modified intention to treat approach; conducted additional analyses with imputed values for missing cases and found identical results | Fiber: sig intv effect (at 1 and 2 yrs) | NR | NR | Predisposing factors (motivation, beliefs, and knowledge): sig intv effect Enabling factors (social support, norms, workplace environment): n.s. Fat stage of change: p value NR Fiber stage of change: p value NR | 70
  | Base | F/U1 | F/U 2
  Intv grp: | 37.2 (0.3) | 35.6 (0.3) | 35.0 (0.4)
  Con grp: | 36.7 (0.2) | 36.4 (0.2) | 35.5 (0.2)
  [total n] | [n = 2836] | [n = 2810] | [n = 2765]

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
201 Stern, Farquhar, Maccoby, 1976 Stanford 3 Community Study | Setting: community mass media campaign (subjects recruited from households in 3 communities) Gender: M,F Age: 35-59 yrs Race: NR Risk: general and high CVD Results presented separately by gender | Design unclear 3 communities selected (2 assigned to intv conditions and 1 to con); subjects within communities selected randomly for survey participation | Participation rate: NR Baseline sample size Intv grps 1and 2: 833 (total) Intv grp 3: 659 Con grp: 659 F/U 1 sample size: NR F/U 2 sample size Intv grps 1and 2: 423 (total) Intv grp 3: 397 Con grp: 384 Ret rate (final f/u pt): 56% (total sample) Comparison of drop-outs: NR | Intv grps (3 intv grps) Intv components: multimedia campaign, including direct mailings of info booklets and cookbooks, newspaper columns, public service announcements, other communications; mass media campaign plus "intensive instruction" about diet, smoking, exercise, and weight for high CVD risk subjects (intv grp 1); "reconstituted" sample of community receiving intv 1, with the effects of the intensive instruction removed (mass media only) (intv grp 2); mass media campaign only (intv grp 3) Intv delivery: media (all grps); physician (intv grp 1 only); health counselor (intv grp 1 only); dietitian (intv grp 1 only) Special features: family component (for intv grp 1 only); ethnically specific (intv was bilingual) Nutr message: decrease chol and sat fat, increase polyunsat fat Con grp Intv components: no intv Theoretical perspective: Cartwright model of mass persuasion | Mass media component: 2 yrs intensive instruction: initial interview with physician, then 9 grp counseling sessions (from 1.5 to 3.5 hrs); tot duration of intensive instruction: 3.5 mos Maintenance: several f/u contacts during yr 2 (intv grp 1 only) | F/U 1: 1 yr after base F/U 2: 2 yrs after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Stern, Farquhar, Maccoby, 1976 | Variables: sat fat (g) sat fat (g/100 lbs body wt) Other variables analyzed: polyunsat fat p/s ratio Instrument: dietary questionnaire with 47 questions about frequency of food items containing fat, chol, refined sugars, and alcohol Statistics: paired t-tests; non-paired t-tests | Sat fat (g; means and se presented in figures, but actual values NR) Men Significance of effects: p for chng (base to f/u 2) in intv grp 1 <.001 p for chng (base to f/u 2) in intv grp 2 <.001 p for chng (base to f/u 2) in intv grp 3 <.001 p for chng (base to f/u 2) in con grp <.005 p for diff in chng b/w intv grp 1 and intv grp 2 n.s. p for diff in chng b/w intv grp 2 and intv grp 3 n.s. p for diff in chng b/w intv grp 3 and con grp <.001 p for diff in chng b/w intv grp 2 and con grp 0.01 Women Significance of effects: p for chng (base to f/u 2) in intv grp 1 <.001 p for chng (base to f/u 2) in intv grp 2 <.001 p for chng (base to f/u 2) in intv grp 3 <.001 p for chng (base to f/u 2) in con grp n.s. p for diff in chng b/w intv grp 1 and intv grp 2 n.s. p for diff in chng b/w intv grp 2 and intv grp 3 n.s. p for diff in chng b/w intv grp 3 and con grp <.001 p for diff in chng b/w intv grp 2 and con grp <.001 Sat fat (g/100 lbs body wt; means and se) Significance of effects: NR Significance of effects: NR Intention to treat: NR | NR | Variables: TC (mg%) TC (mg% corrected for postural effect) Instrument: fasting blood samples; chol concentrations determined simultaneously on a zeolite-treated isopropanol extract of plasma using an AutoAnalyzer II based on Lipid Res Clinics Manual of Lab. Methods procedure Statistics: NR | TC (mg%; means and se) Significance of effects: NR Significance of effects: NR TC (mg% corrected for postural effect; means; se NR) Significance of effects: NR Significance of effects: NR Intention to treat: NR | NR | 68
  Men
  | Base | F/U1 | F/U 2
  2
  Intv grps 1 and 2 (n NR): | 23.5 (0.9) | NR | NR
  Intv grp 3 (n NR): | 25.6 (0.8) | NR | NR
  Con grp (n NR): | 23.1 (0.8) | NR | NR
  Women
  | Base | F/U1 | F/U 2
  2
  Intv grps 1 and 2 (n NR): | 23.8 (0.8) | NR | NR
  Intv grp 3 (n NR): | 22.5 (0.7) | NR | NR
  Con grp (n NR): | 19.5 (0.6) | NR | NR
  Men
  | Base | F/U 1
  Intv grp 1 (n NR): | 226.3 (6.0) | NR
  Intv grp 2 (n NR): | 214.4 (3.3) | NR
  Intv grp 3 (n NR): | 214.8 (3.0) | NR
  Con grp (n NR): | 210.7 (2.8) | NR
  | F/U 2 | Chng (f/u2)
  Intv grp 1 (n NR): | 225.8 (5.4) | -0.5
  Intv grp 2 (n NR): | 214.5 (3.3) | +0.1
  Intv grp 3 (n NR): | 214.4 (3.0) | -0.4
  Con grp (n NR): | 217.6 (2.7) | +6.9
  Women
  | Base | F/U 1
  Intv grp 1 (n NR): | 239.4 (6.4) | NR
  Intv grp 2 (n NR): | 209.4 (3.4) | NR
  Intv grp 3 (n NR): | 210.3 (2.6) | NR
  Con grp (n NR): | 207.5 (2.8) | NR
  | F/U 2 | Chng (f/u2)
  Intv grp 1 (n NR): | 236.1 (7.1) | -2.9
  Intv grp 2 (n NR): | 214.7 (3.3) | +5.3
  Intv grp 3 (n NR): | 210.7 (2.5) | +0.4
  Con grp (n NR): | 216.4 (2.6) | +8.9
  Men
  | Base | F/U1 | F/U2 | Chng
  Intv grp 1 (n NR): | 233.1 | NR | NR | -7.3
  Intv grp 2 (n NR): | 220.8 | NR | NR | -6.3
  Intv grp 3 (n NR): | 221.2 | NR | NR | -6.8
  Con grp (n NR): | 217.0 | NR | NR | +0.6
  Women
  | Base | F/U1 | F/U2 | Chng
  Intv grp 1 (n NR): | 246.5 | NR | NR | -10.4
  Intv grp 2 (n NR): | 215.7 | NR | NR | -1.0
  Intv grp 3 (n NR): | 216.6 | NR | NR | -5.9
  Con grp (n NR): | 213.7 | NR | NR | +2.7

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
053 Jaycox, Baranowski, Nader, 1983 Family Health Project | Setting: community Gender: NR Age: 3rd-6th graders Race: NR Risk: NR | NR | Participation rate: NR Baseline sample size* Intv grp: 23 Con grp: 19 F/U sample size Intv grp: 16 (n used in analyses) Con grp: 15 (n used in analyses) Ret. rates: NR Comparison of drop-outs: NR *the current article focuses on a subsample of children who participated in the family intv | Intv grp Intv components: separate sessions for children and parents; children's component included activities (picture sorting; identification of high sodium and fat foods; label reading; Am Heart Assoc films; stories; low-salt and low sat fat snacks; family role playing) Intv delivery: older peers; delivery of other components NR Special features: family component, small group, social support, food interactions Nutr message: decrease sat fat and sodium Con grp Intv components: NR Theoretical perspective: Social Learning Theory; Social Support Theory | 8 wkly evening sessions (children's component: 25 mins) Maintenance: NR | NR (presumably 8 wks after base) | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Jaycox, Baranowski, Nader, 1983 | Variables: "foods high in sat fat" (units NR) Instrument: NR ("self-administered instrument to assess the frequency of consumption of foods high in sat fat) Statistics: one-way ANOVA comparing the intv and con grps | Foods high in sat fat (means and sd) Significance of effects: p for diffs b/w grps at base n.s. p for diffs b/w grps at f/u <0.05 p for diffs b/w grps in chng scores <0.05 *chng score only computed for subjects with both base and f/u data | NR | NR | NR | NR | 28
  | Base | F/U | Chng score*
  Intv grp: | 4.78(1.53) | 3.01(1.40) | 1.493(1.99)
  [n] | [n = 23] | [n = 16] | [n = 16]
  Con grp: | 5.04(2.24) | 4.76(2.61) | .401(2.84)
  [n] | [n = 19] | [n = 15] | [n = 15]

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
153 Nader, Baranowski, Vanderpool, 1983 Family Health Project | Setting: community/ school (families recruited from media advertisements) Gender: M,F Age: families of 3rd-6th graders (adults b/w 24-44 yrs; children b/w 6-16 yrs) Race: W,B,H Risk: general | RCT 24 families randomly assigned within ethnic grps to intv or con grps | Participation rate: NR Baseline sample size Intv grp: 42 individuals Con grp: 36 individuals F/U sample size Intv grp: 30-34 (n's used in analyses) Con grp: 26-30 (n's used in analyses) Ret. rate Intv grp: ~ 76% Con grp: ~ 78% Comparison of drop-outs: NR | Intv grp Intv components: family ed sessions and discussion (set goals, overcome barriers, role-playing, problem-solving); low-fat, low-salt snacks; printed educational materials; aerobic exercise Int delivery: group facilitators, small groups, food interactions, goal setting Special features: family component; social support; ethnically homogenous grp sessions Nutr message: decrease sat fat and sodium Con grp Intv components: received printed materials; offered abbreviated delayed intv Theoretical perspective: Social Learning Theory | 8 wkly sessions (1.5 hrs in duration) Maintenance: NR | 12 wks after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Nader, Baranowski, Vanderpool, 1983 | Variables: total sat fats (index score that estimates the n of times/day sat fat items were consumed) cheeses or cheese products* (units NR) cakes,cookies, stuffing, tortillas, or pie crusts with butter, lard, animal fat, or Crisco* (units NR) *these foods were classified as "high sat fat foods"; only sig results were presented in the article; the other 10 categories of high sat fat foods were NR Other variables analyzed: skim milk 10 other categories of high sat fat foods Instrument: frequency estimates of food categories (13 categories of high sat fat foods) with 6-category response scales ("never" to "more than once a day") Statistics: ANOVA, ANCOVA (effects of tx, age, ethnicity on changes in consumption frequencies) | Sat fats (means and sd) Significance of effects: p for tx effect on change scores <0.05 Cheese products Means NR Significance of effects: p for diff in chng b/w grps <0.005 Cakes, etc Means NR Significance of effects: p for diffs in chng b/w grps < 0.10 Intention to treat: NR | Bread or bread products: sig intv effect | Variables: NR Instrument: serum lipoprotein analyses conducted by Baylor Lipid Research Clinic laboratory (fasting status NR) Statistics: NR | Statistics NR, but text stated that no sig grp diffs b/w intv and con grps were obtained for serum lipoproteins | Total CVD risk knowledge: sig intv effect Sat fat knowledge: sig intv effect | 61
  | Base | F/U | Chng
  Intv grp (n = 31): | NR | NR | 1.63 (1.8)
  Con grp (n = 28): | NR | NR | 0.38 (2.2)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
154 Nader, Sallis, Patterson, 1989 San Diego Family Health Project | Setting: school (families recruited from elementary schools) Gender: M,F Age: families of 5th and 6th graders Race: H,W Risk: general analyses separate for adults and children; separate for Anglo and Mexican | Design not clear Blind pairing into intv or con conditions preceded recruitment; 12-15 elementary schools matched for SES of neighborhoods of families of attending (presumably intv) students | Participation rate: 26% (total Anglo families); 46% (total Mexican-Am families) Baseline sample size: 623 individuals (206 families total) F/U sample size: NR Ret rates: 89% (total) Comparison of drop-outs: NR | Intv grp Intv components: group sessions; healthy snack; self-monitoring, goal setting, modeling; exercise portion Intv delivery: graduate students Special features: family component; culturally specific; small groups; social support, food interactions Nutr message: decrease high-fat, (sat fat) high-salt food Con Grp Intv components: NR Theoretical perspective: Social Learning Theory | 12 wkly grp meetings (1.5 hrs in length) 3 mos of intensive wkly intv Maintenance: 9 mos of monthly or bimonthly maintenance sessions (6 total maintenance sessions) | 24 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Nader, Sallis, Patterson, 1989 | Variables: total fat (% energy) fat score index of low-fat, low-sodium foods to high-fat, high-sodium foods Instrument:24-hr recall, modified for use with children and scored at Univ of Minnesota Nutr Coordinating Center (used to derive % energy from total fat) 3-day food records (2 wkdays; 1 wkend day) used to derive 3-day "fat score" 36-item FFQ (used to create index of low-fat, low-sodium foods to high-fat, high-sodium foods) Statistics: Repeated measures ANCOVA (conducted separately for Anglo-Am adults, Anglo-Am children, Mexican-Am adults, and Mexican-Am children) | Total fat (% energy) ("post-intv shift") Anglo-Am adults (n NR) -5.6 (p = .0001) Anglo-Am children(n NR) NR (p n.s.) Mexican-Am adults (n NR) NR (p n.s.) Mexican-Am children (n NR) NR (p n.s.) Fat score ("post-intv shift") Anglo-Am adults (n NR) -6.2 (p =.0001) Anglo-Am children (n NR) -4.41 (p =.0005) Mexican-Am adults (n NR) NR (p n.s.) Mexican-Am children (n NR) NR (p n.s.) Index of low-fat, low-sodium foods ("post-intv shift") Anglo-Am adults (n NR) 0.242 (p = .0001) Anglo-Am children (n NR) 0.116 (p = .02) Mexican-Am adults (n NR) 0.244 (p = 0001) Mexican-Am children (n NR) 0.135 (p = .002) Intention to treat: NR | NR | Variables: LDL-C (mg/dL) Instrument: fasting venous blood sample analyzed using Lipid Research Clinic procedures Statistics: Repeated measures ANCOVA (conducted separately for Anglo-Am adults, Anglo-Am children, Mexican-Am adults, and Mexican-Am children) | LDL-C ("post-intv shift") Anglo-Am adults (n NR) -0.351 (p = .01) Anglo-Am children(n NR) NR (p n.s.) Mexican-Am adults (n NR) NR (p n.s.) Mexican-Am children (n NR) NR (p n.s.) Significance of effects: sig chge for Anglo-Am families (t value = 2.14, p = 0.036), but not for Mex-Am families Intention to treat: NR | Knowledge of fat and salt intake (and physical activity): sig intv effect (for all grps except Anglo adults) | 75

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
034 Baranowski, Henske, Simons-Morton,1990 | Setting: community ed center (families recruited from all Black students in 5th-7th grades in local school system) Gender: M,F Age: family members of 5th-7th graders (mean age of adults 32, mean age of children 10) Race: B Risk: general Separate analyses for mothers, boys, and girls; depending on n of sessions attended (0-1, less than half, or more than half) | RCT families randomly assigned to intv or con grp | Participation rate: NR Baseline sample size: Intv grp: 50 families (n = 127 indiv) Con grp: 46 families (n = 107 indiv) F/U sample size: Intv grp: (n = 103 indiv) Con grp:(n = 95 indiv) Retention Rate (indivs): Intv grp: 81% Con grp: 89% Comparison of drop-outs: NR | Intv Grp * Intv components: group ed, behavioral family counseling, goal setting, healthy snack, problem solving, aerobic activity Intv delivery: nutritionist, health educator, exercise physiologist, aerobics instructor Special features: whole family counseling, family intervention, culturally/ethnically specific Nutr. message: decrease sodium, tot fat, and sat fat intake Con Grp Intv components: no intv *Subjects classified into 3 intv "dose" groups: -attending 0-1 session (low) -attending less than half of the sessions (med) -attending more than half of the sessions (high) Theoretical perspective: Social Cognitive Theory, Social Support Theory; Adult Education Theory | 1.5-hr sessions (encouraged to attend 3/wk) wkly for 14 wks Maintenance: NR | 14 wks after baseline (immediately following intv) | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Baranowski, Henske, Simons-Morton, 1990 | Variables: high total fat foods (mean n of times consumed high total fat foods per 2 wks) high sat fat foods (mean n of times consumed high sat fat foods per 2 wks) low total fat foods (mean n of times consumed low total fat foods per 2 wks) Other variables analyzed: high polyunsat foods Instrument: 159 item FFQ Statistics: 2-way ANOVA, with tx grp and participant type (mothers, boys, girls) as factors, separately by intv "dose" | High total fat foods (means; sd/se NR) Significance of effects: main effect across attendance grps (p<.05); con grp and low attendance grp sig diff from med attendance grp (p<.05) High sat fat foods (means; sd/se NR) Significance of effects: main effect across attendance groups (p<.05); main effect across type of participant grps (mothers and boys diff, p< .005); med attendance grp differed from con grp and low attendance grp Low total fat foods (means; sd/se NR) Significance of effects: p (for all effects) n.s. | High calcium foods: sig intv effect | NR | NR | Behav capability: n.s. Self-efficacy: n.s. | 61
  Mothers | Base | F/U
  Intv grp - low (n = 14): | NR | 45.0
  Intv grp - med (n = 22): | NR | 35.9
  Intv grp - high (n = 9): | NR | 30.0
  Con grp (n = 43): | NR | 58.8
  Boys | Base | F/U
  Intv grp - low (n = 8): | NR | 77.5
  Intv grp - med (n = 16): | NR | 37.6
  Intv grp - high (n = 6): | NR | 53.2
  Con grp (n = 19) | NR | 58.2
  Girls | Base | F/U
  Intv grp - low (n = 11): | NR | 50.2
  Intv grp - med (n = 12): | NR | 35.3
  Intv grp - high (n = 5): | NR | 33.4
  Con grp (n = 33): | NR | 55.5
  Mothers | Base | F/U
  Intv grp - low (n = 14): | NR | 25.6
  Intv grp - med (n = 22): | NR | 14.7
  Intv grp - high (n = 9): | NR | 15.7
  Con grp (n = 43) | NR | 29.3
  Boys | Base | F/U
  Intv grp - low (n = 8): | NR | 51.6
  Intv grp - med (n = 16): | NR | 24.5
  Intv grp - high (n = 6): | NR | 29.3
  Con grp (n = 19): | NR | 33.5
  Girls | Base | F/U
  Intv grp - low (n = 11): | NR | 28.5
  Intv grp - med (n = 12): | NR | 20.3
  Intv grp - high (n = 5): | NR | 15.0
  Con grp (n = 33): | NR | 29.6
  Mothers | Base | F/U
  Intv grp - low (n = 14): | NR | 63.7
  Intv grp - med (n = 22): | NR | 59.5
  Intv grp - high (n = 9): | NR | 51.7
  Con grp (n = 43): | NR | 70.2
  Boys | Base | F/U
  Intv grp - low (n = 8): | NR | 63.4
  Intv grp - med (n = 16): | NR | 57.4
  Intv grp - high (n = 6): | NR | 54.8
  Con grp (n = 19): | NR | 63.8
  Girls | Base | F/U
  Intv grp - low (n = 11): | NR | 61.5
  Intv grp - med (n = 12): | NR | 39.4
  Intv grp - high (n = 5): | NR | 51.6
  Con Grp (n = 33): | NR | 54.5

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
120 Knutsen, Knutsen, 1991 Tromsø Heart Study | Setting: home (subjects recruited from National Health Screening Services) Gender: M,F Age: 30-50-yr-old men and their families Race: NR Risk: CVD Country: Norway Results presented separately for men, spouses, and children | RCT families identified through pop-based screening and randomly allocated to intv or con grp using table of random numbers | Participation rate: NR Baseline sample size Men: 1373 (total) Spouses: 1143 (total) Children: 2838 (total) F/U sample size Men: 1060 (total) Spouses: 935 (total) Children: 1103 (total) Ret. Rates Men: 77% (total) Spouses: 82% (total) Children: 39% (total) Comparison of drop-outs: NR | Intv Grp Intv components: info letter, home visits, newsletters, anti-smoking clinics, physician counseling, dietary advice Intv delivery: dietitian, physician Special features: family component Nutr message: decrease total fat (to 30% total), sat fat, and sugar; some families advised to reduce salt intake Con Grp Intv components: NR Theoretical perspective: NR | 2 home visits; quarterly newsletters (duration NR); 2 f/u phone calls, 2 meetings on nutr; 1 meeting on exercise; 3 smoking cessation clinics; total duration of intv NR Maintenance: NR | 6 yrs after baseline survey (~ 3-4 yrs after intv) | Variables: fruit intake (% eating > "4" per wk; units NR) fruit intake (% eating < "2" per wk, units NR) "veg with dinner" (%; units NR) Instrument: diet history Statistics: chi-square (for diffs in n's practicing dietary habits) | Fruit intake (% eating > 4/wk; se NR) Significance of effects: p for diffs at f/u n.s for men, spouses, or children Fruit intake (% eating <2/wk; se NR) Significance of effects: p for diffs at f/u n.s for men or children; p for diff b/w intv and con among spouses <.01 Veg w/ dinner (%; se NR) Significance of effects: p for diffs at f/u n.s for men or children; p for spouses <.05
  Men | Base | F/U
  Intv grp (n = 4 91): | NR | 28%
  Con grp (n = 506): | NR | 24%
  Spouses | Base | F/U
  Intv grp (n = 444): | NR | 48%
  Con grp (n = 432): | NR | 44%
  Children | Base | F/U
  Intv grp (n = 489): | NR | 43%
  Con grp (n = 505): | NR | 39%
  Men | Base | F/U
  Intv grp (n = 491): | NR | 39%
  Con grp (n = 506): | NR | 41%
  Spouses | Base | F/U
  Intv grp (n = 444): | NR | 20%
  Con grp (n = 432): | NR | 28%
  Children | Base | F/U
  Intv grp (n = 489): | NR | 23%
  Con grp (n = 505): | NR | 25%
  Men | Base | F/U
  Intv grp (n = 491): | NR | 60%
  Con grp (n = 506): | NR | 60%
  Spouses | Base | F/U
  Intv grp (n = 444): | NR | 72%
  Con grp (n = 432): | NR | 64%
  Children | Base | F/U
  Intv grp (n = 489): | NR | 51%
  Con grp (n = 505): | NR | 53%

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Knutsen and Knutsen, 1991 | Variables: butter/hard marg as spread (% using) butter/hard marg for cooking (% using) soft marg/oil for cooking (% using) Other variables analyzed: soft marg/oil for spread no spread on bread fat on dinner whole-fat milk low-fat fish cod liver oil Instrument: diet history Statistics: chi-square (for diffs in n's practicing dietary habits) | Butter as spread (%; se NR) Significance of effects: diffs at f/u sig for men, spouses, and children (p<.001) Butter for cooking (%; se NR) Significance of effects: diffs at f/u sig for men (p<.001), spouses (p<.001), and children (p<.001) Soft marg/oil for cooking (%; se NR) Significance of effects: diffs at f/u sig for men, spouses, and children (p<.001) | Milk: n.s. Bread: n.s. | Variables: TC (mmol/L) Instrument: non-fasting sample, TC measured directly by enzymatic oxidase method Statistics: ANOVA, with age as covariate, to test diffs b/w grps | TC (means and sd) Significance of effects: p for chng from base to f/u b/w grps sig for men (p<.01); n.s. for spouses; no sig diffs at f/u for children | NR | 55
  Men | Base | F/U
  Intv grp (n = 491): | NR | 8%
  Con grp (n = 506): | NR | 18%
  Spouses | Base | F/U
  Intv grp (n = 444): | NR | 9%
  Con grp (n = 432): | NR | 17%
  Children | Base | F/U
  Intv grp (n = 489): | NR | 5%
  Con grp (n = 505): | NR | 11%
  Men | Base | F/U
  Intv grp (n = 491): | NR | 20%
  Con grp (n = 506): | NR | 36%
  Spouses | Base | F/U
  Intv grp (n = 444): | NR | 20%
  Con grp (n = 432): | NR | 36%
  Children | Base | F/U
  Intv grp (n = 489): | NR | 25%
  Con grp (n = 505): | NR | 35%
  Men | Base | F/U
  Intv grp (n = 491): | NR | 74%
  Con grp (n = 506): | NR | 54%
  Spouses | Base | F/U
  Intv grp (n = 444): | NR | 75%
  Con grp (n = 432): | NR | 56%
  Children | Base | F/U
  Intv grp (n = 489): | NR | 67%
  Con grp (n = 505): | NR | 53%
  Men | Base | F/U
  Intv grp (n = 525): | 7.49 (1.14) | 7.08 (1.15)
  Con grp (n = 535): | 7.51 (1.20) | 7.26 (1.21)
  Spouses | Base | F/U
  Intv grp (n = 422): | 6.01 (1.23) | 6.07 (1.27)
  Con grp (n = 387): | 6.08 (1.26) | 6.22 (1.34)
  Children | Base | F/U
  Intv grp (n = 422): | NR | 4.57 (0.82)
  Con grp (n = 387): | NR | 4.63 (0.93)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
321 Turnin, Beddok, Clottes, 1992 | Setting: home/tailored computer intv (recruitment NR) Gender: M,F Age: >18 yrs Race: NR Risk: type 2 diabetes Country: France | RCT subjects identified and randomly assigned to intv grp or con grp, then the con grp received the intv (both sets of results presented) | Participation rate: NR Baseline sample size Intv grp 1: 54 Intv grp 2: 51 F/U 1 sample size Intv grp 1: 45 Intv grp 2: 50 F/U 2 sample size Intv grp 1: n/a (study complete for this grp) Intv grp 2: 53 Retention rate Intv grp 1: 83% Intv grp 2: 98% Comparison of drop-outs: NR | Intv grps (2 intv grps) Intv components: computer-assisted diet education system (personalized counseling; dietary calculations, adapted menus, recipe consultation; general dietary information) -intv grp 1 received the intv first -intv grp 2 served as a con grp for the first f/u period, then received the intv Intv delivery: self-administered Special features: individually tailored Nutr message: (dependent on individuals' dietary requirements and intake patterns) Con grp (no con grp; intv grp 2 served as con grp for f/u 1) Theoretical perspective: NR | 1-hr grp demonstration of the system; individual demonstration (duration NR); average use of system: 6 times/mo for 15 mins/session for a total of 90 mins/mo; total duration of intv: 6 mos Maintenance: NR | F/U 1: 6 mos after base F/U 2: 12 mos after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Turnin, Beddok, Clottes, 1992 | Variables: total fat (% energy) Instrument: 3-day "dietary investigation" Statistics: t-tests for matched samples | Total fat (mean and se) First study period (intv grp 2 serves as con grp) Significance of effects: p for chng from base to f/u 1 for intv grp1 <0.05 p for chng from base to f/u 1 for intv grp 2 n.s. Second study period (intv grp 2 serves as intv grp) Significance of effects: p for chng from f/u 1 (base) to f/u 2 for intv grp 2 n.s. Intention to treat: NR | NR | NR | NR | Dietary knowledge: sig intv effect | 56
  | Base | F/U 1
  Intv grp 1 (n = 43): | 38.3 (1.0) | 36.0 (0.9)
  Intv grp 2 (n = 46): | 38.8 (0.8) | 38.5 (0.8)
  | F/U 1 (base) | F/U 2
  Intv grp 1: | n/a | n/a
  Intv grp 2 (n = 41): | 39.5 (0.8) | 38.2 (1.1)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
184 Rodgers, Kessler, Portnoy, 1994 Eat for Health | Setting: supermarket (population recruited from shoppers) Gender: NR Age: 21-75 yrs Race: NR Risk: general | Matched pairs design (quasi-exp) 20 intv stores and 20 comp stores selected from larger pool 3 cross-sectional waves of consumer surveys conducted 3 cross-sectional waves of store sales data collected | Participation rate (stores): NR Participation rate (consumers): 62.6% (wave 1); 62.2% (wave 2) Wave 1 sample size: 20 "pairs" of stores; 958 consumers (total) Wave 2 sample size: 20 "pairs" of stores; 1045 consumers (total) Wave 3 sample size: 20 "pairs" of stores; 1031 consumers (total) Retention rate: n/a (cross-sectional surveys at 3 time periods) Comparison of drop-outs: n/a | Intv Grp Intv components: special shelf price labels, food guide (nutr info), signs in produce dept, multimedia advertising campaign Intv delivery: supermarket staff Special features: NR Nutr message: decrease fats, increase fiber, F&V, knowledge of foods related to cancer, knowledge of relationship b/w diet and disease Con Grp Intv components: NR Theoretical perspective: NR | 2 yrs (also did indiv 3-mo interventions evaluated separately) Maintenance: NR | Wave 2: 1 yr from wave 1 Wave 3: 2 yrs from wave 1 | Variables: self-reported (consumer) consumption of veg fruit self-reported (consumer) purchasing of veg fruit store sales data (in ounces) for fresh produce frozen veg canned veg dried fruit Instrument (consumer data): shortened version of NCI Health Habits and History Questionnaire FFQ (store sales data): record purchases by Universal Produce Code Statistics: diff in chng calculated from wave 1 to wave 3 b/w intv and comp stores, controlling for demographics and health characteristics | Consumer-reported consumption of veg (adj percentage diff; sd/se NR): 1.2 (n.s) n (for analyses) NR Consumer-reported consumption of fruit (adj percentage diff; sd/se NR): 0.6 (n.s) n (for analyses) NR Consumer-reported purchase of veg (adj percentage diff; sd/se NR): 3.8 (n.s) n (for analyses) NR Consumer-reported purchase of fruit (adj percentage diff; sd/se NR): -2.0 (n.s) n (for analyses) NR Sales of fresh produce, frozen veg, canned veg, dried fruit data/statistics NR n (for analyses) NR Intention to treat: n/a

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Rodgers, Kessler, Portnoy, 1994 | Variables: self-reported (consumer) consumption of high-fat foods fried foods fats/oils self-reported (consumer) purchasing of high-fat foods Other variables analyzed: self-reported (consumer) consumption and purchasing of bakery/snacks whole milk products low-fat/skim milk products poultry fish self-reported (consumer) low-fat cooking methods Instrument (consumer data): shortened version of NCI Health Habits and History Questionnaire FFQ Statistics: diff in chng calculated from wave 1 to wave 3 b/w intv and comp stores, controlling for demographics and health characteristics | Consumer-reported consumption of high-fat foods (adj percentage diff; sd/se NR): -4.2 (p<.05) n (for analyses) NR Consumer-reported consumption of fried foods (adj percentage diff; sd/se NR): -0.8 (n.s) n (for analyses) NR Consumer-reported consumption of fats/oils (adj percentage diff; sd/se NR): -1.1 (n.s) n (for analyses) NR Consumer-reported purchase of high-fat foods (adj percentage diff; sd/se NR): -1.4 (n.s) n (for analyses) NR Intention to treat: n/a | Whole grain consumption: n.s. whole milk products: n.s. Low-fat/skim milk products: n.s. | NR | NR | Knowledge of fruit for reducing cancer risk: sig intv effect Knowledge of veg for reducing cancer risk: n.s. Knowledge of the relationship b/w diet and cancer: sig intv effect | 33

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
058 Cox, Parker, Watson, 1995 | Setting: EFNEP (pop recruited from Virginia EFNEP) Gender: F Age: 20-45 Race: B,W Risk: general low-income pop | NR subjects were placed into 2 intv grps and 1 con grp | Participation rate: NR Baseline sample size Intv grp 1: 113 Intv grp 2: 116 Con grp: 110 F/U sample size Intv grp 1: 113 Intv grp 2: 116 Con grp: 110 Retention rate: 100% Comparison of drop outs: NR | Intv Grps (2 grps) Intv components: EFNEP lessons (Intv grp 1) EFNEP lessons and cancer prevention lessons (including visuals and hands-on food activities) (Intv grp 2) Intv delivery: indigenous paraprofessionals Special features: food interactions Nutr message: decrease fats, nitrites, and mutagens, increase carotenoids, vitamins A,C,E, folate, calcium, fiber Con Grp Intv component: money management lessons Theoretical perspective: Health Belief Model | (Intv grp 1) 10-13 EFNEP lessons (Intv grp 2) 9 EFNEP lessons, 9 cancer prev lessons (Con grp) 11 money management lessons Total intv duration: 6 mos Maintenance: NR | "post-intv" (assume 6 mos after base) | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Cox, Parker, Watson, 1995 | Variables: total fat (% energy) Instrument: 3 random-repeat 24-hr recalls conducted face to face Statistics: ANOVA | Total fat (mean and se) Significance of effects: con grp sig diff (p<.05) from intv grp 1 and intv grp 2 Intention to treat: NR | Fiber: sig intv effect (intv grp 2) Calcium: n.s. | NR | NR | NR | 26
  | Base | F/U | Chng
  Intv grp 1 (n = 113): | NR | NR | -3.7 (0.7)
  Intv grp 2 (n = 116): | NR | NR | -4.9 (0.8)
  Con grp (n = 110): | NR | NR | -0.3 (0.8)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
082 Fitzgibbon, Stolley, Avellone, 1996 | Setting: community/family (Hispanic families recruited from literacy training program) Gender: M (children only), F (both children and mothers) Age: 7-12 yrs (children); mean age for mothers 35 yrs Race: H Risk: general low-income pop. Some analyses presented separately for mothers and children | RCT families randomly assigned to either intv or con grp | Participation rate: NR Baseline sample size: 38 families (38 mothers; 48 children) (total) F/U sample size: 36 families (total) Retention rate (families): 95% (total) Comparison of drop-outs: mothers who dropped out had fewer children than mothers who completed intv; no other sig diffs | Intv grp Intv components: activity-based curriculum; classes; group discussions Intv delivery: NR Special features: family component, culturally specific, small groups, food interactions Nutr message: decrease dietary fat, increase fiber intake Con grp Intv components: received standard pamphlets on health behavior and nutr Theoretical perspective: NR | 1-hr classes wkly for 12 wks total Maintenance: NR | 1 wk after end of intv (presumably ~ 13 wks after base) | Variables: F&V (units NR) (mothers only) fruits (units NR) (children only) vegetables (units NR) (children only) Instrument: Food Beh Checklist (simplified 24-hr recall) (administered to mothers only) FFQ (containing 37 items for children in grades 1-3 and 87 items for children in grades 4-6) (administered to children only) Statistics: repeated measures MANOVA (with tx grp and time as factors); with follow up univariate ANOVAs | F&V (means and sd) Mothers Significance of effects: p for diffs b/w grps at base <0.006 p for grp effect (ANOVA) at f/u <0.01 p for time effect (ANOVA) at f/u <0.05 p for grp*time interaction (ANOVA) NR Fruit (means and sd) Children Significance of effects: p for diffs b/w grps at base n.s. p for grp effect (ANOVA) n.s. p for time effect (ANOVA) sig (value NR) p for grp*time interaction (ANOVA) n.s. Vegetable (means and sd) Children Significance of effects: p for diffs b/w grps at base n.s. p for grp effect (ANOVA) n.s. p for time effect (ANOVA) n.s. p for grp*time interaction (ANOVA) n.s. Intention to treat: NR *data presented for "older" children only
  | Base | F/U
  Intv grp (n = 18): | 2.0 (1.30) | 2.6 (1.20)
  Con grp (n = 18): | 0.9 (1.00) | 1.5 (1.00)
  | Base | F/U
  Intv grp (n = 9*): | 2.7 (0.96) | 2.6 (0.86)
  Con grp (n = 11*): | 2.5 (0.60) | 2.5 (0.80)
  | Base | F/U
  Intv grp (n = 9*): | 2.1 (0.63) | 2.0 (0.50)
  Con grp (n = 11*): | 1.7 (0.48) | 1.7 (0.63)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Fitzgibbon, Stolley, Avellone, 1996 | Variables: total fat (% energy) (mothers only) sat fat (% energy) (mothers only) Instrument: Quick Check for Fat (computer-assisted FFQ with 46 items) (used to measure total fat and sat fat among mothers only) Statistics: repeated measures MANOVA (with tx grp and time as factors); with follow up univariate ANOVAs | Total fat (means and sd) Mothers Significance of effects: p for diffs b/w grps at base (mothers) n.s. p for grp effect at f/u (mothers) < 0.05 p for time effect (MANOVA) at f/u (mothers) <0.001 p for grp* time interaction (MANOVA) at f/u (mothers) n.s. p for diffs b/w grps at base (children) n.s. Sat fat (means and sd) Mothers Significance of effects: p for diffs b/w grps at base (mothers) n.s. p for grp effect at f/u (mothers) < 0.05 p for time effect (MANOVA) at f/u (mothers) <0.001 p for grp* time interaction (MANOVA) at f/u (mothers) n.s. Intention to treat: NR | Fiber (mothers): n.s. | NR | NR | Parental support and role modeling for healthy eating (mothers): sig intv effect (but grp*time interaction n.s.) Nutr knowledge (mothers): n.s. Nutr knowledge (children): sig intv effect | 51
  | Base | F/U
  Intv grp (n = 18): | 34.3 (6.20) | 29.3 (8.50)
  Con grp (n = 18): | 36.3 (5.50) | 36.7 (6.10)
  | Base | F/U
  Intv grp (n = 18): | 12.2 (2.60) | 11.2 (4.00)
  Con grp (n = 18): | 12.9 (2.20) | 13.6 (3.10)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
018 Brug, Steenhuis, van Assema, 1996 | Setting: computer/worksite (employees recruited from laboratory) Gender: M,F Age: range NR; mean 39 yrs Race: NR Risk: general Country: The Netherlands | RCT employees invited to participate in study; randomly assigned to intv or con grp | Participation rate: 74% (total) Baseline sample size: 507(total) F/U sample size Intv grp: 178 Con grp: 169 Retention rate: 68%(total) Comparison of drop-outs: no sig diffs b/w drop-outs and responders | Intv grp Intv components: computer-tailored feedback messages; personal letter Intv delivery: n/a (computer generated) Special features: indiv tailored Nutr messag: decrease fat intake, increase F&V consumption Con grp Intv components: general nutr ed (leaflets from Netherlands Bureau for Food and Nutr Ed) Theoretical perspective: Theory of Reasoned Action; Social Cognitive Theory | Length of nutr info letters: 4-9 pgs; total duration of intv NR Maintenance: NR | 3 wks after intv | Variables: Fruit (servings/d) Veg (servings/d) Instrument: 30-item FFQ Statistics: ANOVA (diffs b/w grps at f/u) | Fruit (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for chng in intv grp n.s. p for chng in con grp n.s. p for diffs b/w grps at f/u n.s Veg (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for chng in intv grp n.s. p for chng in con grp < 0.05 p for diffs b/w grps at f/u n.s. Intention to treat: NR
  | Base | F/U
  Intv grp (n = 178): | 1.49 (1.00) | 1.57 (0.96)
  Con grp (n = 169): | 1.61 (1.14) | 1.57 (1.19)
  | Base | F/U
  Intv grp (n = 178): | 1.03 (0.36) | 1.07 (0.36)
  Con grp (n = 169): | 1.00 (0.31) | 1.06 (0.37)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Brug, Steenhuis, van Assema, 1996 | Variables: fat consumption score (range: 12-60) Instrument: 30-item FFQ Statistics: ANOVA (diffs b/w grps at f/u) | Fat (mean and sd) Significance of effects: p for diffs b/w grps at base n.s. p for chng in intv grp <0.01 p for chng in con grp <0.05 p for diff b/w grps at f/u <0.01 Intention to treat: NR | NR | NR | NR | Dietary attitude: sig intv effect Intention to change diet: sig intv effect Self-efficacy for diet: n.s. | 55
  | Base | F/U
  Intv grp (n = 178): | 29.0 (5.0) | 26.9 (4.9)
  Con grp (n = 169): | 28.0 (5.3) | 27.2 (5.5)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
016 Cullen, Bartholomew, Parcel, 1997 | Setting: Girl Scout troops recruited from local Girl Scout Council) Gender: F Age: 9-12 yrs Race: B,H,W,O Risk: general | RCT 22 troops recruited and randomized (by grade level) into intv or con conditions | Participation rate (troops): NR Participation rate (individuals): NR Baseline sample size: Intv grp: 126 Con grp: 133 F/U 1 sample size: Intv grp: 101 Con grp: 109 F/U 2 sample size: Intv grp: 80 Con grp: 82 Retention rate (troops): 100% (total) Retention rate (indiv.): 81.5% (total) Comparison of drop-outs: NR | Intv grp Intv components: classes, self-help materials, F&V tastings, parental info sheets, goal setting, Eat 5 badge Intv delivery: principal investigator, troop leader Special features: buddy/group planning Nutr message: increase F&V Con Grp Intv components: delayed intervention Theoretical perspective: Social Cognitive Theory | 4 sessions, 1 hour each, and home activities; total duration of intv: 5-6 wks Maintenance: NR | F/U 1: 5-6 wks from base (immediately post-intv) F/U 2: 3 mos post-intv | Variables: F&V (servings/d) Instrument: 25 F&V item FFQ (FRF) Statistics: nested hierarchical ANOVA (troop as unit as analysis) to assess change in F&V intake | F&V (mean and sd) Significance of effects: p (for diff b/w grps) at base <.01 p (change for base to f/u 1) for intv grp < .01 p (change for base to f/u 1) for con grp n.s. p (change to f/u 2) for intv grp n.s. p (change to f/u 2) for con grp n.s. Intention to treat: NR
  | Base | F/U 1
  Intv grp: | 3.02 (2.21) | 3.39 (1.93)
  [n] | [n = 126] | [n = 101]
  Con grp: | 2.20 (1.96) | 2.06 (1.71)
  [n] | [n = 133] | [n = 109]
  | F/U 2
  Intv grp (n = 80): | 2.89 (1.60)
  Con grp (n = 82): | 2.32 (1.81)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Cullen, Bartholomew, Parcel, 1997 | NR | NR | NR | NR | NR | F&V knowledge: sig intv effect F&V preferences: sig intv effect F&V self-efficacy: n.s. Barriers: n.s. Norms: n.s. Skills: n.s. | 68

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
103 Hartman, McCarthy, Park, 1997 Innovative Dietary Education Approaches Project | Setting: EFNEP setting (EFNEP educators and participants recruited) Gender: M,F Age: range NR; mean: 27-31 yrs Race: W,B,O Risk: general Low-income pop | quasi-experimental nutrition education assistants randomly designated as either intv or con educators (8 educators designated as intv and 8 designated as con); intact social grps allocated to study condition | Participation rate (educators): NR Participation rate (subjects): NR Baseline sample size Intv grp: 8 educators; 134 subjects Con grp: 8 educators; 70 subjects F/U sample size Intv grp: 11 educators; 130 subjects Con grp: 7 educators; 70 subjects Retention rate (educators) Intv grp: 138% Con grp: 88% Retention rate (subjects): 64% (total) Comparison of drop-outs: minority and "voluntary" participants (attendance not required by agencies, schools, or tx facilities) less likely to complete study | Intv grp Intv components: educators received low-fat nutr ed curriculum ("Help Yourself to Health") and materials to distribute to intv participants; participants received sessions and take-home reinforcers Intv delivery: Nutrition Education Assistants (trained paraprofessionals who live in the community they serve) Special features: NR Nutr message: lower fat intake Con grp Intv components: educators received usual EFNEP materials (based on "Eating Right is Basic 2" curriculum) Theoretical perspective: NR | 10 sessions (duration NR); total duration of intv NR Maintenance: NR | 8 wks from base (mean length of f/u) | Variables: F&V (frequency of increasing) Instrument: eating behaviors questionnaire (containing 5 scales measuring frequency of individual low- fat eating strategies; responses range from 1-4 with lower scores considered preferred responses) Statistics: mixed-model reg analyses predicting status at f/u, after controlling for base values and relevant covariates (determined by statistical significance) | F&V (mean and 95% CI; sd/se NR) Significance of effects: mean diff in chng b/w grps: -0.01 (-0.04; 0.02) (n.s.) Intention to treat: NR
  | Base | F/U | Chng
  Intv grp (n = 130): | NR | NR | 0.47(0.45;0.48)
  Con grp (n = 70): | NR | NR | 0.48(0.46;0.50)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Hartman, McCarthy, Park, 1997 | Variables: total fat (kcals) sat fat (% energy) overall low-fat eating pattern score Other variables analyzed: frequency of replacing high-fat foods with lower- fat alternatives frequency of using low-fat food preparation techniques frequency of adding fat on veg and bread frequency of eating less meat 10 individual eating behaviors Instrument: 1 24-hr recall analyzed by NDS (presumably for measurement of total fat and sat fat) eating behaviors questionnaire (containing 5 scales measuring frequency of individual low-fat eating strategies; responses range from 1-4, with lower scores considered preferred responses) Statistics: mixed-model reganalyses predicting status at f/u, after controlling for base values and relevant covariates (determined by statistical significance) | Total fat (mean and 95% CI; sd/se NR) Significance of effects: mean diff in chng b/w grps: -1.1 (-4.3; 2.1) (n.s.) Sat fat (mean and 95% CI; sd/se NR) Significance of effects: mean diff in chng b/w grps: -0.9 (-2.5; 0.8) (n.s.) Overall low-fat eating patterns score (mean and 95% CI; sd/se NR) Significance of effects: mean diff in chng b/w grps: -0.03 (-0.01; -0.0005) (sig chng) Intention to treat: NR | NR | Variables: TC (mg/dL) Instrument: non-fasting blood samples obtained by venipunctures; analyzed via enzymatic method Statistics: mixed-model reg analyses predicting status at f/u, after controlling for base values and relevant covariates (determined by statistical significance) | TC (mean and 95% CI; sd/se NR) Significance of effects: mean diff in chng b/w grps: 3.5 (-7.1; 14.2) (n.s.) Intention to treat: NR | Self-efficacy: n.s. Healthy eating interest: n.s. Family concerns/barriers: n.s. Overall attitude score: n.s. | 43
  | Base | F/U | Chng
  Intv grp (n = 130): | NR | NR | 33.1 (31.4;34.9)
  Con grp (n = 70): | NR | NR | 34.2 (31.7;36.7)
  | Base | F/U | Chng
  Intv grp (n = 130): | NR | NR | 11.7 (10.8;12.6)
  Con grp (n = 70): | NR | NR | 12.6 (11.3;13.8)
  | Base | F/U | Chng
  Intv grp (n = 130): | NR | NR | 0.54 (0.53;0.56)
  Con grp (n = 70): | NR | NR | 0.57 (0.55;0.59)
  | Base | F/U
  Intv grp (n = 130): | NR | NR
  Con grp (n = 70): | NR | NR
  | Chng
  Intv grp (n = 112): | 182.6 (177.2; 188.0)
  Con grp (n = 45): | 179.1 (170.5; 187.7)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
006 Pierce, Faerber, Wright, 1997 | Setting: telephone (recruited from hosp cancer registry, physicians, public) Gender: F Age: 33-71 yrs Race: NR Risk: cancer | RCT Subjects stratified by age and stage of disease; randomized to intv or con grp | Participation rate: 40% Baseline sample size: Intv grp: 47 Con grp: 46 F/U 1 sample size Intv grp: 44 Con grp: 43 F/U 2 sample size Intv grp: 39 con grp: 32 Retention rate Intv grp: 91-94% Con grp: 93% Comparison of drop-outs: no sig diffs | Intv grp Intv components: telephone counseling, monthly cooking classes, goal setting, self-monitoring Intv delivery: NR Special features: NR Nutr message: eat 5 veg servings/d, 3 fruit servings, 16 oz fresh veg juice, 15% energy from fat, 30 g/d fiber Con Grp Intv components: provided with NCI F&V recommendations and USDA Good Sources of Nutrients Theoretical perspective: Social Cognitive Theory | Phone calls conducted in 3 phases of intensity; n of calls NR; duration of intv NR Maintenance: last phase of phone calls was designed for "relapse prevention" | F/U 1: 6 mos from base F/U 2: 12 mos from base | Variables: veg (servings/d) fruit (servings/d) Instrument: 4 24-hr recalls conducted randomly and stratified for wkend and wkday Statistics: t-tests | Veg (mean and se) Significance of effects: p for diffs b/w grps at base: 0.88 p for diffs b/w grps at f/u 1: 0.0001 p for diffs b/w grps at f/u 2: 0.0001 Fruit (mean and se) Significance of effects: p for diffs b/w grps at base: 0.76 p for diffs b/w grps at f/u 1: 0.01 p for diffs b/w grps at f/u 2: 0.002 Intention to treat: NR
  | Base | F/U 1 | F/U 2
  Intv grp: | 2.8 (0.2) | 7.4 (0.5) | 6.7 (0.5)
  [n] | [n = 47] | [n = 44] | [n = 39]
  Con grp | 2.7 (0.2) | 3.0 (0.3) | 3.0 (0.3)
  [n] | [n = 46] | [n = 43] | [n = 32]
  | Base | F/U 1 | F/U 2
  Intv grp: | 2.9 (0.2) | 3.6 (0.3) | 4.0 (0.3)
  [n] | [n = 47] | [n = 44] | [n = 39]
  Con grp | 3.1 (0.3) | 2.6 (0.3) | 2.5 (0.3)
  [n] | [n = 46] | [n = 43] | [n = 32]

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Pierce, Faerber, Wright, 1997 | Variables: total fat (% energy) Instrument: 4 24-hr recalls conducted randomly and stratified for wkend and wkday Statistics: t-tests | Total fat intake (mean and se) Significance of effects: p for diffs b/w grps at base: 0.71 p for diffs b/w grps at f/u 1: 0.001 p for diffs b/w grps at f/u 2: 0.002 Intention to treat: NR | Fiber: sig intv effect Dietary adherence (overall index of dietary intake): sig intv effect | Variables: beta-carotene (mmol/L) lycopene (mmol/L) alpha-carotene (mmol/L) Other variables analyzed: lutein beta-cryptoxanthin Instrument: fasting blood samples; circulating carotenoids separated and quantified using the HPLC methods of Nierenberg and Nann (1992), and Peng et al. (1995). Statistics: t-tests | Beta-Carotene (Mean and se) Significance of effects: p for diffs b/w grps at base n.s. p for diffs in chng b/w grps (f/u 1): 0.0001 p for diffs in chng b/w grps (f/u 2): 0.0001 Lycopene (Mean and se) Significance of effects: p for diffs b/w grps at base n.s. p for diffs in chng b/w grps (f/u 1) n.s. p for diffs in chng b/w grps (f/u 2): 0.0001 Alpha-Carotene (Mean and se) Significance of effects: p for diffs b/w grps at base n.s. p for diffs in chng b/w grps (f/u 1): 0.005 p for diffs in chng b/w grps (f/u 2): 0.0008 Intention to treat: NR | NR | 59
  | Base | F/U 1 | F/U 2
  Intv grp: | 29.4 (1.2) | 18.9 (1.2) | 20.5 (1.2)
  [n] | [n = 47] | [n = 44] | [n = 39]
  Con grp | 28.8 (1.2) | 25.1 (1.2) | 26.5 (1.5)
  [n] | [n = 46] | [n = 43] | [n = 32]
  | Base | F/U 1 | F/U 2
  Intv grp: | 0.60 (.07) | 1.39 (.22) | 1.28 (.17)
  [n] | [n = 42] | [n = 39] | [n = 36]
  Con grp: | 0.75 (.11) | 1.03 (.22) | 0.99 (.20)
  [n] | [n = 40] | [n = 34] | [n = 30]
  | Base | F/U 1 | F/U 2
  Intv grp: | 0.53(.04) | 0.51(.04) | 0.70(.06)
  [n] | [n = 42] | [n = 39] | [n = 36]
  Con grp: | 0.62(.06) | 0.56(.04) | 0.65(.05)
  [n] | [n = 40] | [n = 34] | [n = 30]
  | Base | F/U 1 | F/U 2
  Intv grp: | 0.12 (.01) | 0.49 (.07) | 0.59(.08)
  [n] | [n = 42] | [n = 39] | [n = 36]
  Con grp: | 0.17 (.03) | 0.29 (.11) | 0.24(.05)
  [n] | [n = 40] | [n = 34] | [n = 30]

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
203 Stolley, Fitzgibbon, 1997 | Setting: community (pop recruited from tutoring program for children at poverty levels) Gender: F Age: 7-12-yr-old girls and their mothers (mean age 33 yrs) Race: B Risk: general low-income pop Results presented separately for moms and daughters | RCT mother-daughter dyads were randomly assigned to intv or con grp | Participation rate: NR Baseline sample size: Intv grp: 64 (32 moms, 32 daughters) Con grp: 63 (30 moms, 33 daughters) F/U sample size: Intv grp: 43 (20 moms, 23 daughters) Con grp: 45 (18 moms, 27 daughters) Retention rate: 78% (mothers; total); 83% (daughters; total) Comparison of drop-outs: thinner moms more likely to drop out | Intv Grp Intv components: group meetings, concept of the wk, modeled after Know Your Body, parental participation, food tastings, meal planning, fat/calorie analysis, menu planning, visited grocery stores, exercises Intv delivery: advanced doctoral student in clinical psych, RD Special features: family component, culturally/ethnically specific, small groups Nutr message: decrease fat, calories, and chol Con Grp Intv components: general health program in small groups Theoretical perspective: NR | Grp meetings 1 hr/wk for 12 wks, then 1 meeting every 3 mos for 15 mos Maintenance: NR | 12 wks from base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Stolley, Fitzgibbon, 1997 | Variables: total fat (%energy) sat fat (% energy) Instrument: FFQ (Quick Check for Fat; n of items NR) Statistics: MANOVA (2*2 rep measures with grp and time as the factors), conducted separately for moms and daughters | Total fat (mean and sd) Significance of effects: sig grp*time effect for moms (p<.001) and daughters (p<.05) Sat fat (mean and sd) Significance of effects: sig grp*time effect for moms (p<.05), but not for daughters Intention to treat: NR | NR | NR | NR | Mother's perceived parental support and role modeling skills for healthy eating: sig intv effect | 53
  Mothers
  | Base | F/U
  Intv grp ( n = 20): | 40.7 (4.9) | 32.8 (6.6)
  Con grp ( n = 18): | 42.8 (2.8) | 41.6 (3.1)
  Daughters
  | Base | F/U
  Intv grp (n = 23): | 39.1 (5.1) | 35.2 (7.0)
  Con grp (n = 27): | 41.9 (4.6) | 40.6 (4.6)
  Mothers
  | Base | F/U
  Intv grp (n = 20): | 13.6 (2.1) | 11.5 (2.7)
  Con grp (n = 18): | 15.3 (1.3) | 15.1 (1.7)
  Daughters
  | Base | F/U
  Intv grp (n = 23): | 13.9 (2.6) | 13.0 (2.8)
  Con grp (n = 27): | 15.0 (2.3 ) | 15.1 (1.8)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
011 Havas, Anliker, Damron,1998 | Setting: WIC program (subjects recruited from Maryland WIC sites) Gender: F Age: >18 yrs Race: B,W,O Risk: general Low-income pop Analyses presented separately by race, age, ed, marital status, employment status, and smoking status | Randomized crossover design 8 sites randomized to intv and 8 to con status; subjects recruited within sites; intv sites became con sites after 10 mos, and vice versa | Participation rate (sites): NR Participation rate (indiv.) Intv phase: 66% Con phase: 87% Baseline sample size: 15 sites; n of participants NR F/U sample size: 15 sites; 3122 participants (total) Retention rate (indiv.): Intv phase: 75% Con phase: 76% Comparison of drop-outs: non-completers were younger, single, employed, in school, completed fewer intv sessions, and were more likely to be Black | Intv Grp Intv components: nutr sessions, printed materials, mailings, food demonstrations Intv delivery: trained peer educators Special features: discussion groups Nutr message: increase F&V intake Con Grp Intv components: < 10 min of nutrition education as part of regular WIC program Theoretical perspective: Stages of Change | Brief nutrition session at enrollment, 3 sessions (45 min each) and 4 letters over a 6-mo period Maintenance: NR | 1 yr after intv (but dietary data presented at 8 mos) | Variables: F&V (servings/d) Instrument: self-administered survey (7 summary questions) Statistics: paired sample t-tests comparing change b/w baseline and 8 mos | F&V (mean and se) Significance of effects: p for diff in chng b/w grps: 0 002 Intention to treat: all analyses used "last value carried forward" method
  | Base | F/U
  Intv phase (n = 1443): | 3.88(0.11) | 4.44(0.08)
  Con phase (n = 1679): | 4.20(0.10) | 4.32(0.07)
  | Chng
  Intv phase (n = 1443): | 0.56 (0.11)
  Con phase (n = 1679): | 0.13 (0.07)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Havas, Anliker, Damron, 1998 | NR | NR | NR | NR | NR | Stages of change: sig intv effect Knowledge: sig intv effect Attitude: sig intv effect Self-efficacy: sig intv effect Social support: sig intv effect Responsibility: n.s. Perceived barriers: n.s. | 61

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
008 Marcus, Morra, Rimer, 1998 | Setting: Cancer Information Service (phone; subjects recruited from callers to CIS) Gender: M,F Age: >18 yrs Race: W,H,B,O Risk: general | RCT eligible callers randomized within CIS offices (based on day of wk) to receive control or intv interview | Participation rate: 96% Baseline sample size: 1187 (total) F/U sample size: 277 (total) Retention rate: 30% of baseline were randomly sampled to take part in f/u; 81% of intv grp, and 77% of con grp, participated in f/u interview Comparison of drop-outs: n/a, but comparison of random f/u sample showed that f/u subjects were less educated and younger than full sample at base | Intv Grp Intv components: telephone messages (based on subjects' stage of change), interactive barriers counseling, f/u mailings Intv delivery: CIS telephone specialist Special features: NR Nutr message: increase consumption of F&V Con Grp Intv components: dietary interview Theoretical perspective: Health Belief Model, Social Cognitive Theory, Stages of Change | One call (avg 7 mins) followed by 2 mailings of ed materials within 2 wks of initial call Maintenance: NR | 4 wks from base | Variables: F&V (servings/d) F&V (adherence to 5 servings/d) Instrument: single item indicator based on Block FFQ Statistics: diffs in means, linear reg, logistic reg | F&V (servings/d; (means; sd/se NR) Significance of effects: p for diff b/w grps at base n.s. p for reg coefficient (b = 0.75; 95%CI: -.42 to 1.08) at f/u: 0.01 F&V (adherance to 5/d; means NR) Significance of effects OR (and 95% CI): 3.50 (1.80, 6.82), p: 0.01 Intention to treat: NR
  | Base | F/U
  Intv grp (n = 135): | 4.0 | NR
  Con grp (n = 142): | 3.9 | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Marcus, Morra, Rimer 1998 | NR | NR | NR | NR | NR | Knowledge of 5 a day: sig. intv. effect Intention to increase F&V: sig. intv. effect Dietary attitudes: n.s | 60

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
009 Marcus, Heimendinger, Wolfe, 1998 | Setting: Cancer Information Service (phone; subjects recruited from callers to CIS) Gender: M,F Age: > 18 yrs Race: W,H,B,O Risk: general | RCT eligible callers randomized within CIS offices (based on day of wk) to receive con or intv interview | Participation rate (CIS sites): 32% Participation rate (subjects): 95% Baseline: 2126 (total) F/U 1: 1672 (total) F/U 2: 1286 (total) Retention rate: 78.6% (total) Comparison of drop-outs: NR | Intv Grp Intv components: staged telephone messages (based on subject's stage of change), interactive barriers counseling, specific beh suggestions; f/u mailings (NCI 5 A Day booklets) Intv delivery: CIS Telephone Service managers/information specialists Special features: NR Nutr message: increase consumption of F&V Con Grp Intv. components: dietary interview Theoretical perspective: Reasoned action; Health Belief Model; Social Cognitive Theory; Stages of Change | One call (avg 5.8 mins for intv subjects; 3.6 mins for con subjects) followed by 2 mailings of ed materials within 2 wks of initial call Maintenance: NR | F/U 1: 4 wks after base F/U 2: 4 mos after base | Variables: F&V (servings/d) Instrument: single-item indicator based on Block FFQ 7-item FFQ patterned after BRFSS items (used at f/u 2 only) Statistics: MLE estimates of a multivariate (repeated measures) model | F&V (means and sd) Significance of effects: p for diffs b/w grps at base: 0.65 p for diffs b/w grps at f/u 1 <0.001 p for diffs b/w grps at f/u 2 (w/ 1-item FFQ) <0.001 p for diffs b/w grps at f/u 2 (w/ 7-item FFQ): 0.006 Intention to treat: NR
  | Base | F/U 1
  Intv grp: | 3.78 (2.11) | 4.44(2.07)
  [n] | [n = 1054] | [n = 821]
  Con grp: | 3.73 (sd NR) | 3.79 (sd NR)
  [n] | [n = 1064] | [n = 818]
  | F/U2(1-item FFQ) | F/U2(7-item FFQ)
  Intv grp: | 4.34 (2.05) | 4.83 (2.27)
  [n] | [n = 609] | [n = 615]
  Con grp: | 3.93 (sd NR) | 4.50 (sd NR)
  [n] | [n = 668] | [n = 671]

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Marcus, Heimendinger, Wolfe, 1998 | NR | NR | NR | NR | NR | Individual "predisposing and enabling psychosoc factors related to F&V intake": n.s. for 13 of 15 questions; sig intv effect for "eating a lot of F&V decreases chances of getting serious diseases," and "I have a lot of info on how to eat in a healthy way" Knowledge of 5 a Day: sig. intv. effect | 73

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
320 Simmons, Fleming, Voyle, 1998 | Setting: church (subjects identified by church) Gender: M,F Age: 14-102 yrs Race: Pacific Islander (W Samoan) Risk: general (but pop. at high risk for type 2 diabetes) Country: New Zealand | Non-equivalent comparison group design 2 churches selected, one assigned to intv and the other to control; subjects identified by pastor and church committee | Participation rate Intv grp: 86% Con grp: 80% Baseline sample size Intv grp: 67 Con grp: 115 F/U sample size Intv grp: 50 Con grp: 92 Retention rate Intv grp: 75% Con grp: 80% Comparison of drop-outs: NR | Intv grp Intv components: diabetes awareness sessions; leaflets, video; posters; cooking demonstrations; diabetes support group; exercise groups Intv delivery: diabetes nurse specialist; trained lay educators; aerobics instructor Special features: culturally specific; support group Nutr message: NR Con grp Intv components: no intv Theoretical perspective: Empowerment Model | 4 diabetes awareness sessions, then exercise sessions held wkly for the first yr and twice per wk thereafter; cooking demonstrations held in 2 blocks of 4 sessions; total duration of intv: 2 yrs Maintenance: NR | 2 yrs after base | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Simmons, Fleming, Voyle, 1998 | Variables: fat index score (% of med/high fat behaviors engaged in) high-fat milk consumption (% consuming high-fat milk) high-fat spread consumption (% consuming high-fat spread) Other variables analyzed: high-fat egg preparation high-fat chops preparation high-fat chicken prep do not cut fat off meat do not cut skin off chicken Instrument: 7-item questionnaire assessing methods for cooking and fat-related behaviors Statistics: one-way ANOVA | Fat index (mean and sd) Significance of effects: p for diff b/w grps at f/u < 0.01 High-fat milk (%; se NR) Significance of effects: p for diff b/w grps at f/u <0.05 High-fat spread (%; se NR) Significance of effects: p for diff b/w grps at f/u n.s. Intention to treat: NR | NR | NR | NR | Diabetes knowledge: sig intv effect | 48
  | Base | F/U | Chng
  Intv grp (n NR): | 77 (17) | 64 (22) | -14 (28)
  Con grp (n NR): | 72 (21) | 76 (23) | +3 (24)
  | Base | F/U | Chng
  Intv grp (n NR): | 73% | 68% | -5%
  Con grp (n NR): | 71% | 74% | +6%
  | Base | F/U | Chng
  Intv grp (n NR): | 98% | 100% | +2%
  Con grp (n NR): | 99% | 95% | +4%

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
210 Tudor-Smith, Nutbeam, Moore, 1998 Heartbeat Wales | Setting: community (households selected with multistage cluster sampling design) Gender: M,F Age: 18-64 yrs Race: NR Risk: general Country: U.K Some analyses separate by age, occupation, and gender | quasi-experimental design 2 independent cross-sectional pop surveys conducted in the intv community and a matched reference area; households selected with a multistage cluster sampling design | Participation rate (wave 1 survey) Intv grp: 67-88% Con grp: 64-84% Participation rate (wave 2 survey) Intv grp: 61-79% Con grp: 61-77% Wave 1 sample size Intv grp: 18,538 Con grp: 1,483 Wave 2 sample size Intv grp: 13,045 Con grp: 4,534 Retention rate: n/a Comparison of drop-outs: n/a | Intv grp Intv components: public ed campaigns (including BBC TV series; smoking cessation project); food labeling and nutr ed with grocery retailer; restaurant and canteen scheme (increasing availability of healthy foods); worksite health promotion program Intv delivery: NR Special features: NR Nutr message: NR Con grp Intv components: no intv Theoretical Perspective: NR | Duration NR Maintenance: NR | wave 2 conducted 5 yrs after wave 1 | Variables: fruit (% consuming fresh fruit > 4 days/wk) veg (% consuming green veg or salad > 4 days/wk) Instrument: NR Statistics: SUDAAN software used (data weighted by demographics); percentage point changes b/w wave 1 and wave 2 in intv site and con site calculated | Fruit ( % and 95% CI; sd/se NR) Significance of effects: Z test for diffs in proportions (intv site vs con site) n.s. Veg (% and 95% CI; sd/se NR) Significance of effects: Z test for diffs in proportions (intv site vs. con site) n.s. Intention to treat: n/a (cross-sectional surveys)
  | Wave 1
  Intv grp (n NR): | 48.3 (47.2; 49.4)
  Con grp (n NR): | 46.2 (41.1; 51.3)
  | Wave 2
  Intv grp (n NR): | 56.7 (55.4; 58.0)
  Con grp (N NR): | 54.8 (52.5; 57.0)
  | Chng
  Intv grp (n NR): | 8.4 (6.7; 10.1)
  Con grp (N NR): | 8.6 (3.0; 14.2)
  | Wave 1
  Intv grp (n NR): | 47.8 (46.5; 49.1)
  Con grp (n NR): | 46.2 (40.0; 52.5)
  | Wave 2
  Intv grp (n NR): | 55.0 (53.4; 56.5)
  Con grp (N NR): | 55.6 (53.0; 58.2)
  | Chng
  Intv grp (n NR): | 7.2 (5.1; 9.3)
  Con grp (N NR): | 9.4 (2.7; 16.1)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Tudor-Smith, Nutbeam, Moore, 1998 | Variables: fried food (% consuming fried food cooked in lard or other solid > 2 days/wk) butter (% mainly using butter on bread) Instrument: NR Statistics: SUDAAN software used (data weighted by demographics); percentage point changes b/w wave 1 and wave 2 in intv site and con site calculated | Fried food (% and 95% CI; sd/se NR) Significance of effects: sig diffs b/w grps at wave 1 Z test for diffs in proportions (intv site vs. con site) n.s. p for t-test (diff in means b/w wave 1 and 2) for con grp <0.01 sig diffs b/w grps at wave 2 Butter (% and 95% CI; sd/se NR) Significance of effects: sig diffs b/w grps at wave 1 Z test for diffs in proportions (Intv site vs. con site) n.s. p for t-test (diff in means b/w wave 1 and 2) for con grp <0.01 sig diffs b/w grps at wave 2 Intention to treat: n/a (cross-sectional surveys) | Wholemeal bread: n.s. Low-fat milk: n.s. | NR | NR | NR | 40
  | Wave 1
  Intv grp (n NR): | 32.5 (31.1; 34.0)
  Con grp (n NR): | 42.8 (36.5; 49.1)
  | Wave 2
  Intv grp (n NR): | 13.8 (12.6; 15.0)
  Con grp (N NR): | 21.3 (18.6; 24.0)
  | Chng
  Intv grp (n NR): | -18.7 (-16.8; -20.6)
  Con grp (N NR): | -21.5 (-14.6; -28.4)
  | Wave 1
  Intv grp (n NR): | 43.1 (42.0; 44.2)
  Con grp (n NR): | 36.8 (34.4; 39.2)
  | Wave 2
  Intv grp (n NR): | 26.1 (24.8; 27.4)
  Con grp (N NR): | 22.1 (20.2; 24.0)
  | Chng
  Intv grp (n NR): | -17.0 (-15.3; -18.7)
  Con grp (N NR): | -14.7 (-11.6; -17.8)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
332 Brug, Glanz, van Assema, 1998 | Setting: computer/home (subjects recruited through newspaper advertisements) Gender: M,F (82% F) Age: range NR; mean age 44 yrs Race: NR Risk: general Country: The Netherlands | RCT Participants randomly assigned to one of three groups | Participation rate: NR Baseline sample size: 762 (NR by tx grp) F/U 1 sample size: 704 (NR by tx grp) F/U 2 sample size Intv grp 1: 211 Intv grp 2: 215 Con grp: 200 Retention rate: 92% Comparison of drop-outs: tx group, gender, age, and dietary intake not sig associated with drop-out | Intv grps (2 intv grps) Intv components: computer tailored feedback letters (intv grp 1); computer tailored and iterative feedback letter (intv grp 2) Intv delivery: n/a (mailed newsletter) Special features: individually tailored Nutr message: tailored (depending on subject's dietary intake), but emphasis on F&V and fat Con grp Intv components: letter providing general nutrition information Theoretical perspective: NR | 1 letter (intv grp 1); 2 letters (intv grp 2) Maintenance component: NR | F/U 1: 4 wks after 1st letter F/U 2: 4 wks after 2nd letter | Variables: fruit (servings/d) veg (servings/d) Instrument: FFQ (32 items) Statistics: repeated measures ANOVA | Fruit (means and sd) Significance of effects: p for grp effect at f/u (mean) <0.01 p for diffs b/w intv grp 1 and 2 at f/u (mean): 0.03 p for diffs b/w intv grp 2 and con grp at f/u (mean): 0.002 p for diff b/w intv grp 1 and con grp at f/u (mean): 0.31 Veg (means and sd) Significance of effects: p for grp effect at f/u (mean) <0.01 p for diffs b/w intv grps 1 and 2, and con grp <0.001 p for diffs b/w intv grp 1 and 2: 0.38 p for grp*time interaction: 0.12
  | Base | F/U 1
  Intv grp 1 (n = 211): | 2.18 (1.72) | 2.25 (1.51)
  Intv grp 2 (n = 215): | 2.13 (1.70) | 2.42 (1.66)
  Con grp (n = 220): | 2.09 (1.75) | 2.02 (1.59)
  | F/U 2
  Intv grp 1 (n = 211): | 2.18 (1.47)
  Intv grp 2 (n = 214): | 2.45 (1.69)
  Con grp (n = 220): | 2.02 (1.59)
  | Base | F/U 1
  Intv grp 1 (n = 211): | 1.06 (0.41) | 1.13 (0.41)
  Intv grp 2 (n = 215): | 1.06 (0.38) | 1.14 (0.38)
  Con grp (n = 220): | 1.02 (0.36) | 1.05 (0.37)
  | F/U 2
  Intv grp 1 (n = 211): | 1.15 (0.41)
  Intv grp 2 (n = 214): | 1.20 (0.36)
  Con grp (n = 220): | 1.08 (0.41)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Brug, Glanz, van Assema, 1998 | Variables: fat score (range 12-60) Instrument: 69-item FFQ Statistics: repeated measures ANOVA | Fat Score (means and sd) Significance of effects: p for grp effect at f/u (mean) <0.001 p for diffs b/w intv grps 1 and 2, and con grp <0.001 p for diffs b/w intv grp 1 and 2: 0.38 p for grp*time interaction: <0.01 | NR | NR | NR | NR | 60
  | Base | F/U 1
  Intv grp 1 (n = 211): | 28.0 (5.3) | 26.4 (5.3)
  Intv grp 2 (n = 215): | 28.3 (5.4) | 27.0 (4.9)
  Con grp (n = 220): | 28.2 (5.2) | 28.3 (5.4)
  | F/U 2
  Intv grp 1 (n = 211): | 26.2 (5.2)
  Intv grp 2 (n = 214): | 25.6 (4.6)
  Con grp (n = 220): | 27.5 (5.6)

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
323 Campbell, Denmark-Wahnefried, Symons, 1999 North Carolina Black Churches United for Better Health | Setting: church (all active members invited to participate) Gender: M,F Age: range NR; mean 53.8 yrs Race: 98% B Risk: general results presented separately by gender, age, ed, marital status, and income | RCT 50 churches in 10 rural counties were stratified according to membership size and randomly assigned to intv or con grp (counties were pair matched on demographic characteristics and served as unit of randomization; 2 small churches and 3 large churches randomly chosen in each county); all active members in each church invited to participate | Participation rate (churches): 100% (including 2nd-tier invitees) Participation rate (subjects): NR Baseline sample size: 50 churches; 3737 individuals F/U sample size: 49 churches; 2519 individuals Retention rate (churches): 98% (total) Retention rate (subjects): 67% (total) Comparison of drop-outs: drop-outs more likely to be younger, male, and unmarried than respondents | Intv grp Intv components: Five a Day ed sessions; cookbook and recipe tasting; F&V served at church functions; tailored bulletins; printed materials; nutrition action team formed within each church; pastor support; grocer-vendor involvement Intv delivery: lay health advisers Special features: culturally specific, social networks targeted, food interactions, tailoring Nutr message: increase F&V Con grp Intv components: delayed intv Theoretical perspective: Social Cognitive Theory; Stages of Change; Social Support Models; PRECEDE-PROCEED Model | Tot duration of intv: 20 mos Maintenance: NR | 2 yrs from base | Variables: F&V (servings/d) fruit (servings/d) veg (servings/d) Instrument: 15-item FFQ (7 of these items used to measure primary outcome) Statistics: mixed model analysis (random effects included county pairs, churches within counties, and study grp assignment; fixed effects included demographics and baseline values) | F&V (mean and se) Significance of effects p for diff b/w grps at base: 0.21 p for diff b/w grps at f/u: 0.0001 Fruit (mean and se) Significance of effects p for diff b/w grps at f/u: 0.0001 Veg (mean and se) Significance of effects p for diff b/w grps at f/u: 0.0003 Intention to treat: NR
  | Base | F/U
  Intv grp (n = 1198): | 3.84 (0.10) | 4.45 (0.08)
  Con grp (n = 1321): | 3.65 (0.10) | 3.60 (0.08)
  | Base | F/U
  Intv grp (n = 1198): | 2.14 (0.06) | 2.64 (0.06)
  Con grp (n = 1321): | 2.04 (0.06) | 1.98 (0.06)
  | Base | F/U
  Intv grp (n = 1198): | 1.69 (0.04) | 1.82 (0.03)
  Con grp (n = 1321): | 1.61 (0.04) | 1.63 (0.03)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Campbell, Denmark-Wahnefried, Symons, 1999 | NR | NR | NR | NR | NR | Stage of change: sig intv effect Self-efficacy for eating 5 servings/d: sig intv effect F&V knowledge: sig intv effect Perceived availability of F&V at church: sig intv effect | 75

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
227 Lutz, Ammerman, Atwood, 1999 | Setting: home (population recruited from HMO) Gender: M,F Age: >18 Race: B,W Risk: general | RCT subjects randomized to 3 intv grps or con grp | Participation rate: 16% (total) Baseline sample size: Intv grp 1: 177 Intv grp 2: 176 Intv grp 3: 177 Con grp: 180 F/U sample size: Intv grp 1: 140 Intv grp 2: 136 Intv grp 3: 146 Con grp: 151 Retention rate: 80.7% (total) Comparison of drop-outs: respondents had more education and were more likely to be married than non-respondents | Intv Grps (3 grps) Intv components: non-tailored newsletter (grp 1) tailored newsletter without goal setting component (grp 2) tailored newsletter with goal setting component (grp 3) Intv delivery: newsletter written by nutritionists and health educators Special features: individually tailored (grps 2 and 3) Nutr message: increase F&V, increase variety of F&V Con Grp Intv components: no newsletter Theoretical perspective: Health Belief Model, Social Cognitive Theory, Stages of Change, Goal setting | 1 newsletter each mo for 4 mos Maintenance: NR | 6 mos after base | Variables: F&V (servings/day) F&V (tot variety/wk) Instrument: 17 item FFQ developed for the study Statistics: ANCOVA, Tukey's honestly sig diff test | F&V (servings/d; mean and se) Significance of effects: Controlling for baseline, sig higher (p<.002) for all 3 intv grps than con grp; diffs in deltas (f/u - base.) n.s. Intention to treat: intv grps 2 and 3 sig. diff from con grp F&V (variety/wk; mean and se) Significance of effects: controlling for baseline, sig higher (p = .0001) for all 3 intv grps than con grp; diffs. in deltas (f/u - base.) n.s Intention to treat: same results
  | Base | F/U
  Intv grp 1 (n = 140): | 3.4 (.18) | 4.1 (.19)
  Intv grp 2 (n = 136): | 3.3 (.19) | 4.1 (.21)
  Intv grp 3 (n = 146): | 3.5 (.21) | 4.4 (.21)
  Con grp (n = 151): | 3.5 (.20) | 3.6 (.16)
  | Base | F/U
  Intv grp 1 (n = 140): | 6.4 (.29) | 7.8 (.29)
  Intv grp 2 (n = 136): | 6.5 (.29) | 7.9 (.30)
  Intv grp 3 (n = 146): | 6.4 (.30) | 8.5 (.29)
  Con grp (n = 151): | 6.7 (.29) | 6.9 (.25)

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Lutz, Ammerman, Atwood, 1999 | NR | NR | NR | NR | NR | NR | 76

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
330 Brug, Steenhuis, van Assema, 1999 | Setting: computer/home (recruitment NR) Gender: M,F (89%F) Age: 19-59 Race: NR Risk: general Country: The Netherlands | RCT 170 subjects assigned to intv grp; 177 assigned to con grp | Participation rate: 50% Baseline sample size Intv grp: 170 Con grp: 177 F/U sample size Intv grp: 152 Con grp: 163 Retention rate Intv grp: 89% Con grp: 92% Comparison of drop-outs: no sig diffs in demographics, BMI, dietary behavior, or tx grp | Intv grp Intv components: tailored letters about dietary feedback; psychosocial feedback (about personal expectancies, perceived social influences, and self-efficacy expectations) Intv delivery: n/a (mailed newsletter) Special features: individually tailored Nutr message: tailored (depending on subjects dietary intake), but related to F&V and fat Con grp Intv component: personal letters with tailored dietary feedback (no psychosocial feedback) Theoretical perspective: NR | 1 letter Maintenance component: NR | NR (presumably 4 wks after base) | Variables: fruit (servings/d) veg (servings/d) Instrument: FFQ (# items NR) Statistics: ANCOVA | Fruit (means; sd/se NR) Significance of effects: p for diffs b/w grps at f/u n.s. Veg (means; sd/se NR) Significance of effects: p for diffs b/w grps at base <0.01 p for diffs b/w grps at f/u <0.07 (higher in con grp)
  | Base | F/U
  Intv grp (n = 152): | 1.62 | 2.02
  Con grp (n = 163): | 1.61 | 1.91
  | Base | F/U
  Intv grp (n = 152): | 1.14 | 1.07
  Con grp (n = 163): | 1.04 | 1.13

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Brug, Steenhuis, van Assema, 1999 | Variables: fat score (range 12-60) Instrument: FFQ (# items NR) Statistics: ANCOVA | Fat (means; sd/se NR) Significance of effects: p for diffs b/w grps at f/u n.s. | NR | NR | NR | NR | 60
  | Base | F/U
  Intv grp (n = 152): | 26.5 | 26.2
  Con grp (n = 163): | 27.4 | 25.9

Evidence Table 4. Interventions to modify dietary behavior: Community/other settings

Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
Author (Year) | Study Setting and Population | Study Design | Sample Size and Retention Rates | Intervention Received | Duration of Intervention | Duration of Follow-Up | F&V: Measurement | F&V: Results
339 Campbell, Honess-Morreale, Farrell, 1999 StampSmart | Setting: multimedia (subjects recruited from Food Stamp office) Gender: F Age:> 18 Race: B,W,H,N,O (87% B) Risk: general Low-income population | RCT Subjects randomized to control or intv grp based on the day they participated | Participation rate: NR Baseline sample size: 526 F/U sample size Intv grp: 165 Con grp: 212 Retention rate: 72% Comparison of drop-outs: NR | Intv grp Intv components: video soap opera, interactive exercises Intv delivery: media Special features: individually tailored Nutr message: decrease fat intake Con grp Intv components: delayed intv (received recipe book and nutr education newsletter after f/u survey) Theoretical perspective: Social Cognitive Theory; Stages-of-Change Transtheoretical Model | 1-time, 30-min session (including a 15-min video soap opera) Maintenance component: NR | 1-3 mos post-intervention | NR | NR

Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Author (year) | Dietary Fat: Measurement | Dietary Fat: Results | Other Dietary Outcomes | Biochemical Indicators: Measures | Biochemical Indicators: Results | Behavioral Mediators | Quality Score
Campbell, Honess-Morreale, Farrell, 1999 | Variables: fat score Instrument: FFQ (16 items) Statistics: ANOVA | Fat score (mean and se) Significance of effects: p for diffs b/w grps at base < 0.001 p for diffs b/w grps at f/u n.s. | NR | NR | NR | Knowledge: sig intv effect Self-efficacy: sig intv effect Stage of change: sig intv effect
  | Base | F/U
  Intv grp (n = 165): | 83.8 (4.7) | 64.1 (3.2)
  Con grp (n = 212): | 101.6 (4.2) | 65.5 (2.8)